# CHAPTER 8 REFERENCES

ACGIH. 2002. Methyl tert-butyl ether. Documentation of the threshold limit values and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adam G, Knuechel R, Vorwerk D, . 1990. Tissue response of the biliary and digestive system of rabbits after MTBE infusion into the gallbladder. Invest Radiol 25(1):58–61. 10.1097/00004424-199001000-00015.2298551
Aetna. 2020. Contact dissolution for gallstones. Aetna, Inc. Medical Clinical Policy Bulletin 0509. http://www.aetna.com/cpb/medical/data/500_599/0509.html. March 9, 2021.
Ahmed FE. 2001. Toxicology and human health effects following exposure to oxygenated or reformulated gasoline. Toxicol Lett 123(2–3):89–113. 10.1016/s0378-4274(01)00375-7.11641038
Akimoto R, Rieger E, Moossa AR, . 1992. Systemic and local toxicity in the rat of methyl tert-butyl ether: A gallstone dissolution agent. J Surg Res 53(6):572–577. 10.1016/0022-4804(92)90257-z.1494290
Alaska DHSS. 1992a. Evaluation of health effects from exposure to oxygenated fuels, Fairbanks, Alaska. Alaska Department of Health and Social Services, Epidemiology. Bulletin No. 26. http://www.epi.hss.state.ak.us/bulletins/docs/b1992_26.pdf. March 9, 2020.
Alaska DHSS. 1992b. Potential illness due to exposure to oxygenated fuels, Anchorage, Alaska. Alaska Department of Health and Social Services.
Alden CL. 1986. A review of unique male rat hydrocarbon nephropathy. Toxicol Pathol 14(1):109–111. 10.1177/019262338601400113.2424069
Alfonso-Gordillo G, Flores-Ortiz CM, Morales-Barrera L, . 2016. Biodegradation of methyl tertiary butyl ether (MTBE) by a microbial consortium in a continuous up-flow packed-bed biofilm reactor: Kinetic study, metabolite identification and toxicity bioassays. PLoS ONE 11(12):e0167494. 10.1371/journal.pone.0167494.27907122
Alishahi S, Zendeh-Boodi Z, Saadat M. 2020. Genotoxicity effect of methyl-tertiary butyl ether on rat lymphocytes using comet assay. EXCLI J 19:668–670.32536836
Allen MJ, Borody TJ, Bugliosi TF, . 1985a. Cholelitholysis using methyl tertiary butyl ether. Gastroenterology 88(1 Pt 1):122–125. 10.1016/s0016-5085(85)80143-8.3964760
Allen MJ, Borody TJ, Bugliosi TF, . 1985b. Rapid dissolution of gallstones by methyl tert-butyl ether. Preliminary observations. N Engl J Med 312(4):217–220. 10.1056/NEJM198501243120406.3965949
Amberg A, Rosner E, Dekant W. 1999. Biotransformation and kinetics of excretion of methyl-tert-butyl ether in rats and humans. Toxicol Sci 51(1):1–8. 10.1093/toxsci/51.1.1.10496672
Amberg A, Rosner E, Dekant W. 2001. Toxicokinetics of methyl tert-butyl ether and its metabolites in humans after oral exposure. Toxicol Sci 61(1):62–67. 10.1093/toxsci/61.1.62.11294975
Amoco. 1992. 28-Day oral toxicity study of methyl tert-butyl ether in rats (final report) with cover letter dated 070192. Amoco Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0540108. 86-920000979. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0540108.xhtml. January 17, 2020.
Andreoli R, Spatari G, Pigini D, . 2015. Urinary biomarkers of exposure and of oxidative damage in children exposed to low airborne concentrations of benzene. Environ Res 142:264–272. 10.1016/j.envres.2015.07.003.26186134
Angle CR. 1991. If the tap water smells foul, think MTBE. JAMA 266(21):2985–2986. 10.1001/jama.1991.03470210053025.
API. 1984. The metabolic fate of methyl-t-butyl ether (MTBE) following an acute intraperitoneal injection. Submission of final report from Bio/dynamics on a single generation inhalation reproduction/fertility study in rats MTBE. American Petroleum Institute. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000219-0. FYI-AX-0983-0219. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002190.xhtml. January 21, 2020.
ARCO. 1980. Methyl tertiary-butyl ether: Acute toxicological studies. Acute tox study on methyl t-butyl ether & letter from Litton Bionetics to ARCO on evaluation rationale & additional info regarding SCE & chromosome aberration assays w/cover. ARCO Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0513481. 86-870000169. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0513481.xhtml. January 17, 2020.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37633. https://www.loc.gov/item/fr054174/. January 8, 2020.
ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Summary report. Subcommittee report on biological indicators of organ damage and dysfunction. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2005. Health consultation: Environmental data review for AM/PM Gas Station: Belmont, San Mateo County, California. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/AMPMGasStation/AmPmGasStationHC122105.pdf. May 4, 2021.
ATSDR. 2022. Methyl tert-butyl ether. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/spl/resources/index.html. June 28, 2023.
Badr A. 2019. Toxic effects of low doses of methyl-tertiary butyl ether on hematological indices in the male rats. Trends Pharm Sci 5(4):173–176. 10.30476/TIPS.2020.84445.1033.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Belpoggi F, Soffritti M, Maltoni C. 1995. Methyl-tertiary-butyl ether (MTBE) - a gasoline additive - causes testicular and lymphohaematopoietic cancers in rats. Toxicol Ind Health 11(2):119–149. 10.1177/074823379501100202.7491630
Belpoggi F, Soffritti M, Filippini F, . 1997. Results of long-term experimental studies on the carcinogenicity of methyl tert-butyl ether. Ann N Y Acad Sci 837:77–95. 10.1111/j.1749-6632.1997.tb56865.x.9472331
Benson JM, Barr EB, Krone JR. 2001. MTBE inhaled alone and in combination with gasoline vapor: uptake, distribution, metabolism, and excretion in rats. Res Rep Health Eff Inst 102(102):73–94; discussion 95-109.
Benson JM, Tibbetts BM, Barr EB. 2003. The uptake, distribution, metabolism, and excretion of methyl tertiary-butyl ether inhaled alone and in combination with gasoline vapor. J Toxicol Environ Health 66(11):1029–1052. 10.1080/15287390306398.
Benson JM, Gigliotti AP, March TH, . 2011. Chronic carcinogenicity study of gasoline vapor condensate (GVC) and GVC containing methyl tertiary-butyl ether in F344 rats. J Toxicol Environ Health 74(10):638–657. 10.1080/15287394.2011.538837.
Berger T, Horner CM. 2003. In vivo exposure of female rats to toxicants may affect oocyte quality. Reprod Toxicol 17(3):273–281. 10.1016/s0890-6238(03)00009-1.12759095
Bergman JJ, Groen AK, Huibregtse K, . 1994. Addition of dimethylsulphoxide to methyl-tert-butyl ether and ethyl propionate increases cholesterol dissolving capacity and cholesterol gall stone dissolution in vitro. Gut 35(11):1653–1658. 10.1136/gut.35.11.1653.7828992
Bermudez E, Willson G, Parkinson H, . 2012. Toxicity of methyl tertiary-butyl ether (MTBE) following exposure of Wistar Rats for 13 weeks or one year via drinking water. J Appl Toxicol 32(9):687–706. 10.1002/jat.1674.22833177
Bevan C, Tyl RW, Neeper-Bradley TL, . 1997a. Developmental toxicity evaluation of methyl tertiary-butyl ether (MTBE) by inhalation in mice and rabbits. J Appl Toxicol 17(Suppl 1):S21–29. 10.1002/(sici)1099-1263(199705)17:1+<s21::aid-jat407>3.3.co;2-5.9179724
Bevan C, Neeper-Bradley TL, Tyl RW, . 1997b. Two-generation reproductive toxicity study of methyl tertiary-butyl ether (MTBE) in rats. J Appl Toxicol 17(Suppl 1):S13–S19. 10.1002/(sici)1099-1263(199705)17:1+<s13::aid-jat406>3.3.co;2-3.9179723
Bexfield LM, Belitz K, Fram MS, . 2022. Volatile organic compounds in groundwater used for public supply across the United States: Occurrence, explanatory factors, and human-health context. Sci Total Environ 827:154313. 10.1016/j.scitotenv.2022.154313.35257755
Bianchi AP, Vamey MS, Phillips J. 1991. Analysis of volatile organic compounds in estuarine sediments using dynamic headspace and gas chromatography-mass spectrometry. J Chromatogr 542:413–450. 10.1016/S0021-9673(01)88779-3.
Bianchi E, Censabella I, Fascetti E. 2009. Aerobic biodegradation of MtBE in an upflow fixed bed reactor. J Chem Technol Biotechnol 84(6):871–876. 10.1002/jctb.2133.
Biles RW, Schroeder RE, Holdsworth CE. 1987. Methyl tertiary butyl ether inhalation in rats: A single generation reproduction study. Toxicol Ind Health 3(4):519–534. 10.1177/074823378700300406.3433288
Billitti JE, Faulkner BC, Wilson BW. 2005. Absence of acute testicular toxicity of methyl-tert butyl ether and breakdown products in mice. Bull Environ Contam Toxicol 75(2):228–235. 10.1007/s00128-005-0742-8.16222491
Bird MG, Burleigh-Flayer HD, Chun JS, . 1997. Oncogenicity studies of inhaled methyl tertiary-butyl ether (MTBE) in CD-1 mice and F-344 rats. J Appl Toxicol 17(Suppl 1):S45–55. 10.1002/(sici)1099-1263(199705)17:1+<s45::aid-jat410>3.3.co;2-b.9179727
Blancato JN, Evans MV, Power FW, . 2007. Development and use of PBPK modeling and the impact of metabolism on variability in dose metrics for the risk assessment of methyl tertiary butyl ether (MTBE). J Environ Prot Sci 1:29–51.
Bogen KT, Heilman JM. 2015. Reassessment of MTBE cancer potency considering modes of action for MTBE and its metabolites. Crit Rev Toxicol 45(Suppl 1):1–56. 10.3109/10408444.2015.1052367.
Bonardi L, Gandini G, Gabasio S, . 1986. Methyl-tert-butyl ether (MTBE) and endoscopic sphincterotomy. A possible solution for dissolving gallstones. Endoscopy 18(6):238–239. 10.1055/s-2007-1018388.3792281
Borghoff SJ, Murphy JE, Medinsky MA. 1996. Development of physiologically based pharmacokinetic model for methyl tertiary-butyl ether and tertiary-butanol in male Fisher-344 rats. Fundam Appl Toxicol 30(2):264–275. 10.1093/toxsci/30.2.264.8812274
Borghoff SJ, Parkinson H, Leavens TL. 2010. Physiologically based pharmacokinetic rat model for methyl tertiary-butyl ether; comparison of selected dose metrics following various MTBE exposure scenarios used for toxicity and carcinogenicity evaluation. Toxicology 275(1–3):79–91. 10.1016/j.tox.2010.06.003.20561556
Brady JF, Xiao F, Ning SM, . 1990. Metabolism of methyl tertiary-butyl ether by rat hepatic microsomes. Arch Toxicol 64(2):157–160. 10.1007/BF01974403.2350236
Brandon JC, Teplick SK, Haskin PH, . 1988. Common bile duct calculi: Updated experience with dissolution with methyl tertiary butyl ether. Radiology 166(3):665–667. 10.1148/radiology.166.3.3340760.3340760
Bravo HA, Camacho RC, Roy-Ocotla R. 1991. Analysis of the change in atmospheric urban formaldehyde and photochemistry activity as result of using methyl-t-butyl-ether (MTBE) as an additive in gasoline of the metropolitan area of Mexico City. Atmos Environ 25(2):285–288. 10.1016/0957-1272(91)90063-K.
Buckley TJ, Prah JD, Ashley D, . 1997. Body burden measurements and models to assess inhalation exposure to methyl tertiary butyl ether (MTBE). J Air Waste Manag Assoc 47(7):739–752. 10.1080/10473289.1997.10463934.9248366
Budavari S. 1989. Methyl tert-butyl ether. In: Merck manual: An encyclopedia of chemicals, drugs, and biologicals. 11th ed. Rahway, NJ: Merck & Co., Inc., 951.
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: a review of past Agency for Toxic Substances and Disease Registry public health evaluations. J Environ Health 75(9):36–41.
Burleigh-Flayer HD, Chun JS, Kintigh WJ. 1992. Methyl tertiary butyl ether - Vapor inhalation oncogenicity study in CD-1 mice, with cover letter dated 10/29/92. MTBE Task Force. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0558685. 42098 G9-2. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0558685.xhtml. January 17, 2020.
Bus JS, Gollapudi BB, Hard GC. 2022. Methyl-tert-butyl ether (MTBE): integration of rat and mouse carcinogenicity data with mode of action and human and rodent bioassay dosimetry and toxicokinetics indicates MTBE is not a plausible human carcinogen. J Toxicol Environ Health B Crit Rev 25(4):1–27. 10.1080/10937404.2022.2041516.34706629
Cain WS, Leaderer BP, Ginsbert GL, . 1994. Human reactions to brief exposures to methyl tertiary-butyl ether (MTBE). Final report, with cover letter dated 032194. Oxygenated Fuels Association, Incorporated. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0556818. 86940000223. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0556818.xhtml. January 20, 2020.
Cain WS, Leaderer BP, Ginsberg GL, . 1996. Acute exposure to low-level methyl tertiary-butyl ether (MTBE): Human reactions and pharmacokinetic response. Inhal Toxicol 8(1):21–48. 10.3109/08958379609005425.
CalEPA. 1998. Evidence on the carcinogenicity of methyl tertiary butyl ether (MTBE). Sacramento, CA: California Environmental Protection Agency. https://oehha.ca.gov/media/downloads/proposition-65/chemicals/dhidmt1.pdf. January 30, 2020.
CDC. 1993a. An investigation of exposure to MTBE and gasoline among motorist and exposed workers in Albany, New York. Atlanta, GA: Centers for Disease Control and Prevention.
CDC. 1993b. An investigation of exposure to methyl tertiary butyl ether among motorists and exposed workers in Stamford, Connecticut. Atlanta, GA: Centers for Disease Control and Prevention. Health Hazard Evaluation Report No. 93-802.
CDC. 1993c. Methyl tertiary butyl ether in human blood after exposure to oxygenated fuel in Fairbanks, Alaska. Atlanta, GA: Centers for Disease Control and Prevention.
CDC. 2019. Fourth report on human exposure to environmental chemicals, updated tables (January 2019). Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/pdf/FourthReport_UpdatedTables_Volume1_Jan2019-508.pdf. December 5, 2019.
Chen CY, Chang KK, Chow NH, . 1995. Toxic effects of cholelitholytic solvents on gallbladder and liver. A piglet model study. Dig Dis Sci 40(2):419–426. 10.1007/BF02065431.7851209
Chen CS, Hseu YC, Liang SH, . 2008. Assessment of genotoxicity of methyl-tert-butyl ether, benzene, toluene, ethylbenzene, and xylene to human lymphocytes using comet assay. J Hazard Mater 153(1–2):351–356. 10.1016/j.jhazmat.2007.08.053.17900805
Chun JS, Kintigh WJ. 1993. Methyl tertiary butyl ether: Twenty-eight day vapor inhalation study in rats and mice. Union Carbide. Submitted to the MTBE Health Effects Testing Task Force. BRRC Report 93N1241.
Chun JS, Burleigh-Flayer HD, Kintigh WJ. 1992. Final report, methyl tertiary butyl ether: Vapor inhalation oncogenicity study in Fischer 344 rats, with cover letter dated 11/19/92. MTBE Task Force. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0558686. 42098G93. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0558686.xhtml. January 20, 2020.
Cinelli S, Ciliutti P, Falezza A, . 1992. Absence of mutagenicity of methyl-tertiary-butyl ether [abstract]. Toxicol Lett 356(Suppl 1):300.
CITI. 2022. Methyl tert-butyl ether. Biodegradation in water: Screening tests. Japan Chemicals Collaborative knowledge database. Japanese National Institute of Technology and Evaluation. https://www.nite.go.jp/chem/jcheck/template.action?ano=6339&mno=2-3220&cno=1634-04-4&request_locale=en. August 24, 2022.
Clary JJ. 1997. Methyl tert butyl ether systemic toxicity. Risk Anal 17(6):661–672. 10.1111/j.1539-6924.1997.tb01273.x.9463923
Clegg ED, Cook JC, Chapin RE, . 1997. Leydig cell hyperplasia and adenoma formation: Mechanisms and relevance to humans. Reprod Toxicol 11(1):107–121. 10.1016/s0890-6238(96)00203-1.9138629
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Conaway CC, Schroeder RE, Snyder NK. 1985. Teratology evaluation of methyl tertiary butyl ether in rats and mice. J Toxicol Environ Health 16(6):797–809. 10.1080/15287398509530789.4093995
Cox RA, Goldstone A. 1982. Atmospheric reactivity of oxygenated motor fuel additives. In: Versino B, Ott HC, eds. Physico-chemical behavior of atmospheric pollutants: Proceedings of the Second European Symposium. London, England: Reidel Publishing Company, 112–110.
Dai KY, Montet J, Zhao XM, . 1989. Dissolution of human brown pigment biliary stones. J Hepatol 9(3):301–311. 10.1016/0168-8278(89)90138-4.2514227
Darwish IAE, Mosallam SAE. 2019. Chromosome aberrations in bone marrow cells of rats treated with MTBE. Pak J Pharm Sci 32(1):89–93.30772795
Daughtrey WC, Gill MW, Pritts IM, . 1997. Neurotoxicological evaluation of methyl tertiary-butyl ether in rats. J Appl Toxicol 17(Suppl 1):S57–64. 10.1002/(sici)1099-1263(199705)17:1+<s57::aid-jat411>3.3.co;2-1.9179728
de Peyster A, Mihaich E. 2014. Hypothesis-driven weight of evidence analysis to determine potential endocrine activity of MTBE. Regul Toxicol Pharmacol 69(3):348–370. 10.1016/j.yrtph.2014.04.017.24813373
de Peyster A, MacLean KJ, Stephens BA, . 2003. Subchronic studies in Sprague-Dawley rats to investigate mechanisms of MTBE-induced Leydig cell cancer. Toxicol Sci 72(1):31–42. 10.1093/toxsci/kfg011.12604832
de Peyster A, Rodriguez Y, Shuto R, . 2008. Effect of oral methyl-t-butyl ether (MTBE) on the male mouse reproductive tract and oxidative stress in liver. Reprod Toxicol 26(3–4):246–253. 10.1016/j.reprotox.2008.08.009.18824092
de Peyster A, Mihaich E, Kim DH, . 2014. Responses of the steroidogenic pathway from exposure to methyl-tert-butyl ether and tert-butanol. Toxicology 319:23–37. 10.1016/j.tox.2014.01.015.24560773
Dekant W, Bernauer U, Rosner E, . 2001. Toxicokinetics of ethers used as fuel oxygenates. Toxicol Letters 124(1–3):37–45. 10.1016/s0378-4274(00)00284-8.
Di Padova C, Di Padova F, Montorsi W, . 1986. Methyl tert-butyl ether fails to dissolve retained radiolucent common bile duct stones. Gastroenterology 91(5):1296–1300. 10.1016/s0016-5085(86)80030-0.3758621
Dodd DE, Kintigh WJ. 1989. Methyl tertiary butyl ether repeated (13-week) vapor inhalation study in rats with neurotoxicity evaluation (final report) with attachments and cover letter dated 09/27/1989. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0528043. 408913440. 42098G62. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0528043.xhtml. January 21, 2020.
Dodd D, Willson G, Parkinson H, . 2013. Two-year drinking water carcinogenicity study of methyl tertiary-butyl ether (MTBE) in Wistar rats. J Appl Toxicol 33(7):593–606. 10.1002/jat.1776.22161475
Dodson RE, Levy JI, Spengler JD, . 2008. Influence of basements, garages, and common hallways on indoor residential volatile organic compound concentrations. Atmos Environ 42(7):1569–1581. 10.1016/j.atmosenv.2007.10.088.
DOE. 2018a. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/. July 26, 2018.
DOE. 2018b. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 26, 2018.
Dong-mei L, Yi G, Chun-Tao Y, . 2009. Effects of subchronic methyl tert-butyl ether ether exposure on male Sprague-Dawley rats. Toxicol Ind Health 25(1):15–23. 10.1177/0748233708101594.19318501
Draper WM, Li N, Solomon GM, . 2022. Organic chemical contaminants in water system infrastructure following wildfire. ACS ES T Water 2(2):357–366. 10.1021/acsestwater.1c00401.35647583
Du HF, Xu LH, Wang HF, . 2005. Formation of MTBE-DNA adducts in mice measured with accelerator mass spectrometry. Environ Toxicol 20(4):397–401. 10.1002/tox.20124.16007660
Duffy LK. 1994. Oxyfuel in Alaska: use of interleukins to monitor effects on the immune system. Sci Total Environ 151(3):253–256. 10.1016/0048-9697(94)90475-8.7521968
ECB. 2002. European Union risk assessment report: Tert-butyl methyl ether. Helsinki, Finland: European Chemicals Bureau. EUR 20417 EN. https://echa.europa.eu/documents/10162/0e071dee-7150-4412-a3fa-9051f503bf5d. March 12, 2020.
Edison SA, Maier M, Kohler B, . 1993. Direct dissolution of gallstones with methyl tert-butyl ether by endoscopic cannulation of the gallbladder. Am J Gastroenterol 88(8):1242–1248.8338092
EIA. 2018. The United States continues to export MTBE, mainly to Mexico, Chile, and Venezuela. U.S. Energy Information Administration. https://www.eia.gov/todayinenergy/detail.php?id=36614. December 24, 2019.
EIA. 2019. Monthly U.S. exports of MTBE (thousand barrels). U.S. Energy Information Administration. https://www.eia.gov/dnav/pet/hist/LeafHandler.ashx?n=PET&s=MMTEX_NUS-Z00_1&f=M. December 24, 2019.
EIA. 2022. Monthly U.S. exports of MTBE (thousand barrels). U.S. Energy Information Administration. https://www.eia.gov/dnav/pet/hist/LeafHandler.ashx?n=PET&s=MMTEX_NUS-Z00_1&f=M. September 8, 2022.
Eidsvoll BE, Aadland E, Stiris M, . 1993. Dissolution of cholesterol gallbladder stones with methyl tert-butyl ether in patients with increased surgical risk. Scand J Gastroenterol 28(8):744–748. 10.3109/00365529309098284.8210992
Elovaara E, Stockmann-Juvala H, Mikkola J, . 2007. Interactive effects of methyl tertiary-butyl ether (MTBE) and tertiary-amyl methyl ether (TAME), ethanol and some drugs: Triglyceridemia, liver toxicity and induction of CYP (2E1, 2B1) and phase II enzymes in female Wistar rats. Environ Toxicol Pharmacol 23(1):64–72. 10.1016/j.etap.2006.07.003.21783738
EPA. 1994. Chemical summary for methyl-tert-butyl-ether. Washington, DC: U.S. Environmental Protection Agency. EPA749F94017a. https://archive.epa.gov/oust/mtbe-a/web/txt/s_mtbe.txt. January 8, 2020.
EPA. 1995a. Response of sensitive groups to methyl tertiary butyl ether (MTBE). Proceedings of the conference on MTBE and other oxygenates: A research update. U.S. Environmental Protection Agency. EPA600R95134. PB95274288. https://cfpub.epa.gov/ncea/risk/era/recordisplay.cfm?deid=30067. May 5, 2020.
EPA. 1995b. Toxic chemical inventory reporting Form R and instructions. Washington DC: U.S. Environmental Protection Agency. EPA745K96001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20001FYO.txt. June 23, 2020.
EPA. 1997. Drinking water advisory: Consumer acceptability advice and health effects analysis on methyl tertiary-butyl ether. Washington, DC: U.S. Environmental Protection Agency. EPA822F97008. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20003HO4.txt. December 16, 2019.
EPA. 2003a. Inhalation exposure to methyl tert-butyl ether (MTBE) using continuous breath analysis. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB2006110285. EPA600R05095. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2006110285.xhtml. October 4, 2022.
EPA. 2003b. Human exposure to methyl ‘tert’-butyl ether (MTBE) while bathing with contaminated water. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB2006110284. EPA600R05094. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2006110284.xhtml. October 4, 2022.
EPA. 2005a. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100EI4V.txt. June 23, 2020.
EPA. 2005b. UCMR 1 (2001-2005) occurrence data: Methyl-tert butyl ether. U.S. Environmental Protection Agency. https://www.epa.gov/dwucmr/occurrence-data-unregulated-contaminant-monitoring-rule#1. December 24, 2019.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2011. Background indoor air concentrations of volatile organic compounds in North American residences (1990-2005): A compilation of statistics for assessing vapor intrusion. Washington, DC: U.S. Environmental Protection Agency. EPA530R10001. https://www.epa.gov/sites/production/files/2015-09/documents/oswer-vapor-intrusion-background-report-062411.pdf. October 20, 2020.
EPA. 2012. MTBE data. Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface. June 25, 2020.
EPA. 2014. National emissions inventory (NEI) data: Methyl-tert butyl ether. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2014-national-emissions-inventory-nei-data. December 30, 2019.
EPA. 2017. National emissions inventory (NEI) data: Methyl-tert butyl ether. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. August 24, 2022.
EPA. 2018a. 2015-2016 National monitoring programs annual report (UATMP, NATTS, and CSATAM). Research Triangle Park, NC: U.S. Environmental Protection Agency. https://www3.epa.gov/ttnamti1/files/ambient/airtox/2015-2016%20NMP%20Report%20508.pdf. December 31, 2019.
EPA. 2018b. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018c. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. June 5, 2019.
EPA. 2018d. About Acute Exposure Guideline Levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2019a. Air quality system annual summary: Methyl-tert butyl ether. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/airdata/download_files.html#Annual. December 31, 2019.
EPA. 2019b. Chemical data reporting (CDR): Propane, 2-methoxy-2-methyl-. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting. December 30, 2019.
EPA. 2022a. Chemical data reporting (CDR): Propane, 2-methoxy-2-methyl-. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting. September 8, 2022.
EPA. 2022b. Environmental protection: More complete data and continued emphasis on leak prevention could improve EPA’s underground storage tank program. U.S. Environmental Protection Agency. https://www.gao.gov/assets/a248658.html. August 24, 2022.
EPA. 2022c. Air quality system annual summary: Methyl-tert butyl ether. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/airdata/download_files.html#Annual. August 24, 2022.
Esch O, Spinosa JC, Hamilton RL, . 1992. Acute effects of topical methyl tert-butyl ether or ethyl propionate on gallbladder histology in animals: a comparison of two solvents for contact dissolution of cholesterol gallstones. Hepatology 16(4):984–991. 10.1002/hep.1840160422.1398506
FDA. 2022. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. January 24, 2022.
Fiedler N, Kelly-McNeil K, Mohr S, . 2000. Controlled human exposure to methyl tertiary butyl ether in gasoline: Symptoms, psychophysiologic and neurobehavioral responses of self-reported sensitive persons. Environ Health Perspect 108(8):753–763. 10.1289/ehp.00108753.10964796
Finneran KT, Lovley DR. 2001. Anaerobic degradation of methyl tert-butyl ether (MTBE) and tert-butyl alcohol (TBA). Environ Sci Technol 35(9):1785–1790. 10.1021/es001596t.11355193
Flanagan SM, Levitt JP, Ayotte JD. 2017. Trends in methyl tert-butyl ether concentrations in private wells in Southeast New Hampshire: 2005 to 2015. Environ Sci Technol 51(3):1168–1175. 10.1021/acs.est.6b04149.28074652
Fujiwara Y, Kinoshita T, Sato H, . 1984. Biodegradation and bioconcentration of alkyl ethers. J Japan Oil Chem Soc 33:111–114. 10.5650/jos1956.33.111. (Japanese)
Ghasemi S, Ahmadi F. 2014. The study of binding of methyl tert-butyl ether to human telomeric G-quadruplex and calf thymus DNA by gas chromatography, a thermodynamic discussion. J Chromatogr 971:112–119. 10.1016/j.jchromb.2014.09.011.
Gholami S, Ansari-Lari M, Khalili L. 2015. Histologic and histomorphometric changes of testis following oral exposure to methyl tertiary-butyl ether in adult rat. Iran J Vet Res 16(3):288–292.27175191
Gilbert CE, Calabrese EJ, eds. 1992. Developing a standard for methyl butyl ether in drinking water. In: Regulating drinking water quality. Boca Raton, FL: Lewis Publishers, 231–252.
Gill MW. 1989. Methyl tertiary butyl ether single exposure vapor inhalation neurotoxicity study in rats. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. 602-823. OTS0528043. 409813440. 4209862. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0528043.xhtml. October 4, 2022.
Gordian ME, Huelsman MD, Brecht ML, . 1995. Health effects of methyl tertiary butyl ether (MTBE) in gasoline in Alaska. Alaska Med 37(3):101–103, 119.8546253
Greenough RJ, McDonald P, Robinson P, . 1980. Methyl tertiary butyl ether (Driveron) three month inhalation toxicity in rats with cover letter dated 020687. Texaco Incorporated. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0513212. 86870000262.
Greenwood MH, Sims RC, McLean JE, . 2007. Sorption of methyl tert-butyl ether (MTBE) and tert-butyl alcohol (TBA) to hyporheic zone soils. Soil Sediment Contam 16(4):423–431. 10.1080/15320380701404672.
Griffith SL, Burney BT, Fry FJ, . 1990. Experimental gallstone dissolution with methyl-tert-butyl ether (MTBE) and transcutaneous ultrasound energy. Invest Radiol 25(2):146–152. 10.1097/00004424-199002000-00010.2312251
Hashemi SH, Kaykhaii M, Mirmoghaddam M, . 2021. Preconcentration and analytical methods for determination of methyl tert-butyl ether and other fuel oxygenates and their degradation products in environment: A review. Crit Rev Anal Chem 51(6):582–608. 10.1080/10408347.2020.1753164.32312086
He Z, Xian H, Tang M, . 2021. DNA polymerase β may be involved in protecting human bronchial epithelial cells from the toxic effects induced by methyl tert-butyl ether exposure. Hum Exp Toxicol 40(12):2135–2144. 10.1177/09603271211022788.34121485
HEI. 2005. Relationships of indoor, outdoor, and personal air (RIOPA). Part I. Collection methods and descriptive analyses. Boston, MA: Health Effects Institute.
Hellstern A, Leuschner M, Frenk H, . 1990. Gall stone dissolution with methyl tert-butyl ether: how to avoid complications. Gut 31(8):922–925.2387519
Hellstern A, Leuschner U, Benjaminov A, . 1998. Dissolution of gallbladder stones with methyl tert-butyl ether and stone recurrence: a European survey. Dig Dis Sci 43(5):911–920. 10.1023/a:1018811409538.9590398
Hiatt MH, Pia JH. 2004. Screening processed milk for volatile organic compounds using vacuum distillation/gas chromatography/mass spectrometry. Arch Environ Contam Toxicol 46(2):189–196. 10.1007/s00244-003-2308-2.15106669
Hine J, Mookerjee PK. 1975. The intrinsic hydrophilic character of organic compounds. Correlations in terms of structural contributions. J Org Chem 40(3):292–298. 10.1021/jo00891a006.
Holder SL, Hedenqvist MS, Nilsson F. 2019. Understanding and modelling the diffusion process of low molecular weight substances in polyethylene pipes. Water Res 157:301–309. 10.1016/j.watres.2019.03.084.30959333
Holl J, Sauerbruch T, Sackmann M, . 1991. Combined treatment of symptomatic gallbladder stones by extracorporeal shock-wave lithotripsy (ESWL) and instillation of methyl tert-butyl ether (MTBE). Dig Dis Sci 36(8):1097–1101. 10.1007/BF01297453.1864203
Hong JY, Wang YY, Bondoc FY, . 1999. Metabolism of methyl tert-butyl ether and other gasoline ethers by human liver microsomes and heterologously expressed human cytochromes P450: Identification of CYP2A6 as a major catalyst. Toxicol Appl Pharmacol 160(1):43–48. 10.1006/taap.1999.8750.10502501
Hong JY, Yang CS, Lee M, . 1997. Role of cytochromes P450 in the metabolism of methyl tert-butyl ether in human livers. Arch Toxicol 71(4):266–269. 10.1007/s002040050386.9101044
Hun DE, Corsi RL, Morandi MT, . 2011. Automobile proximity and indoor residential concentrations of BTEX and MTBE. Build Environ 46(1):45–53. 10.1016/j.buildenv.2010.06.015.
IARC. 1999. Methyl tert-butyl ether. IARC monographs on the evaluation of carcinogenic risks to humans: Some chemicals that cause tumours of the kidney or urinary bladder in rodents and some other substances. Lyon, France: International Agency for Research on Cancer. Vol. 73, http://publications.iarc.fr/91. December 16, 2019.
IRIS. 1993. Methyl tert-butyl ether (MTBE). Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0545_summary.pdf. December 16, 2019.
Janowitz P, Schumacher KA, Swobodnik W, . 1993. Transhepatic topical dissolution of gallbladder stones with MTBE and EDTA. Results, side effects, and correlation with CT imaging. Dig Dis Sci 38(11):2121–2129. 10.1007/BF01297094.8223089
Japar SM, Wallington TJ, Richert JFO, . 1990. The atmospheric chemistry of oxygenated fuel additives: t-butyl alcohol, dimethyl ether, and methyl t-butyl ether. Int J Chem Kinet 22(12):1257–1269. 10.1002/kin.550221205.
Jensen HM, Arvin E. 1990. Solubility and degradability of the gasoline additive methyl t-butyl ether, and gasoline compounds in water. In: Arendt F, Hinsenveld M, van den Brink WJ, eds. Contaminated Soil ‘90. Vol. 1. Dodrecht, Netherlands: Kluwer Academic Publishers, 445–448.
Johanson G, Nihlen A, Lof A. 1995. Toxicokinetics and acute effects of MTBE and ETBE in male volunteers. Toxicol Lett 82–83:713–718. 10.1016/0378-4274(95)03589-3.
Joseph PM, Weiner MG. 2002. Visits to physicians after the oxygenation of gasoline in Philadelphia. Arch Environ Health 57(2):137–154. 10.1080/00039890209602929.12194159
Kado NY, Kuzmicky PA, Loarca-Pina G, . 1998. Genotoxicity testing of methyl tertiary-butyl ether (MTBE) in the Salmonella microsuspension assay and mouse bone marrow micronucleus test. Mutat Res 412(2):131–138. 10.1016/s1383-5718(97)00179-4.9580226
Kalkbrenner AE, Windham GC, Zheng C, . 2018. Air toxics in relation to autism diagnosis, phenotype, and severity in a U.S. family-based study. Environ Health Perspect 126(3):037004. 10.1289/ehp1867.29553459
Kaye GL, Summerfield JA, McIntyre N, . 1990. Methyl tert butyl ether dissolution therapy for common bile duct stones. J Hepatol 10(3):337–340. 10.1016/0168-8278(90)90142-e.2365983
Khalili L, Gholami S, Ansari-Lari M. 2015. Evaluation of offspring sex ratio, sex hormones and antioxidant enzymes following exposure to methyl tertiary butyl ether in adult male Sprague-Dawley rats. EXCLI J 14:75–82. 10.17179/excli2014-580.26417352
Kim G, Malayaman SN, Green MS. 2015. Use of methyl tert-butyl ether for the treatment of refractory intrahepatic biliary strictures and bile casts: A modern perspective. Case Rep Surg 2015:408175. 10.1155/2015/408175.26236535
Kim D, Andersen ME, Pleil JD, . 2007. Refined PBPK model of aggregate exposure to methyl tertiary-butyl ether. Toxicol Lett 169(3):222–235. 10.1016/j.toxlet.2007.01.008.17336003
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kuder T, Wilson JT, Kaiser P, . 2005. Enrichment of stable carbon and hydrogen isotopes during anaerobic biodegradation of MTBE: microcosm and field evidence. Environ Sci Technol 39(1):213–220. 10.1021/es040420e.15667097
Le Gal A, Dreano Y, Gervasi PG, . 2001. Human cytochrome P450 2A6 is the major enzyme involved in the metabolism of three alkoxyethers used as oxyfuels. Toxicol Lett 124(1–3):47–58. 10.1016/s0378-4274(00)00286-1.11684357
Leavens TL, Borghoff SJ. 2009. Physiologically based pharmacokinetic model of methyl tertiary butyl ether and tertiary butyl alcohol dosimetry in male rats based on binding to alpha2u-globulin. Toxicol Sci 109(2):321–335. 10.1093/toxsci/kfp049.19270017
Lee CW, Mohr SN, Weisel CP. 2001. Toxicokinetics of human exposure to methyl tertiary-butyl ether (MTBE) following short-term controlled exposures. J Expo Anal Environ Epidemiol 11(2):67–78. 10.1038/sj.jea.7500149.11409007
Leuschner U, Hellstern A, Ansell A, . 1994. Manual and automatic gallstone dissolution with methyl tert-butyl ether. Dig Dis Sci 39(6):1302–1308. 10.1007/BF02093797.8200264
Leuschner U, Hellstern A, Schmidt K, . 1991. Gallstone dissolution with methyl tert-butyl ether in 120 patients--efficacy and safety. Dig Dis Sci 36(2):193–199. 10.1007/BF01300756.1988263
Leuschner U, Hellstern A, Wendt T, . 1988. Endoscopy of the gallbladder as control of gallstone therapy with methyl-tert-butyl ether. Am J Gastroenterol 83(2):169–172.3341341
Lewis RJ. 1987. Methyl tert-butyl ether. In: Hawley’s condensed chemical dictionary. 12th ed. New York, NY: Van Nostrand Reinhold Company, 760.
Li DM, Han XD. 2006. Evaluation of toxicity of methyl tert-butyl ether (MTBE) on mouse spermatogenic cells in vitro. Toxicol Ind Health 22(7):291–299. 10.1177/0748233706070310.17022436
Li D, Yin D, Han X. 2007. Methyl tert-butyl ether (MTBE)-induced cytotoxicity and oxidative stress in isolated rat spermatogenic cells. J Appl Toxicol 27(1):10–17. 10.1002/jat.1178.17177168
Li SS, Zhang D, Yan W. 2014. Enhanced biodegradation of methyl tert-butyl-ether by a microbial consortium. Curr Microbiol 68(3):317–323. 10.1007/s00284-013-0480-9.24162446
Li D, Zhu M, Yang X, . 1991. Pharmacokinetics of methyl tert-butyl ether (MTBE) in rats. Chin J Pharmacol Toxicol 5(4):287–290.
Li D, Yuan C, Gong Y, . 2008. The effects of methyl tert-butyl ether (MTBE) on the male rat reproductive system. Food Chem Toxicol 46(7):2402–2408. 10.1016/j.fct.2008.03.024.18467015
Li D, Liu Q, Gong Y, . 2009. Cytotoxicity and oxidative stress study in cultured rat Sertoli cells with methyl tert-butyl ether (MTBE) exposure. Reprod Toxicol 27(2):170–176. 10.1016/j.reprotox.2008.12.004.19150650
Licata AC, Dekant W, Smith CE, . 2001. A physiologically based pharmacokinetic model for methyl tert-butyl ether in humans: implementing sensitivity and variability analyses. Toxicol Sci 62(2):191–204. 10.1093/toxsci/62.2.191.11452131
Lide DR. 1994. Methyl tert-butyl ether. In: CRC Handbook of chemistry and physics. 74th ed. Boca Raton, FL: CRC Press, 3–146.
Lington AW, Dodd DE, Ridlon SA, . 1997. Evaluation of 13-week inhalation toxicity study on methyl t-butyl ether (MTBE) in Fischer 344 rats. J Appl Toxicol 17(Suppl 1):S37–44. 10.1002/(sici)1099-1263(199705)17:1+<s37::aid-jat409>3.3.co;2-h.9179726
Lioy PJ, Weisel CP, Jo W, . 1994. Microenvironmental and personal measurements of methyl-tertiary butyl ether (MTBE) associated with automobile use activities. J Expo Anal Environ Epidemiol 4(4):427–441.
Little CJ, Dale AD, Whatley JA. 1979. Methyl tert-butyl ether: A new chromatographic effluent. J Chromatogr 169:381–385. 10.1016/0021-9673(75)85064-3.
Lorenzetti MS. 1994. On the road with oxygenates. Chem Bus (January):15–17.
Ma J, Xiong D, Li H, . 2017. Vapor intrusion risk of fuel ether oxygenates methyl tert-butyl ether (MTBE), tert-amyl methyl ether (TAME) and ethyl tert-butyl ether (ETBE): A modeling study. J Hazard Mater 332:10–18. 10.1016/j.jhazmat.2017.02.057.28279869
Mackay D, Wan YS, Ma KC. 1993. Fate models. In: Illustrated handbook of physical-chemical properties and environmental fate for organic chemicals: Volume III: Volatile organic chemicals. Boca Raton, FL: Lewis Publishers, 18–27, 756–757, 834–837.
Martienssen M, Fabritius H, Kukla S, . 2006. Determination of naturally occurring MTBE biodegradation by analysing metabolites and biodegradation by-products. J Contam Hydrol 87(1–2):37–53. 10.1016/j.jconhyd.2006.04.007.16828928
Martin JV, Bilgin NM, Iba MM. 2002. Influence of oxygenated fuel additives and their metabolites on the binding of a convulsant ligand of the gamma-aminobutyric acid_A_ (GABA_A_) receptor in rat brain membrane preparations. Toxicol Lett 129(3):219–226. 10.1016/s0378-4274(02)00020-6.11888705
Martin JV, Iyer SV, McIlroy PJ, . 2004. Influence of oxygenated fuel additives and their metabolites on gamma-aminobutyric acid_A_ (GABA_A_) receptor function in rat brain synaptoneurosomes. Toxicol Lett 147(3):209–217. 10.1016/j.toxlet.2003.10.024.15104112
McGahan JP, Tesluk H, Brock JM, . 1988. Dissolution of gallstones using methyl tertiary-butyl ether in an animal model. Invest Radiol 23(8):599–603. 10.1097/00004424-198808000-00010.3417437
McGregor D. 2006. Methyl tertiary-butyl ether: studies for potential human health hazards. Crit Rev Toxicol 36(4):319–358. 10.1080/10408440600569938.16809102
McGregor DB, Cruzan G, Callander RD, . 2005. The mutagenicity testing of tertiary-butyl alcohol, tertiary-butyl acetate and methyl tertiary-butyl ether in Salmonella typhimurium. Mutat Res 565(2):181–189. 10.1016/j.mrgentox.2004.10.002.15661616
McGregor DB, Brown A, Cattanach P, . 1988. Responses of the L5178Y tk+/tk− mouse lymphoma cell forward mutation assay. II: 18 coded chemicals. Environ Mol Mutagen 11(1):91–118. 10.1002/em.2850110110.3338442
McKee RH, Vergnes JS, Galvin JB, . 1997. Assessment of the in vivo mutagenic potential of methyl tertiary-butyl ether. J Appl Toxicol 17(Suppl 1):S31–36. 10.1002/(sici)1099-1263(199705)17:1+<s31::aid-jat408>3.3.co;2-1.9179725
McMahon PB, Lindsey BD, Conlon MD, . 2019. Hydrocarbons in upland groundwater, Marcellus Shale Region, Northeastern Pennsylvania and Southern New York, U.S.A. Environ Sci Technol 53(14):8027–8035. 10.1021/acs.est.9b01440.31246428
McNulty J, Chua A, Keating J, . 1991. Dissolution of cholesterol gall stones using methyltertbutyl ether: a safe effective treatment. Gut 32(12):1550–1553. 10.1136/gut.32.12.1550.1773965
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299. 10.1016/0045-6535(93)90355-9.
Meylan WM, Howard PH, Boethling RS, . 1999. Improved method for estimating bioconcentration/bioaccumulation factor from octanol/water partition coefficient. Environ Toxicol Chem 18(4):664–672. 10.1002/etc.5620180412.
Michigan DEQ. 2005. Detroit air toxics initiative: Risk assessment report. Lansing, MI: State of Michigan Department of Environmental Quality. https://www.michigan.gov/documents/DATI_-_COMPLETE_FINAL_REPORT_11-9-05_142053_7.pdf. October 19, 2020.
Mihelcic JR. 1990. Modeling the potential effect of additives on enhancing the solubility of aromatic solutes contained in gasoline. Ground Water Monit Remed 10(3):132–137. 10.1111/j.1745-6592.1990.tb00012.x.
Miller MJ, Ferdinandi ES, Klan M, . 1997. Pharmacokinetics and disposition of methyl t-butyl ether in Fischer-344 rats. J Appl Toxicol 17(Suppl 1):S3–12. 10.1002/(sici)1099-1263(199705)17:1+<s3::aid-jat405>3.3.co;2-#.9179722
Mohr SN, Fiedler N, Weisel C, . 1994. Health effects of MTBE among New Jersey garage workers. Inhal Toxicol 6(6):553–562. 10.3109/08958379409003040.
Moolenaar RL, Hefflin BJ, Ashley DL, . 1994. Methyl tertiary butyl ether in human blood after exposure to oxygenated fuel in Fairbanks, Alaska. Arch Environ Health 49(5):402–409. 10.1080/00039896.1994.9954993.7524452
Moser GJ, Wong BA, Wolf DC, . 1996. Methyl tertiary butyl ether lacks tumor-promoting activity in N-nitrosodiethylamine-initiated B6C3F1 female mouse liver. Carcinogenesis 17(12):2753–2761. 10.1093/carcin/17.12.2753.9006116
Moser GJ, Wolf DC, Sar M, . 1998. Methyl tertiary butyl ether-induced endocrine alterations in mice are not mediated through the estrogen receptor. Toxicol Sci 41(1):77–87. 10.1006/toxs.1997.2366.9520343
MTBE Committee. 1990a. Disposition of radioactivity and metabolism of MTBE in male and female Fischer-344 rats after nose-only inhalation to 14-C MTBE. MTBE Committee. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0528044. 409013459. 42098G712.
MTBE Committee. 1990b. Mass balance of radioactivity and metabolism of methyl tert-butyl ether (MTBE) in male and female Fischer-344 rats after intravenous, oral and dermal administration of 14C-MTBE. MTBE Committee. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0528044. 409013459. 42098G712.
MTBE Committee. 1990c. Pharmacokinetics of methyl tert-butyl ether (MTBE) and tert-butyl alcohol (TBA) in male and female Fischer-344 rats after administration of MTBE by the intravenous, oral and dermal routes. MTBE Committee. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0528044. 40-9013459. OTS0528044. 409013459. 42098G712.
MTBE Committee. 1990d. Pharmacokinetics of methyl tert-butyl ether (MTBE) and tert-butyl alcohol (TBA) in male and female Fischer-344 rats after single and repeated inhalation (nose-only) exposures to MTBE (final report). MTBE Committee. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0528044. 409013459. 42098G712.
MTBE Committee. 1991. Mass balance of radioactivity in male Fischer-344 rats after intravenous oral & dermal administration of 14C-methyl tertiary-butyl ether with cover letter dated 010692. MTBE Committee. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0533848. 86920000735. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0533848.xhtml. January 21, 2020.
Murray WR, LaFerla G, Fullarton GM. 1988. Choledocholithiasis - in vivo stone dissolution using methyl tertiary butyl ether (MTBE). Gut 29(2):143–145. 10.1136/gut.29.2.143.3345924
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Neeper-Bradley TL. 1991. Two-generation reproduction study of inhaled methyl tert-butyl ether in CD (Sprague-Dawley) rats (final report) with attachments and cover letter dated 081691. MTBE Task Force. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0534056. 409113465. 42098G82. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0540108.xhtml. January 17, 2020.
Neoptolemos JP, Hall C, O’Connor HJ, . 1990. Methyl-tert-butyl-ether for treating bile duct stones: the British experience. Br J Surg 77(1):32–35. 10.1002/bjs.1800770111.2302510
Neubrand M, Holl J, Sackmann M, . 1994. Combination of extracorporeal shock-wave lithotripsy and dissolution of gallbladder stones with methyl tert-butyl ether: a randomized study. Hepatology 19(1):133–137. 10.1002/hep.1840190122.8276350
Nicholls HCG, Mallinson HEH, Rolfe SA, . 2020. Influence of contaminant exposure on the development of aerobic ETBE biodegradation potential in microbial communities from a gasoline-impacted aquifer. J Hazard Mater 388:122022. 10.1016/j.jhazmat.2020.122022.31962211
Nihlén A, Lof A, Johanson G. 1998b. Experimental exposure to methyl tertiary-butyl ether. I. Toxicokinetics in humans. Toxicol Appl Pharmacol 148(2):274–280. 10.1006/taap.1997.8333.9473535
Nihlén A, Walinder R, Lof A, . 1998a. Experimental exposure to methyl tertiary-butyl ether. II. Acute effects in humans. Toxicol Appl Pharmacol 148(2):281–287. 10.1006/taap.1997.8342.9473536
NIOSH. 1993a. Health hazard evaluation report: National Centers for Environmental Health, Stamford, Connecticut. Cincinnati, OH: National Institute for Occupational Safety and Health. HETA938022338. https://www.cdc.gov/niosh/hhe/reports/pdfs/1993-0802-2338.pdf. January 8, 2020.
NIOSH. 1993b. Health hazard evaluation report: National Centers for Environmental Health, Fairbanks, Alaska. National Institute for Occupational Safety and Health. HETA936062336. https://www.cdc.gov/niosh/hhe/reports/pdfs/1993-0606-2336.pdf. January 8, 2020.
NIOSH. 2018. NIOSH pocket guide to chemical hazards. Index of Chemical Abstracts Service Registry Numbers (CAS No.). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgdcas.html. September 2, 2019.
NJDEP. 1994. Occurrence of methyl tertiary butyl ether in public and non public water systems in New Jersey: Treatability and estimated statewide costs to achieve a proposed maximum contaminant level of 50 ppb in drinking water. Trenton, NJ: New Jersey Department of Environmental Protection.
NLM. 2020. PubChem: Compound summary: Methyl tert-butyl ether. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/Methyl-tert-butyl-ether. December 2, 2020.
Nobles CJ, Williams A, Ouidir M, . 2019a. Differential effect of ambient air pollution exposure on risk of gestational hypertension and preeclampsia. Hypertension 74(2):384–390. 10.1161/HYPERTENSIONAHA.119.12731.31230552
Nobles CJ, Williams A, Ouidir M, . 2019b. Supplemental material: Differential effect of ambient air pollution exposure on risk of gestational hypertension and preeclampsia. Hypertension 74(2) 10.1161/HYPERTENSIONAHA.119.12731.
NTP. 2016. Report on carcinogens, Fourteenth edition. Appendix C: Substances reviewed but not recommended for listing in the report on carcinogens. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/appendix_c.pdf. January 3, 2020.
NTP. 2021. CASRN index. In: Report on carcinogens. 15th ed. National Toxicology Program, https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. January 10, 2022.
NTSB. 2016. Collision between bulk carrier Conti Peridot and tanker Carla Maersk, Houston Ship Channel near Morgan’s Point, Texas. March 9, 2015. Washington, DC: National Transportation Board. MAR1601. PB2016103277. https://www.ntsb.gov/investigations/AccidentReports/Reports/MAR1601.pdf. June 23, 2020.
NYSDOH. 2006. Appendix C: Volatile organic chemicals in air - summary of background databases. Albany, NY: New York State Department of Health. https://www.health.ny.gov/environmental/investigations/soil_gas/svi_guidance/docs/svi_appendc.pdf. October 19, 2020.
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1000.pdf. August 28, 2022.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-55.pdf. August 28, 2022.
OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-438. https://ota.fas.org/reports/9031.pdf. June 29, 2020.
Pankow JF, Rathbun RE, Zogorski JS. 1996. Calculated volatilization rates of fuel oxygenate compounds and other gasoline-related compounds from rivers and streams. Chemosphere 33(5):921–937. 10.1016/0045-6535(96)00227-5.
Peine CJ, May GR, Nagorney DM, . 1990. Safety of same-day sequential extracorporeal shock wave lithotripsy and dissolution of gallstones by methyl tert-butyl ether in dogs. Mayo Clin Proc 65(12):1564–1569. 10.1016/s0025-6196(12)62190-9.2255218
Phillips S, Palmer RB, Brody A. 2008. Epidemiology, toxicokinetics, and health effects of methyl tert-butyl ether (MTBE). J Med Toxicol 4(2):115–126. 10.1007/BF03160966.18570173
Pleil JD, Kim D, Prah JD, . 2007. Exposure reconstruction for reducing uncertainty in risk assessment: example using MTBE biomarkers and a simple pharmacokinetic model. Biomarkers 12(4):331–348. 10.1080/13547500701246334.17564841
Ponchon T, Baroud J, Pujol B, . 1988. Renal failure during dissolution of gallstones by methyl-tert-butyl ether. Lancet 2(8605):276–277. 10.1016/s0140-6736(88)92562-7.
Poulsen M, Lemon L, Barker JF. 1992. Dissolution of monoaromatic hydrocarbons into groundwater from gasoline-oxygenated mixtures. Environ Sci Technol 26(12):2483–2489. 10.1021/es00036a022.
Prah J, Ashley D, Blount B, . 2004. Dermal, oral, and inhalation pharmacokinetics of methyl tertiary butyl ether (MTBE) in human volunteers. Toxicol Sci 77(2):195–205. 10.1093/toxsci/kfh009.14600279
Prah JD, Goldstein GM, Devlin R, . 1994. Sensory, symptomatic, inflammatory, and ocular responses to and the metabolism of methyl tertiary butyl ether in a controlled human exposure experiment. Inhal Toxicol 6(6):521–538. 10.3109/08958379409003038.
Prescott-Mathews JS, Wolf DC, Wong BA, . 1997. Methyl tert-butyl ether causes alpha2u-globulin nephropathy and enhanced renal cell proliferation in male Fischer-344 rats. Toxicol Appl Pharmacol 143(2):301–314. 10.1006/taap.1996.8085.9144447
Rajasarkka J, Pernica M, Kuta J, . 2016. Drinking water contaminants from epoxy resin-coated pipes: A field study. Water Res 103:133–140. 10.1016/j.watres.2016.07.027.27448038
Rao HV, Ginsberg GL. 1997. A physiologically-based pharmacokinetic model assessment of methyl t-butyl ether in groundwater for a bathing and showering determination. Risk Anal 17(5):583–598. 10.1111/j.1539-6924.1997.tb00899.x.9404048
RePORTER. 2022. Methyl-tert-butyl ether. Research Portfolio Online Reporting Tools, National Institutes of Health. http://projectreporter.nih.gov/reporter.cfm. August 31, 2022.
Rhodes IA, Olvera RZ, Leon JA. 1991. Determination of gasoline range total petroleum hydrocarbons (TPH) and approximate boiling point distribution in soil by gas chromatography. In: Kostecki PT, Calabrese EJ, eds. Hydrocarbon contaminated soils and groundwater. Vol. 1. London, England: CRC Press Inc., 273–290.
Robinson M, Bruner RH, Olson GR. 1990. Fourteen- and ninety-day oral toxicity studies of methyl tertiary-butyl ether in Sprague-Dawley rats. J Am Coll Toxicol 9(5):525–540. 10.3109/10915819009078761.
Rosenkranz HS, Klopman G. 1991. Predictions of the lack of genotoxicity and carcinogenicity in rodents of two gasoline additives: Methyl- and ethyl-t-butyl ethers. In Vitro Toxicol 4(1):49–54.
Saeedi A, Fardid R, Khoshnoud MJ, . 2017. Disturbance of zinc and glucose homeostasis by methyl tert-butyl ether (MTBE); evidence for type 2 diabetes. Xenobiotica 47(6):547–552. 10.1080/00498254.2016.1201872.27389249
Salimi A, Vaghar-Moussavi M, Seydi E, . 2016. Toxicity of methyl tertiary-butyl ether on human blood lymphocytes. Environ Sci Pollut Res Int 23(9):8556–8564. 10.1007/s11356-016-6090-x.26797945
Sanders PF, Hers I. 2006. Vapor intrusion in homes over gasoline-contaminated ground water in Stafford, New Jersey. Ground Water Monit Remed 26(1):63–72. 10.1111/j.1745-6592.2006.00048.x.
Saraya A, Rai RR, Tandon RK. 1990. Experience with MTBE as a solvent for common bile duct stones in patients with T-tube in situ. J Gastroenterol Hepatol 5(2):130–134. 10.1111/j.1440-1746.1990.tb01817.x.2103393
Savolainen H, Pfaffli P, Elovaara E. 1985. Biochemical effects of methyl tertiary-butyl ether in extended vapour exposure of rats. Arch Toxicol 57(4):285–288. 10.1007/BF00324794.4091653
Sax SN, Bennett DH, Chillrud SN, . 2004. Differences in source emission rates of volatile organic compounds in inner-city residences of New York City and Los Angeles. J Expo Anal Environ Epidemiol 14(Suppl 1):S95–109. 10.1038/sj.jea.7500364.15118751
Schenk L, Rauma M, Fransson MN, . 2018. Percutaneous absorption of thirty-eight organic solvents in vitro using pig skin. PLoS ONE 13(10):e0205458. 10.1371/journal.pone.0205458.30379962
Schumacher KA, Swobodnik W, Janowitz P, . 1990. Radiographic aspects in transcatheter contact dissolution of calcified gallbladder concrements. Eur J Radiol 10(1):28–34. 10.1016/0720-048x(90)90082-m.2107076
Sernau RC. 1989. Mutagenicity test on methyl tertiary butyl ether drosophila melanogaster sex-linked recessive lethal test (final report) with cover letter dated 041489. MTBE Committee. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0528039. 408913430. 42098G22.
Shamsipur M, Miran Beigi AA, Teymouri M, . 2012. Biotransformation of methyl tert-butyl ether by human cytochrome P450 2A6. Biodegradation 23(2):311–318. 10.1007/s10532-011-9510-0.21915685
Shanley A. 1990. Methyl t-butyl ether helps loosen the clean air/octane vise. Chem Bus 12(2):14–16.
Silva LK, Espenship MF, Pine BN, . 2019. Methyl tertiary-butyl ether exposure from gasoline in the U.S. Population, NHANES 2001-2012. Environ Health Perspect 127(12):127003. 10.1289/EHP5572.31821015
Smith DF, Kleindienst TE, Hudgens EE, . 1991. The photooxidation of methyl tertiary butyl ether. Int J Chem Kinet 23(10):907–924. 10.1002/kin.550231006.
Snamprogetti. 1980. Snamprogetti MTBE toxicological data with cover letter dated 101386. Texas Petrochemicals Corporation. Submitted to the U.S. Environmental Protection Agency under section FYI. OTS00005180. FYIOTS10860518. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00005180.xhtml. October 4, 2022.
Snyder R. 1979. Studies on the metabolism of t-butyl methyl ether (TBME). Philadelphia, PA: Jefferson Medical College.
Solomon GM, Hurley S, Carpenter C, . 2021. Fire and water: Assessing drinking water contamination after a major wildfire. ACS ES T Water 1(8):1878–1886. 10.1021/acsestwater.1c00129.34423333
Swenberg JA, Dietrich DR. 1991. Immunohistochemical localization of a2u-globulin in kidneys of treated and control rats of a 13-week vapor inhalation study undertaken with methyl tertiary butyl w-letter 092091. MTBE Task Force. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0533555. 86910001009. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0533555.xhtml. October 4, 2022.
Swenberg JA, Short B, Borghoff S, . 1989. The comparative pathobiology of alpha 2u-globulin nephropathy. Toxicol Appl Pharmacol 97(1):35–46. 10.1016/0041-008x(89)90053-7.2464861
Tang Y, Ren Q, Wen Q, . 2019. Effect of methyl tert-butyl ether on adipogenesis and glucose metabolism in vitro and in vivo. J Environ Sci (China) 85:208–219. 10.1016/j.jes.2019.06.015.31471028
Tepper JS, Jackson MC, McGee JK, . 1994. Estimation of respiratory irritancy from inhaled methyl tertiary butyl ether in mice. Inhal Toxicol 6(6):563–569. 10.3109/08958379409003041.
Texaco Inc. 1981. A nine day inhalation toxicity study of MTBE in the rat with cover letter dated 020687. Texaco Incorporated. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0513213. 86870000263.
Thistle JL, May GR, Bender CE, . 1989. Dissolution of cholesterol gallbladder stones by methyl tert-butyl ether administered by percutaneous transhepatic catheter. N Engl J Med 320(10):633–639. 10.1056/NEJM198903093201004.2918875
Tobio-Calo R, Llerena JM, Pinto-Pabon I, . 1992. Dissolution of multiple biliary duct stones using methyl tert-butyl ether (MTBE): experience in two cases. Cardiovasc Intervent Radiol 15(4):247–250. 10.1007/BF02733932.1394363
TRI21. 2022. TRI explorer: Methyl tert-butyl ether. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. December 14, 2022.
Tritapepe R, Pozzi C, Caspani P, . 1989. Unexpected dilatation of the common bile duct after methyl tertiary butyl ether (MTBE) in rabbits. Possible implications to findings in man. Gut 30(2):206–212. 10.1136/gut.30.2.206.2703142
Tuazon EC, Carter WPL, Aschmann SM, . 1991. Products of the gas-phase reaction of methyltertbutyl ether with the OH radical in the presence of NOx. Int J Chem Kinet 23(11):1003–1015. 10.1002/kin.550231105.
Tyl RW. 1989. Developmental toxicity study of inhaled methyl tertiary butyl ether in New Zealand white rabbits (final report) with attachments and cover letter dated 07/12/1989. Union Carbide Corp. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0528041. 408913426. 42098G42. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0528041.xhtml. January 21, 2020.
Tyl RW, Neeper-Bradley TL. 1989. Developmental toxicity study of inhaled methyl tertiary butyl ether in CD-1 mice (final report) with attachments and cover letter dated 072689. Union Carbide Corp. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0528042. 408913432. 42098G52. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0528042.xhtml. January 21, 2020.
Uchida N, Nakatsu T, Hirabayashi S, . 1994. Direct dissolution of gallstones with methyl tert-butyl ether (MTBE) via endoscopic transpapillary catheterization in the gallbladder (ETCG). J Gastroenterol 29(4):486–494. 10.1007/BF02361248.7951860
USC. 2005. Energy Policy Act of 2005. U.S. Congress. 42 USC §§ 15801 et seq. https://www.congress.gov/109/plaws/publ58/PLAW-109publ58.pdf. December 24, 2019.
USGS. 1995. Occurrence of the gasoline additive MTBE in shallow ground water in urban and agricultural areas. U.S. Geological Survey. FS11495. 10.3133/fs11495.
USGS. 2006. Volatile organic compounds in the nation’s ground water and drinking-water supply wells. Reston, VA: U.S. Geological Survey. Circular 1292. https://pubs.usgs.gov/circ/circ1292/pdf/circular1292.pdf. December 30, 2019.
USGS. 2014. Water quality in principal aquifers of the United States, 1991–2010. Reston, VA: U.S. Geological Survey. Circular 1360. https://pubs.usgs.gov/circ/1360/pdf/circ1360report.pdf. October 4, 2022.
USGS. 2016. Determination of heat purgeable and ambient purgeable volatile organic compounds in water by gas chromatography/mass spectrometry. Reston, VA: U.S. Geological Survey. TM5B12. 10.3133/tm5B12.
USGS. 2019. Baseline environmental monitoring of groundwater, surface water, and soil at the ammonium perchlorate rocket motor destruction facility at the Letterkenny Army Depot, Chambersburg, Pennsylvania, 2016. Reston, VA: U.S. Geological Survey. OFR20191094. https://pubs.er.usgs.gov/publication/ofr20191094. December 24, 2019.
Vainiotalo S, Pekari K, Aitio A. 1998. Exposure to methyl tert-butyl ether and tert-amyl methyl ether from gasoline during tank lorry loading and its measurement using biological monitoring. Int Arch Occup Environ Health 71(6):391–396. 10.1007/s004200050297.9766912
Vainiotalo S, Riihimaki V, Pekari K, . 2007. Toxicokinetics of methyl tert-butyl ether (MTBE) and tert-amyl methyl ether (TAME) in humans, and implications to their biological monitoring. J Occup Environ Hyg 4(10):739–750. 10.1080/15459620701551540.17668360
van Sonnenberg E, Hofmann AF, Neoptolemus J, . 1986. Gallstone dissolution with methyl-tert-butyl ether via percutaneous cholecystostomy: success and caveats. AJR Am J Roentgenol 146(4):865–867. 10.2214/ajr.146.4.865.3485362
van Sonnenberg E, Zakko S, Hofmann AF, . 1991. Human gallbladder morphology after gallstone dissolution with methyl tert-butyl ether. Gastroenterology 100(6):1718–1723. 10.1016/0016-5085(91)90674-a.2019376
Vergnes JS, Morabit ER. 1989. Methyl tertiary butyl ether repeated exposure vapor inhalation study in rats: In vivo cytogenetic evaluation (final report) with cover letter dated 051889. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0528040. 408913431. 42098G32. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0528040.xhtml. January 17, 2020.
Vergnes JS, Kintigh WJ. 1993. Methyl tertiary butyl ether: Bone marrow micronucleus test in mice with cover letter dated 111593. MTBE Committee. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0556627. 86940000031. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0556627.xhtml. January 20, 2020.
Vergnes JS, Chun JS. 1994. Methyl tertiary butyl ether: In vivo-in vitro hepatocyte unscheduled DNA synthesis assay in mice with cover letter dated 06/13/94. MTBE Task Force. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557384. 86940000975. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557384.xhtml. January 20, 2020.
Vergunst H, Brakel K, Nijs HG, . 1994. Methyl tert-butyl ether improves the efficacy of extracorporeal shock wave lithotripsy of human gallstones implanted in pigs. Eur J Surg 160(11):619–625.7858047
Vosahlikova M, Cajthaml T, Demnerova K, . 2006. Effect of methyl tert-butyl ether in standard tests for mutagenicity and environmental toxicity. Environ Toxicol 21(6):599–605. 10.1002/tox.20223.17091504
Wallington TJ, Dagaut P, Liu R, . 1988. Gas-phase reactions of hydroxyl radicals with the fuel additives methyl tert-butyl ether and tert-butyl alcohol over the temperature range 240-440 K. Environ Sci Technol 22(7):842–844. 10.1021/es00172a017.22195672
Ward JB, Au WW, Whorton EB, . 1994. Genetic toxicity of methyl-tertiary butyl ether. Galveston, TX: University of Texas Medical Branch.
White RD, Daughtrey WC, Wells MS. 1995. Health effects of inhaled tertiary amyl methyl ether and ethyl tertiary butyl ether. Toxicol Letters 82–83:719–724. 10.1016/0378-4274(95)03590-7.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Wickliffe JK, Stock TH, Howard JL, . 2020. Increased long-term health risks attributable to select volatile organic compounds in residential indoor air in southeast Louisiana. Sci Rep 10(1):21649. 10.1038/s41598-020-78756-7.33303920
Williams HJ, Bender CE, LeRoy AJ. 1990. Dissolution of cholesterol gallstones using methyl tert-butyl ether. Cardiovasc Intervent Radiol 13(4):272–277. 10.1007/BF02578030.2121355
Williams TM, Cattley RC, Borghoff SJ. 2000. Alterations in endocrine responses in male Sprague-Dawley rats following oral administration of methyl tert-butyl ether. Toxicol Sci 54(1):168–176. 10.1093/toxsci/54.1.168.10746943
Williams-Hill D, Spears CP, Prakash S, . 1999. Mutagenicity studies of methyl-tert-butylether using the Ames tester strain TA102. Mutat Res 446(1):15–21. 10.1016/s1383-5718(99)00137-0.10613182
Winterberg M, Schulte-Korne E, Peters U, . 2012. Methyl tert-butyl ether. In: Ullmann’s Encyclopedia of Industrial Chemistry. Vol. 23. Weinheim, Germany: Wiley-VCH Verlag GmbH & Co., 119–130. 10.1002/14356007.a16_543.pub2.
Wisconsin DHSS. 1995. An investigation of health concerns attributed to reformulated gasoline use in southeastern Wisconsin. Final Report. Madison, WI: Wisconsin Department of Health and Social Services.
WQP. 2022. Methyl tert-butyl ether. Water quality portal. National Water Quality Monitoring Council. https://www.waterqualitydata.us/. August 24, 2022.
Yang J, Wei Q, Peng X, . 2016. Relationship between methyl tertiary butyl ether exposure and non-alcoholic fatty liver disease: A cross-sectional study among petrol station attendants in southern China. Int J Environ Res Public Health 13(10):946. 10.3390/ijerph13100946.27669281
Yeh CK, Novak JT. 1991. Anaerobic biodegradation of oxygenates in the subsurface. In: Proceedings of the 1991 Petroleum hydrocarbons and organic chemicals in ground water: Prevention, detection, and restoration. Dublin, OH: Ground Water Management, 427–441.
Yoshikawa M, Arashidani K, Katoh T, . 1994. Pulmonary elimination of methyl tertiary-butyl ether after intraperitoneal administration in mice. Arch Toxicol 68(8):517–519. 10.1007/s002040050105.7802593
You DD, Cho SJ, Kim OH, . 2019. Superior gallstone dissolubility and safety of tert-amyl ethyl ether over methyl-tertiary butyl ether. World J Gastroenterol 25(39):5936–5952. 10.3748/wjg.v25.i39.5936.31660031
Yuan Y, Wang HF, Sun HF, . 2007. Adduction of DNA with MTBE and TBA in mice studied by accelerator mass spectrometry. Environ Toxicol 22(6):630–635. 10.1002/tox.20295.18000852
Zakko S, Oberstein R, Tomicic T, . 1995. A method to quantitatively compare in vivo the effects of gallstone solvents on intestinal mucosal function: A controlled study comparing mono-octanoin with methyl tert-butyl ether in the rat. Proc Soc Exp Biol Med 209(2):190–194. 10.3181/00379727-209-43895.7770471
Zheng G, Zhang W, Zhang Y, . 2009. g-Aminobutyric acid_A_ (GABA_A_) receptor regulates ERK1/2 phosphorylation in rat hippocampus in high doses of methyl tert-butyl ether (MTBE)-induced impairment of spatial memory. Toxicol Appl Pharmacol 236(2):239–245. 10.1016/j.taap.2009.01.004.19344668
Zhou W, Yuan D, Huang G, . 2000. Mutagenicity of methyl tertiary butyl ether. J Environ Pathol Toxicol Oncol 19(1&2):35–39.10905506
Zhu J, Newhook R, Marro L, . 2005. Selected volatile organic compounds in residential air in the city of Ottawa, Canada. Environ Sci Technol 39(11):3964–3971. 10.1021/es050173u.15984771
Zhu Q, Zhu S, Li Q, . 2022. Methyl tert-butyl ether inhibits pubertal development of Leydig cells in male rats by inducing mitophagy and apoptosis. Ecotoxicol Environ Saf 232:113282. 10.1016/j.ecoenv.2022.113282.35131586