# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Gaston Casillas, Ph.D. (Lead)
  Mike Fay, Ph.D.
  Jennifer Przybyla, Ph.D.

- ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA

- Kimberly Zaccaria, Ph.D., D.A.B.T.
  Mario Citra, Ph.D.
  Lisa Ingerman, Ph.D., D.A.B.T.
  Sabah Tariq, M.S.
  David W. Wohlers, Ph.D.

- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

- Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

- ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA.

## PEER REVIEWERS

Peer Reviewers for the full profile:

1. Clifford P. Weisel, Ph.D.; Professor; Environmental and Occupational Health Sciences Institute; SPH - Rutgers University; 170 Frelinghuysen Road; Piscataway, New Jersey
2. Deborah A. Cory-Slechta, Ph.D.; Professor of Environmental Medicine, Pediatrics and Public Health Sciences; Department of Environmental Medicine, Box EHSC; University of Rochester Medical Center; Rochester, New York
3. James V. Bruckner, Ph.D.; Emeritus; Interdisciplinary Toxicology Program, Professor Pharmaceutical and Biomedical Sciences, College of Pharmacy; University of Georgia, Athens, Georgia

Peer Reviewers for the intermediate-duration oral MRL:

1. Krassimira Hristova, Ph.D.; Associate Professor; Biological Sciences Department; Marquette University; Milwaukee, Wisconsin
2. James V. Bruckner, Ph.D.; Emeritus; Pharmaceutical & Biomedical Sciences, College of Pharmacy; University of Georgia; Athens, Georgia
3. Clifford P. Weisel, Ph.D.; Environmental and Occupational Health Sciences Institute; SPH - Rutgers University; Piscataway, New Jersey

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.