# VERSION HISTORY

Date | Description
September 2023 | Final toxicological profile released
January 2022 | Draft for public comment toxicological profile released
August 1996 | Final toxicological profile released