# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding MTBE in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for MTBE.

Table 7-1 Regulations and Guidelines Applicable to Methyl tert-Butyl Ether (MTBE)

Agency | Description | Information | Reference
Air
EPA | RfC | 3 mg/m^3^ (0.83 ppm) | IRIS 1993
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | Health-based values not provided^a^ | EPA 2018b, EPA 1997
EPA | National primary drinking water regulations | Not listed | EPA 2009
EPA | RfD | Not evaluated | IRIS 1993
WHO | Drinking water quality guidelines | Not derived^b^ | WHO 2022
FDA | Substances Added to Food | Not listed^c^ | FDA 2022
Cancer
HHS | Carcinogenicity classification | No data | NTP 2021
EPA | Carcinogenicity classification | No data | IRIS 1993
IARC | Carcinogenicity classification | Group 3^d^ | IARC 1999
Occupational
ACGIH | TLV (TWA) | 50 ppm | ACGIH 2002
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | No data | OSHA 2021a, 2021b, 2021c
NIOSH | REL (up to 10-hour TWA) | No data | NIOSH 2018
Emergency Criteria
EPA | AEGLs-air | | EPA 2018c
EPA | AEGL 1^e^ | | EPA 2018c
EPA | 10-minute, 30-minute, 60-minute, 4-hour, 8-hour | 50 ppm | EPA 2018c
EPA | AEGL 2^e^ | | EPA 2018c
EPA | 10-minute | 1,400 ppm | EPA 2018c
EPA | 30-minute | 800 ppm | EPA 2018c
EPA | 60-minute | 570 ppm | EPA 2018c
EPA | 4-hour, 8-hour | 400 ppm | EPA 2018c
EPA | AEGL 3^e^ | | EPA 2018c
EPA | 10-minute | 13,000 ppm^f^ | EPA 2018c
EPA | 30-minute | 7,500 ppm^g^ | EPA 2018c
EPA | 60-minute | 5,300 ppm^g^ | EPA 2018c
EPA | 4-hour | 2,700 ppm^g^ | EPA 2018c
EPA | 8-hour | 1,900 ppm^g^ | EPA 2018c
DOE | PACs-air | | DOE 2018a
DOE | PAC-1^h^ | 50 ppm | DOE 2018a
DOE | PAC-2^h^ | 570 ppm | DOE 2018a
DOE | PAC-3^h^ | 5,300 ppm | DOE 2018a

a Advisory recommends that keeping contamination levels in the range of 20–40 µg/L or below (odor/taste thresholds) to protect consumer acceptance of the water would also provide a margin of safety from toxic effects.

b Reason for not establishing guideline value: guideline would be significantly higher than concentrations at which MTBE would be detected by odor.

c The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

d Group 3: not classifiable as to its carcinogenicity to humans.

e Definitions of AEGL terminology are available from EPA (2018d).

f Value is higher than 50% of the LEL of MTBE in air (16,000 ppm); therefore, extreme safety considerations on the hazard of explosion must be taken into account.

g Value is higher than 10% of the LEL of MTBE in air (16,000 ppm); therefore, safety considerations on the hazard of explosion must be taken into account.

h Definitions of PAC terminology are available from DOE (2018b).

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; LEL = lower explosive limit; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit value; TWA = time-weighted average; WHO = World Health Organization