# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

MTBE is a VOC that was added to gasoline to reduce air pollution. MTBE and other components, commonly known as “oxygenates,” were added to gasoline to increase the octane number and reduce carbon monoxide emissions. Information regarding the chemical identity of MTBE is presented in Table 4-1.

Table 4-1 Chemical Identity of Methyl tert-Butyl Ether (MTBE)

Characteristic | Information | Reference
Chemical name | Methyl tert-butyl ether | Budavari 1989
Synonym(s) and registered trade name(s) | tert-Butyl methyl ether; 2-methoxy-2-methylpropane; MTBE; methyl t-butyl ether | Budavari 1989
Chemical formula | C_5_H_12_O | Budavari 1989
Chemical structure | [image]
CAS Registry Number | 1634-04-4 | Budavari 1989

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

MTBE is a relatively volatile chemical and is moderately soluble in water. It is very soluble in some organic solvents such as alcohol and ether. MTBE is flammable and is a moderate fire risk (Lewis 1987). Information regarding the physical and chemical properties of MTBE is presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of Methyl tert-Butyl Ether (MTBE)

Property | Information | Reference
Molecular weight | 88.15 | Lide 1994
Color | Colorless | Winterberg et al. 2012
Physical state | Liquid | Budavari 1989
Melting point | -109°C | Lide 1994
Boiling point | 55.2°C | Lide 1994
Density at 20°C | 0.7405 g/cc | Lide 1994
Odor | Terpene-like | Gilbert and Calabrese 1992
Odor threshold:
Water | 15–680 ppb | Angle 1991; EPA 1997; Gilbert and Calabrese 1992
Air | 180 ppb | Prah et al. 1994
Solubility:
Water at 20°C | 4–5% | Gilbert and Calabrese 1992
Organic solvents | Soluble in alcohol, ether | Lide 1994
Partition coefficients:
Log K_ow_ | 0.94 | NLM 2020
Log K_oc_ | 1.05 (estimated) | Gilbert and Calabrese 1992
Log K_oc_ | 2.13±0.060 (measured) | Greenwood et al. 2007
Vapor pressure at 20°C | 245 mm Hg at 25°C | Budavari 1989
Henry’s law constant at 25°C | 5.87x10^-4^ atm-m^3^/mol | Hine and Mookerjee 1975
Autoignition temperature | 224°C | Budavari 1989
Flashpoint | -28°C | Budavari 1989
Flashpoint | 28°C (closed cup) | Gilbert and Calabrese 1992
Flammability limits | No data
Conversion factors
ppm (v/v) to mg/m^3^ in air at 25°C | 1 ppm=3.61 mg/m^3^
mg/m^3^ to ppm (v/v) in air at 25°C | 1 mg/m^3^=0.28 ppm
Explosive limits | 1.65–8.4% in air | Gilbert and Calabrese 1992