# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## Methyl tert-butyl ether (MTBE) Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methyl tert-butyl ether (MTBE)
CAS Numbers: | 1634-04-4
Date: | September 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 2 ppm
Critical Effect: | Neurobehavior (altered gait)
Reference: | Daughtrey et al. 1997; Gill 1989
Point of Departure: | BMCL_10_ of 454 ppm (BMCL_HEC_ of 70.1 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 8
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 2 ppm was derived for MTBE based on neurological effects in female rats exposed to concentrations ≥4,000 ppm for 6 hours/day; a NOAEL of 800 ppm was identified (Daughtrey et al. 1997; Gill 1989). The MRL is based on a BMCL_10_ (95% lower confidence limit on the benchmark concentration [BMC; subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk]) of 454 ppm for increased incidence of altered gait in female rats. The BMCL_10_ was adjusted to continuous duration exposure and converted to a human equivalent concentration (BMCL_HEC_) of 70.1 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans after dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: Available acute-duration inhalation studies report numerous MTBE-related effects at lowest-observed-adverse-effect levels (LOAELs) in the range of 1,000–4,000 ppm, including neurological effects in rats and mice, hepatic effects in female mice, and decreased fetal weights in mouse offspring (see Table A-1). Renal effects in male rats were also observed at exposure levels ≥1,500 ppm; however, these effects were not considered an appropriate basis for the MRL because available toxicity and mechanistic studies indicate that renal effects in males are partially attributable to α2u-globulin, which is not relevant for human health (Ahmed 2001; Bogen and Heilman 2015; McGregor 2006; Phillips et al. 2008). Therefore, only neurological, respiratory, hepatic, and developmental effects were considered for MRL derivation.

Table A-1 Summary of Relevant NOAEL and LOAEL Values Following Acute-Duration Inhalation MRL to Methyl tert-Butyl Ether (MTBE)

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Neurological effects
Fischer-344 rat | 13 days; 6 hours/day | ND | 2,000 | Hypoactivity | Dodd and Kintigh 1989
CD-1 mouse | 13 days; 6 hours/day | ND | 2,000 | Hypoactivity | Dodd and Kintigh 1989
CD-1 mouse | 2 days; 6 hours/day | 400 | 3,000 | Hypoactivity, decreased startle response | Vergnes and Chun 1994
Fischer-344 rat | 6 hours | 800 | 4,000 | Altered gait and decreased limb strength in females | Daughtrey et al. 1997; Gill 1989
Respiratory effects
Sprague-Dawley rat | 9 days; 5 days/week; 6 hours/day | ND | 1,000 | Inflammation of nasal mucosa and trachea | Texaco Inc. 1981
Hepatic effects
CD-1 mouse | 13 days; 6 hours/day | ND | 2,000 | Increased relative liver weight in females | Dodd and Kintigh 1989
Developmental effects
CD-1 mouse | 10 days; (GDs 6–15); 6 hours/day | 1,000 | 4,000 | Decreased fetal weights | Bevan et al. 1997a

GD = gestation day; LOAEL = lowest observed adverse effect level; MRL = Minimal Risk Level; ND = not determined; NOAEL = no-observed-adverse-effect level

In order to identify the most sensitive POD, benchmark dose (BMD) modeling was attempted for critical neurological, respiratory, hepatic, and developmental endpoints in Table A-1 when data were amenable to modeling. The data were fit to all available dichotomous or continuous models in EPA’s Benchmark Dose Software (BMDS; version 3.2) using a benchmark response (BMR) of 1 standard deviation (grip strength, liver weight), 10% extra risk (altered gait incidence), or 5% relative deviation (developmental body weight). Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, a 95% lower confidence limit on the benchmark concentration (BMCL) that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all models providing adequate fit to the data, the lowest BMCL was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest Akaike information criterion (AIC) was chosen.

The datasets used for BMD modeling are presented in Tables A-2, A-3, and A-4. Neurological data from Dodd and Kintigh (1989) and Vergnes and Chun (1994) were inadequate for BMD modeling (incidence data not reported), and nasal and tracheal inflammation data from Texaco Inc. (1981) were inadequate for BMD modeling because the endpoint was only evaluated in control and high-exposure animals.

Table A-2 Neurological Endpoints in Female Rats Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) for 6 Hours

| Concentration (ppm)
| 0 | 800 | 4,000 | 8,000
Altered gait; Incidence (percent incidence) | 1/8; (13%) | 2/8; (25%) | 6/8^a^; (75%) | 8/8^b^; (100%)
Hind limb grip strength (kg); Mean±SD (n) | 0.40±0.079; (8) | 0.38±0.082; (8) | 0.35±0.051^a^; (8) | 0.28±0.084^b^; (8)

a p<0.05.

b p<0.01.

(n) = number of animals; SD = standard deviation

Source: Gill 1989 (unpublished report associated with published study by Daughtrey et al. 1997)

Table A-3 Fetal Weights in Mouse Offspring Following Maternal Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) on GDs 6–15 (6 Hours/Day)

| Concentration (ppm)
| 0 | 1,000 | 4,000 | 8,000
Fetal body weight/litter (%); Mean±SD (n) | 1.4±0.1; (27) | 1.4±0.1; (29) | 1.3±0.1^a^; (26) | 1.1±0.1^a^; (26)

a p<0.01.

GD = gestation day; (n) = number of animals; SD = standard deviation

Source: Bevan et al. 1997a

Table A-4 Liver Weights in Female Mice Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) for 13 Days (6 Hours/Day)

| Concentration (ppm)
| 0 | 2,000 | 4,000 | 8,000
Relative liver weight (percent body weight); Mean±SD (n) | 5.830±0.4339; (5) | 6.719±0.2502^a^; (5) | 6.644±0.1258^a^; (5) | 7.141±0.1970^a^; (5)

a p<0.01.

(n) = number of animals per group; SD = standard deviation

Source: Dodd and Kintigh 1989

Details of the modeling results for the model predictions for altered gait in female rats are in Table A-5. In accordance with the selection criteria mentioned above, the Probit model, a frequentist, unrestricted model, was selected for altered gait.

Table A-5 Model Predictions for Increased Incidence of Altered Gait in Female Rats Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) for 6 Hours (Daughtrey et al. 1997; Gill 1989)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Dichotomous Hill | 3,257.91 | 176.07 | 0.52 | 30.44 | 0.45 | -0.0001
Gamma^d^ | 886.04 | 180.30 | 0.56 | 30.50 | 0.25 | -0.32
Log-Logistic^e^ | 3,288.52 | 176.07 | 0.52 | 30.44 | 0.45 | -4.19x10^-05^
Multistage Degree 3^f^ | 635.33 | 189.94 | 0.88 | 30.06 | -0.04 | 0.07
Multistage Degree 2^f^ | 757.08 | 186.31 | 0.72 | 30.21 | -0.08 | 0.15
Multistage Degree 1^f^ | 287.81 | 168.16 | 0.68 | 29.18 | 0.23 | -0.48
Weibull^d^ | 1,027.72 | 184.48 | 0.64 | 30.30 | 0.30 | -0.18
Logistic | 772.71 | 446.91 | 0.92 | 28.29 | -0.07 | 0.18
Log-Probit | 2,873.77 | 181.50 | 0.52 | 30.44 | 0.45 | -0.0001
Probit ^g^ | 732.29 | 453.69 | 0.96 | 28.14 | -0.07 | 0.14

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Selected model. All models provided an adequate fit to the data. BMCLs were sufficiently close (differed by <3-fold). Therefore, the model with the lowest AIC was selected (Probit).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

Details of the modeling results for the model predictions in female rats for hindlimb strength and in mice for decreased fetal weights are in Tables A-6 and A-7, respectively. In accordance with the selection criteria mentioned above, the constant variance, frequentist, restricted 3-degree polynomial model was selected for hindlimb strength and constant variance, frequentist, restricted 2-degree polynomial model was selected for decreased fetal weights. An adequate model was not identified for increased relative liver weight in mice because models failed to meet conventional goodness-of-fit criteria.

Table A-6 Results from Benchmark Dose (BMD) Analysis (Constant Variance) for Decreased Hindlimb Grip Strength in Female Rats Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) for 6 Hours (Daughtrey et al. 1997; Gill 1989)

Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Exponential (model 2)^d^ | 4,673.41 | 2,881.26 | 0.84 | -72.71 | 0.48 | -0.25
Exponential (model 3)^d^ | 5,470.26 | 2,915.30 | 0.65 | -70.86 | 0.13 | -0.04
Exponential (model 4)^d^ | 4,673.42 | 2,881.26 | 0.84 | -72.71 | 0.48 | -0.25
Exponential (model 5)^d^ | 5,470.26 | 2,915.30 | 0.65 | -70.86 | 0.13 | -0.04
Hill^e^ | 4,263.15 | 3,835.68 | 0.57 | -70.74 | 2.78x10^-7^ | 1.57x10^-5^
Polynomial (3-degree) ^e^ ^,^ ^f^ | 5,613.07 | 3,311.80 | 0.95 | -72.95 | 0.07 | -0.01
Polynomial (2-degree)^e^ | 5,512.37 | 3,307.32 | 0.94 | -72.93 | 0.10 | -0.02
Power | 5,441.54 | 3,298.56 | 0.68 | -70.89 | 0.15 | -0.04
Linear | 4,932.20 | 3,286.39 | 0.89 | -72.83 | 0.36 | -0.15

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Coefficients restricted to be negative.

f Selected model. The constant variance model provided an adequate fit to the data. All models provided adequate fits to the means. The BMCLs were sufficiently close (<3-fold); therefore, the model with the lowest AIC was selected (3-degree polynomial).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC(subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a change of 1 standard deviation from the control)

Table A-7 Results from Benchmark Dose (BMD) Analysis (Constant Variance) for Decreased Fetal Weights in Mouse Offspring Following Maternal Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) on GDs 6–15 (6 Hours/Day) (Bevan et al. 1997a)

Model | BMC_RD5_^a^ (ppm) | BMCL_RD5_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_RD5_^a^ (ppm) | BMCL_RD5_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Exponential (model 2)^d^ | | | 0.03 | -181.89 | 0.77 | 1.73
Exponential (model 3)^d^ | 3,171.81 | 2,196.77 | 0.69 | -186.78 | 0.31 | -0.10
Exponential (model 4)^d^ | | | 0.03 | -181.89 | 0.77 | 1.73
Exponential (model 5)^d^ | | | NA | -184.78 | 0.30 | -0.09
Hill^e^ | 3,891.22 | 3,786.64 | 1.00 | -186.94 | -0.0003 | -0.0008
Polynomial (3-degree)^e^ | 3,108.92 | 2,020.52 | 0.80 | -188.51 | 0.51 | -0.23
Polynomial (2-degree) ^e^ ^,^ ^f^ | 3,108.92 | 2,055.83 | 0.80 | -188.51 | 0.51 | -0.23
Power | 3,141.84 | 2,142.12 | 0.64 | -186.73 | 0.35 | -0.12
Linear | | | 0.07 | -183.73 | 0.68 | 1.47

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Coefficients restricted to be negative.

f Selected model. The constant variance model provided an adequate fit to the data. All models provided adequate fits to the means except for the Exponential models 2, 4, and 5 and the linear model. The BMCLs of the adequately fitting models were sufficiently close (<3-fold); therefore, the model with the lowest AIC was selected (2-degree polynomial). While it appears that the 2- and 3-degree polynomial models have the same AIC due to rounding, if you go out 10 decimal places, the 2-degree is slightly lower; therefore, it is the selected model.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., RD5 = dose associated with a 5% relative deviation); GD = gestation day; NA = not applicable

The candidate PODs for neurological, respiratory, hepatic, and developmental effects are summarized in Table A-8. The lowest PODs were identified for neurological effects, with adjusted BMCL/NOAEL values of 100–114 ppm. Therefore, neurological effects were selected as the critical effect.

Table A-8 Summary of Candidate Effects and POD Values Considered for Derivation of an Acute-Duration Inhalation MRL for Methyl tert-Butyl Ether (MTBE)

Species | Duration | Effect | Candidate POD (ppm) | POD type | Reference
Neurological effects
Fischer-344 rat | 13 days; 6 hours/day | Hypoactivity | 500 | LOAEL_ADJ_ | Dodd and Kintigh 1989
CD-1 mouse | 13 days; 6 hours/day | Hypoactivity | 500 | LOAEL_ADJ_ | Dodd and Kintigh 1989
CD-1 mouse | 2 days; 6 hours/day | Hypoactivity, decreased startle response | 100 | NOAEL_ADJ_ | Vergnes and Chun 1994
Fischer-344 rat | 6 hours | Altered gait in females | 114 | BMCL_ADJ_ | Daughtrey et al. 1997; Gill 1989^a^
Fischer-344 rat | 6 hours | Decreased limb strength in females | 828 | BMCL_ADJ_ | Daughtrey et al. 1997; Gill 1989^a^
Respiratory effects
Sprague-Dawley rat | 9 days; 5 days/week; 6 hours/day | Inflammation of nasal mucosa and trachea | 179 | LOAEL_ADJ_ | Texaco Inc. 1981
Hepatic effects
CD-1 mouse | 13 days; 6 hours/day | Increased relative liver weight in females | 500 | LOAEL_ADJ_ | Dodd and Kintigh 1989
Developmental effects
CD-1 mouse | 10 days; (GDs 6–15); 6 hours/day | Decreased fetal weights | 514 | BMCL_ADJ_ | Bevan et al. 1997a

a Gill (1989) is the unpublished report associated with Daughtrey et al. (1997). Raw data for benchmark dose modeling was acquired from Gill (1989) (not available in published report).

BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL_ADJ_ = 95% lower confidence limit on the BMC (adjusted for continuous exposure); GD = gestation day; LOAEL_ADJ_ = lowest observed adverse effect level (adjusted for continuous exposure); MRL = Minimal Risk Level; NA = not applicable; ND = not determined; NOAEL_ADJ_ = no-observed-adverse-effect level (adjusted for continuous exposure); POD = point of departure

Selection of the Principal Study: Potential PODs for deriving an acute-duration inhalation MRL for MTBE based on neurological effects include:

- NOAEL_ADJ_ of 100 ppm for hypoactivity and decreased startle response in mice (Vergnes and Chun 1994)
- BMCL_ADJ_ of 114 ppm for altered gait in female rats (Daughtrey et al. 1997; Gill 1989)
- LOAEL_ADJ_ of 500 ppm for hypoactivity in rats and mice (Dodd and Kintigh 1989)
- BMCL_ADJ_ of 828 ppm for decreased limb strength in female rats (Daughtrey et al. 1997; Gill 1989)

The BMCL_ADJ_ of 114 ppm for neurological effects (altered gait) in female rats observed by Daughtrey et al. (1997) following a 6-hour exposure to MTBE was selected as the POD for the acute-duration inhalation MRL. Data for this study are also available in the unpublished report by Gill (1989). This POD was selected over the NOAEL_ADJ_ of 100 ppm for neurological effects reported by Vergnes and Chun (1994) because the selected study was designed to examine potential neurological effects following acute-duration inhalation exposure to MTBE, including clinical signs, a functional observation battery (FOB), and motor activity, while Vergnes and Chun (1994) only evaluated clinical signs in the context of an in vivo genotoxicity assay. Additionally, the selected study included more animals per dose than Vergnes and Chun (1994). Therefore, there is higher confidence in the neurological POD from the study by Daughtrey et al. (1997). Additionally, quantitative data adequate for BMD modeling were only available for Daughtrey et al. (1997) (from the associated unpublished report by Gill 1989). Model fit for altered gait is shown in Figure A-1 (Probit model).

Figure A-1 Fit of Probit Model to Incidence Data for Altered Gait in Female Rats Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) for 6 Hours (Gill 1989)

Summary of the Principal Study:

Daughtrey WC, Gill MW, Pritts IM, . 1997. Neurotoxicological evaluation of methyl tertiary-butyl ether in rats. J Appl Toxicol 17(Suppl 1):S57–S64.9179728

Gill MW. 1989. Methyl tertiary butyl ether single exposure vapor inhalation neurotoxicity study in rats. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. 602-823. OTS0528043. 409813440.

Daughtrey et al. (1997) exposed Fischer 344 rats to MTBE vapor for 6 hours at concentrations of 0, 800, 4,000, or 8,000 ppm. Groups were comprised of 22 males and 22 females. Groups of 14 male and 14 female rats were evaluated for motor activity prior to and within 1 hour following a single 6-hour exposure. The length of the test sessions was either 90 minutes (pre-exposure) or 5 hours (post-exposure). The remaining eight rats/sex/group were given an FOB of tests (piloerection, respiratory pattern, gait, urination, startle response, pupil size, pupil response, catatonic pose, fore and hind paw grip strength, treadmill, inclined screen turn, toe pinch, time to tail flick, rectal temperature, and hind leg splay) prior to exposure and at 1, 6, and 24 hours after exposure. Data for this study are also available in the unpublished report by Gill (1989).

No rats died prematurely. No body weight effects were noted. No clinical signs of overt toxicity were observed. In the FOB, evidence of transient CNS depression was observed at the 1-hour observation at ≥4,000 ppm; no effects were observed at the 6- or 24-hour observations. Altered gait (ataxia, duck walk) and decreased body temperature were observed in females at ≥4,000 ppm and males at 8,000 ppm. Decreased grip strength was observed in females only at ≥4,000 ppm. Other significant behavioral findings in males and/or females at 8,000 ppm included decreased muscle tone, decreased treadmill performance, hindlimb splay, and labored respiration. Lacrimation was also observed but was attributed to the irritative nature of MTBE vapors. No significant behavioral observations were found in the 800-ppm group during the FOB. In motor activity testing, a biphasic result was observed in both sexes at 8,000 ppm, with a significant 60–67% reduction in motor activity at 10 minutes followed by significant increases up to 17-fold between 30 and 60 minutes, compared to controls. No significant findings were observed at 4,000 ppm. Significant changes in motor behavior at 800 ppm were observed only at 10 minutes and included a 24% increase in males and a 16% decrease in females. These findings were not considered biologically relevant due to lack of dose-response, low magnitude of effect, and differential findings in males versus females. Motor activity testing during the initial 180 minutes of the dark phase showed a statistically significant decrease in activity during the first hour of darkness only at 8,000 ppm (magnitude of effect not reported by the study authors).

Selection of the Point of Departure for the MRL: The BMCL_10_ of 454 ppm for neurological effects (altered gait) in female rats was selected as the POD. This value represents the lowest available POD for the critical effect (neurotoxicity) from an acute-duration comprehensive neurological study (Daughtrey et al. 1997). This value was selected over the NOAEL of 400 ppm based on clinical signs in the context of an in vivo genotoxicity assay by Vergnes and Chun (1994) due to higher confidence in the value derived from the more comprehensive study by Daughtrey et al. (1997).

Calculations

Intermittent Exposure: The BMCL_10_ of 454 ppm was adjusted from intermittent exposure to account for a continuous exposure scenario:

- BMCL_ADJ_ = 454 ppm × (6 hours/24 hours) = 114 ppm.

Human Equivalent Concentration: While several PBPK models have been developed for MTBE, further refinement is needed to decrease uncertainty in estimated exposure levels, particularly for humans (see Sections 3.1.5 and 6.2 for more details). Therefore, a human equivalent concentration (HEC) for extrarespiratory effects was calculated by multiplying the BMCL_ADJ_ by the ratio of animal:human blood gas partition coefficients, using a reported rat blood gas partition coefficient of 11.5 (Rao and Ginsberg 1997) and the midpoint of the range of human blood gas partition coefficients (17.7–19.6) reported by Rao and Ginsberg (1997) and Kim et al. (2007):

- BMCL_HEC_ = BMCL_ADJ_ × ratio of animal:human blood gas partition coefficients
- BMCL_HEC_ = 114 ppm × (11.5/18.7)
- BMCL_HEC_ = 114 ppm × (0.615)
- BMCL_HEC_ = 70.1 ppm

Uncertainty Factor: The BMCL_HEC_ is divided by a total uncertainty factor (UF) of 30.

- 3 for extrapolation from animals to humans after dosimetric adjustment
- 10 for human variability

MRL = BMCL_HEC_ ÷ UF 70.1 ppm ÷ ( 3 × 10 ) = 2 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Selection of a neurological effect as the critical effect following acute-duration inhalation exposure is supported by consistent observation of CNS depressive effects following inhalation exposure to concentrations ≥2,000 ppm following acute-, intermediate-, and chronic-duration studies (Bevan et al. 1997a, 1997b; Bird et al. 1997; Dodd and Kintigh 1989; Lington et al. 1997; Moser et al. 1996; MTBE Committee 1990a; Vergnes and Chun 1994; Vergnes and Morabit 1989). Additionally, some studies have reported effects consistent with transient CNS depression in humans exposed to MTBE in fuel, including headache, nausea or vomiting, dizziness, and a feeling of spaciness or disorientation (Alaska DHSS 1992a, 1992b; CDC 1993a; Moolenaar et al. 1994; Wisconsin DHSS 1995). When using the neurological NOAEL of 400 ppm from Vergnes and Chun (1994), the MRL calculates to the same value.

Agency Contacts (Chemical Managers): Gaston Casillas

## Methyl tert-butyl ether (MTBE) Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methyl tert-butyl ether (MTBE)
CAS Numbers: | 1634-04-4
Date: | September 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 1 ppm
Critical Effect: | CNS depression and elevated liver weight
Reference: | Bevan et al. 1997b; Bird et al. 1997
Point of Departure: | NOAEL of 400 ppm (NOAEL_HEC_ of 43.9 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 27, 29
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 1 ppm was derived for MTBE based on CNS depression in rats and mice and elevated liver weight in rats exposed to concentrations ≥3,000 ppm for 6 hours/day, 5 days/week for 4–19 weeks; a NOAEL of 400 ppm was identified (Bevan et al. 1997b; Bird et al. 1997). The MRL is based on the NOAEL of 400 ppm, which was adjusted to continuous duration exposure and converted to a NOAEL_HEC_ of 43.9 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans after dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: Available intermediate-duration inhalation studies report numerous MTBE-related effects, with NOAEL and LOAEL values of 400 and 3,000 ppm, respectively (see Table A-9). Effects observed at ≥3,000 ppm included neurological effects in rats and mice, hepatic effects in male and female rats and female mice, endocrine (adrenal) effects in rats, and decreased neonatal weights in F1 and F2 rat offspring. Renal effects in male rats were also observed at exposure levels ≥3,000 ppm; however, these effects were not considered an appropriate basis for the MRL because available toxicity and mechanistic studies indicate that renal effects in males are partially attributable to α2u-globulin, which is not relevant for human health (Ahmed 2001; Bogen and Heilman 2015; McGregor 2006; Phillips et al. 2008). Additionally, the adversity of elevated adrenal gland weight in female rats at ≥3,000 ppm in the absence of histopathological alterations at concentrations up to 8,000 ppm, reported in Bird et al. (1997), is unclear. Only one study reported adrenal lesions in female mice (loss of zona reticularis) at 8,000 ppm, in the absence of altered adrenal weight (Moser et al. 1998); however, no histopathological evidence of damage to the adrenal gland was observed in intermediate-duration inhalation studies in rats at concentrations up to 8,000 ppm (Greenough et al. 1980; Lington et al. 1997). Therefore, only neurological, hepatic, and developmental effects were further considered for MRL derivation.

Table A-9 Summary of Relevant NOAEL and LOAEL Values Following Intermediate-Duration Inhalation to Methyl tert-Butyl Ether (MTBE)

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference^a^
Neurological effects
Fischer-344 rat | 28 days; 5 days/week; 6 hours/day | 400 | 3,000 (serious LOAEL) | Ataxia, hypoactivity, loss of startle response, blepharospasm | Bird et al. 1997; Chun and Kintigh 1993
Sprague-Dawley rat | 2 generations; ~14–19 weeks/generation; 5 days/week; 6 hours/day | 400 | 3,000 | Hypoactivity, blepharospasm, lack of startle response in F0 and F1 adults | Bevan et al. 1997b; Neeper-Bradley 1991
CD-1 mouse | 28 days; 5 days/week; 6 hours/day | 400 | 3,000 (serious LOAEL) | Ataxia, hypoactivity, loss of startle response | Bird et al. 1997; Chun and Kintigh 1993
Fischer-344 rat | 13 weeks; 5 days/week; 6 hours/day | 800 | 4,000 | Transient hypoactivity | Lington et al. 1997
Hepatic effects
Fischer-344 rat | 28 days; 5 days/week; 6 hours/day | 400 | 3,000 | Increased relative liver weight in males and females | Bird et al. 1997; Chun and Kintigh 1993
Sprague-Dawley rats | 2 generations; ~14–19 weeks/generation; 5 days/week; 6 hours/day | 400 | 3,000 | Increased relative liver weight in F1 adult males | Bevan et al. 1997b
CD-1 mouse | 28 days; 5 days/week; 6 hours/day | 400 | 3,000 | Increased relative liver weight in females | Bird et al. 1997; Chun and Kintigh 1993
Fischer-344 rat | 13 weeks; 5 days/week; 6 hours/day | ND | 800 | Increased relative liver weight in males | Lington et al. 1997
Endocrine effects
Fischer-344 rat | 28 days; 5 days/week; 6 hours/day | 400 | 3,000 | Increased relative adrenal gland weight in females | Bird et al. 1997; Chun and Kintigh 1993
Fischer-344 rat | 13 weeks; 5 days/week; 6 hours/day | 800 | 4,000 | Increased relative adrenal gland weight | Lington et al. 1997
Developmental effects
Sprague-Dawley rat | 2 generations; ~14–19 weeks/generation; 5 days/week; 6 hours/day | 400 | 3,000 | Decreased F1 and F2 offspring body weight during lactation | Bevan et al. 1997b; Neeper-Bradley 1991

a Both published and unpublished studies are cited when unpublished data were referred to for additional information.

LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

In order to identify the most sensitive POD, BMD modeling was attempted for critical neurological and developmental endpoints in Table A-9 when data were amenable to modeling. The data were fit to all available continuous models in EPA’s BMDS (version 3.2) using a BMR of 1 standard deviation (liver weight) or 5% relative deviation (developmental body weight). Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMDL that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all models providing adequate fit to the data, the lowest BMCL (95% lower confidence limit on the BMC) was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest AIC was chosen. The datasets used for BMD modeling are presented in Tables A-10, A-11, and A-12. BMD modeling could not be conducted on neurological data because the dataset provides limited information on the dose-response between the extremes of 0% incidence in controls and low-concentration groups and 100% incidence at the LOAEL.

Table A-10 Relative Liver Weights in Rats and Mice Following Inhalation Exposure for 28 Days (5 Days/Week, 6 Hours/Day)

| Concentration (ppm)
| 0 | 400 | 3,000 | 8,000
Male rat relative liver weight (% BW); Mean±SD (n) | 3.756±0.2057; (10) | 3.844±0.0959; (10) | 4.094±0.2473^a^; (10) | 4.393±0.2749^a^; (10)
Female rat relative liver weight (% BW); Mean±SD (n) | 3.556±0.0854; (10) | 3.606±0.2525; (10) | 3.869±0.1446^a^; (10) | 3.916±0.1347^b^; (10)
Female mouse relative liver weight (% BW); Mean±SD (n) | 5.428±0.4886; (10) | 5.334±0.4029; (10) | 5.895±0.4654^a^; (9) | 6.120±0.3768^a^; (10)

a p<0.05.

b p<0.01.

BW = body weight; (n) = number of animals; SD = standard deviation

Source: Chun and Kintigh 1993 (unpublished report associated with published study by Bird et al. 1997)

Table A-11 Relative Liver Weights in Male Rats Following Inhalation Exposure for 13 Weeks (5 Days/Week, 6 Hours/Day)

| Concentration (ppm)
| 0 | 800 | 4,000 | 8,000
Male rat relative liver weight (% BW); Mean±SD (n) | 3.15±0.16; (15) | 3.39±0.16; (15) | 3.78±0.26^a^; (15) | 4.37±0.19^a^; (15)

a p≤0.05.

BW = body weight; (n) = number of animals; SD = standard deviation

Source: Lington et al. 1997

Table A-12 Body and Liver Weights in Rat Offspring in a 2-Generation Inhalation Exposure Study (5 Days/Week, 6 Hours/Day

| Concentration (ppm)
| 0 | 400 | 3,000 | 8,000
F1 female body weight on PND 14 (g); Litter mean±SD (n) | 25.43±2.808; (22) | 25.43±2.456; (22) | 22.94±3.452^a^; (25) | 22.16±2.845^b^; (20)
F2 body weight on PND 21 (g); Litter mean±SD (n) | 45.67±2.707; (22) | 44.25±3.479; (22) | 41.29±4.178^b^; (22) | 38.28±8.844^b^; (21)
Adult F1 male relative liver weight (%); Mean±SD (n) | 3.42±0.29; (25) | 3.49±0.32; (25) | 3.76±0.37^b^; (25) | 4.31±0.42^b^; (25)

a p<0.05.

b p<0.01.

(n) = number of animals; PND = postnatal day; SD = standard deviation

Sources: Bevan et al. 1997b; Neeper-Bradley 1991

Details of the modeling results for the model predictions for relative liver weight in female mice reported by Chun and Kintigh (1993) are in Table A-13. In accordance with the selection criteria mentioned above, the constant variance, frequentist, restricted Exponential 4 model was selected. No adequate models were identified for increased relative liver weight in male or female rats (Bird et al. 1997); quantitative data obtained from unpublished report by Chun and Kintigh 1993) because they failed to meet conventional goodness-of-fit criteria.

Table A-13 Results from Benchmark Dose (BMD) Analysis (Constant Variance) of Relative Liver Weight in Female Mice Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) for 28 Days (5 Days/Week, 6 Hours/Day) (Bird et al. 1997; Chun and Kintigh 1993)

Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Exponential (model 2)^d^ | 4,701.60 | 3,395.20 | 0.22 | 50.54 | 1.39 | -0.42
Exponential (model 3)^d^ | 4,702.65 | 3,395.19 | 0.22 | 50.54 | 1.39 | -0.41
Exponential (model 4) ^d^ ^,^ ^e^ | 2,255.57 | 843.27 | 0.30 | 50.60 | -0.79 | 0.29
Exponential (model 5)^d^ | | | NA | 51.74 | -0.34 | 0.00
Hill^f^ | | | NA | 51.74 | -0.34 | 0.00
Polynomial (3-degree)^f^ | 4,517.82 | 3,195.00 | 0.24 | 50.36 | 1.33 | -0.43
Polynomial (2-degree)^f^ | 4,517.82 | 3,195.02 | 0.24 | 50.36 | 1.33 | -0.43
Power | 4,517.82 | 3,194.95 | 0.24 | 50.36 | 1.33 | -0.43
Linear | 4,517.82 | 3,195.02 | 0.24 | 50.36 | 1.33 | -0.43

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Selected model. The constant variance model provided an adequate fit to the data. All models except Exponential 5 and Hill models provided adequate fits to the means. The BMCLs differed by >3-fold; therefore, the model with the lowest BMCL was selected (Exponential 4).

f Coefficients restricted to be positive.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a change of 1 standard deviation from the control); NA = not applicable

Details of modeling results for the model predictions for relative liver weight in male rats reported by Lington et al. (1997) are in Table A-14. In accordance with the selection criteria mentioned above, the constant variance, frequentist, restricted Power model was selected.

Table A-14 Results from Benchmark Dose (BMD) Analysis (Constant Variance) of Relative Liver Weight in Male Rats Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) for 13 Weeks (5 Days/Week, 6 Hours/Day) (Lington et al. 1997)

Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Exponential (model 2)^d^ | 1,541.55 | 1,320.87 | 0.13 | -18.79 | 1.30 | 0.41
Exponential (model 3)^d^ | 1,541.79 | 1,320.87 | 0.13 | -18.79 | 1.30 | 0.41
Exponential (model 4)^d^ | | | 0.08 | -17.94 | 1.32 | -0.59
Exponential (model 5)^d^ | | | 0.08 | -17.95 | 1.33 | -0.50
Hill^e^ | | | NA | -8.04 | 2.23 | 0.0002
Polynomial (3-degree)^e^ | 1,338.81 | 1,136.63 | 0.21 | -19.80 | 1.34 | -0.18
Polynomial (2-degree)^e^ | 1,338.81 | 1,136.63 | 0.21 | -19.80 | 1.34 | -0.18
Power ^f^ | 1,338.80 | 1,136.64 | 0.21 | -19.80 | 1.34 | -0.18
Linear | 1,338.81 | 1,136.63 | 0.21 | -19.80 | 1.34 | -0.18

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Coefficients restricted to be positive.

f Selected model. The constant variance model provided an adequate fit to the data. All models except Exponential 4 and 5 and Hill models provided adequate fits to the means. The BMDLs were sufficiently close (<3-fold); therefore, the model with the lowest AIC was selected (Power). While it appears that the several models have the same AIC due to rounding, if you go out 7 decimal places, the Power model is slightly lower; therefore, it is the selected model.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a change of 1 standard deviation from the control); NA = not applicable

Details of modeling results for the model predictions for F1 female body weight on PND 14, F2 body weight on PND 21, and adult F1 male relative liver weight in mice reported by Bevan et al. (1997b) and Neeper-Bradley (1991) are in Table A-15, A-16, and A-17, respectively. In accordance with the selection criteria mentioned above, the constant variance, frequentist, restricted Exponential 4 model was selected for F1 female body weight; the nonconstant variance, frequentist, restricted Exponential 2 model was selected for F2 body weight; and the constant variance, frequentist, unrestricted Linear model was selected for F1 male relative liver weight.

Table A-15 Results from Benchmark Dose (BMD) Analysis (Constant Variance) of Decreased F1 Body Weights in Female Rat Offspring on PND 14 Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) in a 2-Generation Study (5 Days/Week, 6 Hours/Day) (Bevan et al. 1997a; Neeper-Bradley 1991)

Model | BMC_RD5_^a^ (ppm) | BMCL_RD5_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_RD5_^a^ (ppm) | BMCL_RD5_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Exponential (model 2)^d^ | 2,756.74 | 1965.74 | 0.18 | 449.55 | 0.65 | -1.54
Exponential (model 3)^d^ | 2,756.44 | 1970.12 | 0.18 | 449.55 | 0.65 | -1.54
Exponential (model 4) ^d^ ^,^ ^e^ | 1,056.04 | 368.70 | 0.49 | 448.58 | 0.52 | -0.21
Exponential (model 5)^d^ | | | NA | 450.11 | 0.01 | 0.00
Hill^f^ | | | NA | 450.11 | 0.03 | 0.00
Polynomial (3-degree)^f^ | 2,936.57 | 2148.57 | 0.15 | 449.85 | 0.69 | -1.61
Polynomial (2-degree)^f^ | 2,936.57 | 2148.42 | 0.15 | 449.85 | 0.69 | -1.61
Power | 2,936.57 | 2151.93 | 0.15 | 449.85 | 0.69 | -1.61
Linear | 2,936.57 | 2148.31 | 0.15 | 449.85 | 0.69 | -1.61

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Selected model. The constant variance model provided an adequate fit to the data. All models except Exponential 5 and Hill models provided adequate fits to the means. The BMCLs differed by >3-fold; therefore, the model with the lowest BMCL was selected (Exponential 4).

f Coefficients restricted to be negative.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., RD5 = dose associated with a 5% relative deviation); NA = not applicable; PND = postnatal day

Table A-16 Results from Benchmark Dose (BMD) Analysis (Nonconstant Variance) of Decreased F2 Body Weights in Rat Offspring on PND 21 Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) in a 2-Generation Study (5 Days/Week, 6 Hours/Day) (Bevan et al. 1997a; Neeper-Bradley 1991)

Model | BMC_RD5_^a^ (ppm) | BMCL_RD5_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_RD5_^a^ (ppm) | BMCL_RD5_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Exponential (model 2) ^d^ ^,^ ^e^ | 2,065.98 | 1,492.44 | 0.33 | 507.064 | -0.67 | -0.65
Exponential (model 3)^d^ | 2,063.24 | 1,492.32 | 0.33 | 507.065 | -0.67 | -0.65
Exponential (model 4)^d^ | 1,687.78 | 902.49 | 0.19 | 508.576 | -0.69 | -0.24
Exponential (model 5)^d^ | 1,692.17 | 902.85 | 0.19 | 508.573 | -0.69 | -0.25
Hill^f^ | 1,645.17 | 709.17 | 0.20 | 508.526 | -0.67 | -0.22
Polynomial (3-degree)^f^ | 2,214.69 | 1,633.73 | 0.28 | 507.389 | -0.65 | -0.81
Polynomial (2-degree)^f^ | 2,212.30 | 1,633.80 | 0.28 | 507.389 | -0.65 | -0.80
Power | 2,214.97 | 1,698.40 | 0.28 | 507.389 | -0.65 | -0.81
Linear | 2,214.56 | 1,633.72 | 0.28 | 507.389 | -0.65 | -0.80

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Selected model. The constant variance did not provide an adequate fit to the data. With nonconstant variance applied, all models provided adequate fit to the means. The BMDLs were sufficiently close (<3-fold), so the model with the lowest AIC was selected (Exponential 2 model).

f Coefficients restricted to be negative.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., RD5 = dose associated with a 5% relative deviation); PND = postnatal day

Table A-17 Results from Benchmark Dose (BMD) Analysis (Constant Variance) of Relative Liver Weight in Adult F1 Male Rats Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) in a 2-Generation Study (5 Days/Week, 6 Hours/Day) (Bevan et al. 1997b)

Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Exponential (model 2)^d^ | 3,388.81 | 2,869.25 | 0.92 | 77.88 | 0.21 | -0.08
Exponential (model 3)^d^ | 3,388.81 | 2,869.25 | 0.92 | 77.88 | 0.21 | -0.08
Exponential (model 4)^d^ | 3,127.92 | 2,591.78 | 0.79 | 79.79 | -0.05 | 0.01
Exponential (model 5)^d^ | 3,135.01 | 2,606.18 | 0.79 | 79.79 | -0.04 | 0.01
Hill^e^ | | | NA | 82.23 | -7.3x10^-5^ | 0.0007
Polynomial (3-degree)^e^ | 3,157.23 | 2,629.08 | 0.96 | 77.79 | -0.02 | -0.002
Polynomial (2-degree)^e^ | 3,157.23 | 2,629.08 | 0.96 | 77.79 | -0.02 | -0.002
Power | 3,157.23 | 2,629.07 | 0.96 | 77.79 | -0.02 | -0.002
Linear ^f^ | 3,157.23 | 2,629.08 | 0.96 | 77.79 | -0.02 | -0.002

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Coefficients restricted to be positive.

f Selected model. The constant variance model provided an adequate fit to the data. All models except the Hill model provided adequate fits to the means. The BMDLs were sufficiently close (<3-fold). Several models had the same lowest AIC value (Linear, Power, Polynomial 2 and 3), and the Polynomial models converged upon the Linear model. Between the Power and the Linear model, the model with the (slightly) lower BMCL was selected (Linear).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a change of 1 standard deviation from the control); NA = not applicable

The candidate PODs are summarized in Table A-18. The most sensitive candidate PODs for all three critical effects (neurological, hepatic, developmental) were comparable (adjusted NOAEL/BMCL values of 65.9–71.4 ppm). Based on consistent evidence across several studies, neurological and hepatic effects were selected as co-critical effects. Decreased PND 14 F1 body weight in females (Bevan et al. 1997b) was not selected as a co-critical effect due to inconsistent findings across postnatal time periods and sexes; additionally, the BMCL for the F2 generation was much higher, further suggesting inconsistencies in the data.

Table A-18 Summary of Candidate Effects and POD Values Considered for Derivation of an Intermediate-Duration Inhalation MRL for Methyl tert-Butyl Ether (MTBE)

Species | Duration | Effect | Candidate POD (ppm) | POD type | Reference^a^
Neurological effects
Fischer-344 rat | 28 days; 5 days/week; 6 hours/day | Ataxia, hypoactivity, loss of startle response, blepharospasm^b^ | 71.4 | NOAEL_ADJ_ | Bird et al. 1997; Chun and Kintigh 1993
Sprague-Dawley rat | 2 generations; ~14–19 weeks/generation; 5 days/week; 6 hours/day | Hypoactivity, blepharospasm, loss of startle response in F0 and F1 adults^b^ | 71.4 | NOAEL_ADJ_ | Bevan et al. 1997b; Neeper-Bradley 1991
CD-1 mouse | 28 days; 5 days/week; 6 hours/day | Ataxia, hypoactivity, loss of startle response^b^ | 71.4 | NOAEL_ADJ_ | Bird et al. 1997; Chun and Kintigh 1993
Fischer-344 rat | 13 weeks; 5 days/week; 6 hours/day | Transient hypoactivity at ≥4,000 ppm; ataxia at 8,000 ppm | 143 | NOAEL_ADJ_ | Lington et al. 1997
Hepatic effects
Fischer-344 rat | 28 days; 5 days/week; 6 hours/day | Increased relative liver weight in males and females^b^ | 71.4 | NOAEL_ADJ_ | Bird et al. 1997; Chun and Kintigh 1993
Sprague-Dawley rats | 2 generations; ~14–19 weeks/generation; 5 days/week; 6 hours/day | Increased relative liver weight in F1 adult males | 469 | BMCL_ADJ_ | Bevan et al. 1997b
CD-1 mouse | 28 days; 5 days/week; 6 hours/day | Increased relative liver weight in females | 151 | BMCL_ADJ_ | Bird et al. 1997; Chun and Kintigh 1993
Fischer-344 rat | 13 weeks; 5 days/week; 6 hours/day | Increased relative liver weight in males | 203 | BMCL_ADJ_ | Lington et al. 1997
Developmental effects
Sprague-Dawley rat | 2 generations; ~14–19 weeks/generation; 5 days/week; 6 hours/day | Decreased body weight in F1 females on PND 14 | 65.9 | BMCL_ADJ_ | Bevan et al. 1997b; Neeper-Bradley 1991
Sprague-Dawley rat | 2 generations; ~14–19 weeks/generation; 5 days/week; 6 hours/day | Decreased body weight in F2 pups on PND 21 | 266 | BMCL_ADJ_ | Bevan et al. 1997b; Neeper-Bradley 1991

a Both published and unpublished studies are cited when unpublished data were referred to for additional information and/or raw data for benchmark dose modeling.

b Selected studies/endpoints for derivation of intermediate-duration inhalation MRL.

BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL_ADJ_ = 95% lower confidence limit on the BMC (adjusted for continuous exposure); MRL = Minimal Risk Level; NOAEL_ADJ_ = no-observed-adverse-effect level (adjusted for continuous exposure); PND = postnatal day; POD = point of departure

Selection of the Principal Studies: The 2-generation study in rats (Bevan et al. 1997b; Neeper-Bradley 1991) and the 28-day day studies in rats and mice (Bird et al. 1997; Chun and Kintigh 1993) were selected as co-principal studies based on identical PODs (NOAEL_ADJ_ of 71.4 ppm) for CNS depression and elevated liver weight.

Summary of the Principal Studies:

Bevan C, Neeper-Bradley TL, Tyl RW, . 1997b. Two-generation reproductive toxicity study of methyl tertiary-butyl ether (MTBE) in rats. J Appl Toxicol 17(Suppl 1):S13–S19.9179723

Neeper-Bradley TL. 1991. Two-generation reproduction study of inhaled methyl tert-butyl ether in CD (Sprague-Dawley) rats (final report) with attachments and cover letter dated 081691. MTBE Task Force. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0534056. 40-9113465. 42098 G8-2. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0540108.xhtml. January 17, 2020.

Bevan et al. (1997b) exposed Sprague-Dawley rats (25/sex/group) to MTBE at concentrations of 0, 400, 3,000, or 8,000 ppm via whole-body inhalation for 6 hours/day, 5 days/week for 10 weeks prior to mating. Exposure continued through the 21-day mating period (males were then randomly allocated to co-house with one female for 7 days maximum until mating was confirmed; after a 7-day period, unmated females were placed with a different male for the remainder of the 21-day mating period). Day of copulation was designated as GD 0. Male exposure continued until the last litter they sired was delivered, at which point they were sacrificed. Females were exposed during the mating period, gestation, lactation (GD 5), and weaning on PND 21. Females were sacrificed after the weaning of their offspring. The total exposure period was 16 weeks in F0 males and 17–19 weeks in F0 females. Birth was recorded as PND 0. On PND 28, at least one F1 rat/sex/litter was selected at random to continue exposure for up to 8 weeks prior to mating for generation of the F2 litter. Mating, exposure, and sacrifice schedule for F1 parental animals followed the same schedule as F0 parental animals. Parental rats were observed for viability twice daily and for clinical signs once daily. Male body weights were recorded weekly. Female body weights were recorded weekly prior to mating and then on GDs 0, 7, 14, and 20 after mating. Food consumption was recorded weekly for both sexes. After mating, female food consumption was recorded at 3–4-day intervals throughout gestation. All parental adults were examined grossly. Reproductive endpoints evaluated in both generations included number of sperm-positive females, number pregnant, number of live litters, gestation length, male and female mating indices, male and female fertility indices, and gestational index. At necropsy, the liver was weighed in F1 parental animals. Histopathological examination was conduction on the following tissues in F0 control and 8,000-ppm groups: pituitary, testes, epididymides, prostate and seminal vesicles, vagina, uterus, ovaries, respiratory tract (with nasal turbinates), and gross lesions. Only the livers from control and 8,000-ppm groups were examined for histopathological changes in F1 parental animals. Litters were examined twice a day for general appearance and any deaths. Offspring were counted, sexed, weighed, and examined for abnormalities on PNDs 0, 1, 4, 7, 14, 21, and 28. Live birth and survival indices were calculated. On PND 4, each litter was reduced to four females and four males via random selection. Culled pups were euthanized and examined for external malformations. Those with observed abnormalities were given a gross postmortem examination. Data for this study are also available in the unpublished report by Neeper-Bradley (1991).

All F0 parental animals survived until scheduled sacrifice. Hypoactivity, blepharospasms, and lack of startle response were observed at ≥3,000 ppm; ataxia was observed at 8,000 ppm. Periocular encrustation and ocular discharge were observed at 8,000 ppm as well (attributed to irritative nature of vapor; see dermal entry). There were no clinical signs of toxicity observed in the 400-ppm group. Body weight was significantly reduced throughout the 10-week premating exposure period for F0 males at 8,000 ppm group, with a 12% reduction the end of the premating period. Body weight gain was also decreased in F0 males at 8,000 ppm from week 1 to 7 of premating exposure (magnitude not reported), and an 8–13% decrease in food consumption was observed from week 1 to 3. Body weights for F0 males were not reported once mating began. In F0 females, body weights were similar to controls prior to mating, during mating, and during gestation. During lactation, a significant 2-fold increase in body weight gain was observed at 8,000 ppm; the biological significance of this increase is unclear especially since food consumption was significantly reduced in this group from PND 7 to 14. No exposure-related changes were observed in reproductive parameters. No exposure-related changes in gross or microscopic histology were observed in the F0 generation.

All F1 parental animals survived until scheduled sacrifice. Hypoactivity, blepharospasms, and lack of startle response were observed at ≥3,000 ppm; ataxia was observed at 8,000 ppm. Periocular encrustation and ocular discharge were observed at 8,000 ppm as well (attributed to irritative nature of vapor). There were no clinical signs of toxicity observed in the 400-ppm group. Body weight gain was reduced throughout the 8-week premating exposure period for F1 males at 8,000 ppm group, with a significant 13–14% decrease during weeks 1 and 2. Final body weight was significantly reduced by 11%. While body weights were significantly reduced for F1 females during the premating exposure period, body weights were lower at the beginning of the exposure period and body weight gains were comparable across groups. Similar to F0 dams, a significant 4-fold increase in body weight gain was observed at 8,000 ppm; the biological significance of this increase is unclear, especially since food consumption was significantly reduced in this group from PND 7 to 14. No exposure-related changes were observed in reproductive parameters. Absolute liver weight was significantly increased at 8,000 ppm in F1 males and females by 12 and 27%, respectively. Relative liver weight was also significantly increased at 8,000 ppm in F1 males and females by 26%. Relative liver weight was significantly increased in F1 males by 10% at 3,000 ppm as well. No exposure-related changes were observed at gross necropsy, and no exposure-related liver lesions were noted.

No exposure-related changes were observed in litter survival parameters for F1 or F2 generations. Exposure-related changes in F1 pups included decreased weights at 8,000 ppm from PND 14 to 28 in both sexes and at 3,000 ppm on PND 14 in females. In addition, body weight gain was reduced in the 3,000- and 8,000-ppm exposed groups on PNDs 7–14 and 14–21. In F2 pups, body weights were significantly reduced at 8,000 ppm from PND 7 to 28 in both sexes and at 3,000 ppm in males from PND 14 to 28. No exposure-related changes were observed at gross necropsy of pups.

Bird MG, Burleigh-Flayer HD, Chun JS, . 1997. Oncogenicity studies of inhaled methyl tertiary-butyl ether (MTBE) in CD-1 mice and F-344 rats. J Appl Toxicol 17(Suppl 1):S45–S55.9179727

Chun JS, Kintigh WJ. 1993. Methyl tertiary butyl ether: Twenty-eight day vapor inhalation study in rats and mice. Union Carbide. Submitted to the MTBE Health Effects Testing Task Force. BRRC Report 93N1241.

Bird et al. (1997) exposed groups of Fischer-344 rats (10/sex/group) to MTBE at concentrations of 0, 400, 3,000, or 8,000 ppm via whole-body inhalation for 6 hours/day, 5 days/week for at least 4 weeks for 23 or 24 exposures (main experiment). Additional groups of rats (5/sex/group) were similarly exposed to 0 or 8,000 ppm for 24 exposures and maintained for 19 days following the last exposure (recovery experiment) or were exposed to 0, 400, 3,000, or 8,000 ppm for 23 exposures to evaluate cell proliferation in the renal tubules (cell proliferation experiment). All rats were examined for clinical signs of toxicity and body weight changes during the study. Clinical blood chemistry parameters (urea nitrogen, creatinine, calcium, phosphorus, sodium, potassium, and chloride) were evaluated only in the 0 or 8,000 ppm groups prior to sacrifice. Urine samples from all exposure groups were evaluated for osmolality, pH, total volume, lactate dehydrogenase, ALP, N-acetyl-beta-D-glucosaminidase, total protein, and protein fraction. Complete necropsy, organ weight determinations (liver, kidneys, uterus, lungs, brain, spleen, thyroid, and adrenals), and measurement of the length and width of the brain were performed on all rats except those in the cell proliferation experiment. Histological examinations were limited to the liver and kidneys. The livers were examined microscopically in the 0 and 8,000 ppm groups only, while the kidneys were examined microscopically in all groups. In addition, slides from all male rat kidneys were examined for protein accumulation in the tubular epithelial cells by Mallory’s Heidenhain technique and for α2u-globulin accumulation using immunostaining with an antibody to α2u-globulin. Data are also available for this study in the unpublished report by Chun and Kintigh (1993).

No exposure-related mortality was observed. Clinical signs consisted of ataxia, hypoactivity, lack of startle response, and blepharospasm in rats during exposures to 3,000 and 8,000 ppm, and ataxia in rats following exposures to 8,000 ppm. Body weight loss (about 2%) occurred in male rats exposed to 8,000 ppm during the first week. Decreased body weight gain was seen throughout the study in male rats exposed to 8,000 ppm, with percentages of decreased body weight gain of 24–35% from exposure days 1–19 to 1–33. Decreased body weight gain was observed in female rats exposed to 8,000 ppm only during the first 2 weeks of exposure. No exposure-related effects on clinical chemistry parameters were found in rats. Urinalysis and urine chemistry evaluations revealed increased urine volume and decreased urinary pH in male and female rats at 8,000 ppm, but there was no other indication of renal damage. Exposure-related organ weight changes were observed in the kidneys, liver, adrenal glands, and spleen. Statistically significant organ weight changes in male rats at 3,000 ppm were limited to an 8 and 13% increase in absolute and relative liver weight, respectively. At 8,000 ppm, statistically significant organ weight changes included a 10% increase in absolute and relative liver weight; an 8% decrease in relative kidney weight; 45 and 53% increases in absolute and relative adrenal weight, respectively; and 18 and 13% decreases in absolute and relative spleen weight, respectively. In females, statistically significant organ weight changes at 3,000 ppm included 9 and 8% increases in absolute and relative liver weight, respectively; 11 and 8% increases in absolute and relative kidney weight, respectively; and 14 and 8% increases in absolute and relative adrenal weight, respectively. At 8,000 ppm, statistically significant organ weight changes in female rats included 17 and 10% increases in absolute and relative liver weight, respectively; a 4% increase in relative kidney weight; 21 and 23% increases in absolute and relative adrenal weight, respectively; and a 6% decrease in relative spleen weight. No gross or histopathological effects were noted in the organs and tissues examined. Although more protein accumulation in male rats exposed to 3,000 and 8,000 ppm was observed, no evidence of α2u-globulin accumulation was found. These results suggest that a mechanism other than α2u-globlin accumulation (perhaps the accumulation of another protein unique to male rats) may be responsible for increased susceptibility in male rats.

Bird et al. (1997) also exposed groups of CD-1 mice (10/sex/group) to MTBE at concentrations of 0, 400, 3,000, or 8,000 ppm via whole-body inhalation for 6 hours/day, 5 days/week for at least 4 weeks for 20 or 21 exposures (main experiment). Additional groups (5/sex/group) were similarly exposed to 0 or 8,000 ppm for 23 exposures and maintained for 21 days following the last exposure (recovery experiment). Animals were evaluated for body weight and clinical signs of toxicity. Select organ weights were recorded (liver, brain, spleen, thyroid). Histopathological evaluations were conducted on liver, kidney, and thyroid. At the end of the exposure period, brains from all male and female mice of the main experiment were homogenized to determine the levels of calcium and magnesium. Special blood chemistry evaluation of total T3, total T4, TSH, total bile acid, and estradiol were conducted. Data are also available for this study in the unpublished report by Chun and Kintigh (1993).

No exposure-related mortality was observed. Clinical signs consisted of ataxia, hypoactivity, and lack of startle response during exposures to 3,000 and 8,000 ppm and ataxia following exposures to 8,000 ppm. No exposure-related clinical signs were observed during the recovery period. No body weight effects were noted. Absolute and relative liver weights were elevated in females at ≥3,000 ppm, and centrilobular hypertrophy was observed in males at 8,000 ppm. Decreased absolute and relative spleen weight was observed in females at 8,000 ppm. However, the spleen was not examined histologically. No exposure-related effects on brain weight were found. No exposure-related effects on brain calcium and magnesium levels were found. Special blood chemistry evaluation of total T3, total T4, TSH, total bile acid, and estradiol revealed that an increase in total T4 and TSH occurred in male mice at 8,000 ppm. However, these increases were not considered to be biologically significant due to the absence of histological evidence of thyroid lesions.

Selection of the Point of Departure for the MRL: The NOAEL of 400 ppm for CNS depression and elevated liver weights in rats and mice was selected as the POD because it is the identified lowest POD for the critical effects (neurotoxicity, hepatotoxicity) identified in the co-principal studies.

Calculations

Intermittent Exposure: The NOAEL of 400 ppm was adjusted from intermittent exposure to account for a continuous exposure scenario:

- NOAEL_ADJ_ = 400 ppm × 6 hours/24 hours × 5 days/7 days = 71.4 ppm

Human Equivalent Concentration: While several PBPK models have been developed for MTBE, further refinement is needed to decrease uncertainty in estimated exposure levels, particularly for humans (see Sections 3.1.5 and 6.2 for more details). Therefore, HEC values for extrarespiratory effects were calculated by multiplying the NOAEL_ADJ_ by the ratio of animal:human blood gas partition coefficients. For rats, the reported rat blood gas partition coefficient of 11.5 (Rao and Ginsberg 1997) and the midpoint of the range of human blood gas partition coefficients (17.7–19.6) reported by Rao and Ginsberg (1997) and Kim et al. (2007) were used:

- Rat NOAEL_HEC_ = NOAEL_ADJ_ × ratio of rat:human blood gas partition coefficients
- Rat NOAEL_HECP_ = 71.4 ppm × (11.5/18.7)
- Rat NOAEL_HEC_ = 71.4 ppm × 0.615 = 43.9 ppm

For mice, the default the animal:human blood gas partition coefficient of 1 was used (mouse blood gas partition coefficient is unknown):

- Mouse NOAEL_HEC_ = NOAEL_ADJ_ × ratio of mouse:human blood gas partition coefficients
- Mouse NOAEL_HEC_ = 71.4 ppm × 1 (default value) = 71.4 ppm

Uncertainty Factor: The rat NOAEL_HEC_ (most conservative HEC value) is divided by a total uncertainty factor (UF) of 30.

- 3 for extrapolation from animals to humans after dosimetric adjustment
- 10 for human variability

MRL = NOAEL_HEC_ ÷ UFs 43.9 ppm ÷ ( 3 × 10 ) = 1 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Selection of a neurological effect as a co-critical effect following intermediate-duration inhalation exposure is supported by consistent observation of CNS-depressive effects following inhalation exposure to concentrations ≥2,000 ppm following acute-, intermediate-, and chronic-duration studies (Bevan et al. 1997a, 1997b; MTBE Committee 1990a; Bird et al. 1997; Dodd and Kintigh 1989; Lington et al. 1997; Moser et al. 1996; Vergnes and Chun 1994; Vergnes and Morabit 1989). Results from epidemiological studies also support CNS depression as a co-critical effect. Taxi drivers and health care workers who routinely traveled via motor vehicles experience greater incidence of MTBE-related symptoms, including headache, spaciness, and nausea, compared to a lesser exposed referent group (exposure levels not reported) (Alaska DHSS 1992a). Workers exposed to automobile exhaust (median MTBE blood concentrations were 0.05 and 0.08 µg/L for nonsmokers and smokers, respectively) experienced a greater incidence of dizziness and headaches compared to controls who were not occupationally exposed to MTBE (MTBE blood concentrations were below the limit of detection for control smokers and nonsmokers) (CDC 1993a). Ecological studies show that residents in areas participating in oxyfuel programs had increased risk of symptoms associated with MTBE exposure compared to those living in areas not participating in the oxyfuel program (Moolenaar et al. 1994; Wisconsin DHSS 1995). Some studies did not show an association between MTBE and neurological effects. For instance, healthy males exposed to up to 50 ppm of MTBE while performing light physical activity did not self-report any neurological effects (Johanson et al. 1995); however, this exposure scenario and population may not be representative of the general population. For more information, see Section 2.15.

Selection of elevated liver weight as a co-critical effect following intermediate-duration inhalation exposure is supported by consistent observation of elevated liver weights in rats and mice following inhalation exposure to concentrations ≥2,000 ppm following acute-, intermediate-, and chronic-duration studies (Bevan et al. 1997a, 1997b; Bird et al. 1997; Dodd and Kintigh 1989; Lington et al. 1997; Moser et al. 1996), with evidence of centrilobular hypertrophy in mice at 8,000 ppm (Bird et al. 1997; Moser et al. 1996).

Agency Contacts (Chemical Managers): Gaston Casillas

## Methyl tert-butyl ether (MTBE) Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methyl tert-butyl ether (MTBE)
CAS Numbers: | 1634-04-4
Date: | September 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic
MRL: | 1 ppm
Critical Effect: | Renal effects
Reference: | Bird et al. 1997; Chun et al. 1992
Point of Departure: | NOAEL of 400 ppm (NOAEL_HEC_ of 43.9 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 42
Species: | Rat

MRL Summary: A chronic-duration inhalation MRL of 1 ppm was derived for MTBE based on renal effects (increased kidney weight and increased incidence and severity of chronic progressive nephropathy) in female rats exposed to concentrations ≥3,000 ppm for 6 hours/day, 5 days/week for 24 months; a NOAEL of 400 ppm was identified (Bird et al. 1997). The MRL is based on the NOAEL of 400 ppm, which was adjusted to continuous duration exposure and converted to a NOAEL_HEC_ of 43.9 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans after dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: Available chronic-duration inhalation studies report relevant MTBE-related effects at 3,000 ppm (renal effects in female rats, hepatic effects in rats and mice) and 8,000 ppm (CNS effects) (see Table A-19). Renal effects were also observed in male rats at ≥400 ppm; however, the higher incidence and greater severity of chronic progressive nephropathy at lower exposure concentrations in male rats compared with female rats may be due to the exacerbation of this syndrome by the accumulation of α2u-globulin, which is not relevant for human health (Ahmed 2001; Bogen and Heilman 2015; McGregor 2006; Phillips et al. 2008). Because enhancement of chronic progressive nephropathy, which led to increased mortality and decreased survival time in males, is associated with α2u-globulin accumulation in male rats only, these endpoints in male rats are not considered for MRL derivation. However, since female rats also had enhanced chronic progressive nephropathy not associated with α2u-globulin accumulation, renal effects in female rats were considered relevant. Therefore, hepatic and female rat renal effects were further considered for MRL derivation.

Table A-19 Summary of NOAEL and LOAEL Values Following Chronic-Duration Inhalation to Methyl tert-Butyl Ether (MTBE)

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference^a^
Neurological effects
Fischer-344 rat | 24 months; 5 days/week; 6 hours/day | 3,000 | 8,000 (serious LOAEL) | Ataxia, prostration, salivation | Bird et al. 1997; Chun et al. 1992
Renal effects
Fischer-344 rat | 24 months; 5 days/week; 6 hours/day | 400 | 3,000 | Increased relative kidney weight and incidence and severity of CPN in females | Bird et al. 1997; Chun et al. 1992
Hepatic effects
Fischer-344 rat | 24 months; 5 days/week; 6 hours/day | 400 | 3,000 | Increased relative liver weight in females | Bird et al. 1997; Chun et al. 1992

a Both published and unpublished studies are cited when unpublished data were referred to for additional information

CPN = chronic progressive nephropathy; LOAEL = lowest observed adverse effect level; NOAEL = no-observed-adverse-effect level

In order to identify the most sensitive POD, BMD modeling was attempted for critical hepatic and female rat renal endpoints in Table A-19 when data were amenable to modeling. The data were fit to all available continuous models in EPA’s BMDS (version 3.2) using a BMR of 1 standard deviation for continuous data or 10% extra risk for dichotomous data. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMDL that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all models providing adequate fit to the data, the lowest BMCL (95% lower confidence limit on the BMC) was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest AIC was chosen. The datasets used for BMD modeling are presented in Table A-20. Incidence data for lesions associated with chronic progressive nephropathy in female rats were not suitable for BMD modeling due to non-monotonic responses and/or high incidence in controls (e.g., tubular proteinosis, glomerulosclerosis, interstitial nephritis, and fibrosis). Therefore, ATSDR used the NOAEL/LOAEL approach for the renal endpoints.

Table A-20 Relative Liver and Kidney Weights in Female Rats Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) for 24 Months (5 Days/Week, 6 Hours/Day)

| Concentration (ppm)
| 0 | 400 | 3,000 | 8,000
Relative liver weight (% BW); Mean±SD (n) | 3.867±0.6629; (30) | 3.725±0.5096; (27) | 4.654±0.6379^a^; (23) | 5.508±1.3994^a^; (25)
Relative kidney weight (% BW); Mean±SD (n) | 0.907±0.2578; (30) | 0.827±0.1427; (27) | 1.072±0.2354^b^; (23) | 1.168±0.2564^a^; (25)

a p<0.01.

b p<0.05.

BW = body weight; (n) = number of animals; SD = standard deviation

Source: Chun et al. 1992 (unpublished report associated with published study by Bird et al. 1997)

Details of the modeling results for the model predictions for relative liver weight in female rats reported by Chun et al. (1992) are in Table A-21. No adequate model fits were observed with the full data set; however, with the highest concentration dropped, the constant variance, frequentist, restricted 2-Degree Polynomial model was selected in accordance with the selection criteria mentioned above. No adequate models were identified for increased relative kidney weight in female rats (Bird et al. 1997; quantitative data obtained from unpublished report by Chun et al. 1992) because they failed to meet conventional goodness-of-fit criteria.

Table A-21 Results from Benchmark Dose (BMD) Analysis (Constant Variance) of Relative Liver Weight in Female Rats Following Inhalation Exposure to Methyl tert-Butyl Ether (MTBE) for 24 Months (5 Days/Week, 6 Hours/Day); Highest Dose Dropped (Bird et al. 1997; Chun et al. 1992)

Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Exponential (model 2)^d^ | 2,130.70 | 1,659.47 | 0.12 | 152.78 | -1.19 | 0.14
Exponential (model 3)^d^ | | | NA | 153.12 | -0.65 | 1.4x10^-7^
Exponential (model 4)^d^ | 2,072.04 | 1,571.16 | 0.10 | 153.00 | -1.25 | 0.18
Exponential (model 5)^d^ | | | 65,535 | 155.12 | -0.65 | 9.8x10^-7^
Hill^e^ | | | 65,535 | 155.12 | -0.65 | 3.66x10^-6^
Polynomial (2-degree) ^e^ ^,^ ^f^ | 2,507.18 | 1,730.39 | 0.61 | 149.30 | -0.72 | 0.01
Power | | | NA | 153.12 | -0.65 | -3.1x10^-8^
Linear | 2,072.63 | 1,564.59 | 0.10 | 153.00 | -1.25 | 0.18

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Coefficients restricted to be positive.

f Selected model. The constant variance model did not provide an adequate fit to the full dataset. With nonconstant variance applied, none of the models provided an adequate fit to the means. With the highest dose dropped, the constant variance model provided an adequate fit the data. Only the Exponential 2, Exponential 4, Polynomial 2, and Linear models provided an adequate fit to the means. BMCLs were sufficiently close (differed by <3-fold). Therefore, the model with the lowest AIC was selected (2^nd^ degree Polynomial).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a change of 1 standard deviation from the control); NA = not applicable

The candidate PODs are summarized in Table A-22. The lowest POD was identified for renal effects in female rats, with a NOAEL value of 400 ppm. Therefore, renal effects in female rats were selected as the critical effect.

Table A-22 Summary of Candidate Effects and POD Values Considered for Derivation of a Chronic-Duration Inhalation MRL for Methyl tert-Butyl Ether (MTBE)

Species | Duration | Effect | Candidate POD (ppm) | POD type | Reference^a^
Renal effects
Fischer-344 rat | 24 months; 5 days/week; 6 hours/day | Increased relative kidney weight and incidence and severity of CPN in females^b^ | 71.4 | NOAEL_ADJ_ | Bird et al. 1997; Chun et al. 1992
Hepatic effects
Fischer-344 rat | 24 months; 5 days/week; 6 hours/day | Increased relative liver weight in females | 309 | BMCL_ADJ_ | Bird et al. 1997; Chun et al. 1992

a Both published and unpublished studies are cited when unpublished data were referred to for additional information and/or raw data for benchmark dose modeling.

b Selected study/endpoint for derivation of chronic-duration inhalation MRL.

BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL_ADJ_ = 95% lower confidence limit on the BMC (adjusted for continuous exposure); MRL = Minimal Risk Level; NOAEL_ADJ_ = no-observed-adverse-effect level (adjusted for continuous exposure); POD = point of departure

Selection of the Principal Study: The 24-month study in rats by Bird et al. (1997) is selected as the principal study based on renal effects in female rats because this study provides the lowest POD for the identified critical effect. Data are also available for this study in the unpublished report by Chun et al. (1992).

Summary of the Principal Study:

Bird MG, Burleigh-Flayer HD, Chun JS, . 1997. Oncogenicity studies of inhaled methyl tertiary-butyl ether (MTBE) in CD-1 mice and F-344 rats. J Appl Toxicol 17(Suppl 1):S45–S55.9179727

Chun JS, Burleigh-Flayer HD, Kintigh WJ. 1992. Final report, methyl tertiary butyl ether: Vapor inhalation oncogenicity study in Fischer 344 rats, with cover letter dated 11/19/92. MTBE Task Force. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0558686. 42098 G9-3. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0558686.xhtml. January 20, 2020.

Bird et al. (1997) exposed groups of Fischer 344 rats (50/sex/group) to MTBE vapor at concentrations of 0, 400, 3,000, or 8,000 ppm via whole-body inhalation for 6 hours/day, 5 days/week for 24 months. Animals were observed individually for mortality and clinical signs of toxicity every day. Body weights were measured weekly up to week 13 and then measured every other week. Blood was collected at 12 months and prior to sacrifice for hematology and serum chemistry analyses in rats from the control and 8,000-ppm groups. In female rats, corticosterone levels were measured in 10 rats/group at sacrifice. In male rats, corticosterone levels were measured from 10 animals each in the control and 8,000-ppm groups at week 81, 10 animals from the 3,000-ppm group at week 94, and 10 animals from the 400-ppm group at week 104. Urinalysis was conducted at termination. Gross necropsy was carried out for all animals after 24 months of exposure, including those that had died prematurely. The brain, liver, kidneys, lungs, spleen, adrenal glands, and testes were weighed. Tissues of all major organ systems were collected for histopathological evaluation from control and 8,000-ppm exposed rats, as well as all rats that died or were sacrificed moribund. In males, the liver, kidneys, testes, and gross lesions were also examined microscopically in the 400- and 3,000-ppm groups. For females, the liver and gross lesions of the 400- and 3,000-ppm groups were examined. Data are also available for this study in the unpublished report by Chun et al. (1992).

Male rats in the 3,000- and 8,000-ppm exposed groups had increased mortality rates and decreased mean survival times with the major cause of death being chronic progressive nephropathy. Due to this, male rats in the 3,000- and 8,000-ppm exposed groups were terminated early at weeks 97 and 82, respectively. Slight, but not significant, increases in mortality and/or decreases in survival time were also observed in males at 400 ppm and females at 3,000 and 8,000 ppm; these were also attributed to chronic progressive nephropathy. Bird et al. (1997) qualitatively reported an increase in clinical signs of neurotoxicity such as blepharospasm, hypoactivity, ataxia, and lack of startle response at 3,000 and 8,000 ppm, with increased salivation in males of these groups, and prostration at 8,000 ppm. However, statistics performed for this review (Fisher’s Exact Probability Test) of incidence data provided by Chun et al. (1992) for rats showing blepharospasm, hypoactivity, salivation, ataxia, and prostration at least once during the chronic-duration study indicate that statistically significant changes were limited to prostration in females at 3,000 ppm (but not 8,000 ppm), increased incidence of ataxia in males and females at 8,000 ppm, and increased prostration and salivation in males at 8,000 ppm. Due to lack of dose-response, it is unclear if prostration observed in females is exposure-related. Quantitative startle response data could not be located for independent statistical review. The only non-neurological clinical sign noted was swollen periocular tissue in male rats at ≥3,000 ppm, which was attributed to irritative effect of direct vapor exposure rather than systemic toxicity. Based on statistics performed for this review (Fisher’s Exact Probability Test) of incidence data provided by Chun et al. (1992), statistically significant increases were observed at 3,000 and 8,000 ppm. Body weight and body weight gain decreased in the 8,000-ppm group throughout the study. Upon termination of males from the 8,000-ppm group at 82 weeks, body weight and body weight gain were decreased by 19 and 29%, respectively, compared to controls. At terminal sacrifice at 104 weeks, body weight and body weight gain in females from the 8,000-ppm group were reduced by 13 and 22%, respectively, compared to controls. No abnormalities were observed in hematological parameters of any MTBE exposed group. Serum corticosterone levels were increased by 2-fold in males from the 3,000-ppm group at week 97, but a 61% decrease was observed in males of the 8,000-ppm group at week 81. No other exposure-related changes were reported for clinical chemistry parameters. Statistical analysis for organ weights was not conducted for males exposed to 3,000 or 8,000 ppm due to early termination. In females, exposure-related and statistically significant changes in organ weight included a 20–45% increase in absolute and relative liver weights at ≥3,000 ppm and a 22–33% increase in relative kidney weight at ≥3,000 ppm.

Histopathological examination confirmed increased incidence and severity of changes associated with chronic progressive nephropathy in males at ≥400 ppm and females at ≥3,000 ppm, including glomerulosclerosis, tubular proteinosis, interstitial nephritis, and interstitial fibrosis. The most severe lesions were observed in male rats at 8,000 ppm. Additional lesions were observed in males, and considered secondary to nephropathy, including fibrous osteodystrophy, parathyroid hyperplasia, and mineralization within numerous tissues. Neoplastic lesions were observed in both the kidneys and testes. The incidence of renal tubular cell tumors was increased in male rats at ≥3,000 ppm, with a significant increase in combined incidence of adenomas and carcinomas for the 3,000-ppm group (8/50) compared to controls (1/50). Early mortality may have contributed to lack of significant increase at 8,000 ppm (3/50). No renal tubular cell tumors were found in males at 400 ppm. The incidence of testicular interstitial cell adenomas was increased significantly in at 3,000 ppm (41/50) and 8,000 ppm (47/50), compared to controls (32/50). However, observed incidences in the exposure groups were within historical controls and the control incidence was low compared to historical data. Since testicular tumors are the most common tumor in this strain of rat, and findings were within historical controls, these tumors were not considered exposure related.

Selection of the Point of Departure for the MRL: The NOAEL of 400 ppm for renal effects in female rats was selected as the POD, as it represents the lowest candidate POD. This POD is protective of local irritative effects on the eyes observed at ≥3,000 ppm and non-dose-related female prostration observed at 3,000 ppm only.

Calculations

Intermittent Exposure: The NOAEL of 400 ppm was adjusted from intermittent exposure to account for a continuous exposure scenario:

- NOAEL_ADJ_ = 400 ppm × 6 hours/24 hours × 5 days/7 days = 71.4 ppm.

Human Equivalent Concentration: While several PBPK models have been developed for MTBE, further refinement is needed to decrease uncertainty in estimated exposure levels, particularly for humans (see Sections 3.1.5 and 6.2 for more details). Therefore, a HEC value for extrarespiratory effects was calculated by multiplying the NOAEL_ADJ_ by the ratio of animal:human blood gas partition coefficients, using reported rat blood gas partition coefficient of 11.5 (Rao and Ginsberg (1997) and the midpoint of the range of human blood gas partition coefficients (17.7–19.6) reported by Rao and Ginsberg (1997) and Kim et al. (2007):

- NOAEL_HEC_ = NOAEL_ADJ_ × ratio of animal:human blood gas partition coefficients
- NOAEL_HEC_ = 71.4 ppm × (11.5/18.7)
- NOAEL_HEC_ = 71.4 ppm × (0.615) = 43.9 ppm

Uncertainty Factor: The NOAEL_HEC_ is divided by a total uncertainty factor (UF) of 30.

- 3 for extrapolation from animals to humans after dosimetric adjustment
- 10 for human variability

MRL = NOAEL_HEC_ ÷ UFs 43.9 ppm ÷ ( 3 × 10 ) = 1 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Selection of a renal effect in female rats as the critical effect following chronic-duration inhalation exposure is supported by evidence of elevated kidney weights in female rats following exposure to ≥4,000 ppm for 13 weeks (Lington et al. 1997), and female mice following exposure to 8,000 ppm for 18 months (Bird et al. 1997).

Agency Contacts (Chemical Managers): Gaston Casillas

## Methyl tert-butyl ether (MTBE) Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methyl tert-butyl ether (MTBE)
CAS Numbers: | 1634-04-4
Date: | September 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data to support derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: Available acute-duration oral studies report MTBE-related effects at LOAELs in the range of 400–450 mg/kg/day, including neurological and male reproductive effects in rats (see Table A-23). Gastrointestinal effects were observed at ≥357 mg/kg/day, but effects are limited to qualitatively reported diarrhea, which may be due to irritative portal-of-entry effects associated with bolus gavage. This is supported by evidence of gastrointestinal effects only in gavage studies (Amoco 1992; Robinson et al. 1990) and not in drinking water studies, even after chronic-duration exposure (Belpoggi et al. 1995, 1997; Bermudez et al. 2012; Dodd et al. 2013). Therefore, diarrhea was not considered for MRL derivation because it may not be a relevant endpoint for humans who are predominantly exposed via drinking water.

Of the candidate endpoints in Table A-23, none were considered adequate for MRL derivation. Reports of neurological effects at ≥400 mg/kg/day had limited qualitative and quantitative reporting, precluding use of these studies as the basis for the MRL. For male reproductive effects, adversity of decreased testes weight and increased serum LH in the absence of other testicular effects is unclear, particularly because neither of these effects were observed after 4 weeks of exposure using the same protocols at doses up to 1,600 mg/kg/day (Dong-mei et al. 2009; Li et al. 2008). Uncertainties in male reproductive effects following acute-duration oral exposure preclude the use of these endpoints as the basis for the MRL.

Table A-23 Summary of NOAEL and LOAEL Values Following Acute-Duration Oral Exposure to Methyl tert-Butyl Ether (MTBE)

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Neurological effects
Fischer 344 rat | Once | 40 | 400 | Drowsiness | MTBE Committee 1990b
Sprague-Dawley rat | 2 weeks | ND | 450 | Lethargy; transient ataxia in some animals | de Peyster et al. 2014
Male reproductive effects
Sprague-Dawley rat | 2 weeks | ND | 400 | Transient decreases in testes weight (not observed at 4 weeks) | Dong-mei et al. 2009
Sprague-Dawley rat | 2 weeks | ND | 400 | Transient increased serum LH (not observed at 4 weeks) | Li et al. 2008

LH = luteinizing hormone; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Gaston Casillas

## Methyl tert-butyl ether (MTBE) Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methyl tert-butyl ether (MTBE)
CAS Numbers: | 1634-04-4
Date: | September 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.4 mg/kg/day
Critical Effect: | Altered male reproductive development (decreased serum testosterone)
Reference: | Zhu et al. 2022
Point of Departure: | BMDL_1SD_ of 36 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 32
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.4 mg/kg/day was derived for MTBE based on developmental reproductive effects (decrease serum testosterone) in rats exposed to doses ≥300 mg/kg/day for 21 days (PNDs 35–56); a NOAEL was not identified (Zhu et al. 2022). The MRL is based on the BMDL of 36 mg/kg/day, which was divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Available intermediate-duration oral studies report the most sensitive MTBE-related effects at LOAELs in the range of 300–440 mg/kg/day, including neurological effects in rats (CNS depression), reproductive effects in adult male rats (sperm effects and changes to seminiferous tubules), and developmental reproductive effects in male rats exposed prior to puberty (decreased serum testosterone) (see Table A-24). Neurological, male reproductive, and developmental effects were all considered for MRL derivation.

Table A-24 Select NOAEL and LOAEL Values Following Intermediate-Duration Oral Exposure to Methyl tert-Butyl Ether (MTBE)

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Neurological effects
Sprague-Dawley rat | 4 weeks; 5 days/week | 90 | 440 | Transient hypoactivity | Amoco 1992
Reproductive effects
Sprague-Dawley rat | 4 weeks | ND | 400 | Increased abnormal sperm | Li et al. 2008
Sprague-Dawley rat | 30 days | ND | 400 | Seminiferous tubule changes | Gholami et al. 2015
Developmental effects
Sprague-Dawley rat | 21 days; PNDs 35–56 | ND | 300 | 50% reduction in serum testosterone | Zhu et al. 2022

LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day

Gastrointestinal effects were also observed in intermediate-duration oral studies at doses ≥100 mg/kg/day, but effects are limited to qualitatively reported diarrhea, which may be due to irritative portal-of-entry effects associated with bolus gavage. This is supported by evidence of gastrointestinal effects only in gavage studies (Amoco 1992; Robinson et al. 1990) and not in drinking water studies, even after chronic-duration exposure (Belpoggi et al. 1995, 1997; Bermudez et al. 2012; Dodd et al. 2013). Therefore, diarrhea was not considered for MRL derivation because it may not be a relevant endpoint for humans who are predominantly exposed via drinking water. One study reported mild hepatic effects (elevated serum cholesterol) in rats following exposure to ≥100 mg/kg/day for 90 days (Robinson et al. 1990); this effect was not considered for MRL derivation due to unclear adversity in the absence of associated hepatic lesions (e.g., fatty liver). Renal effects in male rats were also observed at ≥209 mg/kg/day; however, renal effects in male rats were not considered an appropriate basis for the MRL because available toxicity and mechanistic studies indicate that renal effects in males are partially attributable to α2u-globulin, which is not relevant for human health (Ahmed 2001; Bogen and Heilman 2015; McGregor 2006; Phillips et al. 2008). One low-dose study reported altered zinc and glucose homeostasis at drinking water doses ≥0.15 mg/kg/day (Saeedi et al. 2017); however, this study evaluated a limited number of endpoints and other studies evaluating serum glucose levels at much higher doses report inconsistent findings (Robinson et al. 1990). Due to unknown adversity of the findings by Saeedi et al. (2017), this study was not considered for MRL derivation.

In order to identify the most sensitive POD, BMD modeling was attempted for critical neurological, male reproductive, and developmental endpoints listed in Table A-24 when data were amenable to modeling. Data modeled for hypoactivity, sperm effects, and developmental reproductive effects (decreased serum testosterone) in male rats are shown in Tables A-25, A-26, and A-27, respectively. Data reporting for changes in the seminiferous tubules were inadequate for modeling because incidence data were not reported by Gholami et al. (2015). The data were fit to all available continuous models in EPA’s BMDS (version 3.2) using a BMR of 1 standard deviation (sperm deformity ratio, serum testosterone) or 10% extra risk (hypoactivity). Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMDL that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all models providing adequate fit to the data, the lowest BMDL (95% lower confidence limit on the BMD) was selected as the POD when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest AIC was chosen.

Table A-25 Neurological Effects in Male Rats Following Gavage Exposure to Methyl tert-Butyl Ether (MTBE) for 4 Weeks (5 Days/Week)

| Dose (mg/kg/day)
| 0 | 90 | 440 | 1,750
Hypoactivity; Incidence (percent incidence) | 0/10; (0%) | 0/10; (0%) | 4/10^a^; (40%) | 4/10^a^; (40%)

a p<0.05.

Source: Amoco 1992

Table A-26 Sperm Effects in Male Rats Following Gavage Exposure to Methyl tert-Butyl Ether (MTBE) for 4 Weeks

| Dose (mg/kg/day)
| 0 | 400 | 800 | 1,600
Sperm deformity ratio (percent); Mean±SD (n) | 12.1±3.3; (8) | 18.5±4.9^a^; (7) | 19.5±2.8^a^; (9) | 29.1±4.5^b^; (9)

a p<0.05.

b p<0.01.

(n) = number of animals; SD = standard deviation

Source: Li et al. 2008

Table A-27 Serum Testosterone Levelsa in Male Rats Following Gavage Exposure to Methyl tert-Butyl Ether (MTBE) on PNDs 35–56

| Dose (mg/kg/day)
| 0 | 300 | 600 | 1,200
Serum testosterone (ng/mL); Mean±SD (n) | 0.98±0.42; (6) | 0.46±0.20^b^; (6) | 0.47±0.20^b^; (6) | 0.41±0.29^b^; (6)

a Estimated from graphically presented data using GrabIt! Software.

b p<0.05.

(n) = number of animals; SD = standard deviation

Source: Zhu et al. 2022

Details of the modeling results for male rats are in Table A-28 for hypoactivity, Table A-29 for sperm effects, and Table A-30 for serum testosterone. In accordance with the selection criteria mentioned above, the Log-Logistic model was selected for hypoactivity, the Polynomial 3 model was selected for sperm effects, and the Exponential 4 model was selected for serum testosterone. All selected models were frequentist, restricted models.

Table A-28 Results from Benchmark Dose (BMD) Analysis of Hypoactivity in Male Rats Following Gavage Exposure to Methyl tert-Butyl Ether (MTBE) for 4 Weeks (5 Days/Week) (Amoco 1992)

Model | BMD_10_^a^ (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_10_^a^ (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Dichotomous Hill | 238.95 | 82.11 | 0.98 | 32.92 | -0.01 | 0.01
Gamma^d,e^ | 236.28 | 137.76 | 0.21 | 33.23 | -0.64 | 1.83
Log-Logistic ^e^ ^,^ ^f^ | 174.53 | 83.54 | 0.37 | 32.34 | -0.0004 | -0.76
Multistage Degree 3^g^ | 236.28 | 137.75 | 0.21 | 33.23 | -0.64 | 1.83
Multistage Degree 2^g^ | 236.28 | 137.75 | 0.21 | 33.23 | -0.64 | 1.83
Multistage Degree 1^g^ | 236.28 | 137.75 | 0.10 | 35.23 | -0.64 | 1.83
Weibull^d^ | 236.28 | 137.76 | 0.21 | 33.23 | -0.64 | 1.83
Logistic | | | 0.03 | 38.90 | 2.25 | -0.37
Log-Probit^h^ | | | 0.11 | 35.90 | -0.82 | 1.23
Probit | | | 0.03 | 38.67 | 2.26 | -0.42

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Recommended model (lowest AIC). The Hill, Gamma, Log-Logistic, Multistage, and Weibul models provided adequate fit to the means. Of these models, the BMDLs were sufficiently close (<3-fold); therefore, the model with the lowest AIC was selected (Log-Logistic).

g Betas restricted to ≥0.

h BMDL 10 times lower than lowest non-zero dose; BMD/BMDL ratio >20.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = dose associated with 10% extra risk)

Table A-29 Results from Benchmark Dose (BMD) Analysis (Constant Variance) of Sperm Deformity Ratio (%) in Male Rats Following Gavage Exposure to Methyl tert-Butyl Ether (MTBE) for 4 Weeks (Li et al. 2008)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential (model 2)^d^ | 522.19 | 431.25 | 0.18 | 188.92 | 1.46 | -0.28
Exponential (model 3)^d^ | 522.19 | 431.24 | 0.18 | 188.92 | 1.46 | -0.28
Exponential (model 4)^d^ | | | 0.09 | 190.32 | -0.37 | 1.26
Exponential (model 5)^d^ | | | 0.09 | 190.34 | -0.35 | 1.24
Hill^d^ | | | 0.09 | 190.36 | -0.33 | 1.24
Polynomial (3-degree) ^d^ ^,^ ^e^ | 409.32 | 297.57 | 0.26 | 188.22 | 1.33 | -0.73
Polynomial (2-degree)^d^ | 394.28 | 296.60 | 0.25 | 188.30 | -0.46 | 1.31
Power^d^ | 377.79 | 296.35 | 0.24 | 188.32 | -0.38 | 1.26
Linear | 377.79 | 296.35 | 0.24 | 188.32 | -0.38 | 1.26

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model (lowest AIC). The constant variance model provided an adequate fit to the data. The Exponential 2, Exponential 3, 3-degree polynomial, 2-degree polynomial, Power, and Linear models provided adequate fit to the means. Of these models, the BMDLs were sufficiently close (<3-fold); therefore, the model with the lowest AIC was selected (Polynomial 3-degree model).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a change of 1 standard deviation from the control)

Table A-30 BMD Model Predictions (Nonconstant Variance) for Serum Testosterone Levels in Male Sprague-Dawley Rats Following Gavage Exposure to Methyl tert-Butyl Ether (MTBE) for 21 Days (PNDs 35 to 56) (Zhu et al. 2022)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential (model 2)^d^ | | | 0.02 | 16.93 | -0.41 | 0.85
Exponential (model 3)^d^ | | | 0.02 | 16.93 | -0.41 | 0.85
Exponential (model 4) ^d^ ^,^ ^e^ | 83.53 | 35.67 | 0.87 | 11.30 | -0.001 | 0.11
Exponential (model 5)^d^ | | | NA | 13.29 | 3.56x10^-5^ | 0.15
Hill^d^ | | | NA | 13.29 | -9.43x10^-7^ | 0.15
Polynomial (3-degree)^d^ | | | 0.01 | 18.51 | -0.70 | 0.48
Polynomial (2-degree)^d^ | | | 0.01 | 18.51 | -0.70 | 0.48
Power^d^ | | | 0.01 | 18.51 | -0.70 | 0.48
Linear | | | 0.01 | 18.51 | -0.70 | 0.48

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model (lowest AIC; only adequate fitting model). The constant variance model provided an adequate fit to the data. Only the Exponential 4 model provided adequate fit to the means and calculated a BMDL; however, the BMDL for this model was 10 times lower than the lowest non-zero dose and is considered an inadequate fit to the data (data not shown). The nonconstant variance model also provided an adequate fit to the data. Only the Exponential 4 model provided adequate fit to the means. Therefore, the model with the lowest AIC and the only model with an adequate fit to the means was selected (Exponential 4).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a change of 1 standard deviation from the control); NA = not applicable; PND = postnatal day

Potential PODs for deriving an intermediate-duration oral MRL for MTBE include:

- BMDL_1SD_ of 36 mg/kg/day based on decreased serum testosterone in rats following early postnatal exposure (Zhu et al. 2022)
- BMDL_ADJ_ of 60 mg/kg/day based on transient hypoactivity in rats (Amoco 1992)
- BMDL_1SD_ of 298 mg/kg/day based on increased abnormal sperm in rats (Li et al. 2008)
- LOAEL of 400 mg/kg/day based on seminiferous tubule changes in rats (Gholami et al. 2015)

The BMDL_1SD_ of 36 mg/kg/day for decreased serum testosterone following developmental exposure was selected as the POD for deriving an intermediate-duration oral MRL for MTBE because it represents the more conservative (health-protective) POD. Model fit for decreased serum testosterone is shown in Figure A-2 (Exponential 4 Model); no alternative models were identified.

Figure A-2 Fit of the Exponential 4 Model (Nonconstant Variance) to Data for Methyl tert-Butyl Ether (MTBE), Serum Testosterone Levels in Male Sprague-Dawley Rats (Zhu et al. 2022)

Selection of the Principal Study: The 21-day prepubertal study in rats by Zhu et al. (2022) was selected as the principal studies because it provided the lowest POD (BMDL = 36 mg/kg/day) for the critical effect (developmental toxicity).

Summary of the Principal Study:

Zhu Q, Zhu S, Li Q, . 2022. Methyl tert-butyl ether inhibits pubertal development of Leydig cells in male rats by inducing mitophagy and apoptosis. Ecotoxicol Environ Saf 232:113282 35131586

Groups of juvenile male rats (6/group) were exposed to 0, 300, 600, or 1,200 mg/kg/day via gavage in corn oil from PND 35 to 56, a time frame that covers late puberty. Body weights were recorded at the beginning and end of the exposure period. After the exposure period, rats were sacrificed. Blood was collected for analysis of testosterone, LH, and FSH levels. The testes and epididymides were removed and weighed. The number and volume of Sertoli and Leydig cells was determined. Biomarkers for Sertoli and Leydig cells were SOX9 and CYP11A1, respectively. Cell proliferation and apoptosis was determined. Protein and RNA were isolated from testicular tissue for expression analysis.

No changes in body or testicular weights were noted. Serum testosterone was significantly decreased by ≥50% at all tested dose levels. No changes in serum LH or FSH were observed. No changes in the number of Sertoli cells were noted; however, the number Leydig cells were significantly decreased by ~20% at 1,200 mg/kg/day, compared to control. Analysis showed that overall cell size and cytoplasmic size of Leydig cells were decreased, while nuclear size was unchanged. The study authors interpreted these findings to indicate a delayed maturation of Leydig cells in high-dose males. Tunnel assay showed that decreased Leydig cell number was, in part, due to a significant increase in Leydig cell apoptosis at ≥600 mg/kg/day. Gene analysis showed reduced messenger RNA (mRNA) levels of cell cycle-related genes, and protein analysis showed alterations in proteins involved in apoptosis and autophagy. In vitro data published with the in vivo study supported inhibition of testosterone synthesis by cultured Leydig cells via reactive oxygen species generation, mitophagy, and apoptosis.

Selection of the Point of Departure for the MRL: The BMDL of 36 mg/kg/day developmental reproductive toxicity (decreased serum testosterone following prepubertal exposure) in rats reported by Zhu et al. (2022) was selected as the POD because it represents the lowest available POD for the critical effect (developmental toxicity).

Intermittent Exposure: Exposure was daily; therefore, no adjustment for intermittent exposure was necessary.

Uncertainty Factor: The BMDL is divided by a total uncertainty factor (UF) of 100:

- 10 for extrapolation from animals to humans;
- 10 for human variability

MRL = BMDL_1SD_ ÷ ( UFs × MF ) 36 mg/kg/day ÷ ( 10 × 10 ) = 0.36 mg/kg/day ≈ 0.4 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Selection of a reduced serum testosterone as the critical effect following intermediate-duration oral exposure during development is supported by progression to decreased Leydig cell number and size at higher doses (Zhu et al. 2022). Studies in adult rats also provide some evidence of adverse male reproductive effects following oral exposure, although there are some inconsistencies across study and exposure durations. Regarding the critical effect, decreased serum testosterone was observed at acute- and intermediate-duration doses ≥800 mg/kg/day in several studies (de Peyster et al. 2003; Khalili et al. 2015; Li et al. 2008; Williams et al. 2000); however, one study did not observe exposure-related changes in serum or testicular testosterone levels in rats at gavage doses as high as 1,200 mg/kg/day for 2 weeks (de Peyster et al. 2014). There is some evidence of testicular damage, including damage to sperm/germ cells, after acute-duration exposure to 1,600 mg/kg/day or intermediate-duration exposure to doses ≥400 mg/kg/day (Gholami et al. 2015; Li et al. 2008). However, other studies in rats reported no non-neoplastic alterations in the testes following acute-duration exposure to ≤1,428 mg/kg/day (Bermudez et al. 2012; Robinson et al. 1990), intermediate-duration exposure to ≤1,750 mg/kg/day (Amoco 1992; Bermudez et al. 2012; Robinson et al. 1990; Williams et al. 2000), or chronic-duration exposure to ≤1,000 mg/kg/day (Belpoggi et al. 1995, 1997; Bermudez et al. 2012; Dodd et al. 2013).

Despite inconsistencies in the oral database, available data suggest that the male reproductive system may be a sensitive target of MTBE toxicity. This is supported by mechanistic data attributing observed male reproductive effects to direct toxic effects of MTBE on testicular cells, which may be mediated via oxidative stress (Li and Han 2006; Li et al. 2007, 2009). Additionally, mechanistic data provide support for inhibition of testosterone synthesis via toxicity to Leydig cells (Zhu et al. 2022).

Agency Contacts (Chemical Managers): Gaston Casillas

## Methyl tert-butyl ether (MTBE) Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methyl tert-butyl ether (MTBE)
CAS Numbers: | 1634-04-4
Date: | September 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data to support derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: Serious effects (death and cancer) were observed at ≥250 mg/kg/day, along with dysplastic proliferation of lymphoreticular tissue (possibly preneoplastic). The only adverse effects observed at doses below this serious LOAEL value are renal effects in male rats at drinking water doses ≥29 mg/kg/day (Bermudez et al. 2012); however, these effects were not considered an appropriate basis for the MRL because available toxicity and mechanistic studies indicate that renal effects in males are partially attributable to α2u-globulin, which is not relevant for human health (Ahmed 2001; Bogen and Heilman 2015; McGregor 2006; Phillips et al. 2008). Renal effects in female rats were not observed until chronic-duration doses 4-fold higher than the identified serious LOAEL (1,042 mg/kg/day; Dodd et al. 2013). Therefore, a chronic-duration oral MRL was not derived.

Agency Contacts (Chemical Managers): Gaston Casillas