# 9 REFERENCES

* Cited in text

*Aaron CK, Howland MA. 1998. Insecticides: Organophosphates and carbamates. In: Goldfrank LR, Flomenbaum NE, Lewin NA, ., ed. Goldfrank’s toxicologic emergencies. Stamford, CT: Appleton & Lange, 1429–1449.
Abe S, Sasaki M. 1982. SCE as an index of mutagenesis and/or carcinogenesis. Chapter 24. In: Sister chromatid exchange. Vol. 2, New York, NY: Alan R. Liss, Inc., 461–514.
Abe T, Fujimoto Y, Tatsuno T, . 1979. Separation of methyl parathion and fenitrothion metabolites by liquid chromatography. Bull Environ Contam Toxicol 22:791–795.486783
*Abu-Qare AW, Abdel-Rahman AA, Kishk AM, . 2000. Placental transfer and pharmacokinetics of a single dermal dose of [^14^C] methyl parathion in rats. Toxicol Sci 53:5–12.10653515
ACGIH. 1998. Documentation of the threshold limit values and biological exposure indices. 6^th^ ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 2000. Documentation of the threshold limit values and biological exposure indices. 6^th^ ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Ackermann H. 1966. [Enzymatic detection of organophosphorus insecticides using thin layer chromatography]. Nahrung 10:273–274. (German)
*Ackermann H, Engst R. 1970. [Presence of organophosphorus insecticides in the fetus]. Arch Toxicol 26:17–22. (German)
*ADEQ. 2001. Arizona research HAPs list. Arizona Department of Environmental Quality. Http://www.adeq.state.az.us/comm/download/air.html. January 19, 2001.
Adhikari M, Das PK, Das K. 1986. Studies on adsorption and desorption of methyl parathion on humic substances. J Indian Chem Soc 63:1027–1029.
*Adhya TK, Barik S, Sethunathan N. 1981. Stability of commercial formulation of fenitrothion, methyl parathion, and parathion in anaerobic soils. J Agric Food Chem 29:90–93.
*Adhya TK, Wahid PA, Sethunathan N. 1987. Persistence and biodegradation of selected organophosphorus insecticides in flooded versus non-flooded soils. Biol Fertil Soils 4:36–40.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect 103(Supplement 7):103–112.
*Agostiano A, Caselli M, Provenzano MR. 1983. Analysis of pesticides and other organic pollutants by preconcentration and chromatographic techniques. Water Air Soil Pollut 19:309–320.
*Ahmed HF. 2000. Monitoring methyl parathion residues in milk and yogurt, and fate of [^14^C] methyl parathion during milk processing. Bull Environ Contam Toxicol 65:207–214.10885998
*Alak AM, Vo-Dinh T. 1987. Surface-enhanced raman spectrometry of organophosphorus chemical agents. Anal Chem 59:2149–2153.3674432
*Albanis TA, Pomonis PJ, Sdoukos AT. 1988a. Describing movement of three pesticides in soil using a CSTR in series model. Water Air Soil Pollut 39:293–302.
*Albanis TA, Pomonis PJ, Sdoukos AT. 1988b. Movement of methyl parathion, lindane and atrazine through lysimeters in field conditions. Toxicol Environ Chem 17:35–45.
Albanis TA, Pomonis PJ, Sdoukos AT. 1988c. The influence of fly ash on hydrolysis, degradation and adsorption of methyl parathion in aqueous soil suspensions. Toxicol Environ Chem 17:351–362.
Albrecht R, P’elissier MA, Manchon P, . 1975. [Effect of methyl parathion or zineb administration on the activity of some hepatic enzymes in rats]. Ann Nutr Aliment 29:223–238. (French)174473
*Albright R, Johnson N, Sanderson TW, . 1974. Pesticide residues in the top soil of 5 west Alabama counties. Bull Environ Contam Toxicol 12:378–384.4139997
*Altman PK, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III, 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Alvarez-Benedi J, Tabernero MT, Atienza J, . 1999. A coupled model representing volatilisation and sorption of soil incorporated herbicides. Chemosphere 38(7):1583–1593.
Ambrus A, Visi W, Zakar F, . 1981. General method for determination of pesticide residues in samples of plant origin, soil, and water. III. Gas chromatographic analysis and confirmation. J Assoc Off Anal Chem 64:749–768.
Amirav A, Jing H. 1998. Simultaneous pulsed flame photometric and mass spectrometric detection for enhanced pesticide analysis capabilities. J Chromatogr 814:133–150.
*Andersen ME, Kirshnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ 3rd, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
*Anderson PN, Eaton DL, Murphy SD. 1992. Comparative metabolism of methyl parathion in intact and subcellular fractions of isolated rat hepatocytes. Fundam Appl Toxicol 18:221–226.1601221
*Anthony DC, Montine TJ, Graham DG. 1996. Toxic responses of the nervous system. In: Wonsiewicz MJ, Sheinis LA, ed. Casarett and Doull’s toxicology: The basic science of poisons. New York, NY: McGraw-Hill, 475–476.
Anver M, Cohen BJ. 1979. Lesions associated with aging. In: Baker HJ, Lindsey JR, Weisbroth SH, eds. The laboratory rat. Volume I: Biology and diseases. New York, NY: Academic Press, 377–399.
Anwar WA. 1997. Biomarkers of human exposure to pesticides. Environ Health Perspect Suppl 105(Supplement 4):801–806.9255564
*AOAC. 1984. Organophosphorus pesticide residues sweep codistillation method: Final action. AOAC Official methods of analysis. 10th ed. Washington, DC: Association of Official Analytical Chemists.
Arbuckle TE, Sever LE. 1998. Pesticide exposures and fetal death: A review of the epidemiologic literature. Crit Rev Toxicol 28:229–270.9631282
Arthun DA, Chakraborti TK, Chapman JL, . 1991. Comparison of in vivo acetylcholinesterase (AChE) inhibition in neonatal and adult rats by three organophosphorus insecticides. Neurotoxicology 12:143.
Arthur RD, Cain JD, Barrentine BF. 1976. Atmospheric levels of pesticides in the Mississippi Delta. Bull Environ Contam 15:129–134.
Ashby J, Paton D. 1995. Chemicals for evaluating the sensitivity and specificity of reduced/transgenic rodent cancer bioasssay protocols. Mutat Res 331:27–38.7666866
Asghar M, Sheikh MA, Hashmi AS. 1994. Effects of orally fed methyl parathion on some haematochemical parameters of rabbits. Pakistan Veterinary J 14:34–36.
*Asmathbanu I, Kaliwal BB. 1997. Temporal effect of methyl parathion on ovarian compensatory hypertrophy, follicular dynamics and estrous cycle in hemicastrated albino rats. J Basic Clin Physiol Pharmacol 8:237–254.9651797
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Division of Toxicology.
*ATSDR. 1999. ATSDR national alerts-toxic substances. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/alerts/961213.html. May 17, 1999.
*Auditore JV, Hartmann RC. 1959. Paroxysmal nocturnal hemoglobinuria—II. Erythrocyte acetylcholinesterase defect. Am J Med 27:401–410.13795054
Aulerich RJ, Ringer RK, Safronoff J. 1987. Primary and secondary toxicity of warfarin, sodium monofluoroacetate, and methyl parathion in mink. Arch Environ Contam Toxicol 16:357–366.3592762
Azaroff LS, Neas LM. 1999. Acute health effects associated with nonoccupational pesticide exposure in rural El Salvador. Environ Res A80:158–164.
Azatyan RA, Voskanyan AZ, Mirzoyan GI. 1987. Cytogenetic activity of some organophosphorus insecticides [Abstract]. Tsitol Genet 21:226–227.3617219
*Badawy MI, El-Dib MA. 1984. Persistence and fate of methyl parathion in sea water. Bull Environ Contam Toxicol 33:40–49.6432077
*Badawy MI, El-Dib MA, Aly OA. 1984. Spill of methyl parathion in the Mediterranean Sea: A case study at Port-Said, Egypt. Bull Environ Contam Toxicol 32:469–477.6713141
*Baker LW, Fitzell DL, Seiber JN, . 1996. Ambient air concentrations of pesticides in California. Environ Sci Technol 30:1365–1368.
*Baker RD, Applegate HG. 1970. Effect of temperature and ultraviolet radiation on the persistence of methyl parathion and DDT in soils. Agron J 62:509–512.
Baker RD, Applegate HG. 1974. Effect of ultraviolet radiation on the persistence of pesticides. Tex J Sci 25:53–59.
Barcelo D. 1988. Application of thermospray liquid chromatography/mass spectrometry for determination of organophosphorus pesticides and trialkyl and triaryl phosphates. Biomed Environ Mass Spectrom 17:363–369.3207925
*Barnes DG, Dourson M. 1988. Reference dose (RfD) description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barr DB, Barr JR, Driskell WJ, . 1999. Strategies for biological monitoring of exposure for contemporary-use pesticides. Toxicol Ind Health 15:168–179.10188199
Barthel E. 1981. [Cancer risk in pesticide exposed agricultural workers]. Arch Geschwulstforsch 51:579–585. (German)7337540
Bartoli S, Bonora B, Colacci A, . 1991. DNA damaging activity of methyl parathion. Res Commun Chem Pathol Pharmacol 71:209–218.1710814
Basha PM, Nayeemunnisa. 1993a. Effect of methyl parathion on Na^+^, K^+^, and Mg^2+^ adenosine triphosphatase activity in developing central nervous system in rats. Indian J Exp Biol 31:785–787.8276452
Basha PM, Nayeemunnisa. 1993b. Methyl parathion induced alterations in GABAergic system during critical stage of central nervous system development in albino rat pups. Indian J Exp Biol 31:369–372.8359836
Bason CW, Colborn T. 1998. U.S. application and distribution of pesticides and industrial chemicals capable of disrupting endocrine and immune systems. J Clean Technol Environ Toxicol Occup Med 7:147–156.
*Baughman GL, Lassiter RR. 1978. Prediction of environmental pollutant concentration. In: Carins J Jr, Dickson KL, Maxi AW, eds. Estimating the hazard of chemical substances to aquatic life. American Society for Testing and Materials, Philadelphia, PA. ASTM STP657, 35–54.
Baynes RE, Bowen JM. 1995. Rapid determination of methyl parathion and methyl paraoxon in milk by gas chromatography with solid-phase extraction and flame photometric detection. J Assoc Off Anal Chem 78:812–815.
*Belisle AA, Swineford DM. 1988. Simple, specific analysis of organophosphorus and carbamate pesticides in sediments using column extraction and gas chromatography. Environ Toxicol Chem 7:749–752.
Bello S, Halton DM. 1985. Occupational chemical exposures and the heart. Hamilton, Ontario: Canadian Centre for Occupational Health and Safety. CCOHS Publication No. P85-5E. NIOSH-00175455.
Benke GM, Murphy SD. 1974. The influence of age and sex on the toxicity and multiple pathways of metabolism of methyl parathion and parathion in rats. Toxicol Appl Pharmacol 29:125.
*Benke GM, Murphy SD. 1975. The influence of age on the toxicity and metabolism of methyl parathion and parathion in male and female rats. Toxicol Appl Pharmacol 31:254–269.1129797
*Benke GM, Cheever KL, Mirer FE, . 1974. Comparative toxicity, anticholinesterase action and metabolism of methyl parathion and parathion in sunfish and mice. Toxicol Appl Pharmacol 28:97–109.4851102
*Berg GL. 1981. Farm chemicals handbook 1981. Willoghby, OH: Meister Publishing Co., C218–C219.
*Berger G. 1994. Epidemiology of endometriosis. In: Modern surgical management of endometriosis. New York, NY: Springer-Verlag.
Berkman CE, Ryu S, Quinn DA, . 1993. Kinetics of the postinhibitory reactions of acetylcholinesterase poisoned by chiral isomalathion: A surprising nonreactivation induced by the Rp stererisomers. Chem Res Toxicol 6:28–32.8448346
*Berry MR, Johnson LS, Jones JW, . 1997. Dietary characterizations in a study of human exposures in the lower Rio Grande Valley: I. Foods and beverages. Environ Int 23:675–692.
*Betowski LD, Jones TL. 1988. Analysis of organophosphorus pesticide samples by high-performance liquid chromatography/mass spectrometry and high-performance liquid chromatography/mass spectrometry/mass spectrometry. Environ Sci Technol 22:1430–1434.22200469
*Bhattacharya S. 1993. Target and non-target effects of anticholinesterase pesticides in fish. Sci Total Environ Supp. 1993:859–866.
*Bhattacharya S, Mondal S. 1997. Disruption of endocrine functions in fish by environmental contaminants. In: International Congress of Comparative Endocrinology, ed. Advances in comparative endocrinology: Proceedings of the 13th International Congress of Comparative Endocrinology, Yokohama, November 16-21, 1997. Bologna: Monduzzi Editore, International Proceedings Division, 1729–1732.
Bhide M, Modi S. 1993. Effect of methyl parathion on the ovarian histopathology and on behavioral changes in albino rats. J Environ Biol 14:211–219.
Blasiak J. 1993. Parathion and methyl parathion-altered fluidity of native and model membranes. Pestic Biochem Physiol 45:72–80.
Blasiak J. 1995. Inhibition of erythrocyte membrane (Ca^2+^ + Mg^2+^)-ATPase by the organophosphorus insecticides parathion and methyl parathion. Comp Biochem Physiol 110C:119–125.
Blasiak J, Kowalik J. 1998. Interaction between organophosphorus compounds and DNA assayed by the restriction endonuclease EcoRI. Acta Univ Lodz Folia Biochim Biophys 13:31–67.
Blasiak J, Kowalik J. 1999. Effect of paraoxon-methyl and parathion-methyl on DNA in human lymphocytes and protective action of vitamin C. Pestic Sci 55:1182–1186.
*BNA. 2001. Environment and safety: States and territories. Bureau of National Affairs. Http://www.bna.com/. February 12, 2001.
Bolognesi C, Bonatti S, Degan P, . 1994. Genotoxicity of some pesticides used in floriculture comparative evaluation of active ingredients and agrochemical formulations. Carcinogenesis 35:144.
*Bowers MD Jr, Goodman E, Sim VM. 1964. Some behavioral changes in man following anticholinesterase administration. J Nerv Ment Dis 138:383–389.14141895
Bowman BT, Sans WW. 1983. Further water solubility determination of insecticidal compounds. J Environ Sci Health B18:221–227.
Boyes WK, Tandon P, Barone S, . 1994. Effects of organophosphates on the visual system of rats. J Appl Toxicol 14:135–143.8027509
Bradman MA, Harnly ME, Draper W, . 1997. Pesticide exposures to children from California’s central valley: Results of a pilot study. J Expo Anal Environ Epidemiol 7:217–234.9185013
*Braeckman RA, Audenaert P, Willems JL, . 1983. Toxicokinetics of methyl parathion and parathion in the dog after intravenous and oral administration. Arch Toxicol 54:71–82.6639354
*Braeckman RA, Godefroot MG, Blondeel GM, . 1980. Kinetic analysis of the fate of methyl parathion in the dog. Arch Toxicol 43:263–271.7387386
*Brahmaprakash GP, Panda S, Sethunathan N. 1987. Relative persistence of hexachlorocyclohexane, methyl parathion and carbofuran in an alluvial soil under flooded and non-flooded conditions. Agric Ecos Environ 19:29–39.
Breau AP, Mitchell WM, Swinson J, . 1985. Mutagenic and cell transformation activities of representative phosphorothioate esters in vitro. J Toxicol Environ Health 16:403–413.4087308
*Brimijoin S, Koenigsberger C. 1999. Cholinesterases in neural development: New findings and toxicologic implications. Environ Health Perspect 107 (Supp. 1):59–64.10229707
Brock A. 1991. Inter and intraindividual variations in plasma cholinesterase activity and substance concentration in employees of an organophosphorus insecticide factory. Br J Ind Med 48:562–567.1878314
*Bronstein AC, Currance PL, eds. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: CV Mosby Company, 66, 199–200.
Buckley TJ, Liddle J, Ashley DL, . 1997. Environmental and biomarker measurements in nine homes in the lower Rio Grande Valley: Multimedia results for pesticides, metals, PAHs, and VOCs. Environ Int 23:705–732.
*Budavari S, ed. 1989. The Merck index. 11^th^ ed. Rahway, NJ: Merck and Co., Inc., 959–960.
Bulusu S, Chakravarty I. 1988. Profile on drug metabolizing enzymes in rats treated with parathion, malathion, and phosalone under various conditions of protein energy malnutrition. Bull Environ Contam Toxicol 40:110–118.3125871
Bureau of the Census. 1980. US Exports, Schedule E. Commodity by country. Washington, DC: U.S. Department of Commerce, Bureau of the Census. FT410/September 1980, 2–88.
Bureau of the Census. 1981. US Exports, Schedule E. Commodity by country. Washington, DC: U.S. Department of Commerce, Bureau of the Census. FT410/September 1981, 2–88.
*Bureau of the Census. 1984. US Exports, Schedule E. Washington, DC: U.S. Department of Commerce, Bureau of the Census, 2–84.
*Bureau of the Census. 1986. US Exports, Schedule B. Commodity by country. Washington, DC: U.S. Department of Commerce, Bureau of the Census, FT446.
*Butler LC, Staiff DC, Davis JE. 1981a. Methyl parathion persistence in soil following simulated spillage. Arch Environ Contam Toxicol 10:451–458.7259307
*Butler LC, Staiff DC, Sovocool GW, . 1981b. Field disposal of methyl parathion using acidified powdered zinc. J Environ Sci Health B16:49–58.
*Butler PA, Schutzmann RL. 1978. Fish, wildlife and estuaries: Residues of pesticides and PCBs in estuarine fish, 1972-1976--national pesticide monitoring program. Pestic Monit J 12:51–59.101966
*California EPA. 1995. Sampling for pesticide residues in California well water: 1995 update of the well inventory data base, for sampling results reported from July 1, 1994 to June 30, 1995. Sacramento, CA: California Environmental Protection Agency, Department of Pesticide Regulation, Environmental Monitoring and Pest Management Branch, Environmental Hazards Assessment Program.
*California EPA. 2001. Evaluation of methyl parathion as a toxic air contaminant. Department of Pesticide Regulation, California Environmental Protection Agency. Http://www.cdpr.ca.gov:8765/. January 19, 2001.
Campbell JL, Smith MA, Eiteman MA, . 2000. Comparison of solvents for removing pesticides form skin using an in vitro porcine model. Am Ind Hyg Assoc J 61:82–88.
*Capriel P, Haisch A, Khan SU. 1986. Supercritical methanol: An efficacious technique for the extraction of bound pesticide residues from soil and plant samples. J Agric Food Chem 34:70–73.
Carey AE, Kutz FW. 1985. Trends in ambient concentrations of agrochemicals in humans and the environment of the United States. Environ Assess 5:155–163.
*Carey AE, Gowen JA, Tai H, . 1979. Pesticide residue levels in soils and crops from 37 states, 1972—national soils monitoring program (IV). Pestic Monit J 12:209–229.461116
Carrano AV, Thompson LH, Lindl PA, . 1978. Sister-chromatid exchange as an indicator of mutagenesis. Nature 271:551–553.622190
*Carricaburu P, Lacroix R, Lacroix J. 1980. Electroretinographic study of the white mouse intoxicated by organophosphorus: Methyl parathion, parathion and paraoxon. Pestic Biochem Physiol 13:244–248.
Carsel RF, Mulkey LA, Lorber MN, . 1985. The pesticide root zone model (PRZM): A procedure for evaluating pesticide leaching threats to groundwater. Ecological Modeling 30:49–69.
Cassil CC, Stanovick RP, Cook RF. 1969. A specific gas chromatographic method for residues of organic nitrogen pesticides. Residue Rev 26:63–87.5807589
*Castillo M, Domingues R, Alpendurada MF, . 1997. Persistence of selected pesticides and their phenolic transformation products in natural waters using off-line liquid solid extraction followed by liquid chromatographic techniques. Anal Chim Acta 353:133–142.
CDC. 1999. Center for Disease Control & Prevention. Http://search.cdc.gov/shd/search2.html. May 25, 1999.
*CDC. 2001. Pesticide applications and field posting. New Jersey Agricultural Experiment Station. Center for Disease Control. Http://search.cdc.gov/search97cgi/s…xt=methyl+parathion&Sortfield=Score. January 17, 2001.
CEC. 1976. Council directive of 23 November 1976 relating to the fixing of maximum levels for pesticide residues in and on fruit and vegetables. Off J Euro Comm L340:26–31.
CEC. 1982. Proposal for a council directive amending Annex II to Directive 76/895/EEC relating to the fixing of maximum levels for pesticide residues in and on fruit and vegetables. Off J Euro Comm C95:6–10.
*Ceron JJ, Panizo CG, Montes A. 1995. Toxicological effects in rabbits induced by endosulfan, lindane, and methyl parathion representing agricultural byproducts contamination. Bull Environ Contam Toxicol 54:258–265.7537992
Ceron Madrigal JJ, Fernandez del Palacio MJ, Bernal Gambin L, . 1995. Inhibicion de acetilcolinesterasa en conejos tras exposicion subcronica a metilparation: Comparacion del los metodos de Ellman y de Voss y Sachsse. Revista de Toxicologia (Iberica) 12:35–38.
Chambers JE, Carr RL. 1995. Biochemical mechanisms contributing to species differences in insecticidal toxicity. Toxicology 105:291–304.8571366
*Chambers JE, Ma T, Boone JS, . 1994. Role of detoxication pathways in acute toxicity levels of phosphorothionate insecticides in the rat. Life Sci 54:1357–1364.7514706
*Chang MJW, Chen YC, Yang HJ. 1997. Comparative evaluation on the biological monitoring of exposure to parathion and its methyl analog. Arch Environ Contam Toxicol 32:422–425.9175510
Chen HH, Sirianni SR, Huang CC. 1982. Sister chromatid exchanges in Chinese hamster cells treated with seventeen organophosphorus compounds in the presence of a metabolic activation system. Environ Mutagen 4:621–624.7140680
*Chen MM, Hsueh JL, Sirianni SR, . 1981. Induction of sister-chromatid exchanges and cell cycle delay in cultured mammalian cells treated with eight organophosphorus pesticides. Mutat Res 88:307–316.7254224
Chen ZM, Zabik MJ, Leavitt RA. 1984. Comparative study of thin film photodegradation rates for 36 pesticides. Industrial and Engineering Chemistry Product Research and Development 23:5–11.
Chian ES, Bruce WN, Fang HH. 1975. Removal of pesticides by reverse osmosis. Environ Sci Technol 9:52–59.
Cho T-H, Wild JR, Connelly KC. 2000. Utility of organophosphorus hydrolase for the remediation of mutagenicity of methyl parathion. Environ Toxicol Chem 19(8):2022–2028.
Chou CHSJ, Holler J, De Rosa CT. 1998. Minimal risk levels (MRLs) for hazardous substances. J Clean Technol Environ Toxicol Occup Med 7:1–24.
*Choudhury C, Ray AK, Bhattacharya S, . 1993. Non lethal concentrations of pesticide impair ovarian function in the freshwater perch, Anabas testudineus. Environ Biol Fishes 36:319–324.
*Clark GJ, Goodin RR, Smiley JW. 1985. Comparison of ultraviolet and reductive amperometric detection for determination of ethyl and methyl parathion in green vegetables and surface water using high-performance liquid chromatography. Anal Chem 57:2223–2228.4061836
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
CLPSD. 1989. Contract Laboratory Program Statistical Database. U.S. Environmental Protection Agency. July 12, 1989.
Cohen ML, Steinmetz WD. 1986. Foliar wash off of pesticides by rainfall. Environ Sci Technol 20:521–523.19994939
Cole LK, Metcalf RL. 1977. Distribution of pesticides and their derivatives in the air, soil, water, and biota of physical model ecosystems. Air Pollut Control Assoc 70th Ann Meet Proc 4:1–15.
*Cooper CM. 1991. Persistent organochlorine and current use insecticide concentrations in major watershed components of Moon Lake, Mississippi, USA. Arch Hydrobiol 121:103–113.
*Costa LG, Murphy SD. 1984. Interaction between acetaminophen and organophosphates in mice. Res Commun Chem Pathol Pharmacol 44:389–400.6205424
*Costa LG, Schwab BW, Murphy SD. 1982. Tolerance to anticholinesterase compounds in mammals. Toxicology 25:79–97.6760465
Coullard CM, Nellis P. 1999. Organochlorine contaminants in mummichog (fundulus heteroclitus) living downstream form a bleache-kraft pulp mill in the Miramichi estuary, New Brunswick, Canada. Environ Toxicol Chem 18(11):2545–2556.
Cowart RP, Bonner FL, Epps EA Jr. 1971. Rate of hydrolysis of seven organophosphate pesticides. Bull Environ Contam Toxicol 6:231.4115900
*Cranmer M. 1970. Determination of p-nitrophenol in human urine. Bull Environ Contam Toxicol 5:329–332.
*Cripe CR, Walker WW, Pritchard PH, . 1987. A shake-flask test for estimation of biodegradability of toxic organic substances in the aquatic environment. Ecotoxicol Environ Safety 14:239–251.3691377
*Crittenden PL, Carr R, Pruett SB. 1998. Immunotoxicological assessment of methyl parathion in female B6C3F1 mice. J Toxicol Environ Health 54:1–20.
*Crossland NO, Bennett D. 1984. Fate and biological effects of methyl parathion in outdoor ponds and laboratory aquaria. I. Fate. Ecotoxicol Environ Safety 8:471–481.6489242
Crowder LA, Whitson RS. 1980. Fate of toxaphene, methyl parathion, and chlordimeform combinations in the mouse. Bull Environ Contam Toxicol 24:444–451.
*Crowder LA, Lanzaro GC, Whitson RS. 1980. Behavioral effects of methyl parathion and toxaphene exposure in rats. J Environ Sci Health B15:365–378.
*Czeizel AE. 1994. Phenotypic and cytogenetic studies in self-poisoned patients. Mutat Res 313:175–181.7523902
Dale WE, Curley A, Cueto C. 1966. Hexane extractable chlorinated insecticides in human blood. Life Sci 5:47–54.5933655
*Daly, IW. 1989. A 13-week subchronic toxicity study of methyl parathion in dogs via the diet followed by a one-month recovery period. Stilwell, KS: Mobay Corporation.
Dan B, Medda JN. 1990. Teratogenic studies of methyl parathion on chick embryos. In:, ed. Impacts of environment on animals and aquaculture. Kalyani, West Bengal: University of Kalyani, 241–245.
Das P, John G. 1999. Induction of sister chromatid exchanges and chromosome aberrations in vivo in Etroplus suratensis (Bloch) following exposure to organophosphorus pesticides. Toxicol Lett 104:111–116.10048756
*Davies JE, Peterson JC. 1997. Surveillance of occupational, accidental, and incidental exposure to organophosphate pesticides using urine alkyl phosphate and phenolic metabolite measurements. Ann NY Acad Sci 837:257–268.9472345
Davis DL, Ahmed AK. 1998. Exposures from indoor spraying of chlorpyrifos pose greater health risks to children than currently estimated. Environ Health Perspect 106:299–301.9618343
Davis JE, Staiff DC, Butler LC, . 1977. Persistence of methyl and ethyl parathion following spillage on concrete surfaces. Bull Environ Contam Toxicol 18:18–25.884332
*Dean A, Pugh J, Embrey K, . 1984. Organophosphate insecticide poisoning among siblings—Mississippi. MMWR 33:592–594.6434935
*Dean BJ. 1972. The mutagenic effects of organophosphorus pesticides on micro-organisms. Arch Toxicol 30:67–74.
De Bleecker JL. 1992. Transient opsoclonus in organophosphate poisoning. Acta Neurol Scand 86:529–531.1481637
*De Bleecker J, Van Den Neucker K, Colardyn F. 1993. Intermediate syndrome in organophosphorus poisoning: A prospective study. Crit Care Med 21:1706–1711.8222687
*De Bleecker J, Willems J, Van Den Neucker K, . 1992. Prolonged toxicity with intermediate syndrome after combined parathion and methyl parathion poisoning. Clin Toxicol 30:333–345.
*De Cassia Stocco R, Becak W, Gaeta R, . 1982. Cytogenetic study of workers exposed to methyl parathion. Mutat Res 103:71–76.7057786
De Ferrari M, Artuso M, Bonassi S, . 1991. Cytogenic biomonitoring of an Italian population exposed to pesticides: Chromosome aberration and sister-chromatid exchange analysis in peripheral blood lymphocytes. Mutat Res 260:105–113.2027334
Degraeve N, Moutschen J. 1984. Absence of genetic and cytogenetic effects in mice treated by the organophosphorus insecticide parathion, its methyl analogue, and paraoxon. Toxicology 32:177–183.6464028
*Degraeve N, Chollet M-C, Moutschen J. 1984a. Cytogenetic and genetic effects of subchronic treatments with organophosphorus insecticides. Arch Toxicol 56:66–67.6517715
Degraeve N, Chollet M-C, Moutschen J. 1984b. Cytogenetic effects induced by organophosphorus pesticides in mouse spermatocytes. Toxicol Lett 21:315–319.6740720
*Degraeve N, Chollet M-C, Moutschen J. 1985. Mutagenic efficiency of organophosphorus insecticides used in combined treatments. Environ Health Perspect 60:395–398.4029101
Degraeve N, Gilot-Delhalle J, Moutschen J, . 1980. Comparison of the mutagen activity of organophosphorus insecticides in mouse in the yeast schizosaccharomyces pombe. Mutat Res 74:201–202.
Degraeve N, Moutschen J, Moutschen-Dahmen M, . 1979. Genetic effects of organophosphate insecticides in mouse [Abstract]. Mutat Res 64:131.
*De Peyster A, Willis WO, Liebhaber M. 1994. Cholinesterase activity in pregnant women and newborns. Clinical Tox 32:683–696.
De Peyster A, Willis WO, Molgaard CA, . 1993. Cholinesterase and self-reported pesticide exposure among pregnant women. Arch Environ Health 48:348–352.8215600
*DePotter M, Muller R, Willems J. 1978. A method for the determination of some organophosphorus insecticides in human serum. Chromatographia 11:220–222.
De Schryver E, De Rue L, Belpaire F, . 1987. Toxicokinetics of methyl paraoxon in the dog. Arch Toxicol 59:319–322.3579595
De Schryver E, De Reu L, Willems JL. 1985. Determination of methyl paraoxon in dog plasma by reversed-phased high performance liquid chromatography. J Chromatogr 338:389–395.3998025
*Desi I, Nagymajtenyi L, Papp A, . 1998. Experimental model studies of pesticide exposure. Neurotoxicology 19:611–616.9745919
De Vreede JAF, Brouwer DH, Stevenson H, . 1998. Exposure and risk estimation for pesticides in high-volume spraying. Ann Occup Hyg 42:151–157.9684555
*Dhondup P, Kaliwal BB. 1997. Inhibition of ovarian compensatory hypertrophy by the administration of methyl parathion in hemicastrated albino rats. Reprod Toxicol 11:77–84.9138636
DHS. 1999. California drinking water standards. Department of Health Services.. http://www.dhs.cahwnet.gov/ps/ddwem/chemicals/mcl/mclindex.htm#Table1. May 10, 1999.
Dick RB, Ahlers H. 1998. Chemicals in the workplace: Incorporating human neurobehavioral testing into the regulatory process. Am J Ind Med 33:439–453.9557167
Di Ilio C, Sacchetta P, Iannarelli V, . 1995. Binding of pesticides to alpha, mu and pi class glutathione transferase. Toxicol Lett 76:173–177.7725348
Dikshith TSS, Raizada RB, Singh V, . 1991. Repeated dermal toxicity of technical HCH and methyl parathion (50EC) to female rats (Rattus norvigicus). Indian J Exp Biol 29:149–155.1714421
*Dille JR, Smith WS. 1964. Central nervous system effects of chronic exposure to organophosphate insecticides. Aerospace Medicine May:475–478.
Dorough HW Jr. 1970. Effect of Temik on methyl parathion toxicity to mice. Texas Agricultural Experiment Station Progress Report. Texas A&M University, College Station, TX. Report No. PR-2771.
DOT. 1987. U.S. Department of Transportation. Federal Register 52:16617.
*Draper WM, Street JC. 1981. Drift from a commercial, aerial application of methyl and ethyl parathion: An estimation of potential human exposure. Bull Environ Contam Toxicol 26:530–536.7236912
DuBois KP, Puchala E. 1961. Studies on the sex difference in toxicity of a cholinergic phosphorothioate (26791). Proc Soc Exp Biol Med 107:908–911.13888060
Dubois M, Plaisance H, Thome JP, . 1996. Hierarchical cluster analysis of environmental pollutants through P450 induction in cultured hepatic cells. Ecotoxicol Environ Saf 34:205–215.8812189
Duggan WJ, Casale GP, Cohen SD. 1984. Paraoxon (PX) induced suppression of the in vitro response of murine spleen cells to sheep red blood cells (SRC) [Abstract]. Toxicologist 4:159.
Dulout FN, Pastori MC, Olivero OA, . 1985. Sister-chromatid exchanges and chromosomal aberrations in a population exposed to pesticides. Mutat Res 143:237–244.4022025
Durand P, Nicaud JM, Mallevialle J. 1984. Detection of organophosphorus pesticides with an immobilized cholinesterase electrode. J Anal Toxicol 8:112–117.6737998
Durham WF, Wolfe HR. 1962. Measurement of the exposure of workers to pesticides. Bull WHO 26:75–91.13888659
Eatock RA, Rusch A. 1997. Developmental changes in the physiology of hair cells. Sem Cell Devel Biol 8:265–275.
Egan H. 1969. IUPAC Commission on the development, improvement, and standardization of methods of pesticide residue analysis. J AOAC 52:306–309.
*Eichelberger JW, Lichtenberg JJ. 1971. Persistence of pesticides in river water. Environ Sci Technol 5:541–544.
*El-Herrawie MA, El-Sayed MM. 1986. Effect of different pesticidal formulations on the toxicity to male mice. Bull Entomol Soc Egypt Econ Ser 157–160.
*Ellenhorn MJ. 1997. Pesticides. In: Ellenhorn MJ, Schonwald S, Ordog G, ., ed. Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. Baltimore, MD: Williams & Wilkins, 1614–1631.
Elliot JW, Walker KC, Penick AE, . 1960. A sensitive procedure for urinary p-nitrophenol determination as a measure of exposure to parathion. J Agric Food Chem 8:111–113.
*EPA. 1974a. U.S. Environmental Protection Agency. Federal Register 39:15236.
*EPA. 1974b. Production, distribution, use, and environmental impact potential of selected pesticides [final report]. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs. EPA 540/1-74-001, 181–188.
EPA. 1978a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
EPA. 1978b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455.
*EPA. 1978c. Environmental pathways of selected chemicals in freshwater systems: Part II. Laboratory studies. Athens, GA: U.S. Environmental Protection Agency, Office of Research and Development, Environmental Research Laboratory. EPA-600/7-78/074.
*EPA. 1978d. Source assessment: Pesticide manufacturing air emissions—overview and prioritization. Washington, DC: U.S. Environmental Protection Agency. EPA-600/2-78-004d, 135.
*EPA 1978e. Teratology and acute toxicity of selected chemical pesticides administered by inhalation. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Health Effects Research Laboratory. EPA-600/1-78-003; NTIS PB-277 077.
*EPA. 1980a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33(e).
*EPA. 1980b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 170.3.
*EPA. 1980c. Adsorption, movement and biological degradation of large concentrations of selected pesticides in soils. Cincinnati, OH: U.S. Environmental Protection Agency. EPA-600/2-80-124.
*EPA. 1980d. Analysis of pesticide residues in human and environmental samples: A compilation of methods selected for use in pesticide monitoring programs. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory. EPA-600/8-80-038. NTIS PB82-208752.
*EPA. 1981a. Acephate, aldicarb, carbophenothion, DEF, EPN, ethoprop, methyl parathion, and phorate: Their acute and chronic toxicity, bioconcentration potential and persistence as related to marine environments. Gulf Breeze, FL: U.S. Environmental Protection Agency, Environmental Research Laboratory. EPA-600/4-81/041. NTIS PB81-244477. 1–275.
*EPA. 1981b. Engineering handbook for hazardous waste incineration. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA-68/03-3/025, 3–9.
EPA. 1982a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.121.
*EPA. 1982b. Retention and transformation of selected pesticides and phosphorus in soil- water systems: A critical review. Athens, GA: U.S. Environmental Protection Agency. EPA-600/S3-82/060.
EPA. 1983. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122, Appendix D, Table V.
*EPA. 1984a. Health and environmental effects profile for methyl parathion. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. NTIS PB88-180534.
EPA. 1984b. U.S. Environmental Protection Agency. Federal Register 49:42789.
EPA. 1984c. U.S. Environmental Protection Agency. Federal Register 49:29110.
EPA. 1985a. Parathion-methyl. EPA chemical profiles. Washington, DC: U.S. Environmental Protection Agency. CIS/86/02010.
*EPA. 1985b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 162.31.
EPA. 1985c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4, Appendix A.
EPA. 1985d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
EPA. 1985e. U.S. Environmental Protection Agency. Federal Register 50:40672.
*EPA. 1985f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.6.
EPA. 1986a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 165.
EPA. 1986b. U.S. Environmental Protection Agency. Federal Register 51:28296–28308.
EPA. 1986c. U.S. Environmental Protection Agency. Federal Register 51:34534.
EPA. 1986d. U.S. Environmental Protection Agency. Federal Register 51:33992–34003.
EPA. 1986e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
EPA. 1986f. Ambient water quality criteria for Parathion - 1986. Washington, DC: U.S. Environmental Protection Agency. Office of Water Regulations and Standards, Criteria and Standards Division. EPA440/5-86-007.
EPA. 1987a. Superfund record of decision (EPA Region 4): Gallaway Ponds site, Gallaway, Tennessee, September 1986. Washington, DC: U.S. Environmental Protection Agency. EPA/ROD/R04-86/013. NTIS PB87-189080.
EPA. 1987b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX.
EPA. 1987c. U.S. Environmental Protection Agency. Federal Register 52:21152.
*EPA. 1987d. Project summary: Single laboratory validation of EPA method 8140. Las Vegas, NV: U.S. Environmental Protection Agency. EPA 600/S4-87-009.
*EPA. 1988a. Health advisories for 50 pesticides (including acifluoren, ametryn, ammonium sulfamate, atrazine, baygon, bentazon, bromacil, butylate, carbaryl, carboxin, chloramben, chlorothalonil, cyanazine, dalapon, dacthal, diazinon, dicamba, 1,3-dichloropropene, dieldrin, dimethrin, dinoseb, diphenamid, …). Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water. NTIS PB88-113543.
EPA. 1988b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII.
*EPA. 1988c. Pesticides in ground water data base. 1988 interim report. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs. EPA 540/09-89-036.
EPA. 1988d. Reference dose (RfD): Description and use in health risk assessment. Vol. I, Appendix A: Integrated risk information system supportive documentation. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8-86-032a.
EPA. 1989a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8-88/066F.
*EPA. 1989b. Recognition and management of pesticide poisonings. 4th ed. Washington, DC: U.S. Environmental Protection Agency, Health Effects Division, Office of Pesticide Programs. EPA 540/9-88-001.
EPA. 1996. Drinking water regulations and health advisories. Washington DC: U.S. Environmental Protection Agency, Office of Water. EPA 822-B-96-002.
*EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency. EPA/630/R-96/012.
EPA. 1998a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261 Subpart D.
EPA. 1998b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.48.
EPA. 1998c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455.20.
EPA. 1998d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455 Subpart E.
EPA. 1998e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.1028.
EPA. 1998f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.318.
EPA. 1998g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.121.
EPA. 1998h. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.2.
EPA. 1998i. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
EPA. 1998j. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
EPA. 1998k. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
EPA. 1999a. National recommended water quality criteria—correction. U. S. Environmental Protection Agency, Office of Water. EPA 822-Z-99-001.
EPA. 1999b. Public access server search results. U.S. Environmental Protection Agency. Http://search.epa.gov/s97is.vis. May, 20 1999.
*EPA. 1999c. Methyl parathion: Reregistration eligibility document, residue chemistry considerations. PC code no. 053501: Case 0153. www.epa/gov/pesticides/op/methyl_parathion.htm. May 18, 1999.
*EPA. 1999d. Methyl parathion risk management decision. Office of Pesticide Programs. U.S. Environmental Protection Agency. Http://www.epa.gov/pesticides/citizens/mpfactsheet.htm. May 20, 1999.
*EPA. 1999e. Methyl parathion, receipt of requests for cancellation; cancellation order. U.S. Environmental Protection Agency. Federal Register 64(207):57877–57881.
*EPA. 1999f. Designation of hazardous substances. Code of Federal Regulations. U.S. Environmental Protection Agency. Http://www.access.gpo.gov/nara/cfr/waisidx_00/40cfr302_00.html. January 15, 2001.
*EPA. 1999g. Chemicals and chemical categories to which this part applies. Code of Federal Regulations. U.S. Environmental Protection Agency. Http://www.access.gpo.gov/nara/cfr/waisidx_99/40cfr372_99.html. January 15, 2001.
*EPA. 2000a. Drinking water standards and health advisories. Office of Water. U.S. Environmental Protection Agency. EPA 822-B-00-001.
*EPA. 2000b. Designation of hazardous substances. Code of Federal Regulations. U.S. Environmental Protection Agency. Http://www.access.gpo.gov/nara/cfr/waisidx_00/40cfrv14_00.html. January 18, 2001.
*EPA. 2000c. Applicability; description of the organic pesticide chemical manufacturing subcategory. Code of Federal Regulations. U.S. Environmental Protection Agency. Http://www.access.gpo.gov/nara/cfr/waisidx_00/40cfr455_00.html. January 18, 2001.
*EPA. 2000d. Discarded commercial chemical products, off-specification species, container residues, and spill residues thereof. Code of Federal Regulations. U.S. Environmental Protection Agency. Http://www.access.gpo.gov/nara/cfr/waisidx_00/40cfr302_00.html. January 15, 2001.
*EPA. 2001. Methyl parathion; notice of pesticide tolerance revocations; final rule. Department of Health and Human Services. U.S. Environmental Protection Agency. 40 CFR Part 180. Federal Register 66(4):1242–1246.
*Esteban E, Rubin C, Hill R, . 1996. Association between indoor residential contamination with methyl parathion and urinary para-nitrophenol. J Expo Anal Environ Epidemiol 6:375–387.8889955
*Evans RT, Wroe JM. 1980. Plasma cholinesterase changes during pregnancy. Anaesthesia 35:651–654.7435932
*Evans RT, O’Callaghan J, Norman A. 1988. A longitudinal study of cholinesterase changes in pregnancy. Clin Chem 34:2249–2252.3180418
Eyer P. 1995. Neuropsychopathological changes by organophosphorus compounds—a review. Hum Exp Toxicol 14:857–864.8588945
Fairbrother A, Bennett RS, Bennett JK. 1989. Sequential sampling of plasma cholinesterase in mallards (Anasplatyrhynchos) as an indicator of exposure to cholinesterase inhibitors. Environ Toxicol Chem 8:117–122.
Fan A, Street JC, Nelson RM. 1978. Immunosuppression in mice administered and carbofuran by diet [Abstract]. Toxicol Appl Pharmacol 45:235.
FAO. 1980. Pesticide residues in food: 1979 Evaluations. Rome, Italy: Food and Agriculture Organization. 367–368.
Fatiadi AJ. 1984. Priority toxic pollutants in human urine: Their occurrence and analysis. Environ Int 10:175–205.
Faust SD, Gomaa HM. 1972. Chemical hydrolysis of some organic phosphorus and carbamate pesticides in aquatic environments. Environ Lett 3:171–201.5072268
*Fazekas GI. 1971. [Macroscopic and microscopic changes in Wofatox (methyl parathion) poisoning]. Zeitschift fur Rechtsmedizin 68:189–194. (German)
*Fazekas GI, Rengei B. 1964. [Lethal “Wofatox” intoxication]. Orvosi Hetilap 105:2335–2335. (Hungarian)14228966
Fazekas IG, Rengei B. 1965. [Fatal methyl parathion (Wofatox) poisoning]. Arch Toxikol 30:323–326. (German)
Fazekas IG, Rengei B. 1967. [Methyl parathion content of human organs after lethal Wofatox poisoning]. Arch Toxikol 22:381–386. (German)5592278
Feroz MK, Khan MA, Feroz MR. 1994. Methyl parathion: Estimation in blood and effect on body weights of orally administered rabbits. Science International 6:343–345.
Finlayson BJ, Harrington JA, Fujimura R, . 1993. Identification of methyl parathion toxicity in Colusa basin drain water. Environ Toxicol Chem 12:291–303.
*Fish SA. 1966. Organophosphorus cholinesterase inhibition and fetal development. Am J Obstet Gynecol 96:1148–1154.5928472
Fleischer O, Wichmann H, Lorenz W. 1999. Release of polychlorinated dibenzo-p-dioxins and dibenzofurans by setting off fireworks. Chemosphere 39(6):925–932.10448567
Fodor-Csorba K, Dutka F. 1986. Selectivity and sensitivity of some thin-layer chromatographic detection systems. J Chromatogr 365:309–314.3771705
*Fomon SJ. 1966. Body composition of the infant. Part I: The male reference infant. In: Falkner F, ed. Human Development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Foreman WT, Majewski MS, Goolsby DA, . 1999. Atmospheric presence and deposition of modern-use pesticides in the midwestern United States. Division of Environmental Chemistry Preprints of Extended Abstracts 39(1):440–442.
*Foster RL. 1974. Detection and measurement of ambient organophosphate pesticides. Proc Annu Ind Air Pollut Control Conf 4:66–98.
Fraser CM, Mays A, ed. 1986. The Merck veterinary manual: A handbook of diagnosis, therapy, and disease prevention and control for the veterinarian. 6th ed. Rahway, NJ: Merck & Co., Inc., 1355–1359.
*Frosch I. 1990. Prenatal toxicology of Wofatox 80 in rats. Teratology 42(2): 26A.
FSTRAC. 1988. Federal-State Toxicology and Regulatory Alliance Committee (FSTRAC) (database), Chemical Communication Subcommittee. Summary of state and federal drinking water standards and guidelines. March, 1988.
FSTRAC. 1999. Federal-State Toxicology and Regulatory Alliance Committee. U. S. Environmental Protection Agency, Office of Water. http://www.epa.gov/ostwater/fstrac/states.html. May 20, 1999.
Fuchs VS, Golbs S, Kuhnert M, . 1976. [Studies into the prenatal toxic action of parathion methyl on Wistar rats and comparison with prenatal toxicity cyclophosphamide and trypan blue]. Arch Exp Vet Med 30:343–350. (German)
*Gabica JJ, Wyllie J, Watson M, . 1971. Example of flame photometric analysis for methyl parathion in rat whole blood and brain tissue. Anal Chem 43:1102–1105.5091138
Gagne J, Brodeur J. 1972. Metabolic studies on the mechanism of increased susceptibility of weanling rats to parathion. Can J Physiol Pharmacol 50:902–915.5084365
*Gaines TB. 1960. The acute toxicity of pesticides to rats. Toxicol Appl Pharmacol 2:88–99.13825957
*Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 4:515–534.
*Galal EE, Latif MA, Kandil A, . 1975. The percutaneous cardiac toxicokinesis of anticholinesterase insecticides. J Drug Res 7:29–43.
*Galal EE, Samaan HA, Nour El Dien S, . 1977. Studies on the acute and subchronic toxicities of some commonly used anticholinesterase insecticides in rats. J Drug Res Egypt 1–17.
*Garcia-Lopez JA, Monteoliva M. 1988. Physiological changes in human erythrocyte cholinesterase as measured with the “pH-stat”. Clin Chem 34:2133–2135.3168232
Garcia-Repetto R, Martinez D, Repetto M. 1995. Coefficient of distribution of some organophosphorous pesticides in rat tissue. Vet Hum Toxicol 37:226–229.7571350
Garcia-Repetto R, Martinez D, Repetto M. 1997. Biodisposition study of the organophosphorus pesticide, methyl-parathion. Bull Environ Contam Toxicol 59:901–908.9400660
Garrett NE, Stack HF, Waters MD. 1986. Evaluation of the genetic activity profiles of 65 pesticides. Mutat Res 168:301–326.3796654
*Gartrell MJ, Craun JC, Podrebarac DS, . 1985. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1979—September 1980. J Assoc Off Anal Chem 68:1184–1197.4086442
*Gartrell MJ, Craun JC, Podrebarac DS, . 1986. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980—March 1982. J Assoc Off Anal Chem 69:146–161.3949687
*Gelardi RC, Mountford MK. 1993. Infant formulas: Evidence of the absence of pesticide residues. Regul Toxicol Pharmacol 17:181–192.8484026
George J, Andrade C, Joseph T. 1992. Delayed effects of acute oral and chronic inhalational exposure to methyl parathion on learning and memory in rats. Indian J Exp Biol 30:819–822.1478717
*Gershon S, Shaw FH. 1961. Psychiatric sequelae of chronic exposure to organophosphorus insecticides. Lancet 1371–1374.
*Gerstl Z, Helling CS. 1985. Fate of bound methyl parathion residues in soils as affected by agronomic practices. Soil Biol Biochem 17:667–673.
Gerstl Z, Helling CS. 1987. Evaluation of molecular connectivity as a predictive method for the adsorption of pesticides by soils. J Environ Sci Health B22:55–69.
Ghosh C, Bandyopadhyay S, Medda JN. 1998. Protective role of thyroxine in methyl parathion intoxicated chick embryos. Drug Chem Toxicol 21:495–506.9839157
*Gianessi LP, Anderson JE. 1995. Pesticide use in U.S. crop production: National data report. ed. Washington, DC: National center for food and agriculture policy,
Gile JD, Gillett JW. 1981. Transport and fate of organophosphate insecticides in a laboratory model ecosystem. J Agric Food Chem 2:616–621.
*Gillespie AM, Walters SM. 1986. HPLC silica column fractionation of pesticides and PCB from butterfat. J Liq Chromatogr 9:2111–2142.
*Gilliom RJ, Alexander RB, Smith RA. 1985. Pesticides in the nations rivers, 1975-1980, and implications for future monitoring. U.S. Geological Survey Water Supply Paper 2271.
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101:65–71.
Gladen BE, Sandler DP, Zahm SH, . 1998. Exposure opportunities of families of farmer pesticide applicators. Am J Ind Med 34:581–587.9816416
Glooschenko WA, Strachan WM, Sampson RC. 1976. Distribution of pesticides and polychlorinated biphenyls in water, sediments, and seston of the upper Great Lakes—1974. Pestic Monit J 10:61–67.826875
Glotfelty DE, Schomburg CJ. 1989. Volatilization of pesticides from soil. Reactions and movement of organic chemicals in soils. SSSA Special Publication No. 22, 181–207.
*Glotfelty DE, Seiber JN, Liljedahl LA. 1987. Pesticides in fog. Nature 325:602–605.3808063
Golbs S, Fuchs V, Leipner E, . 1978a. [Studies into effects of pesticide combinations on laboratory rats. 1st communication: Determination of the acute oral toxicity (LD50) of pesticide combinations]. Arch Exp Vet Med Leipzig 32:557–561. (German)
Golbs S, Fuchs V, Leipner E, . 1978b. [Studies into effects of pesticide combinations on laboratory rats. 2nd communication: Studies into action on selected hematological parameters and blood glucose]. Arch Exp Vet Med Leipzig 32. (German)
Golbs S, Fuchs V, Leipner E, . 1978c. [Studies into effects of pesticide combinations in laboratory rats. 3rd communication: Experiments about influence on different serum enzymes]. Arch Exp Vet Med Leipzig 32:569–577. (German)
Goldey ES, Tilson HA, Crofton KM. 1995. Implications of the use of neonatal birth weight, growth, viability, and survival data for predicting developmental neurotoxicity: A survey of the literature. Neurotoxicol Teratol 17(3):313–332.7542737
Goldman LR. 1995. Case studies of environmental risks to children. Critical Issues for Children and Youths 5:27–33.
*Golubchikov MV. 1991. Toxicological substantiation of the safe use of xenobiotics. Gig. San. (1):56–58.
Gomez-Arroyo S, Baiza AM, Lopez G, . 1985. A comparative study of the cytogenetic effects of the insecticides heptachlor, malathion, and methyl parathion in Vicia faba. Contaminacion Ambiental 1:7–16.
Gómez-Arroyo S, Díaz-Sánchez Y, Meneses-Pérez MA, . 2000. Cytogenetic biomonitoring in a Mexican floriculture worker group exposed to pesticides. Mutat Res 466:117–124.10751733
*Gomez-Arroyo S, Noriega-Aldana N, Juarez-Rodriguez D, . 1987. Sister chromatid exchanges induced by the organophosphorus insecticides methyl parathion, dimethoate, phoxim and methyl azinphos in cultured human lymphocytes. Contaminacion Ambiental 3:63–70.
*Goncharuk EI, Sidorenko GI, Golubchikov MV. 1990. [Use of the mother-fetus-newborn infant system of combined effects of pesticides and other chemicals]. Gig Sanit Jun(6):4–7. (Russian) (Translation attached)
Gordon CJ. 1994. Thermoregulation in laboratory mammals and humans exposed to anticholinesterase agents. Neurotoxicol Teratol 16:427–453.7845326
Gosselin RE, Smith RP, Hodge HC. 1984. Clinical toxicology of commercial products. 5th ed. Baltimore, MD: Williams & Wilkins.
*Griffin DE III, Hill WE. 1978. In vitro breakage of plasmid DNA by mutagens and pesticides. Mutat Res 52:161–169.368611
*Grob D, Garlick WL, Harvey AM. 1950. The toxic effects in man of the anticholinesterase insecticide parathion (p-nitrophenyl diethylthionophosphate). Johns Hopkins Med J 87:106–129.
*Grover IS, Malhi PK. 1985. Genotoxic effects of some organophosphorus pesticides. I. Induction of micronuclei in bone marrow cells in rat. Mutat Res 155:131–134.4038779
Guengerich FP, Min KS, Persmark M, . 1994. Dihaloaklanes and polyhaloalkenes. IARC Sci Publ 125:57–72.
*Guidotti M, Ravaioli G, Vitali M. 1999. Total p-nitrophenol determination in urine samples of subjects exposed to parathion and methyl-parathion by SPME and GC/MS. J High Resolut Chromatogr 22(11):628–630.
Guillette EA, Meza MM, Aquilar MG, . 1998. An anthropological approach to the evaluation of preschool children exposed to pesticides in Mexico. Environ Health Perspect 106:347–353.9618351
*Gunderson EL. 1995a. Dietary intakes of pesticides, selected elements, and other chemicals: FDA total diet study, June 1984-April 1986. J Assoc Off Anal Chem 78:910.
*Gunderson EL. 1995b. FDA total diet study, July 1986-April 1991, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 78:1353.
Gunderson EL. 1988. FDA total diet study, April 1982 - April 1984, dietary intakes of pesticides, selected elements and other chemicals. J Assoc Off Anal Chem 71:1200–1209.3240978
Gupta RC, Goad JT, Kadel WL. 1996. Distribution and responses of brain biomarkers to anticholinesterase insecticides exposure. FASEB J 10:A690.
Gupta RC, Goad JT, Milatovic D, . 2000. Cholinergic and noncholinergic brain biomarkers of insecticide exposure and effects. Hum Exp Toxicol 19:297–308.10918524
*Gupta RC, Rech RH, Lovell KL, . 1985. Brain cholinergic, behavioral, and morphological development in rats exposed in utero to methyl parathion. Toxicol Appl Pharmacol 77:405–413.3975908
*Gupta RC, Thornburg JE, Stedman DB, . 1984. Effect of subchronic administration of methyl parathion on in vivo protein synthesis in pregnant rats and their conceptuses. Toxicol Appl Pharmacol 72:457–468.6710496
*Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Hahn T, Ruhnke M, Luppa H. 1991. Inhibition of acetylcholinesterase and butyrylcholinesterase by the organophosphorus insecticide methyl parathion in the central nervous system of the golden hamster (Mesocricetus auratus). Acta Histochem (Jena) 91:13–19.1801511
Haley TJ, Farmer JH, Harmon JR, . 1975a. Estimation of the LD1 and extrapolation of the LD0.1 for 5 organophosphate pesticides. Arch Toxicol 34:103–109.1242884
*Haley TJ, Farmer JH, Harmon JR, . 1975b. Estimation of the LD1 and extrapolation of the LD0.1 for 5 organothiophosphate pesticides. Eur J Toxicol 8:229–235.
Hall GL, Whitehead WE, Mourer CR, . 1986. A new gas chromatographic retention index for pesticides and related compounds. J High Resolut Chromatogr Commun 9:266–271.
Hamilton DJ, Holland PT, Ohlin B, . 1999. Optimum use of available residue data in the estimation of dietary intake of pesticides. Pestic Sci 55(2):220–221.
Hansen E, Meyer O. 1980. Neurobehavioral effects of prenatal exposure to parathion-methyl on rats. Acta Morphol Acad Sci Hung 28:210.
Hansen LG. 1983. Biotransformation of organophosphorus compounds relative to delayed neurotoxicity. Neurotoxicology 4:97–111.6308528
Hansen ME, Wilson BW. 1999. Oxime reactivation of RBC acetylcholinesterases for biomonitoring. Arch Environ Contam Toxicol 37:283–289.10473783
*Hasan M, Khan NA. 1985. Methyl parathion induced dose related alteration in lipid levels and lipid peroxidation in various regions of rat brain and spinal cord. Indian J Exp Biol 23:141–144.4054956
*Hawley GG. 1987. The condensed chemical dictionary. 11th ed. New York, NY: Van Nostrand Reinhold Company, 777.
*HazDat. 1999. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. April 14, 1999.
He F. 1993. Biological monitoring of occupational pesticides exposure. Int Arch Occup Environ Health 93:S69–S76.
*Henry J. 1984. Todd-Sanford-Davidsohn clinical diagnosis by laboratory methods. Philadelphia, PA: WB Saunders, 271–272.
*Hild DN, Laughlin JM, Gold RE. 1989. Laundry parameters as factors in lowering methyl parathion residue in cotton polyester fabrics. Arch Environ Contam Toxicol 18:908–914.2619330
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84:313–320.1738181
*Hollingworth RM, Alstott RL, Litzenberg RD. 1973. Glutathione-S-aryl transferase in the metabolism of parathion and its analogs. Life Sci 13:191–199.4750916
*Hollingworth RM, Metcalf RL, Fukuto IR. 1967. The selectivity of sumithion compared with methyl parathion. Metabolism in the white mouse. J Agric Food Chem 15:242–249.
*Holm HW, Kollig HP, Payne WR Jr, . 1983. Fate of methyl parathion in aquatic channel microcosms. Environ Toxicol Chem 2:169–176.
Holm HW, Kollig HP, Proctor LM, . 1982. Laboratory ecosystems for studying chemical fate: An evaluation using methyl parathion. Athens, GA: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/S3-82/020.
*Howard JK, East NJ, Chaney JL. 1978. Plasma cholinesterase activity in early pregnancy. Arch Environ Health September/October: 277–278.
HSDB. 1989. Hazardous Substances Data Bank (database). Bethesda, MD: National Institutes of Health, National Library of Medicine.
*HSDB. 1999. Methyl parathion. Hazardous Substances Data Bank. Bethesda, MD: National Library of Medicine, National Toxicology Information Program. April 16, 1999.
*HSDB. 2001. Methyl parathion. Hazardous Substances Data Bank. Bethesda, MD: National Library of Medicine, National Toxicology Information Program. January 18, 2001.
*Huang CC. 1973. Effect on growth but not on chromosomes of the mammalian cells after treatment with three organophosphorus insecticides (36952). Proc Soc Exp Biol Med 142:36–40.4683261
*Huang YS, Sultatos LG. 1993. Glutathione-dependent biotransformation of methyl parathion by mouse liver in vitro. Toxicol Lett 68:275–284.8516780
Huling SG, Pope DF, Matthews JE, . 1995. Wood preserving waste-contaminated soil: Treatment and toxicity response. In: Hinchee RE ., ed. Bioremediation of recalcitrant organics. Columbus, OH: Battell Press, 101–109.
*Hundley HK, Cairns T, Luke MA, . 1988. Pesticide residue findings by the luke method in domestic and imported foods and animal feeds for fiscal years 1982-1986. J Assoc Off Anal Chem 71:875–892.3235407
Hutson DH. 1981. The metabolism of insecticides in man. In: Hutson DH, Roberts TR, eds. Progress in Pesticide Biochemistry. Vol. 1, New York, NY: John Wiley & Sons, Ltd., 287–333.
*IARC. 1983. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to humans. Vol. 30. Miscellaneous Pesticides. Lyon, France: International Agency for Research on Cancer, World Health Organization.
IARC. 1987. IARC Monographs on the evaluation of carcinogenic risks to humans. Overall evaluations of carcinogenicity: An updating of IARC monographs volumes 1 to 42. Supplement 7:186 Lyon, France: International Agency for Research on Cancer, World Health Organization.
*IARC. 2001. Methyl parathion (group 3). International Agency for Research on Cancer. Http://193.51.164.11/htdocs/Monographs/Suppl7/methylparathion.html. January 17, 2001.
Institoris L, Siroki O, Desi I. 1995. Immunotoxicity study of repeated small doses of dimethoate and methyl parathion administered to rats over three generations. Hum Exp Toxicol 14:879–883.8588948
Institoris L, Siroki O, Toth S, . 1992. Immunotoxic effects of MPT-IP containing 60% methyl parathion. Hum Exp Toxicol 11:11–16.1354454
*International Labour Office. 1983. Encyclopedia of Occupational Health and Safety. Vol. I and II, Geneva, Switzerland: International Labour Office, 1639.
IRIS. 1990. Integrated Risk Information System (database). Washington, DC: U.S. Environmental Protection Agency.
IRIS. 1999. Methyl parathion. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. Http://www.epa.gov/iris/subst/index.htm.. April 19, 1999.
*IRIS. 2001. Methyl parathion. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. Http://www.epa.gov/iris/subst/index.htm.. January 18, 2001.
Isshiki K, Miyata K, Martsui S, . 1983. [Effects of post-harvest fungicides and piperonyl butoxide on the acute toxicity of pesticides in mice. Safety evaluation for intake of food additives. III]. Skokuchin Eiseigaku Zasshi 24:268–274. (Japanese)
Izmirova H. 1980. Methods for determination of exposure of agricultural workers to organophosphorus pesticides. In: Tordoir WF, Van Heemstra EA, eds. Field worker exposure during pesticide application. New York, NY: Elsevier Sci. Publ. Co., 169–172.
Izmirova H, Shalash S, Kaloianova F. 1984. [Dynamics of inhibition of cholinesterase activity in methyl parathion intoxication]. Probl Khig 9:42–49. (Russian)6483827
*Jackson MD, Lewis RG. 1978. Volatilization of two methyl parathion formulations from treated fields. Bull Environ Contam Toxicol 20:793–796.749977
Jacoby RO, Bhatt PN, Jonas AM. 1979. Viral diseases. In: Baker HJ, Lindsey JR, Weisbroth SH, eds. The laboratory rat. Volume I: Biology and diseases. New York, NY: Academic Press, 272–306.
Jaglan PS, Gunther FA. 1969. Column esterification in the gas chromatography of the desalkyl metabolites of methyl parathion and methyl paraoxon. Anal Chem 41:1671–1673.5811590
Jaglan PS, Gunther FA. 1970. Single column gas liquid chromatography of methyl parathion and metabolites using temperature programming. Bull Environ Contam Toxicol 5:111–114.24185801
Jaglan PS, March RB, Fukuto TR, . 1970. Gas-liquid chromatographic determination of methyl parathion and metabolites. J Agric Food Chem 18:809–813.5474235
Jaglan PS, March RB, Gunther FA. 1969. Column esterification in the gas chromatography of the desalkyl metabolites of methyl parathion and methyl paraoxon. Anal Chem 41:1671–1673.5811590
*James RH, Adams RE, Finkel JM, . 1985. Evaluation of analytical methods for the determination of POHC in combustion products. J Air Pollut Control Assoc 35:959–969.
Jensen J. 1996. Chlorophenols in the terrestrial environment. Rev Environ Contam Toxicol 146:25–51.8714220
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johns RJ, McQuillen MP. 1966. Syndrome simulating myasthenia gravis: Asthenia with anticholinesterase tolerance. Ann NY Acad Sci 135:385–397.5221352
Johnson RD, Manske DD, New DH, . 1984. Pesticide, metal and other chemical residues in adult total diet samples (XIII). August 1976-September 1977. J Assoc Off Anal Chem 67:154–166.6546566
Jorgenson TA, Rushbrook CJ, Newell GW. 1976. In vivo mutagenesis investigations of ten commercial pesticides [Abstract]. Toxicol Appl Pharmacol 37:109.
*Joshi UM, Thornburg JE. 1986. Interactions between cimetidine, methyl parathion, and parathion. J Toxicol Environ Health 19:337–344.3772983
Juhler RK, Larsen SB, Meyer O, . 1999a. Human semen quality in relation to dietary pesticide exposure and organic diet. Arch Environ Contam Toxicol 37:415–423.10473800
Juhler RK, Lauridsen MG, Christensen MR, . 1999b. Pesticide residues in selected food commodities: Results from the Danish National Pesticide Monitoring Program 1995-1996. J AOAC Int 82(2):337–358.10191540
*Jury WA, Spencer WF, Farmer WJ. 1983. Use of models for assessing relative volatility, mobility, and persistence of pesticides and other trace organics in soil systems. In: Saxena J, ed. Hazard assessment of chemicals: Current developments. Vol. 2, New York, NY: Academic Press, 1–43.
*Jury WA, Focht DD, Farmer WJ. 1987a. Evaluation of pesticide groundwater pollution potential from standard indices of soil-chemical adsorption and biodegradation. J Environ Qual 16:422–428.
*Jury WA, Winer AM, Spencer WF, . 1987b. Transport and transformation of organic chemicals in the soil-air-water ecosystem. Rev Environ Contam Toxicol 99:119–164.
*Kadoum AM. 1968. Cleanup procedure for water, soil, animal, and plant extracts for the use of electron-capture detector in the gas chromatographic analysis of organophosphorus insecticide residues. Bull Environ Contam Toxicol 3:247–253.24185209
*Kalow W. 1956. Familial incidence of low pseudocholinesterase levels [Letter]. Lancet 2:576–577.
*Kan-Do Office and Pesticide Team. 1995. Accumulated pesticide and industrial chemical findings from a ten-year study of ready-to-eat foods. J Assoc Off Anal Chem 78:614–631.
*Karickhoff SW. 1981. Semi-empirical estimation of sorption of hydrophobic pollutants on natural sediments and soils. Chemosphere 10:833–846.
Kaur P, Grover IS. 1985a. Cytological effects of some organophosphorus pesticides: I. Mitotic effects. Cytologia 50:187–197.
Kaur P, Grover IS. 1985b. Cytological effects of some organophosphorus pesticides: II. Meiotic effects. Cytologia 50:199–211.
*Kawahara FK, Lichtenberg JJ, Eichelberger JW. 1967. Thin-layer and gas chromatographic analysis of parathion and methyl parathion in the presence of chlorinated hydrocarbons. J Water Pollut Control Fed 39:446–457.6021839
*Keith LH, Walters DB, ed. 1985. Compendium of safety data sheets for research and industrial chemicals. Parts I, II, and III. Deerfield Beach, FL: VCH Publishers, 1136.
*Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–38.7379718
*Khan NA, Hasan M. 1988. Dose-related neurochemical changes in the levels of gangliosides and glycogen in various regions of the rat brain and spinal cord following methyl parathion administration. Exp Pathol 35:61–65.3229466
Kimbrough RA, Litke DW. 1996. Pesticides in streams draining agricultural and urban areas in Colorado. Environ Sci Technol 30:908–916.
Kimbrough RM, Gaines TB. 1968. Effect of organic phosphorus compounds and alkylating agents on the rat fetus. Arch Environ Health 16:805–808.5654550
*Kimmerle G, Lorke D. 1968. Toxicology of insecticidal organophosphates. Pflanzenschutz-Nacher 21:111–142.
Kirchner K, Berge H. 1975a. [Determination of parathion-methyl and its metabolites in samples from animals and in foodstuffs]. Arch Exp Veterinarmed 29:643–647. (German)1230101
Kirchner K, Berge H. 1975b. [TAS method for the detection of parathion-methyl and various transformation products in organic substances]. Arch Exp Veterinarmed 29:649–653. (German)1230102
Kishk FM, Abu-Sharar TM, Bakry N, . 1979a. Adsorption of methyl parathion by soils. Bull Environ Contam Toxicol 22:733–738.486777
Kishk FM, Abu-Sharar TM, Bakry NM, . 1979b. Sorption-desorption characteristics of methyl parathion by clays. Arch Environ Contam Toxicol 8:637–645.533311
Kitchin KT, Brown JL, Kulkarni AP. 1992. Predictive assay for rodent carcinogenicity using in vivo biochemical parameters: Operational characteristics and complementarity. Mutat Res 266:253–272.1373835
Kitchin KT, Brown JL, Kulkarni AP. 1993. Predicting rodent carcinogenicity of Ames test false positives by in vivo biochemical parameters. Mutat Res 290:155–164.7694106
*Kjolholt J. 1985. Occurrence of organophosphorus compounds in polluted marine sediments near a pesticide manufacturing plant. Chemosphere 14:1763–1770.
Klopman G, Contreras R, Rosenkranz HS, . 1985. Structure-genotoxic activity relationships of pesticides: Comparison of the results from several short-term assays. Mutat Res 147:343–356.3932848
*Koen JG, Huber JF. 1970. A rapid method for residue analysis by column liquid chromatography with polarographic detection: Application to the determination of parathion and methyl parathion on crops. Anal Chim Acta 51:303–307.5448739
*Kolpin DW, Barbash JE, Gilliom RJ. 1998. Occurrence of pesticides in shallow groundwater of the United States: Initial results from the National Water-Quality Assessment Program. Environ Sci Technol 32:558–566.
*Kolpin DW, Goolsby DA, Thurman EM. 1995. Pesticides in near-surface aquifers: An assessment using highly sensitive analytical methods and tritium. J Environ Qual 24:1125–1132.
Komeil AA, Abdalla MA, Younis HM, . 1988. Teratogenicity of three different insecticides in pregnant mice [Abstract]. Teratology 38:21A.
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
*Krapac IG, Roy WR, Smyth CA, . 1995. Occurrence and distribution of pesticides in soil at agrichemical facilities in Illinois. J Soil Contam 4:209–226.
*Krill RM, Sonzogni WC. 1986. Chemical monitoring of Wisconsin’s groundwater. J Am Water Works Assoc 78:70–75.
*Krishnan K, Andersen ME, Clewell H 3rd, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang R, ed. Toxicology of chemical mixtures. New York, NY: Academic Press, 399–437.
Kumar D, Khan PK, Sinha SP. 1995. Cytogenetic toxicity and no-effect limit dose of pesticides. Food Chem Toxicol 33:309–314.7537710
Kumar KBS, Devi KS. 1992. Teratogenic effects of methyl parathion in developing chick embryos. Vet Hum Toxicol 34:408–410.1455605
*Kumar KBS, Devi KS. 1996. Methyl parathion induced teratological study in rats. J Environ Biol 17:51–57.
*Kumar KBS, Ankathil R, Devi KS. 1993. Chromosomal aberrations induced by methyl parathion in human peripheral lymphocytes of alcoholics and smokers. Hum Exp Toxicol 12:285–288.8104005
*Kumar MVS, Desiraju T. 1992. Effect of chronic consumption of methyl parathion on rat brain regional acetylcholinesterase activity and on levels of biogenic amines. Toxicology 75:13–20.1455421
*Kunimatsu T, Kamita Y, Isobe N, . 1996. Immunotoxicological insignificance of fenitrothion in mice and rats. Fundam Appl Toxicol 33:246–253.8921343
Kutz FW. 1983. Chemical exposure monitoring. Residue Rev 85:277–292.6828798
*Landrigan PJ, Claudio L, Markowitz SB, . 1999. Pesticides and inner-city children: Exposures, risks, and prevention. Environ Health Perspect 107(Suppl. 3):431–437.
Larsen K-O, Hanel HK. 1982. Effect of exposure to organophosphorus compounds on S-cholinesterase in workers removing poisonous depots. Scand J Work Environ Health 8:222–226.7156940
Larson SJ, Capel PD, Goolsby DA, . 1995. Relations between pesticide use and riverine flux in the Mississippi River basin. Chemosphere 31:3305–3321.
*Lartiges SB, Garrigues PP. 1995. Degradation kinetics of organophosphorus and organonitrogen pesticides in different waters under various environmental conditions. Environ Sci Technol 29:1246–1254.22192018
*Laughlin J, Gold RE. 1987. The vaporization of methyl parathion from contaminated cotton fabrics. Textile Chemist and Colorist 19:39–42.
*Laughlin J, Gold RE. 1989a. Evaporative dissipation of methyl parathion from laundered protective apparel fabrics. Bull Environ Contam Toxicol 42:566–573.2713533
*Laughlin J, Gold RE. 1989b. Methyl parathion redeposition during laundering of functionally finished protective apparel fabrics. Bull Environ Contam Toxicol 42:691–698.2743000
Laurent C, Jadot P, Chabut C. 1996. Unexpected decrease in cytogenetic biomarkers frequencies observed after increased exposure to organophosphorus pesticides in a production plant. Int Arch Occup Environ Health 68:399–404.8891775
*Layer PG. 1990. Cholinesterase preceding major tracts in vertebrate neurogenesis. Bioessays 12:415–420.2256905
*Layer PG, Willbold E. 1994. Cholinesterase in avian neurogenesis. International Review of Cytology 151:139–181.8014021
*Le Bel GL, Williams DT, Griffith G, . 1979. Isolation and concentration of organophosphorus pesticides from drinking water at the ng/L level, using macroreticular resin. J AOAC 62:241–249.
*Lederman SA. 1996. Environmental contaminants in breast milk from the central Asian republics. Reprod Toxicol 10(2):93–104.8919605
*Lee H-B, Weng L-D, Chau AS. 1984. Confirmation of pesticide residue identity: XI. Organophosphorus pesticides. J AOAC 67:553–556.
*Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44:55–77.9057784
*Lefkowitz RJ, Hoffman BB, Taylor P. 1996. Neurotransmission: The autonomic and somatic motor nervous systems. In: Hardman JG, Limbird LE, eds. Goodman & Gilman’s the pharmacological basis of therapeutics. New York, NY: McGraw-Hill, 105–139.
*Lehmann H, Ryan E. 1956. The familial incidence of low pseudocholinesterase level [Letter]. Lancet 2:124.
LeNoir J, Aston L, Datta S, . 1998. Pesticides and polychlorinated biphenyls in Sierra Nevada ecosystems: Potential relationship to decline of amphibians. Division of Environmental Chemistry Preprints of Extended Abstracts 38(2):264–266.
*Leng G, Lewalter J. 1999. Role of individual susceptibility in risk assessment of pesticides. Occup Environ Med 56:449–453.10472315
*Leonas KK, Easter EP, Dejonge JO. 1989. Effect of fabric characteristics on pesticide penetration through selected apparel fabrics. Bull Environ Contam Toxicol 43:231–238.2775891
*Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. New York, NY: Stockton Press, 153–164.
*Lewis DL, Holm HW. 1981. Rates of transformation of methyl parathion and diethyl phthalate by aufwuchs microorganisms. Appl Environ Microbiol 42:698–703.16345869
Lewis DL, Hodson RE, Freeman LF III. 1984. Effects of microbial community interactions on transformation rates of xenobiotic chemicals. Appl Environ Microbiol 48:561–565.6541888
Lewis RG, Fortmann RC, Camann DE. 1994. Evaluation of methods for monitoring the potential exposure of small children to pesticides in the residential environment. Arch Environ Contam Toxicol 26:37–46.8110022
Lichtenstein EP, Katan J, Anderegg BN. 1977. Binding of “persistent” and “nonpersistent” 14C-labelled insecticides in an agricultural soil. J Agric Food Chem 25:43–47.
*Lino CM, da Silveira MIN. 1992. Organophosphorus pesticide residues in cow’s milk: Levels of cis-mevinfos, methyl-parathion, and paraoxon. Bull Environ Contam Toxicol 49:211–216.1611242
*Lisi P, Caraffini S, Assalve D. 1987. Irritation and sensitization potential of pesticides. Contact Dermatitis 17:212–218.2962818
Lisovik Z, Gorbacheva NA. 1977. [Gas chromatographic determination of metaphos, methyl nitrophos and methyl-ethyl thiophos in the blood]. Farmatsiia 26:44–51. (Russian)
Litchfield JJ, Wilcoxon F. 1949. A simplified method of evaluating dose-effect experiments. J Pharmacol Exp Ther 96:99–133.18152921
*Liu J, Olivier K, Pope CN. 1999. Comparitive neurochemical effects of repeated methyl parathion or chlorpyrifos exposures in neonatal and adult rats. Toxicol Appl Pharmacol 158:186–196.10406933
Liu PS, Kao LS, Lin MK. 1994. Organophosphates inhibit catecholamine secretion and calcium influx in bovine adrenal chromaffin cell. Toxicology 90:81–91.8023345
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301.351201
Lodovici M, Aiolli S, Monserrat C, . 1994. Effect of mixture of 15 commonly used pesticides on DNA levels of 8-hydroxy-2-deoxyguanosine and xenobiotic metabolizing enzymes in rat liver. J Environ Pathol Toxicol and Oncol 13:163–168.7722883
Lodovici M, Casalini C, Briani C, . 1997. Oxidative liver DNA damage in rats treated with pesticide mixtures. Toxicology 117:55–60.9020199
Lohman PHM. 1999. Qualitative and quantitative procedures for health risk assessment. Mutat Res 428:237–254.10517997
Lohman PHM, Mendelsohn ML, Moore DH, . 1992. A method for comparing and combining short-term genotoxicity test data: The basic system. Mutat Res 266:7–25.1372964
Lopes VICF, Antunes-Madeira MC, Madeira VMC. 1997. Effects of methylparathion on membrane fluidity and its implications for the mechanisms of toxicity. Toxicol in Vitro 11:337–345.20654320
*Lores EM, Bradway DE. 1977. Extraction and recovery of organophosphorus metabolites from urine using an anion exchange resin. J Agric Food Chem 25:75–79.
Lotti M, Becker CE. 1982. Treatment of acute organophosphate poisoning: Evidence of a direct effect on central nervous system by 2-PAM (pyridine-2-aldoxime methyl chloride). J Toxicol Clin Toxicol 19:121–127.7109004
Lovell RA, McChesney DG, Price WD. 1996. Organohalogen and organophosphorus pesticides in mixed feed rations: Findings from FDA’s domestic surveillance during fiscal years 1989-1994. J Assoc Off Anal Chem 79:544–548.
Lukaszewicz-Hussain A, Moniuszko-Jakoniuk J, Pawlowska D. 1985. Blood glucose and insulin concentration in rats subjected to physical exercise in acute poisoning with parathion-methyl. Pol J Pharmacol Pharm 37:647–651.3913953
Luke MA, Masumoto HT, Cairns T, . 1988. Levels and incidence of pesticide residues in various foods and animal feeds analyzed by the luke multiresidue methodology for fiscal years 1982-1986. J Assoc Off Anal Chem 71:415–420.3384794
Lybeck H, Leppaluoto J, Aito H. 1964. [The effect of an organophosphorus cholinesterase inhibitor, methyl parathion, upon the accumulation of iodide by the thyroid gland]. Ann Acad Sci Frenn (Med) 106:3–8. (Finnish)
*Mabey W, Mill T. 1978. Critical review of hydrolysis of organic compounds in water under environmental conditions. J Phys Chem Ref Data 7:383–415.
*Mackay D, Shiu WY. 1981. A critical review of Henry’s law constant for chemicals of environmental interest. J Phys Chem Ref Data 10:1175–1199.
*Maddy KT, Fong HR, Lowe JA, . 1982. A study of well water in selected California communities for residues of 1,3-dichloropropene, chloroallyl alcohol and 49 organophosphate or chlorinated hydrocarbon pesticides. Bull Environ Contam Toxicol 29:354–359.7126926
Maes RA. 1975. Organic thiophosphate esters (type A & B procedures). In: Sunshine I, ed. Methodology for analytical toxicology. Vol. 1, Cleveland, OH: CRC Press, Inc., 288–291.
*Maitra SK, Sarkar R. 1996. Influence of methyl parathion on gametogenic and acetylcholinesterase activity in the testis of whitethroated munia (Lonchura malabarica). Arch Environ Contam Toxicol 30:384–389.8854969
*Majewski MS, Foreman WT, Goolsby DA, . 1998. Airborne pesticide residues along the Mississippi. Environ Sci Technol 32:3689–3698.
Malhi PK, Grover IS. 1987. Genotoxic effects of some organophosphorus pesticides: II. In vivo chromosomal aberration bioassay in bone marrow cells in rat. Mutat Res 188:45–51.3574336
*Mallatou H, Pappas CP, Kondyli E, . 1997. Pesticide residues in milk and cheeses from Greece. Sci Total Environ 196:111–117.9129331
Marcus M, Spigarelli J, Miller H. 1978. Organic compounds in organophosphorus pesticide manufacturing waste waters. Washington, DC: U.S. Environmental Protection Agency. NTIS PB-289821.
Martin EA. 1972. [Fluorometric determination of some pesticides]. Can J Pharmacol Sci 7:21–22. (French)
Martin EW. 1978. Hazards of medication. 2nd ed. Philadelphia, PA: JB Lippincott, Co., 442.
Martins JM, Monrozier LJ, Chalamet A, . 1997. Microbial response to repeated applications of low concentrations of pentachlorophenol in an alfisol under pasture. Chemosphere 35(8):1637–1650.9353904
Marutoiu C, Sarbu C, Vlassa M, . 1986. A new separation and identification method of some organophosphorus pesticide by means of temperature programming gradient thin-layer chromatography. Analysis 14:95–98.
Marutoiu C, Vlassa M, Sarbu C, . 1987. Separation and identification of organophosphorus pesticides in water by HPTL. J High Resolution Chromatog Chromatog Comm 19:465–466.
*Mathew G, Vijayalaxmi KK, Rahiman MA. 1992. Methyl parathion-induced sperm shape abnormalities in mouse. Mutat Res 280:169–173.1381479
Maxwell DM, Brecht KM. 1992. Quantitative structure-activity analysis of acetylcholinesterase inhibition by oxono and thiono analougues of organophosphorus compounds. Chem Res Toxicol 5:66–71.1581539
*Mayr U, Butsch A and Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McConell R, Cedillo L, Keifer M, . 1992. Monitoring organophosphate insecticide-exposed workers for cholinesterase depression: New technology for office or field use. J Occup Med 34:34–37.1552378
McConnell R, Pacheco F, Wahlberg K, . 1999. Subclinical health effects of environmental pesticide contamination in a developing country: Cholinesterase depression in children. Environ Res A81:87–91.
*McLean JE, Sims RC, Doucette WJ, . 1988. Evaluation of mobility of pesticides in soil using U.S. EPA Methodology. J Environ Engin 114:689–703.
*Medved LI, Kagan JS. 1983. Petrochemicals. Encyclopedia of occupational health and safety. Vol. I&II, Geneva, Switzerland: International Labour Office, 1646.
Megharaj M, Singleton I, McClure NC. 1998. Effect of pentachlorophenol pollution towards microalgae and microbial activities in soil from a former timber processing facility. Bull Environ Contam Toxicol 61:108–115.9657838
*Meister R., ed. 1988. Farm chemicals handbook. Willoughby, OH: Meister Publishing Company, C147–C148.
*Meister RT, Sine C, Towns RL, . eds. 1999. Farm chemicals handbook. Willoughby, OH: Meister Publishing Company.
Melnyk LJ, Berry MR, Sheldon LS. 1997. Dietary exposure from pesticide application on farms in the agricultural health pilot study. J Expo Anal Environ Epidemiol 7:61–80.9076610
Mendelsohn ML, Moore DH, Lohman PHM. 1992. A method for comparing and combining short-term genotoxicity test data: Results and interpretation. Mutat Res 266:43–60.1372963
Mendoza CE, Shields JB. 1971. Esterase specificity and sensitivity to organophosphorus and carbamate pesticides: Factors affecting determination by thin layer chromatography. J Assoc Off Anal Chem 54:507–512.5005789
*Metcalf RL, March RB. 1953. The isomerization of organic thionophosphate insecticides. J Econ Entomol 46:288–294.
*Midtling JE, Barnett PG, Coye MJ, . 1985. Clinical management of field worker organophosphate poisoning. West J Med 142:514–518.4013266
Mingelgrin U, Gerstl Z. 1983. Reevaluation of partitioning as a mechanism of nonionic chemicals adsorption in soils. J Environ Qual 12:1–11.
Minyard JP, Roberts WE. 1991. State findings on pesticide residues in foods—1988-1989. J Assoc Off Anal Chem 74:438–453.1874687
*Mirer FE, Levinl BS, Murphy SD. 1977. Parathion and methyl parathion toxicity and metabolism in piperonyl butoxide and diethyl maleate pretreated mice. Chem Biol Interactions 17:99–112.
Misra D, Bhuyan S, Adhya TK, . 1992. Accelerated degradation of methyl parathion, parathion, and fenitrothion by suspensions from methyl parathion- and p-nitrophenol-treated soils. Soil Biol Biochem 24:1035–1042.
*Miyamoto J. 1964. Studies on the mode of action of organophosphorus compounds. Part III. Activation and degradation of sumithion and methyl parathion in mammals in vivo. Agric Biol Chem 28:411–421.
Miyamoto J, Sato Y, Kadota T, . 1963a. Studies on the mode of action of organophosphorus compounds. Part I. Metabolic fate of P32 labeled sumithion and methylparathion in guinea pig and white rat. Agric Biol Chem 27:381–389.
*Miyamoto J, Sato Y, Kadota T, . 1963b. Studies on the mode of action of organophosphorus compounds. Part II. Inhibition of mammalian cholinesterase in vivo following the administration of sumithion and methylparathion. Agric Biol Chem 27:669–676.
Moeller HC, Rider JA. 1959. The effects of various organic phosphate insecticides on RBC and plasma cholinesterase in humans [Abstract]. Fed Proc 18:424.
Mohammed SA, Sorensen DL, Sims RC, . 1998. Pentachlorophenol and phenanthrene biodegradation in creosote contaminated aquifer material. Chemosphere 37(1):103–111.9637006
*Mohn G. 1973. 2-Methyltryptophan resistance mutations in Escherichia coli K-12: Mutagenic activity of monofunctional alkylating agents including organophosphorus insecticides. Mutat Res 20:7–15.4357387
Molozhanova EG. 1980. Distribution dynamics of organophosphate pesticides in the soil and their migration in the soil-water ecological system. Migr Lagrya Veshchestv Pochvakh Sopredel-Nykh Srekakh, Tr Vses Soveshch 2:232–234.
*Morgan DP, Hetzler HL, Slach EF, . 1977. Urinary excretion of paranitrophenol and alkyl phosphates following ingestion of methyl or ethyl parathion by human subjects. Arch Environ Contam Toxicol 6:159–173.900999
*Morse DL, Baker EL, Landrigan PJ. 1979. Cut flowers: A potential pesticide hazard. Am J Public Health 69:53–56.420356
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants. Clin Pharmacokin 5:485–527.
Motoyama N, Dauterman WC. 1978. Multiple forms of rat liver glutathione S-transferases: Specificity for conjugation of O-alkyl and O-aryl groups of organophosphorus insecticides. J Agr Food Chem 26:1296–1301.730943
Muir J, Eduljee G. 1999. PCP in the freshwater and marine environment of the European Union. Sci Total Environ 236:41–56.10535143
*Mukerjee S, Ellenson WD, Lewis RG, . 1997. An environmental scoping study in the lower Rio Grande Valley of Texas- III. Residential microenvironmental monitoring for air, house dust, and soil. Environ Int 23:657–673.
*Murphy SD. 1980. Toxic interactions with dermal exposure to organophosphate insecticides [Abstract]. Toxicol Lett 5(Supplement 1):34.
*Murphy SD. 1982. Toxicity of hepatic metabolism of organophosphate insecticides in developing rats. In: Hunt VR, Smith MK, Worth D, eds. Banbury report, Vol. II. Environmental factors in human growth and development symposium, November 1-4, 1981. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 125–136.
*Murphy SD, DuBois KP. 1958. The influence of various factors on the enzymatic conversion of organic thiophosphates to anticholinesterase agents. J Pharmacol Exp 124:194–202.
*Nabb DP, Whitfield F. 1967. Determination of cholinesterase by an automated pH-stat method. Arch Environ Health 15:147–154.4951705
Nagymajtenyi L, Schulz H, Desi I. 1995. Changes in EEG of freely-moving rats caused by three-generation organophosphate treatment. Arch Toxicol 17 (Supp):288–294.
Nakagawa M, Uchiyama M. 1974. Effect of organophosphate pesticides on lecithin-cholesterol acyltransferase in human plasma. Biochem Pharmacol 23:1641–1645.4847537
*Nakatsugawa T, Tolman NM, Dahm PA. 1968. Degradation and activation of parathion analogs by microsomal enzymes. Biochem Pharmacol 17:1517–1528.4386233
*Namba T, Nolte CT, Jackrel J, . 1971. Poisoning due to organophosphate insecticides—Acute and chronic manifestations. Am J Med 50:475–492.4324629
Nanda Kumar NV, Visweswaraiah K, Majumder SK. 1976. Thin layer chromatography of parathion as paraoxon with cholinesterase inhibition detection. J Assoc Off Anal Chem 59:641–643.1270394
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences, National Research Council. Washington, DC: National Academy Press, 15–35.
NATICH. 1988. National Air Toxics Information Clearinghouse (database): Report on state, local, and EPA air toxics activities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. July, 1988. EPA 450/5-88-007.
*Nations BK, Hallberg GR. 1992. Pesticides in Iowa precipitation. J Environ Qual 21:486–492.
*NCI. 1979. Bioassay of methyl parathion for possible carcinogenicity. Bethesda, MD: U.S. Department of Health, Education, and Welfare, National Institutes of Health, National Cancer Institute, Carcinogenesis Testing Program. DHEW (NIH) Publication No. 79-1713; NCI-CG-TR-157, 112.
*Neal RA, DuBois KP. 1965. Studies on the mechanism of detoxification of cholinergic phosphorothioates. J Pharmacol Exp Ther 148:185–192.14301009
Nehez M, Boros P, Ferke A, . 1988. Cytogenetic examination of people working with agrochemicals in the southern region of Hungary. Regul Toxicol Pharmacol 8:37–44.3368584
*Neidert E, Saschenbrecher PW. 1996. Occurrence of pesticide residues in selected agricultural food commodities available in Canada. J Assoc Off Anal Chem 79:549.
*Nemec SJ, Adkisson PL, Dorough HW. 1968. Methyl parathion adsorbed on the skin and blood cholinesterase levels of persons checking cotton treated with ultra-low-volume sprays. J Econ Entomol 61:1740–1742.5723772
*NFPA. 1986. Fire protection guide on hazardous materials. 9th ed. Boston, MA: National Fire Protection Association, 49–64.
Ni Z, Li S, Liu Y, . 1993. [Induction of micronucleus by organophosphorus pesticides both in vivo and in vitro]. J West China Univ Med Sci 24:82–86. (Chinese).
Nigg HN, Knaak JB. 2000. Blood cholinesterases as human biomarkers of organophosphorus pesticide exposure. Rev Environ Contam Toxicol 163:29–112.10771584
*NIOSH. 1976. Criteria for a recommended standard. Occupational exposure to methyl parathion. Washington, DC: U.S. Department of Health, Education, and Welfare, National Institute for Occupational Safety and Health. DHEW (NIOSH) Publication No. 77-106.
NIOSH. 1984. NIOSH manual of analytical methods (method 5012-1). Washington, DC: U.S. Department of Health, Education and Welfare, National Institute for Occupational Safety and Health.
NIOSH. 1999. Methyl parathion. Pocket guide to chemical hazards. Washington DC: National Institute for Occupational Safety and Health, U.S. Department of Health and Human Services.
*NIOSH. 2001. Methyl parathion. Pocket guide to chemical hazards. Washington DC: National Institute for Occupational Safety and Health, U.S. Department of Health and Human Services. January 17, 2001.
*NPIRS. 1986. National Pesticide Information Retrieval System (database). Chemical fact sheet for: Methyl parathion. U.S. Environmental Protection Agency, Office of Pesticide Programs, Washington, DC: December, 1986.
*NRC. 1977. Drinking water and health. Vol. 1, Washington, DC: National Academy of Sciences, National Academy of Sciences Press. 626–635, 796–797.
*NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
Nyer E, Boettcher G, Morello B. 1991. Using the properties of organic compounds to help design a treatment system. Ground Water Monit Rev 11:81–86.
*Ohio EPA. 2001. List of extremely hazardous substances. Ohio Environmental Protection Agency. Http://www.epa.state.oh.us/derr/cepps/cepd/hazard.html. January 19, 2001.
Ohkawa H, Oshita H, Miyamoto J. 1980. Comparison of inhibitory activity of various organophosphorus compounds against acetylcholinesterase and neurotoxic esterase of hens with respect to delayed neurotoxicity. Biochem Pharmacol 29:2721–2727.7437078
Okumura D, Melnicoe R, Jackson T, . 1989. Pesticide residues in food crops analyzed by the California Department of Food and Agriculture in 1989. Rev Environ Contam Toxicol 118:87–152.
*Ortiz D, Yáñez L, Gómez H, . 1995. Acute toxicological effects in rats treated with a mixture of commercially formulated products containing methyl parathion and permethrin. Ecotoxicol Environ Safety 32: 154–158.8575360
OSHA. 1982. Occupational Safety and Health Administration. Federal Register 47:30420–30438.
OSHA. 1989. U.S. Department of Health and Human Services, Occupational Safety and Health Administration. Federal Register 54:2923–2960.
*OSHA. 2001. OSHA preambles - air contaminants. Occupational Safety and Health Administration. U.S. Department of Labor. Code of Federal Regulations. Http://search.osha-slc.gov/search97…ower.hts&QueryText=methyl+parathion. January 18, 2001.
*Ou L, Rao PS, Davidson JM. 1983. Methyl parathion degradation in soil: Influence of soil-water tension. Soil Biol Biochem 15:211–215.
*Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human Development. Philadelphia, PA: WB Saunders, 222–238.
Padungtod C, Hassold TJ, Millie E, . 1999. Sperm aneuploidy among Chinese pesticide factory workers: Scoring by the FISH method. Am J Ind Med 36:230–238.10398931
*Pagulayan IF, Baoanan ZG, Villa LQ. 1994. The effect of methyl parathion on the sperm head morphology of the ICR strain mice. Asia Life Sci 3(1): 45–54.
Palmer JS. 1978. Toxicologic evaluation of a microencapsulated formulation of methyl parathion applied dermally to cattle. Am J Vet Res 39:429–431.637391
*Pappas CJ, Kyriakids NB, Athanasopoulos PE. 1999. Degradation of parathion methyl on field-sprayed apples and stored apples. J AOAC 82(2):359–363.
Parent-Massin D, Thouvenot D. 1993. In vitro study of pesticide hematotoxicity in human and rat progenitors. J Pharmacol Toxicol Methods 30:203–207.8123901
Park BH, Lee TP. 1978. Effects of pesticides on human leukocyte function. In: Asher IM, ed., Proc 4th FDA Science Symposium, Annapolis, MD: 273–274.
*Parkinson A. 1996. Biotransformation of xenobiotics: Carboxylesterases. In: Klassen CD, ed. Casarett and Doull’s toxicology: The basic science of poisons. New York, NY: McGraw-Hill, 115–118.
*Paschal DC, Bicknell R, Dresbach D. 1977. Determination of ethyl and methyl parathion in runoff water with high performance liquid chromatography. Anal Chem 49:1551–1554.900491
Patil M, Kulkarni RS. 1996. Ovarian lipid and cholesterol response to Sumaach (a crude form of HCG) under pesticide treatment in the freshwater fish, Channa punctatus (Bloch). Proc Natl Acad Sci India Sect B 66:135–137.
Pawlowska D, Moniuszko-Jakoniuk J, Soltys M. 1985a. Parathion-methyl effect on the activity of hydrolytic enzymes after single physical exercise in rats. Pol J Pharmacol 37:629–638.
Pawlowska D, Moniuszko-Jakoniuk J, Soltys M. 1985b. The effect of chronic physical exercise on the activity of hydrolytic enzymes in acute poisoning with parathion-methyl in rats. Pol J Pharmacol Pharm 37:639–646.3008132
Pedersen F, Petersen GI. 1996. Variability of species sensitivity to complex mixtures. Water Sci Technol 33:109–119.
*Petit F, Le Goff P, Cravedi JP, . 1997. Two complementary bioassays for screening the estrogenic potency of xenobiotics: Recombinant yeast for trout estrogen receptor and trout hepatocyte cultures. J Molecular Endocrinology 19:321–335.
Pewnim T, Seifert J. 1993. Structural requirements for altering the L-tryptophan metabolism in mice by organophosphorous and methylcarbamate insecticides. Eur J Pharmacol 248:237–241.7507440
*Plapp FW, Casida JE. 1958. Hydrolysis of the alkyl-phosphate bond in certain dialkyl aryl phosphorothioate insecticides by rats, cockroaches, and alkali. J Econ Entomol 51:800–803.
Polidoro G, DiIlio C, Arduini A, . 1982. Glutathione peroxidase and glutathione S-transferase activities in human fetal tissues. Inability of acidic forms of glutathione S-transferase to catalyze the reduction of organic hydroperoxides. Biochem Int 4:637–645.
*Pope CN, Chakraborti TK. 1992. Dose-related inhibition of brain and plasma cholinesterase in neonatal and adult rats following sublethal organophosphate exposures. Toxicology 73:35–43.1375401
Pope CN, Liu J. 1997. Age-related differences in sensitivity to organophosphorus pesticides. Environ Toxicol Pharmacol 4:309–314.21781839
*Pope CN, Chakraborti TK, Chapman ML, . 1991. Comparison of in vivo cholinesterase inhibition in neonatal and adult rats by three organophosphorothioate insecticides. Toxicology 68:51–61.1714639
Prasada Rao KS, Ramana Rao KV. 1987. The possible role of glucose-6-phosphate dehydrogenase in the detoxification of methyl parathion. Toxicol Lett 39:211–214.3686551
Prinsloo SM, De Beer P143R. 1985. Gas chromatographic relative retention data for pesticides on nine packed columns: I. Organophosphorus pesticides, using flame photometric detection. J Assoc Off Anal Chem 68:1100–1108.
*Pritchard PH, Cripe CR, Walker WW, . 1987. Biotic and abiotic dehydration rates of methyl parathion in freshwater and estuarine water and sediment samples. Chemosphere 16:1509–1520.
*Proctor NH, Hughes JP, Fischman ML, eds. 1988. Chemical hazards of the workplace. 2nd ed. Philadelphia, PA: JB Lippincott Company, 340–344.
Radulovic LL, Kulkarni AP, Dauterman WC. 1987. Biotransformation of methyl parathion by human foetal liver glutathione S-transferases: An in vitro study. Xenobiotic 17:105–114.
Radulovic LL, Laferla JJ, Kulkarni AP. 1986. Human placental glutathione S-transferase-mediated metabolism of methyl parathion. Biochem pharmacol 35:3473–3480.3768034
Raju J, Gupta VK. 1989. A new extractive spectrophotometric method using malonyl dihydrazide for the determination of organophosphorus pesticides in surface residues. Microchem J 39:166–171.
Rani NL, Lalithakumari D. 1994. Degradation of methyl parathion by Pseudomonas putida. Can J Microbiol 40:1000–1006.7704828
*Rao PS, Davidson JM. 1979. Adsorption and movement of selected pesticides at high concentrations in soils. Water Res 13:375–380.
*Rashid KA, Mumma RO. 1984. Genotoxicity of methyl parathion in short-term bacterial test systems. J Environ Sci Health B19:565–577.
*Reddy KS, Gambrell RP. 1987. Factors affecting the adsorption of 2,4-D and methyl parathion in soils and sediments. Agric Ecosyst Environ 18:231–241.
Rehner TA, Kolbo JR, Trump R, . 2000. Depression among victims of south Mississippi’s methyl parathion disaster. Health Soc Work 25(1):33–40.10689601
Reich GA, Gallaher GL, Wiseman JS. 1968. Characteristics of pesticide poisoning in south Texas. Texas Med 64:56–58.
Renhof M. 1984. Parathion-methyl (Folidol M actice ingredient): Study for embryotoxic effects on rabbits after oral administration. Bayer AG Institute of Toxicology, Wuppertal, West Germany. Unpublished Report No. 12907.
Riccio E, Shepherd A, Pomeroy K, . 1981. Comparative studies between the S. cerevisiae D3 and D7 assays of eleven pesticides [Abstract]. Environ Mutagen 3:327.
*Rice CP, Chernyak SM, McConnell LL. 1997. Henry’s law constants for pesticides measured as a function of temperature and salinity. J Agric Food Chem 45:2291–2298.
Rider JA, Moeller HC. 1964. Studies on the anticholinesterase effects of systox and methyl parathion in humans [Abstract]. Fed Proc 23:176.
Rider JA, Puletti EJ. 1969. Studies on the anticholinesterase effects of gardona, methyl parathion, and guthion in human subjects. Fed Proc 28:479.
Rider JA, Moeller HC, Puletti EJ. 1966. Continuing studies on anticholinesterase effect of methyl parathion in humans and determination of level of incipient toxicity of OMPA [Abstract]. Fed Proc 25:687.
Rider JA, Moeller HC, Puletti EJ. 1967. Continuing studies on anticholinesterase effect of methyl parathion, initial studies with guthion, and determination of incipient toxicity level of dichlorvos in humans [Abstract]. Fed Proc 26:427.
*Rider JA, Moeller HC, Puletti EJ, . 1969. Toxicity of parathion, systox, octamethyl pyrophosphoramide, and methyl parathion in man. Toxicol Appl Pharmacol 14:603–611.4306871
Rider JA, Swader JI, Puletti EJ. 1970. Methyl parathion and guthion anticholinesterase effects in human subjects [Abstract]. Fed Proc 29:349.
*Rider JA, Swader JI, Puletti EJ. 1971. Anticholinesterase toxicity studies with methyl parathion, guthion, and phosdrin in human subjects [Abstract]. Fed Proc 30:443.
Ritter L. 1997. Report of a panel on the relationship between public exposure to pesticides and cancer. Cancer 80:2019–2033.9366307
Roach JA, Andrzejewski D. 1987. Analysis for pesticide residues by collision-induced fragmentation. In: Rosen JD, ed. Applications of new mass spectrometry techniques in pesticide chemistry. New York, NY: Wiley & Co., 187–210.
Roan CC, Morgan DP, Cook N, . 1969. Blood cholinesterases, serum parathion concentrations and urine p-nitrophenol concentrations in exposed individuals. Bull Environ Contam Toxicol 4:362–369.24185629
*Roberts DK, Silvey NJ, Bailey EM Jr. 1988. Brain acetylcholinesterase activity recovery following acute methyl parathion intoxication in two feral rodent species comparison to laboratory rodents. Bull Environ Contam Toxicol 41:26–35.3052658
Rodgers KE, Leung N, Imamura T, . 1986. Rapid in vitro screening assay for immunotoxic effects of organophosphorus and carbamate insecticides on the generation of cytotoxic T lymphocyte responses. Pestic Biochem Physiol 26:292–301.
*Rodnitzky RL, Levin HS, Morgan PP. 1978. Effects of ingested parathion on neurobehavioral functions. Clin Toxicol 13:347–359.743864
*Roggi C, Mazzei B, Berselli E, . 1991. Riflessi della contaminazione ambientale sul latte materno. L’lgiene Moderna 96: 1–16.
Roney N, Henriques WD, Fay M, . 1998. Determining priority hazardous substances related to hazardous waste sites. Toxicol Ind Health 14:521–532.9664643
Rosenberg A, Alexander M. 1979. Microbial cleavage of various organophosphorus insecticides. Appl Environ Microbiol 37:886–891.225990
Rosenkranz HS, Klopman G. 1994. Structural implications of the ICPEMC method for quantifying genotoxicity data. Mutat Res 305:99–116.7508550
*Roy RR, Wilson P, Laski RR, . 1997. Monitoring of domestic and imported apples and rice by the U.S. Food and Drug Administration pesticide program. J Assoc Off Anal Chem 80:883–894.
*RTECS. 1989. Registry of Toxic Effects of Chemical Substances (database). U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Washington, DC.
RTECS. 1999. Methyl parathion. Registry of Toxic Effects of Chemical Substances. National Institute for Occupational Safety and Health. April 19, 1999.
*Rudel H. 1997. Volatilization of pesticides from soil and plant surfaces. Chemosphere 35:143–152.
Rupa DS, Reddy PP, Reddi OS. 1991. Clastogenic effect of pesticides in peripheral lymphocytes of cotton-field workers. Mutat Res 261:177–180.1719409
*Ruth JH. 1986. Odor thresholds and irritation levels of several chemical substances: A review. Am Ind Hyg Assoc J 47:A142–A151.3706135
*Sabharwal AK, Belsare DK. 1986. Persistence of methyl parathion in a carp rearing pond. Bull Environ Contam Toxicol 37:705–709.3779154
Saleh MA. 1980. Mutagenic and carcinogenic effects of pesticides. J Environ Sci Health B15:907–927.
*Sanders PF, Seiber JN. 1983. A chamber for measuring volatilization of pesticides from model soil and water disposal systems. Chemosphere 12:999–1012.
*Sanz P, Rodriguez-Vicente MC, Diaz D, . 1991. Red blood cell and total blood acetylcholinesterase and plasma pseudocholinesterase in humans: Observed variances. Clin Toxicol 29:81–90.
Sartorelli P, Aprea C, Bussani R, . 1997. In vitro percutaneous penetration of methyl-parathion from a commercial formulation through the human skin. Occup Environ Med 54:524–525.9282131
Schattenberg HJ, Hsu JP. 1992. Pesticide residue survey of produce from 1989-1991. J Assoc Off Anal Chem 75:925–933.
Schilter B, Renwick AG, Huggett AC. 1996. Limits for pesticide residues in infant foods: A safety-based proposal. Regul Toxicol Pharmacol 24:126–140.8933626
Schimmel SC, Garnas RL, Patrick JM, . 1983. Acute toxicity, bioconcentration and persistence of AC 222,705, benthiocarb, chlorpyrifos, fenvalerate, methyl parathion and permethrin in the estuarine environment. J Agric Food Chem 31:104–113.6681821
Schmidt RR. 1984. Altered development of immunocompetence following prenatal or combined prenatal-postnatal insult: A timely review. J Am College Toxicol 3:57–72.
*Schomburg CJ, Glotfelty DW, Seiber JN. 1991. Pesticide occurrence and distribution in fog collected near Monterey, California. Environ Sci Technol 25:155–160.
*Schultz JA, Manigold DB, Andrews FL. 1973. Pesticides in selected western streams—1968-1971. Pestic Monit J 7:73–85.4758205
Schwab BW, Murphy SD. 1981. Induction of anticholinesterase tolerance in rats with doses of disulfoton that produce no cholinergic signs. J Toxicol Environ Health 8:199–204.7328703
*Seiber JN, McChesney MM, Woodrow JE. 1989. Airborne residues resulting from use of methyl parathion, molinate and thiobencarb on rice in the Sacramento Valley, California. Environ Toxicol Chem 8:577–588.
*Senanayake N, Karalliedde L. 1992. Intermediate syndrome in anticholinesterase neurotoxicity. In: Ballantyne B, Marrs TC, ed. Clinical and experimental toxicology of organophosphates and carbamates. Jordan Hill, Oxford, England: Butterworth-Heinemann Ltd., 57–62.
*Senseman SA, Lavy TL, Mattice JD, . 1997. Trace level pesticide detections in Arkansas surface waters. Environ Sci Technol 31:395.
*Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Sever LE, Arbuckle TE, Sweeney A. 1997. Reproductive and developmental effects of occupational pesticide exposure: The epidemiologic evidence. Occup Med 12:305–325.9220488
*Shafik TM, Bradway DE, Enos HR, . 1973a. Human exposure to organophosphorus pesticides: A modified procedure for the gas-liquid chromatographic analysis of alkylphosphate metabolites in urine. J Agr Food Chem 21:625–629.4268895
*Shafik TM, Sullivan HC, Enos HR. 1973b. Multiresidue procedure for halo- and nitrophenols. Measurement of exposure to biodegradable pesticides yielding these compounds as metabolites. J Agr Food Chem 21:295–297.4688914
*Sharma RP, Reddy RV. 1987. Toxic effects of chemicals on the immune system. In: Haley TJ, Berndt WO, eds. Handbook of Toxicology. New York, NY: Hemisphere Publishing Corp., 555–591.
Sharmila M, Ramanand K, Sethunanthan N. 1981. Hydrolysis of methyl parathion in a flooded soil. Bull Environ Contam Toxicol 43:45–51.
*Sharmila M, Ramanand K, Adhya TK, . 1988. Temperature and the persistence of methyl parathion in a flooded soil. Soil Biol Biochem 20:399–401.
*Sheridan RS, Meola JR. 1999. Analysis of pesticide residues in fruits, vegetables, and milk by gas chromatography/tandem mass spectrometry. J AOAC Int 82(4):982–990.10444835
Shevchenko MA, Taran PH, Marchenko PV. 1982. Modern methods of purifying water from pesticides. Soviet J Water Chem Technol 4:53–71.
*Shigaeva MK, Savitskaya IS. 1981. Comparative study of the mutagenic activity of some organophosphorus insecticides in bacteria. Tsitol Genet 15:68–72.
*Shtenberg AI, Dzhunusova RM. 1968. Depression of immunobiological reactivity of animals by some organophosphorus pesticides. Bull Exp Biol Med 65:317–318.
Simcox NJ, Fenske RA, Wolz SA, . 1995. Pesticides in household dust and soil: Exposure pathways for children of agricultural families. Environ Health Perspect 103:1126–1134.8747019
Simmon VF, Poole DC, Newell GW. 1976. In vitro mutagenic studies of twenty pesticides [Abstract]. Toxicol Appl Pharmacol 37:109.
Simmon VF, Poole DC, Riccio ES, . 1979. In vitro mutagenicity and genotoxicity assays of 38 pesticides [Abstract]. Environ Mutagen 1:142–143.
Singh S, Lehmann-Grube B, Boedde HW. 1984. Cytogenetic effects of paraoxon and methyl-parathion on cultured human lymphocytes: SCE, clastogenic activity and cell cycle delay. Int Arch Occup Environ Health 54:195–200.6092281
Sirianni SR, Huang CC. 1980. Comparison of induction of sister chromatid exchange, 8-azaguanine- and ouabain-resistant mutants by cyclophosphamide, ifosfamide and 1-(pyridyl-3)-3,3-dimethyltriazene in Chinese hamster cells cultured in diffusion chambers in mice. Carcinogenesis 1:353–355.7273275
*Skinner CS, Kilgore WW. 1982a. Acute dermal toxicities of various organophosphate insecticides in mice. J Toxicol Environ Health 9:491–497.7097799
*Skinner CS, Kilgore WW. 1982b. Application of a dermal self-exposure model to worker reentry. J Toxicol Environ Health 9:461–481.7097797
Smith S, Willis GH, McDowell LL, . 1987. Dissipation of methyl parathion and ethyl parathion from cotton foliage as affected by formulation. Bull Environ Contam Toxicol 39:280–285.3663982
*Sobti RC, Krishan A, Pfaffenberger CD. 1982. Cytokinetic and cytogenetic effects of some agricultural chemicals on humans lymphoid cells in vitro: Organophosphates. Mutat Res 102:89–102.6981766
*Solecki R, Faqi AS, Pfeil R, . 1996. Effects of methyl parathion on reproduction in the Japanese quail. Bull Environ Contam Toxicol 57:902–908.8875837
Somara S, Siddavattam D. 1995. Plasmid mediated organophosphate pesticide degradation by Flavobactrium balustinum. Biochem Molec Biol Int 36:627–631.7549962
*Sonnenschein P, Golbs S, Weigel B, . 1989a. [Ferment-diagnostic and histological investigations of blood and liver of surviving rats, following one and two applications of mean lethal doses of parathionmethyl. Second communication: Tyrosine-amino transferase and pathologico-morphological liver findings]. Arch Exp Veterinarmed, Leipzig 43:9–15. (German)
*Sonnenschein P, Golbs S, Wiezorek WD. 1989b. [The ferment-diagnostic and histological (sic.) investigations of blood liver surviving rats (sic.), following one and two applications of mean lethal doses of parathionmethyl. First communication: Results obtained from studies into activity of plasma enzymes AlAT, AsAT, AP, and gamma-GT]. Arch Exp Veterinarmed, Leipzig 43:1–8. (German)
Soratur SM, Kaliwal BB. 1998. Effect of methyl parathion on pregnancy in albino rats. Ecol Env and Cons 4:145–149.
Sortur SM, Kaliwal BB. 1999. Effect of methyl parathion formulation on estrous cycle and reproductive performance in albino rats. Indian J Exp Biol 37:176–178.10641139
*Soto AM, Sonnenschein C, Chung KL, . 1995. The E-SCREEN assay as a tool to identify estrogens: An update on estrogenic environmental pollutants. Environ Health Perspect 103 (Supp. 7):113–122.
*Spencer EY. 1982. Guide to the chemicals used in crop protection. 7th ed. Ottawa. Ontario, Canada: Agriculture Canada, Research Institute. Publication No. 1093, 394.
Spencer WF, Shoup TD, Cleath MM, . 1979. Vapor pressures and relative volatility of ethyl and methyl parathion. J Agric Food Chem 27:273–278.
*Stan H-J. 1989. Application of capillary gas chromatography with mass selective detection to pesticide residue analysis. J Chromatogr 467:85–98.
*Stan H-J, Mrowetz D. 1983. Residue analysis of organophosphorus pesticides in food with 2-dimensional gas chromatography using capillary columns and flame photometric detection. J High Resol Chromatog Chromatog Comm 6:255–263.
Stanley CW, Barney II JE, Helton, MR, . 1971. Measurement of atmospheric levels of pesticides. Environ Sci Technol 5:430–435.
State of Vermont Agency of Natural Resources. 1988. Chapter 12. Ground water protection rule and strategy. Vermont: State of Vermont, Agency of Natural Resources, Department of Environmental Conservation. 099/1100/GW2, 28.
Stork A, Ophoff H, Smelt JH, . 1998. Volatilization of pesticides: Measurements under simulated field conditions. In: Fuhr F, Hance RJ, Plimmer JR, ., ed. The Lysimeter Concept: Environmental behavior of pesticides. Washington, DC: American Chemical Society, 21–39.
Stover EL, Kincannon DF. 1983. Contaminated groundwater treatability – a case study. J Am Water Works Assoc 75:292–298.
*Street JC, Sharma RP. 1975. Alteration of induced cellular and humoral immune responses by pesticides and chemicals of environmental concern: Quantitative studies of immunosuppression by DDT, Aroclor 1254, carbaryl, carbofuran, and methyl parathion. Toxicol Appl Pharmacol 32:587–602.50651
*Stutz DR, Janusz SJ, eds. 1988. Hazardous materials injuries. A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation, 149, 372–374.
*Suba, LA. 1981. Information in support of the registration of methyl parathion: One-year chronic feeding study in dogs. Monsanto Agricultural Products Company, St. Louis, MO.
*Suba, LA. 1984. Additional information to support the registration of methyl parathion: Two year chronic feeding study of methyl parathion in rats. Monsanto Agricultural Products Company, St. Louis, MO.
*Sultatos LG. 1987. The role of the liver in mediating the acute toxicity of the pesticide methyl parathion in the mouse. Drug Metab Disp 15:613–617.
*Sultatos LG. 1994. Mammalian toxicolgoy of organophosphorus pesticides. J Toxicol Environ Health 43:271–289.7966438
Sultatos LG, Woods L. 1988. The role of glutathione in the detoxification of the insecticides methyl parathion and azinphos-methyl in the mouse. Toxicol Appl Pharmacol 96:168–174.3188022
Sultatos LG, Huang GJ, Jackson O, . 1991. The effect of glutathione monoethyl ester on the potentiation of the acute toxicity of methyl parathion, methyl paraoxon or fenitrothion by diethyl maleate in the mouse. Toxicol Lett 55:77–83.1998199
*Sunshine I, ed. 1969. CRC handbook of analytical toxicology. Cleveland, OH: The Chemical Rubber Co., 522.
*Swann R, Laskowski D, McCAll P, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:18–28.
*Tafuri J, Roberts J. 1987. Organophosphate poisoning. Ann Emerg Med 16:193–202.3541700
*Tanimura T, Katsuya T, Nishimura H. 1967. Embryotoxicity of acute exposure to methyl parathion in rats and mice. Arch Environ Health 15:609–613.6066266
Taylor P. 1985. Anticholinesterase agents. Chapter 6. In: Gilman AG, Goodman LS, Rall TW, ., eds. Goodman and Gilman’s the pharmacological basis of therapeutics. 7th ed., New York, NY: MacMillan Publishing Co. 110–129.
*Taylor P. 1996. Anticholinesterase agents. In: Hardman JG, Limbird LE, eds. Goodman & Gilman’s the pharmacological basis of therapeutics. New York, NY: McGraw-Hill, 161–176.
Tegeris AS, Underwood PC. 1978. Methyl parathion: Ninety-day feeding to dogs. Unpublished study. Laurel, MD: Pharmacopathics Research Laboratories, Inc. Report No. 7758, 77–117; MRID 00072512.
*Tessari JD, Spencer DL. 1971. Air sampling for pesticides in the human environment. J AOAC 54:1376–1382.
Tewari SN, Harplani SP. 1972. Detection of organo-phosphorus pesticide residues in autopsy tissues by thin layer chromatography. Proc Nat Acad Sci India 42(A):287–292.
Tharr D. 1998. Rapid assessment of organophosphate-induced cholinesterase depression: A comparison of laboratory and field kit methods to detect human exposure to organophosphates. Appl Occup Environ Hyg 13:265–268.
Thompson HM, Langton SD, Hart ADM. 1995. Prediction of inter-species differences in the toxicity of organophosphorus pesticides to wildlife—a biochemical approach. Comp Biochem Physiol 111C:1–12.
*Tian Y, Piao F, Xie X, . 1997. Dose-related effect of methyl-parathion on T cell subpopulations. Environ Sci 5:169–175.
Tiess D, Wegener R, Tamme A. 1982. [A case of accidental parathion-methyl (Wofatox) poisoning with lethal result]. Deutsch Gesundheitswes 37:1540–1542. (German)
Tikhonova ON, Obert AS, Vinokurov YI. 1995. [Influence of environmental factors upon the frequency and severity of intestinal dysbiosis in infants] (Russian). Pediatriya 5:61–62.
Tinker TL, Collins CM, King HS, . 2000. Assessing risk communication effectiveness: Perspectives of agency practitioners. J Hazard Mater B73:117–127.
*Tomlin C. 1994. Parathion-methyl: Insecticide. In: The pesticide manual: Incorporating the agrochemicals handbook. 10^th^ ed. Cambridge: Crop Protection Publications. 771–772.
*Torres CM, Pico Y, Marin R, . 1997. Evaluation of organophosphorus pesticide residues in citrus fruits from the Valencian community (Spain). J Assoc Off Anal Chem 80:1122–1128.
TRI96. 1999. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD
*TRI98. 2000. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD
*TRI99. 2001. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access, Offices of Environmental Information, U.S. Environmental Protection Agency. Toxic Release Inventory. Http://www.epa.gov/triexplorer/. April 27, 2001.
Tripathy G, Shukla SP. 1988. Inhibition of liver and skeletal enzymes by methyl parathion. Biochem Arch 4:55–62.
*Tripathy NK, Dey L, Majhi B, . 1987. Genotoxicity of metacid established through the somatic and germ line mosaic assays and the sex-linked recessive lethal test in drosophila. Arch Toxicol 61:53–57.3125818
Trujillo A, Gnanasambandan T, Freiser H. 1984. Determination of organophosphorus compounds by dye-assisted chromatography. Analyt Chim Acta 162:333–338.
*Tvede KG, Loft S, Poulsen HE, . 1989. Methyl parathion toxicity in rats is changed by pretreatment with the pesticides chlordecone, mirex and linuron. Arch Toxicol Suppl 13:446–447.
UATW. 1999a. Unified Air Toxics Website. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. Http://www.epa.gov/ttnuatw1/uatwn.html. May 26, 1999.
UATW. 1999b. Unified Air Toxics Website. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. Http://www.epa.gov/ttnuatw1/uatwn.html. May 31, 1999.
*Udaya Bhaskar S, Nanda Kumar NV. 1981. Thin layer chromatographic determination of methyl parathion as paraoxon by cholinesterase inhibition. J AOAC 64:1312–1314.
*Undeger U, Institóris L, Siroki O, . 2000. Simultaneous geno- and immunotoxicological investigations for early detection of organophosphate toxicity in rats. Ecotoxicol Environ Saf 45:43–48.10677266
*US Tarriff Commission. 1953. Synthetic organic chemicals, U.S. production and sales, 1952. Washington, DC: U.S. Government Printing Office. Report No. 190, Second series, 106.
*US Tarriff Commission. 1972. Imports of benzoid chemicals and products, 1971. Washington, DC: U.S. Government Printing Office. TC Publishing No. 496, 96.
*USDA. 1978. Farmers’ use of pesticides in 1976. Agricultural economic report No. 418. Washington, DC: Report to U.S. Department of Agriculture by Economics, Statistics, and Cooperative Services, 16.
*USITC. 1973. Synthetic organic chemicals—United States production and sales, 1972. Washington, DC: U.S. International Trade Commission. USITC Publication No. 681, 195–198.
*USITC. 1975. Synthetic organic chemicals—United States production and sales, 1973. Washington, DC: U.S. International Trade Commission. USITC Publication No. 728, 187–196.
*USITC. 1977a. Synthetic organic chemicals—United States production and sales, 1974. Washington, DC: U.S. International Trade Commission. USITC Publication No. 804, 181–182, 187.
*USITC. 1977b. Synthetic organic chemicals—United States production and sales, 1976. Washington, DC: U.S. International Trade Commission. USITC Publication No. 833:263–270, 277, 278, 281.
*USITC. 1979. Synthetic organic chemicals—United States production and sales, 1978. Washington, DC: U.S. International Trade Commission. USITC Publication No. 1001, 288, 292.
*USITC. 1981. Synthetic organic chemicals—United States production and sales, 1980. Washington, DC: U.S. International Trade Commission. USITC Publication No. 1183, 239, 244.
*USITC. 1982. Synthetic organic chemicals—United States production and sales, 1981. Washington, DC: U.S. International Trade Commission. USITC Publication No. 1292, 218, 223.
*USITC. 1983. Synthetic organic chemicals—United States production and sales, 1982. Washington, DC: U.S. International Trade Commission. USITC Publication No. 1422, 232, 236.
*USITC. 1984. Synthetic organic chemicals—United States production and sales, 1983. Washington, DC: U.S. International Trade Commission. USITC Publication No. 1588, 230, 234.
*USITC. 1985. Synthetic organic chemicals—United States production and sales, 1984. Washington, DC: U.S. International Trade Commission. USITC Publication No. 1745, 227, 232.
*USITC. 1986a. Synthetic organic chemicals—United States production and sales, 1985. Washington, DC: U.S. International Trade Commission. USITC Publication No. 1892, 236, 241.
*USITC. 1986b. Synthetic organic chemicals—United States production and sales, 1986. Washington, DC: U.S. International Trade Commission. USITC Publication No. 2009, 187, 190.
*USITC. 1987. Synthetic organic chemicals—United States production and sales, 1987. Washington, DC: U.S. International Trade Commission. USITC Publication No. 2118, 13–6, 13–10.
*USITC. 1989. Synthetic organic chemicals—United States production and sales, 1988. Washington, DC: U.S. International Trade Commission. USITC Publication No. 2219, 13–2.
Uzokwu M. 1974. Comparative feto-toxicity of organophosphate insecticide in mice. Bulletin of Epizoot Dis Afr 22:161–166.
*Van Bao T, Szabo I, Ruzicska P, . 1974. Chromosome aberrations in patients suffering acute organic phosphate insecticide intoxication. Humangenetik 24:33–57.4426631
Vandekar M, Reiner E, Svetlicic, . 1965. Value of ED50 testing in assessing hazards of acute poisoning by carbamates and organophosphates. Br J Ind Med 22:317–320.5836574
Vanio H. 1999. Fruits, vegetables and pesticides -- do we know what we are eating? Scand J Work Environ Health 25(3):161–162.10450767
Veena P, Murthy PB. 1994. Effect of starvation on organophosphorus pesticide induced genotoxicity in rats. Int J Food Sci Nutr 45:71–77.
Veningerová M, Prachar V, Kovacicová J, . 1998. Levels of chlorinated phenols in Danube river water. Fresenius Environ Bull 7:224–231.
*Venkataraman BV, Niyer GY, Narayanan R, . 1990. Erythrocyte and plasma cholinesterase activity in normal pregnancy. Indian J Physiol Pharmacol 34:26–28.2361719
Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Co., 559–560.
Vettorazi G, van den Hurk, ed. 1985. Pesticides reference index. JMPR 41.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
View Database. 1989. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. September 25, 1989.
Vijayaraghavan M, Nagarajan B. 1994. Mutagenic potential of acute exposure to organophosphorus and organochlorine compounds. Mutat Res 321:103–111.7510838
Vilanova E, Sogorb MA. 1999. The role of phosphotriesterases in the detoxication of organophosphorus compounds. Crit Rev Toxicol 29(1):21–57.10066159
Voccia I, Blakley B, Brousseau P, . 1999. Immunotoxicity of pesticides: a review. Toxicol Ind Health 15:119–132.10188195
Wade MJ. 1979. Organophosphorus pesticides in the marine environment: Their transport and fate. Dissertation Abstracts International 40:4704.
*Ware GW, Morgan DP, Estesen BJ, . 1973. Establishment of reentry intervals for organophosphate-treated cotton fields based on human data. I. Ethyl- and methyl parathion. Arch Environ Contam Toxicol 1:48–59.4775398
*Ware GW, Morgan DP, Estesen BJ, . 1974. Establishment of reentry intervals for organophosphate-treated cotton fields based on human data. II. Asodrin, ethyl and methyl parathion. Arch Environ Contam Toxicol 2:117–129.4851905
*Ware GW, Morgan DP, Estesen BJ, . 1975. Establishment of reentry intervals for organophosphate-treated cotton fields based on human data. III. 12 to 17 hours post-treatment to monocrotophos, ethyl- and methyl parathion. Arch Environ Contam Toxicol 3:289–306.1190841
*Waters MD, Sandhu SS, Simon VF, . 1982. Study of pesticide genotoxicity. Basic Life Sci 21:275–326.7150196
Waters MD, Stack HF, Jackson MA, . 1994. The performance of short-term tests in identifying potential germ cell mutagens: A qualitative and quantitative analysis. Mutat Res 341:109–131.7527489
*Wauchope RD, Leonard RA. 1980. Maximum pesticide concentrations in agricultural runoff: A semiempirical prediction formula. J Environ Qual 9:665–672.
Weinbaum Z, Schenker MB, O’Malley MA, . 1995. Determinants of disability in illnesses related to agricultural use of organophosphates (OPs) in California. Am J Ind Med 28:257–274.8585522
*Weir RJ, Hazleton LW. 1981. Patty’s industrial hygiene and toxicology. Vol. 2C, 3rd ed. New York, NY: John Wiley & Sons, 4826.
*Weiss G, ed. 1986. Hazardous chemicals data book. 2nd ed. Park Ridge, NJ: Noyes Data Corporation, 687.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Whittier JB, McBee K. 1999. Use of flow cytometry to detect genetic damage in mallards dosed with mutagens. Environ Toxicol Chem 18(7):1557–1563.
WHO. 1976. 1975 Evaluations of some pesticide residues in food. World Health Organization Pesticide Residue Series., No. 5. Geneva, Switzerland: World Health Organization, 242–255.
*WHO. 2001. Methyl parathion. World Health Organization. Environmental Health Criteria, No. 145. Http://www.who.int/dsa/cat97/zehc2.html. January 17, 2001.
Wiaderkiewicz R, Walter Z, Reimschussel W. 1986. Sites of methylation of DNA bases by the action of organophosphorus insecticides in vitro. Acta Biochim Pol 33:73–85.3766014
*Wicker GW, Williams WA, Guthrie FE. 1979. Exposure of field workers to organophosphorus insecticides: Sweet corn and peaches. Arch Environ Contam Toxicol 8:175–182.539831
*Widdowson EM, Dickerson JWT. 1964. Chapter 17: Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York, NY: Academic Press.
*Williams MW, Fuyat HN, Fitzhugh OG. 1959. The subacute toxicity of four organic phosphates to dogs. Toxicology 1:1–7.
Williams WM, Holden PW, Parsons DW, . 1988. Pesticides in groundwater data base: 1988 interim report. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs. NTIS PB89 164230 AS.
Willis GH, McDowell LL. 1982. Pesticides in agricultural runoff and their effects on downstream water quality. Environ Toxicol Chem 1:267–279.
Willis GH, McDowell LL. 1987. Pesticide persistence on foliage. Rev Environ Contam Toxicol 100:23–73.
Willis WO, de Peyster A, Molgaard CA, . 1993. Pregnancy outcome among women exposed to pesticides through work or residence in an agricultural area. J Occup Med 35:943–949.8229348
*Wills JH. 1972. The measurement and significance of changes in the cholinesterase of erythrocytes and plasma. CRC Crit Rev Toxicol 153–202.
Wilson BW, Sanborn JR, O’Malley MA, . 1997. Monitoring the pesticide-exposed worker. Occup Med 12:347–363.9220490
*Winterlin W, Seiber JN, Craigmill A, . 1989. Degradation of pesticide waste taken from a highly contaminated soil evaporation pit in California. Arch Environ Contam Toxicol 18:734–747.
*Wisconsin DNR. 2001. Draft working list: September 2000 NR 445 chemicals list. Http://www.dnr.state.wi.us/scripts/. February 2001.
Wolfe NL. 1980. Organophosphate and organophosphorothionate esters: Application of linear free energy relationships to estimate hydrolysis rate constants for use in environmental fate assessment. Chemosphere 9:571–579.
Wolfe NL, Kitchens BE, Macalady DL, . 1986. Physical and chemical factors that influence the anaerobic degradation of methyl parathion in sediment systems. Environ Toxicol Chem 5:1019–26.
Wolff MS, McConnell R, Cedillo L, . 1992. Dermal levels of methyl-parathion, organochlorine pesticides, and acetylcholinesterase among formulators. Bull Environ Contam Toxicol 48:671–678.1380351
*Worthing CR, ed. 1979. The pesticide manual—A world compendium. 6th ed. Croyton, UK: British Crop Protection Council, 402.
Xamena N, Velazquez A, Batiste-Alentorn M, . 1988. Genotoxicity studies with four organophosphorus insecticides using the unstable white-zeste system of drosophila melanogaster. Mutat Res 204:251–256.3125427
*Yamamoto T, Egashira T, Yoshida T, . 1982. Comparison of the effect of an equimolar and low dose of fenitrothion and methylparathion on their own metabolism in rat liver. J Toxicol Sci 7:35–41.
Yamamoto T, Egashira T, Yoshida T, . 1983. Comparative metabolism of fenitrothion and methylparathion in male rats. Acta Pharmacol Toxicol 53:96–102.
Yess NJ. 1992. Residue monitoring 1991. J Assoc Off Anal Chem 75:135A–157A.
*Yess N, Gunderson E, Roy R. 1993. U.S. Food and Drug Administration monitoring of pesticide residues in infant foods and adult foods eaten by infants/children. J Assoc Off Anal Chem 76(3):492–507.
*Youssef SHA, El-Sayed MGA, Atef M. 1987. Influence of gentamicin and rifamycin on toxicity and biotransformation of methyl parathion in rats. Dtsch Tierarztl Wochenschr 94:203–205.3297603
Yu YD, Jia YC, Hong CF, . 1984. Studies on the mutagenicity and teratogenicity of methyl parathion. I. Mutation, cancer, and malformation. Environ Sci Res 31:842–843.
Zahm SH, Ward MH. 1998. Pesticides and childhood cancer. Environ Health Perspect Suppl 106(Supplement 3):893–908.9646054
Zahm SH, Ward MH, Blair A. 1997. Pesticides and cancer. Occup Med 12:269–289.9220486
*Zhang HX, Sultatos LG. 1991. Biotransformation of the organophosphorus insecticides parathion and methyl parathion in male and female rat livers perfused in situ. Drug Metab Dispos 19:473–477.1676657
*Ziegler EE, Edwards BB, Jensen RL . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zlateva M, Maleva E. 1978. [Late morphologic changes in the myocardium of experimental animals after chronic Wofatox poisoning]. Eksp Med Morfol (Bul) 17:99–103 [CA 89(25)211020V]. (Russian)