# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding methyl parathion in air, water, and other media are summarized in Table 8-1.

Methyl parathion is a restricted-use pesticide (EPA 1985b, 1999a). Methyl parathion formulations must be used under the direct supervision of a certified pesticide applicator (EPA 1980b). The certified pesticide applicator must be physically present during mixing, loading, application, equipment repair, and equipment cleaning (NPIRS 1986). Originally, no worker was allowed to enter a field treated with methyl parathion less than 48 hours after the treatment (EPA 1980b); that interval has been increased to 4–5 days (EPA 1999d). Methyl parathion is not registered for use by homeowners or for use indoors.

EPA (1999d, 1999e) has canceled many food crop uses of methyl parathion, including uses on fruits and vegetables commonly eaten by children (apples, peaches, pears, grapes, nectarines, cherries, plums, carrots, succulent peas and beans, and tomatoes) and some other vegetables, and some nonfood uses such as ornamental plants and nursery stock uses. Pesticide tolerances on these food crops also have been canceled for methyl parathion (EPA 2001). The cancellations occurred because of a concern for risks to children and workers. Existing stocks of methyl parathion products with canceled crop uses were allowed to be applied through December 31, 1999 (EPA 1999d). As listed in Table 8-1, tolerances have been retained for a large number of raw agricultural commodities (EPA 2001).

ATSDR has derived an intermediate-duration oral MRL of .0007 mg/kg/day for methyl parathion based on a minimal LOAEL of 0.22 mg/kg/day for electrophysiological effects in the central and peripheral nervous systems in rats (Desi et al. 1998).

ATSDR has derived a chronic-duration oral MRL of .0003 mg/kg/day for methyl parathion based on a NOAEL of 0.025 mg/kg/day for reduced hematocrit and erythrocyte counts in rats (Suba 1984).

EPA has derived an RfD of .00025 mg/kg/day, based on a NOAEL of 0.025 for reduced hematocrit, erythrocyte counts, and hemoglobin (cholinesterase inhibition was also listed as a critical effect but the reason for this was not explained). This NOAEL appears to be from the same study as for the ATSDR chronic-duration oral MRL, although the study is referenced differently (IRIS 2001).

Table 8-1 Regulations and Guidelines Applicable to Methyl Parathion

Agency | Description | Information | References
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenic classification | Group 3^a^ | IARC 2001
WHO | No evidence of carcinogenicity | | WHO 2001
[underlined: NATIONAL]
Regulations and guidelines:
a. Air
ACGIH | TLV–TWA^b^ | 0.2 mg/m^3^ | ACGIH 2000
NIOSH | REL^b^ | 0.2 mg/m^3^ | NIOSH 2001
OSHA | PEL (8-hour TWA)^b^ | 0.2 mg/m^3^ | OSHA 2001
b. Water
EPA | 1-Day health advisory (10-kg child) | 0.3 mg/L | EPA 2000a
EPA | 10-Day health advisory (10-kg child) | 0.3 mg/L | EPA 2000a
EPA | Lifetime health advisory | 2x10^-3^ mg/L | EPA 2000a
EPA | DWEL | 9x10^-3^ mg/L | EPA 2000a
c. Food
EPA | Revocation of tolerances for fruits and vegetables commonly eaten by children, and other vegetables | | EPA 1999e
EPA | Establishment/retention of tolerances for residues in or on raw agricultural commodities in food crops (ppm) | | EPA 2001
EPA | Almonds | 0.1 | EPA 2001
EPA | Apricots | 1.0 | EPA 2001
EPA | Avocados | 1.0 | EPA 2001
EPA | Barley | 1.0 | EPA 2001
EPA | Beans (dried) | 1.0 | EPA 2001
EPA | Beets (sugar), including tops | 0.1 | EPA 2001
EPA | Blackberries | 1.0 | EPA 2001
EPA | Blueberries | 1.0 | EPA 2001
EPA | Boysenberries | 1.0 | EPA 2001
EPA | Cabbage | 1.0 | EPA 2001
EPA | Clover | 1.0 | EPA 2001
EPA | Corn | 1.0 | EPA 2001
EPA | Cottonseed | 0.75 | EPA 2001
EPA | Cranberries | 1.0 | EPA 2001
EPA | Cucumbers | 1.0 | EPA 2001
EPA | Currants | 1.0 | EPA 2001
EPA | Dates | 1.0 | EPA 2001
EPA | Dewberries | 1.0 | EPA 2001
EPA | Eggplants | 1.0 | EPA 2001
EPA | Endive (escarole) | 1.0 | EPA 2001
EPA | Figs | 1.0 | EPA 2001
EPA | Filberts | 0.1 | EPA 2001
EPA | Garlic | 1.0 | EPA 2001
EPA | Gooseberries | 1.0 | EPA 2001
EPA | Guavas | 1.0 | EPA 2001
EPA | Hops | 1.0 | EPA 2001
EPA | Mangoes | 1.0 | EPA 2001
EPA | Melons | 1.0 | EPA 2001
EPA | Mustard seed | 0.2 | EPA 2001
EPA | Oats | 1.0 | EPA 2001
EPA | Okra | 1.0 | EPA 2001
EPA | Olives | 1.0 | EPA 2001
EPA | Onions | 1.0 | EPA 2001
EPA | Parsley | 1.0 | EPA 2001
EPA | Parsnips | 1.0 | EPA 2001
EPA | Parsnip greens | 1.0 | EPA 2001
EPA | Peanuts | 1.0 | EPA 2001
EPA | Peas (dried) | 1.0 | EPA 2001
EPA | Pecans | 0.1 | EPA 2001
EPA | Peppers | 1.0 | EPA 2001
EPA | Pineapple | 1.0 | EPA 2001
EPA | Potatoes | 0.1 | EPA 2001
EPA | Pumpkins | 1.0 | EPA 2001
EPA | Quinces | 1.0 | EPA 2001
EPA | Radishes (with or without tops) | 1.0 | EPA 2001
EPA | Rape (canola) seed | 0.2 | EPA 2001
EPA | Raspberries | 1.0 | EPA 2001
EPA | Rice | 1.0 | EPA 2001
EPA | Safflower seed | 0.1 | EPA 2001
EPA | Sorghum | 0.1 | EPA 2001
EPA | Soybeans | 0.1 | EPA 2001
EPA | Squash | 1.0 | EPA 2001
EPA | Strawberries | 1.0 | EPA 2001
EPA | Summer squash | 1.0 | EPA 2001
EPA | Sunflower seeds | 0.2 | EPA 2001
EPA | Sweet potatoes | 0.1 | EPA 2001
EPA | Swiss chard | 1.0 | EPA 2001
EPA | Walnuts | 0.1 | EPA 2001
EPA | Wheat | 1.0 | EPA 2001
EPA | Youngberries | 1.0 | EPA 2001
d. Other
ACGIH | Carcinogenic classification | A4^c^ | ACGIH 2000
EPA | RfD | 2.5x10^-4^ mg/kg/day | IRIS 2001
EPA | Carcinogenic classification | Group D^d^ | EPA 2000a
EPA | Designated hazardous substance in accordance with Section 311(b)(2)(a) | | EPA 2000b; 40CFR116.4
EPA | Pesticide chemicals manufacturing discharges | | EPA 2000c; 40CFR455.20
EPA | RCRA—identification and listing as a hazardous waste | P071 | EPA 2000d; 40CFR261.33
EPA | CERCLA—reportable quantity | 100 pounds | EPA 1999f; 40CFR302.4
EPA | Toxic chemical release reporting; Community Right-to-Know—effective date | 01/01/95 | EPA 1999g; 40CFR372.65
[underlined: STATE]
Regulations and guidelines:
a. Air:
Arkansas | Hazardous Air Pollutant | | ADEQ 2001
Arkansas | RAC | 0.3 µg/m^3^ | BNA 2001
California | RAC | 0.3 µg/m^3^ | BNA 2001
California | Toxic Air Contaminant | | California EPA 2001
Colorado | Hazardous air pollutant | | BNA 2001
Colorado | 8 hour | 4 µg/m^3^ | BNA 2001
Colorado | 30 minutes | 20 µg/m^3^ | BNA 2001
Delaware | RAC | 0.3 µg/m^3^ | BNA 2001
Idaho | Toxic air pollutants | | BNA 2001
Idaho | OEL | 0.2 mg/m^3^ | BNA 2001
Idaho | EL | 0.013 pounds/hour | BNA 2001
Idaho | AAC | 0.01 mg/m^3^ | BNA 2001
Illinois | RAC | 0.3 µg/m^3^ | BNA 2001
Kentucky | RAC | 0.3 µg/m^3^ | BNA 2001
New Hampshire | Regulated toxic air contaminant | | BNA 2001
New Hampshire | OEL | 0.2 mg/m^3^ | BNA 2001
South Carolina | RAC | 0.3 µg/m^3^ | BNA 2001
Tennessee | RAC | 0.3 µg/m^3^ | BNA 2001
Wisconsin | Proposed threshold | | Wisconsin DNR 2001
Wisconsin | 24 hour<25 feet (pounds/hour) | 0.0107 | Wisconsin DNR 2001
Wisconsin | 24 hour•25 feet<75 feet (pounds/hour) | 0.0417 | Wisconsin DNR 2001
Wisconsin | 24 hour•75 feet (pounds/hour) | 0.324 | Wisconsin DNR 2001
Wisconsin | AAC | 4.8 µg/L | Wisconsin DNR 2001
Wyoming | RAC | 0.3 µg/m^3^ | BNA 2001
b. Water:
Arizona | Drinking water guideline | 1.8 µg/L | HSDB 2001
California | Drinking water guideline | 30 µg/L | HSDB 2001
Florida | Drinking water guideline | 10 µg/L | HSDB 2001
Kentucky | Hazardous constituent for groundwater monitoring | | BNA 2001
Maine | Drinking water guideline | 2 µg/L | HSDB 2001
Vermont | Enforcement standard | 2.0 µg/L | BNA 2001
Vermont | Preventive action level | 1.0 µg/L | BNA 2001
c. Food: | | No data
d. Other:
Arizona | Soil remediation level | | BNA 2001
Arizona | Residential | 16.0 mg/kg | BNA 2001
Arizona | Non-residential | 170 mg/kg | BNA 2001
Massachusetts | RfD | 2.5x10^-4^ mg/kg/day | BNA 2001
Missouri | Hazardous constituent | | BNA 2001
New Jersey | Requires field posting | | CDC 2001
Ohio | Extremely hazardous substance | | Ohio EPA 2001

a Group 3: not classifiable as to its carcinogenicity to humans

b Skin notation: danger of cutaneous absorption

c A4: not classifiable as a human carcinogen

d Group D: inadequate or no human or animal evidence of carcinogenicity

AAC = acceptable ambient concentration; ACGIH = American Conference of Governmental Industrial Hygienists; ADEQ = Arizona Department of Environmental Quality; BNA = Bureau of National Affairs; CDC = Center for Disease Control; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DNR = Department of Natural Resources; DWEL = drinking water equivalent level; EL = emissions level; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; NIOSH = National Institute of Occupational Safety and Health; OEL = occupational exposure limit; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; RAC = reference air concentration; REL = recommended exposure limit; RCRA = Resource Conservation and Recovery Act; RfD = reference dose; TLV = threshold limit value; TWA = time-weighted average; WHO = World Health Organization