# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

The chemical identity of methyl parathion is shown in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of methyl parathion are summarized in Table 4-2.

Table 4-1 Chemical Identity of Methyl Parathion

Characteristic | Value | Reference
Chemical name | Methyl parathion | Budavari 1989
Synonyms | Dimethyl 4-nitrophenyl phosphorothioate; dimethyl p-nitrophenyl phosphorothioate; dimethyl p-nitrophenyl thiophosphate; dimethyl parathion; O,O-dimethyl O-(p-nitrophenyl) phosphorothioate | HSDB 1999
Trade names | A-Gro; Metaphos; Bay 11405; Bladan-M; Cekumethion; Dalf; Devithion; Drexel Methyl Parathion 4E; ENT 17,292; Floidal M; Gearphos; M40 & 80; ME-Parathion | IARC 1983; NPIRS 1986; RTECS 1989
Manufacture trade names | Paratox; Bladan; Metacide; Morphos; Frog; Parataf; Romethyl-P; Prompt; Sweeper; Fortune-P1; Silmepar; Metpar; Paramet; Foxy | Meister et al. 1999
Formulators’ trade names | Amithion; Agrodol; Paration Metilico 500 or 720; Agro-Parathion; Vitamethion; Cekmethion; Devithion; Dhanudol; Penncap-M; Bration; Methion; Kikdot; Parathol; Woprophos-M; Parasul; Gearphos; Kilex Parathion; Metaphos; Patron M; Tekwaisa | Meister et al. 1999
Discontinued names | Paraton; Wofatox; Veto; Fosferna M50; Nitrox 80; Parapest M050; Sytemp | Meister et al. 1999
Chemical formula | C_8_H_10_NO_5_PS | Budavari 1989
Chemical structure | [image] | Budavari 1989
Identification numbers:
CAS registry | 298-00-0 | HSDB 1999
NIOSH RTECS | TG0175000 | HSDB 1999
EPA hazardous waste | P071 | HSDB 1999
OHM/TADS | 7216537 | HSDB 1999
DOT/UN/NA/IMCO shipping | Methyl parathion, liquid (DOT); Methyl parathion mixture, dry (DOT); methyl parathion, solid (DOT); UN 3017; organophosphorus pesticides, liquid, toxic, flammable, not otherwise specified | HSDB 1999; RTECS 1989
HSDB | NA 2783 (DOT) | HSDB 1999
NCI | 1168 | RTECS 1989
NCI | NCI-C02971 | HSDB 1999

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data Systems; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Methyl Parathion

Property | Information | Reference
Molecular weight | 263.23 | Budavari 1989
Color | White solid (pure) or brownish liquid (technical) | Weiss 1986
Physical state | Solid (crystals from cold methanol) | Budavari 1989
Physical state | Solid | Weiss 1986
Melting point | 37–38 °C | Budavari 1989
Boiling point | 154 °C at 136 Pa | HSDB 1999
Boiling point | Decomposes above ambient temperature
Boiling point | Decomposes violently at 120 °C | Keith and Walters 1985
Density at 20 °C | 1.358 g/mL | Budavari 1989
Odor | Characteristic, like rotten eggs or garlic | Keith and Walters 1985; Weiss 1986
Odor threshold:
Water | No data
Air | 0.012 ppm | Ruth 1986
Solubility:
Water at 25 °C | 50 ppm | Budavari 1989
Organic solvents | Soluble in ethanol, chloroform, and aromatic and aliphatic solvents | Sunshine 1969
Organic solvents | ≤10 mg/mL (at 23 °C) in DMSO and ethanol; very soluble in acetone | Keith and Walters 1985
Organic solvents | Sparingly soluble in petroleum ether and some types of mineral oil | Tomlin 1994
Partition coefficients:
Log octanol/water (K_ow_) | 2.86 | Hansch et al. 1995
Log K_oc_ | 2.7 | EPA 1980c
Vapor pressure at 20 °C | 9.7x10^-6^ mm Hg | Keith and Walters 1985
Henry’s law constant | 6.2x10^-6^ atm m^3^/mol | Sanders and Seiber 1983
Henry’s law constant | 4.4x10^-7^ atm m^3^/mol | Mackay and Shiu 1981
Autoignition temperature | No data
Flashpoint | 31.9 °C (open cup) | NFPA 1986
Flammability limits | No data
Conversion factors | 1 ppm = 10.8 mg/m^3^
Explosive limits | May develop sufficient internal pressure at ambient temperature to cause a container to rupture violently | NFPA 1986
Explosive limits | Explosion risk when heated | Hawley 1987

DMSO = dimethylsulfoxide