# APPENDIX A ATSDR MINIMAL RISK LEVEL AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## Methyl parathion Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methyl parathion
CAS Number: | 298-00-0
Date: | June 22, 2001
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to Figure: | 32
Species: | Rats

[underlined: Minimal Risk Level]: 0.0007 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: Desi I, Nagymajtenyi L, Papp A, . 1998. Experimental model studies of pesticide exposure. Neurotoxicology 19:611–616.9745919

[underlined: Experimental design] (human study details or strain, number of animals per exposure/control groups, sex, dose administration details): Male rats were treated with methyl parathion in an aqueous vehicle through gavage administration to their dams during days 5–15 of gestation and days 2–28 of lactation at doses of 0.22, 0.44, or 0.88 mg/kg/day, followed by direct treatment of the male offspring in the same manner for 8 weeks, from weaning through 11–12 weeks of age. Electrophysiological testing was performed on the male offspring at the end of the treatment period.

[underlined: Effects noted in study and corresponding concentrations]: Dose-related changes on electrocorticograms of the somatosensory, visual, and auditory centers, on evoked potentials, and on tail nerve conduction velocity and refractory period were observed in the male offspring (Desi et al. 1998). The results were stated to be significantly different from controls at all three dose levels, but results specifically for methyl parathion were shown only for the electrocorticograms of the somatosensory area. No overt signs of toxicity or effects on body weight were seen in the male offspring.

In the same study (Desi et al. 1998), no significant effects on these end points were seen in male rats exposed to methyl parathion only through the treatment of their dams during gestation or during gestation and lactation, and then maintained without treatment until testing at 11–12 weeks of age.

[underlined: Concentration and end point used for MRL derivation]: 0.22 mg/kg/day; electrophysiological effects in the central and peripheral nervous systems

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent][underlined: concentration:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] NA

[underlined: Other additional studies or pertinent information that lend support to this MRL:] Methyl parathion affects the nervous system by inhibiting acetylcholinesterase activity. Cholinesterase inhibition and neurological effects have been observed in humans and animals, for all exposure routes and durations (for example, Dean et al. 1984; Desi et al. 1998; EPA 1978e; Gupta et al. 1985; Nemec et al. 1968; Suba 1984).

[underlined: Agency Contact (Chemical Manager):] Jewell D. Wilson, Ph.D.

## Methyl parathion Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methyl parathion
CAS Number: | 298-00-0
Date: | June 22, 2001
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Key to Figure: | 38
Species: | Rats

[underlined: Minimal Risk Level]: 0.0003 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: Suba, LA. 1984. Additional information to support the registration of methyl parathion: Two year chronic feeding study of methyl parathion in rats. St. Louis, MO: Monsanto Agricultural Products Company.

[underlined: Experimental design] (human study details or strain, number of animals per exposure/control groups, sex, dose administration details): Sprague-Dawley CD rats (60/sex/dose) were fed methyl parathion at dietary concentrations of 0, 0.5, 5, or 50 ppm (0, 0.025, 0.25, or 2.5 mg/kg/day) for 26 months (males) or 28 months (females). Animals were observed twice daily for clinical signs and weighed weekly. Hematological and clinical chemistry, and urinalysis determinations were performed at 6, 12, 18, and 24 months and at study termination. Five rats/sex/group were killed at approximately 24 months for examination of the brain, spinal cord and sciatic nerves. Complete necropsies and histopathological examinations of a wide range of organs and tissues were performed.

[underlined: Effects noted in study and corresponding concentrations]: No adverse effects were observed in the low-dose male and female rats. Mean hemoglobin, hematocrit, and erythrocyte counts were significantly reduced in the high-dose females at 6–24 months of treatment; mean hematocrit and erythrocyte counts were significantly reduced in the mid- and high-dose males at 24 months of treatment.

Abnormal gait involving the hind legs was observed in 1 mid-dose female from week 77 until termination, in 4–14 of the high-dose female rats from week 19 to termination, and in 1 high-dose male around the beginning of the second year. Slight tremor was noted during the first 3 weeks to 4 months of treatment in both sexes of the high-dose group. Peripheral neuropathy of the proximal and distal sciatic nerve was considered to be related to exposure to methyl parathion at the high dose. Methyl parathion did not induce histopathological effects in the brain or spinal cord. Statistical significance was not reported for these clinical signs and histopathological effects. Mean plasma, erythrocyte, and brain cholinesterase activities were significantly reduced by 67–88, 9–20, and 76–79%, respectively, in rats of both sexes following 2-year exposures only at the high dose of methyl parathion.

Additional effects, which occurred only at the high dose, were retinal degeneration or atrophy and posterior subcapsular cataracts in the females. Slightly reduced body weights occurred in both sexes at the high dose at 2 years, but not consistently throughout the study, and food consumption was slightly elevated in the high-dose females.

[underlined: Concentration and end point used for MRL derivation]: 0.025 mg/kg/day; decreased mean hematocrit and erythrocyte counts

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Yes. A chronic food factor of 0.05 kg feed/kg body weight/day for rats was used to convert from ppm in food to mg/kg as follows: 0.5 ppm x 0.05 = 0.025 mg/kg/day. (Data regarding body weight and food consumption were not available.) This is the food factor used in the original MRL derivation.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent][underlined: concentration:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] NA

[underlined: Other additional studies or pertinent information that lend support to this MRL:] An intermediate-duration gavage study in rats found decreased hematocrit and erythrocyte counts relative to before-treatment values (Galal et al. 1977), but this study had some limitations, including lack of a control group and disparities between text and tables. Another intermediate duration gavage study in male rats demonstrated dose-related significant decreases in mean corpuscular volume (Undeger et al. 2000). An effect on the erythrocyte is plausible because erythrocyte cholinesterase has a function in the control of erythrocyte permeability (Wills 1972).

[underlined: Agency Contact (Chemical Manager):] Jewell D. Wilson, Ph.D.