# 7 REGULATIONS AND ADVISORIES

Because of its potential to cause adverse health effects in exposed people, a number of regulations and guidelines have been established for methyl mercaptan by various national and state agencies. These values are summarized in Table 7-1.

TABLE 7-1 Regulations and Guidelines Applicable to Methyl Mercaptan

Agency | Description | Information | Reference
[underlined: NATIONAL]
Regulations:
a. Air:
OSHA | PEL TWA | 0.5 ppm (1 mg/m^3^) | OSHA 1989 (29 CFR 1910.1000) Table Z-l-A
b. Water:
EPA OWRS | General permits under NPDES | Yes | 40 CFR 122, Appendix D, Table V
EPA OWRS | Hazardous substance Reportable quantity | 100 lbs | 40 CFR 116 40 CFR 117.3
c. Nonspecific media:
EPA OERR | Reportable quantity | 100 lbs | EPA 1989a (40 CFR 302.4)
EPA OERR | Extremely hazardous substance TPQ | 500 lbs | EPA 1987a (40 CFR 355)
EPA OSW | Hazardous waste constituent (Appendix VIII) | Yes | 40 CFR 261
EPA OSW | Land disposal restrictions (proposed) | Yes | EPA 1989c (40 CFR 264, 268)
FDA | Food additive - synthetic flavoring substance | Yes | 21 CFR 172.515
Guidelines:
a. Air:
ACGIH | TLV TWA | 0.5 ppm (1 mg/m^3^) | ACGIH 1986
NIOSH | IDLH | 400 ppm | NIOSH 1985
NIOSH | CEILING (15 min) | 0.5 ppm
[underlined: STATE]
Regulations:
a. Air: | Acceptable ambient air concentration | | NATICH 1989
New York | | 3.30 μg/m^3^ (1 yr)
Virginia | | 16.0 μg/m^3^ (24 hr)
North Dakota | Maximum Acceptable Ambient Level | 10 μg/m^3^ | Rydell 1990

ACGIH = American Conference of Governmental Industrial Hygienists; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IDLH = Immediately Dangerous to Life or Health Level; NIOSH = National Institute for Occupational Safety and Health; NPDES = National Pollutant Discharge Elimination System; OERR = Office of Emergency and Remedial Response; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Wastes; OWRS = Office of Water Regulations and Standards; PEL = Permissible Exposure Limit; TLV = Threshold Limit Value; TPQ = Threshold Planning Quantity; TWA = Time-Weighted Average