# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Common synonyms, trade names, and other pertinent identification information for methyl mercaptan are listed in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Important physical and chemical properties of methyl mercaptan are listed in Table 3-2.

TABLE 3-1 Chemical Identity of Methyl Mercaptan

Characteristic | Information | Reference
Chemical name | Methyl mercaptan | Windholz 1983
Synonyms | Methanethiol; thiomethyl alcohol; methyl sulfhydrate; mercaptomethane; thiomethanol | HSDB 1989; Windholz 1983
Trade names | No data
Chemical formula | CH_4_S | Windholz 1983
Chemical structure | [image]
Identification numbers:
CAS Registry | 74-93-1 | Sax and Lewis 1987
NIOSH RTECS | PB4375000 | HSDB 1989
EPA Hazardous Waste | U153 | NLM 1989
OHM/TADS | No data
DOT/UN/NA/IMCO Shipping | UN 1064 | NLM 1989
DOT/UN/NA/IMCO Shipping | IMCO 2.0 | HSDB 1989
HSDB | 813 | NLM 1989
NCI | No data

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of Methyl Mercaptan

Property | Information | Reference
Molecular weight | 48.11 | Windholz 1983
Color | Colorless | Verschueren 1983
Physical state | Gas | Verschueren 1983
Melting point | −123.1 °C | Verschueren 1983
Boiling point | 5.95 °C | Windholz 1983
Density at 20°C | 0.8665 | Windholz 1983
Odor | Rotten cabbage | Windholz 1983
Odor threshold:
Water | 0.000024 mg/L | Amoore and Hautala 1983
Air | 0.0016 ppm | Amoore and Hautala 1983
Solubility:
Water at 20°C | 23.3 g/L | Windholz 1983
Water at 25°C | 15.39 g/L | Hine and Mookerjee 1975
Organic solvents | Soluble in alcohol, ether, petroleum, naphtha | Sax and Lewis 1987
Partition coefficients:
Log K_ow_ | No data
Log K_oc_ | No data
Vapor Pressure at 25°C | 1,500 mmHg | EPA 1983
pKa | No data
Henry’s law constant | 3.85×10^−3^ atm-m^3^/mol | EPA 1983
Autoignition temperature | No data
Flashpoint | 0°F (= −18 °C) (open cup) | HSDB 1989
Flammability limits | No data
Conversion factors | 1 ppm = 2.05 mg/m^3^; 1 mg/m^3^ = 0.488 ppm | Verschueren 1983
Explosive limits | 3.9%–21.8% | Sax and Lewis 1987