# APPENDIX C PEER REVIEW

A peer review panel was assembled for methyl mercaptan. The panel consisted of the following members: Dr. Sharon Johnson, Visiting Scientist, Department of Biology, Johns Hopkins University; Dr. Derek Hodgson, Chairman, Department of Chemistry, University of Wyoming; Dr. Shane Que Hee, Associate Professor, School of Public Health, University of California. These experts collectively have knowledge of methyl mercaptan’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(i)(13) of the Comprehensive Environmental Response, Compensation, and Liability, as amended.

A joint panel of scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) and the Environmental Protection Agency has reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.