# 8 REFERENCES

* Cited in text

Abelson PH. 1993. Health risk assessment. Regul Toxicol Pharmacol 17:219–223.8484029
*ACGIH. 1986. Methylene chloride. Documentation of the threshold limit values and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 1990. Methylene chloride. Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 1998. Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH 1999. Methylene chloride. Documentation of the threshold limit values and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*AK Dept Env Conserv. 1999. Drinking water. Alaska Department of Environmental Conservation. Rule 18 AAC 80. http://www.state.ak.us/local/akpages/ENV.CONSERV/home.htm
*AL Dept Env Management. 1998. Water quality criteria. Alabama Department of Environmental Management, Water Division. http://www.adem.state.al.us/
*Allen J, Kligerman A, Campbell J, . 1990. Cytogenetic analyses of mice exposed to dichloromethane. Environ Mol Mutagen 15:221–228.2357975
Allen MR, Braithwaite A, Hills CC. 1997. Trace organic compounds in landfill gas at seven U.K. waste disposal sites. Environ Sci Technol 31:1054–1061.
*Altman PK, Dittmer DS. 1974. Biological handbooks: Biology data book, Vol 3. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology 1987–2008, 2041.
*Altshuller AP. 1980. Lifetimes of organic molecules in the troposphere and lower stratosphere. Adv Environ Sci Technol 10:181–219.
*Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
*Anders MW, Sunram JM. 1982. Transplacental passage of dichloromethane and carbon monoxide. Toxicol Lett 12:231–234.7135421
Anders MW, Kubic VL, Ahmed AE. 1977. Metabolism of halogenated methanes and macromolecular binding. J Environ Pathol Toxicol 1:117–124.95415
Andersen ME. 1995. Development of physiologically based pharmacokinetic and physiologically based pharmacodynamic models for applications in toxicology and risk assessment. Toxicol Lett 79:35–44.7570672
*Andersen ME, Krishnan K. 1994. Physiologically based pharmacokinetics and cancer risk assessment. Environ Health Perspect 1:103–108.
*Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharm 87:185–205.
*Andersen ME, Clewell HJ, Gargas ML, . 1991. Physiologically based pharmacokinetic modeling with dichloromethane, its metabolite, carbon monoxide, and blood carboxyhemoglobin in rats and humans. Toxicol Appl Pharmacol 108:14–27.1900959
*Andersen ME, Clewell HJ, Mahle DA, . 1994. Gas uptake studies of deuterium isotope effects on dichloromethane metabolism in female B6C3F1 mice in vivo. Toxicol Appl Pharmacol 128:158–165.8079349
Andersen MW, Maronpot RR. 1993. Methylene chloride-induced turmorigenesis. Carcinogenesis 14:787–788.8504469
Andrae U, Wolff T. 1983. Dichloromethane is not genotoxic in isolated rat hepatocytes. Arch Toxicol 52:287–290.6870541
Angelo MJ, Pritchard AB. 1984. Simulations of methylene chloride pharmacokinetics using a physiologically based model. Regul Toxicol Pharm 4:329–339.
*Angelo MJ, Pritchard AB, Hawkins DR, . 1986a. The pharmacokinetics of dichloromethane. I. Disposition in B6C3F_1_ mice following intravenous and oral administration. Food Chem Toxicol 24:965–974.3096853
*Angelo MJ, Pritchard AB, Hawkins DR, . 1986b. The pharmacokinetics of dichloromethane. II. Disposition in Fischer 344 rats following intravenous and oral administration. Food Chem Toxicol 24(9):975–980.3096854
Antoine SR, DeLeon IR, O’Dell-Smith RM. 1986. Environmentally significant volatile organic pollutants in human blood. Bull Environ Contam Toxicol 36:364–371.3955247
*Anundi H, Lind ML, Friis L, . 1993. High exposures to organic solvents among graffiti removers. Int Arch Occup Environ Health 65:247–251.8144235
*APHA. 1977. Methods of air sampling and analysis. 2nd ed. Washington, DC: American Public Health Association, 894–902.
*APHA. 1989a. Purge and trap capillary-column gas chromatographic method. In: Standard methods for the examination of water and wastewater. 17th ed. Washington, DC: American Public Health Association.
*APHA. 1989b. Purge and trap capillary-column gas chromatographic/mass spectrometric method. In: Standard methods for the examination of water and wastewater. 17th ed. Washington, DC: American Public Health Association.
*APHA. 1998a. Method - 6210B. Standard methods for the evaluations of water and wastewater. 20^th^ ed. Washington, DC: American Public Health Association.
*APHA. 1998b. Method - 6230B. Standard methods for the evaluations of water and wastewater. 20^th^ ed. Washington, DC: American Public Health Association.
Arulgnanendran VRJ, Nirmalakhandan N. 1997. Microbial toxicity in soil medium. Ecotoxicol Environ Saf 39:48–56.
*Ashley DI, Bonin MA, Cardinali FL, . 1994. Blood concentrations of volatile organic compounds in a non occupationally exposed US population and in groups with suspected exposure. Clin Chem 40:1401–1404.8013127
*Åstrand I, Övrum P, Carlsson A. 1975. Exposure to methylene chloride: I. Its concentration in alveolar air and blood during rest and exercise and its metabolism. Scand J Work Environ Health 1:78–94.1226509
*ATSDR. 1989. Agency for Toxic Substances and Disease Registry. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Federal Register 54(174):37618–37634.
*ATSDR. 1990. Methylene chloride toxicity. Case studies in environmental medicine. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services. PB 85-241529.
*ATSDR. 1993. Toxicological profile for methylene chloride. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services. PB 93-182483.
*ATSDR/CDC. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction, Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*Aviado DM, Belej MA. 1974. Toxicity of aerosol propellants on the respiratory and circulatory systems: I. Cardiac arrhythmia in the mouse. Toxicology 2:31–42.4823736
Aviado DM, Zakhari S, Watanabe T. 1977. Methylene chloride. In: Goldberg L, ed. Non-fluorinated propellants and solvents for aerosols. Cleveland, OH: CRC Press, 19–45.
Bader R, Leisinger T. 1994. Isolation and characterization of the Methylophilus sp. strain DM11 gene encoding dichloromethane dehalogenase/glutathione s-transferase. J Bacteriol 176:3466–3473.8206823
*Bahnick DA, Doucette WJ. 1988. Use of molecular connectivity indices to estimate soil sorption coefficients for organic chemicals. Chemosphere 17(9):1703–1715.
*Bakinson MA, Jones RD. 1985. Gassings due to methylene chloride, xylene, toluene, and styrene reported to Her Majesty’s factory inspectorate 1961-80. Br J Ind Med 42:184–190.3970884
*Ballantyne B, Gazzard MF, Swanson DW. 1976. Ophthalmic toxicology of dichloromethane. Toxicology 6:173–187.61632
Balmer FM, Smith FA, Leach LJ, . 1972. Effects in the liver of methylene chloride inhaled alone and with ethyl alcohol. Am Ind Hyg Assoc J 37:345–352.
Balogh S, Onayiga R, Edblad D. 1998. Evaluation of an automatic composite sampler for volatile organic compounds in raw wastewater. J Air Waste Manage Assoc 48:271–275.
Banerjee S, Howard PH. 1988. Improved estimation of solubility and partitioning through correction of UNIFAC-derived activity coefficients. Environ Sci Technol 22:839–841.22195671
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Barrowcliff DF, Knell AJ. 1979. Cerebral damage due to endogenous chronic carbon monoxide poisoning caused by exposure to methylene chloride. J Soc Occup Med 29:12–14.423541
*Bell BP, Franks P, Hildreth N, . 1991. Methylene chloride exposure and birthweight in Monroe County, New York. Environ Res 55:31–39.1855488
Bell DA, Taylor JA, Paulson DF, . 1993. Genetic risk and carcinogen exposure: A common inherited defect of the carcinogen-metabolism gene glutathione S-transferase M1 (GSTM1) that increases susceptibility to bladder cancer. J Natl Cancer Inst 85:1159–1164.8320745
*Bellar TA, Lichtenberg JJ, Kroner RC. 1974. The occurrence of organohalides in chlorinated drinking waters. J Am Water Works Assoc (December):703–706.
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Berger M, Fodor GG. 1968. CNA disorders under the influence of air mixtures containing dichloromethane. Zentrabl Bakteriol 215:417.
Blancato JN. 1991. Physiologically-based pharmacokinetic models in risk and exposure assessment. Ann Ist Super Sanita 27(4):601–608.1820732
*Blocki FA, Logan MSP, Baoli C, . 1994. Reaction of rat liver glutathione s-transferase and bacterial dichloromethane dehalogenase with dihalomethanes. J Biol Chem 269:8826–8830.8132617
*Bogaards JJP, van Ommen B, van Bladeren PJ. 1993. Interindividual differences in the in vitro conjugation of methylene chloride with glutathione by cytosolic glutathione S-transferase in 22 human liver samples. Biochem Pharmacol 45:2166–2169.8512599
*Bonventre J, Brennan O, Juson D, . 1977. Two deaths following accidental inhalation of dichloromethane and 1,1,1- trichloroethane. J Anal Toxicol 1:158–160.
Borisover MD, Graber ER. 1997. Specific interactions of organic compounds with soil; Organic carbon. Chemosphere 34(8):1761–1776.
*Bornschein RL, Hastings L, Mason JM. 1980. Behavioral toxicity in the offspring of rats following maternal exposure to dichloromethane. Toxicol Appl Pharmacol 52:29–37.7361313
Brack W, Rottler H, Frank H. 1998. Volatile fractions of landfill leachates and their effect on chlamydomonas reinhardtii: in vivo chlorophyll a fluorescence. Environ Toxicol Chem 17(10):1982–1991.
Brewer WE, Galipo RC, Morgan SL, . 1997. The confirmation of volatiles by solid-phase microextraction and GC/MS in the investigation of two traffic fatalities. J Anal Toxicol 21: 286–290.9248946
*Briving C, Hamberger A, Kjellstrand P, . 1986. Chronic effects of dichloromethane on amino acids, glutathione and phosphoethanolamine in gerbil brain. Scand J Work Environ Health 12:216–220.3749836
Brodbelt JS, Cooks RG, Tou JC, . 1987. In vivo mass spectrometric determination of organic compounds in blood with a membrane probe. Anal Chem 59:454–458.3565763
Brodzinski R, Singh HB. 1983. Volatile organic chemicals in the atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Sciences Research Laboratory. EPA-600/S/3-83-027.
Brooke D, Howe P. 1994. Environmental hazard assessment: Dichloromethane. London, England: Toxic Substances Division, Department of the Environment.
*Brown KW, Donnelly KC. 1988. An estimation of the risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Hazardous Waste and Hazardous Materials 5(1):1–30.
*Brown-Woodman PDC, Hayes LC, Huq F, . 1998. In vitro assessment of the effect of halogenated hydrocarbons: chloroform, dichloromethane, and dibromoethane on embryonic development of the rat. Teratology 57:321–333.9664640
*Bruce BW, McMahon PB. 1996. Shallow ground-water quality beneath a major urban center: Denver, Colorado, USA. J Hydrol 186:129–151.
*Brunner WD, Staub D, Leisinger T. 1980. Bacterial degradation of dichloromethane. Appl Environ Microbiol 40(5):950–958.16345659
*Brzezinski MR, Boutelet-Bochan H, Person RE, . 1999. Catalytic and quantitation of cytochrome P-450 2E1 in prenatal human brain. J Pharmacol Exp Ther 289(3):1648–1653.10336564
Budavari S, O’Neil M, Smith A, eds. 1989. The Merck index: An encyclopedia of chemicals drugs and biologicals. 11th ed. Rahway, NJ: Merck and Company, Inc.
*Bukowski JA, Sargent EV, Pena BM. 1992. Evaluation of the utility of a standard history questionnaire in assessing the neurological effects of solvents. Am J Ind Med 22:337–345.
Burek JD, Nitschke KD, Bell TJ, . 1980. Methylene chloride: A two-year inhalation toxicity and oncogenicity study in rats and hamsters. Dow Chemical Company, Health and Environmental Sciences, Toxicology Research Laboratory, Midland, MI.
*Burek JD, Nitschke KD, Bell TJ, . 1984. Methylene chloride: A two-year inhalation toxicity and oncogenicity study in rats and hamsters. Fund Appl Toxicol 4:30–47.
Bus JS, Reitz RH. 1992. Dose-dependent metabolism and dose setting in chronic studies. Toxicol Lett 64/65:669–676.1471221
Butler FE, Coppedge EA, Suggs JC, . 1988. Development of a method for determination of methylene chloride emissions at stationary sources. JAPCA 38:272–277.3379454
Butler R, Solomon IJ, Snelson A. 1978. Rate constants for the reaction of OH with halocarbons in the presence of O_2_ + N_2_. J Air Pollut Control Assoc 28:1131–1133.
Cabbar HC, Varol N, McCoy BJ. 1998. Sorption and diffusion of chlorinated methanes in moist clay. AIChE J 44(6):1351–1355.
*California Environmental Protection Agency. 1992. Health risk assessment of dichloromethane (methylene chloride) in California ground water. California: Lawrence Livermore National Laboratory, U.S. Department of Energy. NTIS no. DE93-018480.
*Callahan MA. 1981. Written communication to Marilyn C. Bracken, Toxic Substances Priorities Committee, regarding the final report of TSPC solvents work group #2. Office of Pesticides and Toxic Substances, U.S. Environmental Protection Agency, Washington, DC.
*Cantor KP, Stewart PA, Brinton LA, . 1995. Occupational exposures and female breast cancer mortality in the United States. J Occ Env Med 37(3):336–348.
*Carlsson A, Hultengren M. 1975. Exposure to methylene chloride: III. Metabolism of ^14^C-labeled methylene chloride in rat. Scand J Work Environ Health 1:104–108.1226505
*Carpenter SP, Lasker JM, Raucy JL. 1996. Expression, induction, and catalytic activity of the ethanol-inducible cytochrome P450 (CYP2E1) in human fetal liver and hepatocytes. Mol Pharmacol 49:260–268.8632758
*Carpenter SP, Savage DD, Schultz ED, . 1997. Etanol-mediated transplantational induction of CYP2E1 in fetal rat liver. J Pharmacol Exp Ther 282:1028–1036.9262372
Casanova M. 1996. Are you a man or a mouse? Regul Toxicol Pharmacol 24:106.8933622
*Casanova M, Deyo DF, Heck HA. 1992. Dichloromethane (Methylene chloride): Metabolism to formaldehyde and formation of DNA-protein cross-links in B6C3F1 mice and Syrian golden hamsters. Toxicol Appl Pharmacol 114:162–165.1585369
*Casanova M, Bell DA, Heck HA. 1997. Dichloromethane metabolism to formaldehyde and reaction of formaldehyde with nucleic acids in hepatocytes of rodents and humans with and without glutathione S-transferase T1 and M1 genes. Fund Appl Toxicol 37:168–180.
*Casanova M, Conolly RB, Heck HA. 1996. DNA-protein crosslinks (DPX) and cell proliferation in B6C3F_1_ mice but not Syrian golden hamsters exposed to dichloromethane: Pharmacokinetics and risk assessment with DPX as dosimeter. Fundam Appl Toxicol 31:103–116.8998946
CCRIS. 1998. Chemical Carcinogenesis Research Information System. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. May 11, 1998.
*C&EN 1996. Production by the U.S. chemical industry. Chemical and Engineering News June 24, 1996.
Chang H-L, Alvarez-Cohen L. 1996. Biodegradation of individual and multiple chlorinated aliphatic hydrocarbons by methane-oxidizing cultures. Appl Environ Microbiol 62(9):3371–3377.8795228
Charnley G. 1992. Cancer dose-response modeling and methylene chloride. In: Zervos C., ed. Oncogene and transgenics correlates of cancer risk assessments. New York, NY: Plenum Press, 231–240.
Chellman GJ, Hurtt ME, Bus JS, . 1987. Role of testicular versus epididymal toxicity in the induction of cytotoxic damage in Fischer-344 rat sperm by methyl chloride. Reprod Toxicol 1:25–35.2980361
Chemical Exposure. 1990. Dialog Information Systems, Inc., Palo Alto, CA. July 19, 1990.
Chemical Regulations and Guidelines. 1990. Dialog Information Systems, Inc., Palo Alto, CA. July 19, 1990.
Chemline. 1990. Chemical dictionary online. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. July 5, 1990.
*Chen C-L, Liu Q, Relling MV. 1996. Simultaneous characterization of glutathione S-transferase M1 and T1 polymorphisms by polymerase chain reaction in American whites and blacks. Parmacogenetics 6:187–191.
*Cherry N, Venables H, Waldron HA, . 1981. Some observations on workers exposed to methylene chloride. Br J Ind Med 38:351–355.7317298
*Cherry N, Venables H, Waldron HA. 1983. The acute behavioral effects of solvent exposure. J Soc Occup Med 33:13–18.6827812
*Ciuchta HP, Savell GM, Spiker RC. 1979. The effect of alcohols and toluene upon methylene chloride-induced carboxyhemoglobin in the rat and monkey. Toxicol Appl Pharmacol 49:347–354.115113
Clewell HJ. 1993. Coupling of computer modeling with in vitro methodologies to reduce animal usage in toxicity testing. Toxicol Lett 68:101–117.8516756
Clewell HJ. 1995. Incorporating biological information in quantitative risk assessment: An example with methylene chloride. Toxicol 102:83–94.
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Clewell HJ, Lee T, Carpenter RL. 1994. Sensitivity of physiologically based pharmacokinetic models to variation in model parameters: Methylene chloride. Risk Anal 14:521–531.7972956
Clewell HJ, Gentry PR, Gearhart JM. 1997. Investigation of the potential impact of benchmark dose and pharmacokinetic modeling in noncancer risk assessment. J Toxicol Environ Health 52:475–515.9397182
*CLPSD. 1990. Contract Laboratory Program Statistical Database. Viar and Company, Management Service Division, Alexandria, VA. July 1990.
Cocco P, Dosemeci M, Gomez MR, . 1994. A retrospective evaluation of exposure to dichloromethane by using a job-exposure matrix. Med Lav 85:84–87.8035750
*Cocco P, Heineman EF, Dosemeci M. 1999. Occupational risk factors for cancer of the central nervous system (CNS) among US women. Am J Ind Med 36:70–74.10361589
Cohen N, Benson SW. 1987. Empirical correlations for rate coefficients for reactions of OH with haloalkanes. J Phys Chem 91:171–175.
*Coleman WE, Lingg RD, Melton RG, . 1976. The occurrence of volatile organics in five drinking water supplies using gas chromatography/mass spectrometry. In: Keith LH, ed. Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science Publishers Inc., 305–327.
Coleman JJ, Blake DR, Rowland FS. 1998. Atmospheric residence time of CH_3_Br estimated from the Junge spatial variability relation. Science 281:392–396.9665878
*Corsi RL, Chang, DPY, Schroeder ED, . 1987. Emissions of volatile and potentially toxic organic compounds from municipal wastewater treatment plants. Proceedings of the 80th annual meeting of the Air Pollution Control Association, New York, NY, June 21-26, 1987.
Cox RA, Denwent RC, Eggleton AEJ, . 1976. Photochemical oxidation of halocarbons in the troposphere. Atmos Environ 10:305–308.
*CPSC. 1987. Labeling of certain household products containing methylene chloride; statement of interpretation and enforcement policy. Consumer Product Safety Commission. Federal Register 52(177):34698–34703.
*CPSC. 1990. Information on methylene chloride containing products; general order for submission. Consumer Product Safety Commission. Federal Register 55(153):32282–32283.
Crebelli R, Benigni R, Franekic J, . 1988. Induction of chromosome malsegregation by halogenated organic solvents in Aspergillus nidulans: Unspecific or specific mechanism? Mutat Res 201:401–411.3050490
CRISP. 1990. Computer Retrieval of Information on Scientific Projects. National Institutes of Health, Division of Research Grants, Bethesda, MD. July 16, 1990.
CRIS/USDA. 1998. Current Research Information System, U.S. Department of Agriculture. Dialog Information Systems, Inc., Palo Alto, CA. May 11, 1998.
Cronn DR, Rasmussen RA, Robinson E. 1977. Report for phase II. Measurement of tropospheric halocarbons by gas chromatography/mass spectrometry. Report to U.S. Environmental Protection Agency.
Cronn DR, Robinson E. 1979. Determination of trace gases in Learjet and U-2 whole-air samples collected during the intertropical convergence zone study. In: Poppoff IG, Page WA, Margozzi AP, eds. Intertropical convergence zone experiment. NASA TMX78577.
*Crutzen PJ, Fishman J. 1977. Average concentrations of OH in the troposphere and the budgets of CH_4_, CO, H_2_ and CH_3_CCl_3_. Geophys Res Lett 4(8):321–324.
*Daft J. 1987. Determining multifumigants in whole grains and legumes, milled and low-fat grain products, spices, citrus fruit, and beverages. J Assoc Off Anal Chem 70(4):734–739.3624185
Daft JL. 1989. Determination of fumigants and related chemicals in fatty and nonfatty foods. J Agric Food Chem 37:560–564.
Dai Y, Rashba-Step J, Cederbaum AI. 1993. Stable expression of human cytochrome P4502E1 in HepG2 cells: Characterization of catalytic activities and production of reactive oxygen intermediates. Biochemistry 32:6928–6937.7687464
*Dankovic DA, Bailer AJ. 1994. The impact of exercise and intersubject variability on dose estimates for dichloromethane derived from a physiologically based pharmacokinetic model. Fundam Appl Toxicol 22:20–25.8125209
DART. 1990. Developmental and Reproductive Toxicology. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. July 6, 1990.
*Davis DD, Machado G, Conaway B, . 1976. A temperature-dependent kinetics study of the reaction of OH with CH_3_Cl, CH_2_Cl_2_, CHCl_3_ and CH_3_. Br J Chem Phys 65:1268–1274.
*Davis EM, Murray HE, Liehr JG, . 1981. Basic microbial degradation rates and chemical byproducts of selected organic compounds. Water Res 15:1125–1127.
*Davis JW, Madsen SS. 1991. The biodegredation of methylene chloride in soils. Environ Toxicol Chem 10:463–474.
*DeJohgn J, Blaauboer BJ. 1996. Simulation of toluene kinetics in the rat by a physiologically based pharmacokinetic model with application of biotransformation parameters derived independently in vitro and in vivo. Fundam Appl Toxicol 32:260–268.8921329
*DeJohgn J, Verhaar HJM, Hermens JLM. 1998. Role of kinetics in acute lethality of nonreactive volatile organic compounds (VOCs). Toxicol Sci 45:26–32.9848107
*DeMarini DM, Shelton ML, Warren SH, . 1997. Glutatione S-transferase-mediated induction of GC AT transitions by halomethanes in Salmonella. Environ Mol Mutagen 30:440–447.9435885
DeMedinilla J, Espigares M. 1988. Contamination by organic solvents in auto paint shops. Ann Occup Hyg 32:509–513.3228264
*d’Errico A, Malats N, Vineis P, . 1999. review of studies of selected metabolic polymorphisms and cancer. In: Vineis P, Malats N, Lang M, . ed. Metabolic polymorphisms and susceptibility to cancer. Lyon, France: International Agency for Research on Cancer, 323–393.
Derwent RG, Jenkin ME, Saunders SM. 1996. Photochemical ozone creation potentials for a large number of reactive hydrocarbons under European conditions. Atmos Environ 30(2):181–199.
*Devereux TR, Foley JF, Maronpot RR, . 1993. Ras proto-oncogene activation in liver and lung tumors from B6C3F1 mice exposed chronically to methylene chloride. Carcinogenesis 14(5): 795–801.8504471
Dhanya S, Saini RD. 1997. Rate constants of OH radical reactions in gas phase with some fluorinated compounds: a correlation with molecular parameters. Int J Chem Kinet 29:187–194.
Dhillon S, Burg RV. 1995. Methylene chloride. J Appl Toxicol 15:329–335.7594205
Dilling HPA, Shillaker RO. 1985. Toxicity review 12-dichloromethane (methylene chloride). Health and Safety Executive. Her Majesty’s Stationary Office, London, England.
*Dilling WL, Tefertiller NB, Kallos GJ. 1975. Evaporation rates of methylene chloride, chloroform, 1,1,1-trichloroethane, trichloroethylene, tetrachloroethylene, and other chlorinated compounds in dilute aqueous solutions. Environ Sci Technol 9(9):833–838.
Dillon D, Edwards I, Combes R, . 1992. The role of glutathione in the bacterial mutagenicity of vapour phase dichloromethane. Environ Mol Mutagen 20:211–217.1396612
*DiVincenzo GD, Kaplan CJ. 1981. Uptake, metabolism, and elimination of methylene chloride vapor by humans. Toxicol Appl Pharmacol 59:130–140.7256750
*DiVincenzo GD, Yanno FJ, Astill BD. 1971. The gas chromatographic analysis of methylene chloride in breath, blood, and urine. Am Ind Hyg Assoc J 32:387–391.5089834
*DiVincenzo GD, Yanno FJ, Astill BD. 1972. Human and canine exposure to methylene chloride vapor. Am Ind Hyg Assoc J 33:125–135.5074669
*Dobbs RA, Wang L, Govind R. 1989. Sorption of toxic organic compounds on wastewater solids: Correlation with fundamental properties. Environ Sci Technol 23:1092–1097.
Domenico PA, Palciauskas VV. 1982. Alternative boundaries in solid waste management. Ground Water 20:303–311.
dos Santos LMF, Livingston AG. 1997. Mineralisation of 1,2-dibromoethane and other brominated aliphatics under aerobic conditions. Water Sci Technol 36(10):17–25.
Dosemeci M, Cocco P, Gomez M, . 1994. Effects of three features of a job-exposure matrix on risk estimates. Epidemiology 5:124–127.8117771
Dow Chemical Company. 1961. The results of chronic skin absorption studies on chlorothene and methylene chloride. Midland, Mississippi. OTS84003A.
Dow Chemical Company. 1982. Ninety day percutaneous absorption study in rabbits with Dow Chemical Company - chlorothene; Dow Chemical Company - Methylene chloride; Dow Chemical Company - Isopropyl Alcohol. Midland, Mississippi. OTS84003A.
Dow Chemical Company. 1994. Initial submission: Toxicological properties and industrial handling hazards of (1) bromochloromethane; (2) methylene chloride; (3) flux oil; (4) bottoms from DBDPO process. EPA/OTS Doc No. FYI-OTS-0794-1085.
*Dowty BJ, Carlisle DR, Laseter JL. 1975. New Orleans drinking water sources tested by gas chromatography-mass spectrometry. Environ Sci Technol 9(8):762–765.
*Dunovant VS, Clark CS, QueHee SS, . 1986. Volatile organics in the wastewater and air spaces of three wastewater treatment plants. J Water Pollut Control Fed 58(9):886–895.
Dupont Chemicals. 1970. Initial submission: toxicity tests on Project Victor samples with cover letter dated 10/15/92. OTS0571515.
*Dyksen JE, Hess AF. 1982. Alternatives for controlling organics in groundwater supplies. J Am Water Works Assoc (74):394–403.
ECSA. 1995. Methylene chloride properties, uses and impact on the environment and health. European Chlorinated Solvent Association. Brussels, Belgium. September 1995.
E. I. Dupont de Nemours & Co. 1992. Inhalation toxicity studies of methylene chloride with cover letter. TSCATS-440754. NTIS/OTS 0555748.
Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology. Diagnosis and treatment of human poisoning. New York, NY: Elsevier Science Inc., 983–985.
*Ellenhorn MJ. 1997. Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier Science Inc., 1422t, 1423t, 1437t, 1438t, 1465–1466, 1408.
Elovaara E, Hemminki K, Vainio H. 1979. Effects of methylene chloride, trichloroethane, trichloroethylene, tetrachloroethylene, and toluene on the development of chick embryos. Toxicology 12:111–119.473229
*El-Zien RA, Zwischenberger JB, Abdel-Rahman SZ, . 1997a. Polymorphism of metabolizing genes and lung cancer histology: prevalence of CYP2E1 in adenocarcinoma. Cancer Lett 112:71–78.9029171
*El-Zein RA, Zwischenberger JB, Wood TG, . 1997b. Combined genetic polymorphism and risk for development of lung cancer. Mutat Res 381:189–200.9434875
*EMMI. 1999a. Environmental monitoring methods index. Version 1.1. PC#4082. Rockville, MD: U.S. Environmental Protection Agency, Government institutes. ASTM D3686.
*EMMI. 1999b. Environmental monitoring methods index. Version 1.1. PC#4082. Rockville, MD: U.S. Environmental Protection Agency, Government institutes. ASTM D3687.
*EMMI. 1999c. Environmental monitoring methods index. Version 1.1. PC#4082. Rockville, MD: U.S. Environmental Protection Agency, Government institutes. ASTM D4490.
Enfield CG, Carsel RF, Cohen SZ, . 1982. Approximating pollutant transport to ground water. Ground Water 20:711–722.
*Engström J, Bjurström R. 1977. Exposure to methylene chloride: Content in subcutaneous adipose tissue. Scand J Work Environ Health 3:215–224.594729
Environment Canada. 1993. Priority substances list assessment report: Dichloromethane. Ottawa, Canada: Canada Communication Group Publishing.
EPA. 1975a. Preliminary assessment of suspected carcinogens in drinking water. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA-560/14-75-005. PB 260961.
*EPA. 1975b. Region V joint federal/state survey of organics and inorganics in selected drinking water supplies. Chicago, IL: U.S. Environmental Protection Agency and Illinois Environmental Protection Agency.
EPA. 1975c. Identification of organic compounds in effluents from industrial sources. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA-560/3-75-002. NTIS no. PB-241641.
*EPA. 1979a. Identification of organic compounds in industrial effluent discharges. Athens, GA: US Environmental Protection Agency, Environmental Research Laboratory. EPA-600/4-79-016. PB 294794.
*EPA. 1979b. Water-related environmental fate of 129 priority pollutants. Vol. II. Halogenated aliphatic hydrocarbons, halogenated ethers, monocyclic aromatics, phthalate esters, polycyclic aromatic hydrocarbons, nitrosamines, and miscellaneous compounds. Washington, DC: U.S. Environmental Protection Agency, Office of Water Planning and Standards. EPA-440/4-79-029b. NTIS no. PB 80-204381.
*EPA. 1980a. Ambient water quality criteria for halomethanes. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA 440/5-80-051. PB 81 117 624.
EPA. 1980b. U.S. Environmental Protection Agency. Federal Register 45:33132–33133.
EPA. 1980c. U.S. Environmental Protection Agency. Part V. Federal Register 45(231):79334–79335.
EPA. 1980d. Acquisition and chemical analysis of mother’s milk for selected toxic substances. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA 560/13-80-029. PB 81-231029.
*EPA. 1980e. Atmospheric measurements of selected hazardous organic chemicals. Research Triangle Park, NC: US Environmental Protection Agency, Environmental Sciences Research Laboratory.
*EPA. 1980f. Fate of toxic and hazardous materials in the air environment. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Sciences Research Lab. NTIS no. PB80-221948. EPA 600/3-80-084.
EPA. 1981. Environmental risk assessment of dichloromethane. Draft report. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
*EPA. 1982a. Chlorinated organic solvents: Trichloroethene, tetrachloroethene, 1,1,1-trichloroethane, dichloromethane, and tetrachloromethane. In: Intermedia priority pollutant guidance documents. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
EPA. 1982b. Purgeable halocarbons-method 601. In: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA 600/4-82-057.
EPA. 1982c. Purgeables-method 624. In: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA 600/4-82-057.
EPA. 1982d. U.S. Environmental Protection Agency. Federal Register 47:26992,27007–27008.
*EPA. 1982e. Aquatic fate process data for organic priority pollutants. Washington, DC: US Environmental Protection Agency, Office of Water Regulations and Standards. EPA 440/4-81-014.
EPA. 1983a. Methods for chemical analysis of water and wastes. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Environmental Monitoring and Support Laboratory. EPA 600/4-79-020.
EPA. 1983b. Treatability manual. Vol. 1. Treatability data. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA 600/2-82-001A.
*EPA. 1983c. Human exposure to atmospheric concentrations of selected chemicals. Vol. 2. Research Triangle Park, NC: U.S. Environmental Protection Agency. NTIS no. PB83-265249.
*EPA. 1984. Health effects assessment for methylene chloride. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. ECAO-CIN-H028. NTIS no. PB86-134392.
EPA. 1985a. Addendum to the health assessment document for dichloromethane (methylene chloride): Updated carcinogen assessment of dichloromethane (methylene chloride): Final report. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA 600/8-82-0044FF.
*EPA. 1985b. Analysis of the applicability of TSCA Section 4(f) to methylene chloride. U.S. Environmental Protection Agency.
EPA. 1985c. Criteria document on dichloromethane. Final draft. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
EPA. 1985d. Environmental profiles and hazard indices for constituents of municipal sludge: Methylene chloride. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards.
*EPA. 1985e. Health assessment document for dichloromethane (methylene chloride): Updated carcinogen assessment of dichloromethane (methylene chloride). Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA/600/8-82/004FA.
EPA. 1985f. Summary of environmental profiles and hazard indices for constituents of municipal sludge: Methods and results. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards.
*EPA. 1985g. Atmospheric fates of organic chemicals: Prediction of ozone and hydroxyl radical reaction rates and mechanisms. Research Triangle Park, NC: U.S. Environmental Protection Agency, Atmospheric Sciences Research Laboratory. EPA/600/3-85/063. NTIS no. PB85-241529.
*EPA. 1985h. Synthetic organic compound sampling survey of public water supplies. Washington, DC: U.S. Environmental Protection Agency. NTIS no. PB85-214427.
EPA. 1986a. Gas chromatography/mass spectrometry for volatile organics-method 8240. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986b. Halogenated volatile organics-method 8010. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986c. Superfund public health evaluation manual. Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. EPA 540/1-86-060.
EPA. 1986d. U.S. Environmental Protection Agency. Federal Register 51:33992–34003.
*EPA. 1986e. Test methods for evaluating solid waste. Washington, DC: Office of Solid Waste, U.S. Environmental Protection Agency. OSW Methods 5041A, 5021, 8010B, 8021B, 8240B, 8260B.
*EPA. 1987a. Dichloromethane health advisory. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water. PB 87-235578. 150-164.
*EPA. 1987b. Health advisory for dichloromethane: Draft. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
EPA. 1987c. Household solvent products: A national usage survey. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1987d. Technical analysis of new methods and data regarding dichloromethane hazard assessments. Draft document. U.S. Environmental Protection Agency.
EPA. 1987e. Update to health assessment document and addendum for dichloromethane (methylene chloride): Pharmacokinetics, mechanism of action, and epidemiology. Draft Report. U.S. Environmental Protection Agency. EPA 600/8-87/1030A.
EPA. 1987f. U.S. Environmental Protection Agency. Part II. Federal Register 52(130):25709–25710.
EPA. 1987g. U.S. Environmental Protection Agency. Part II. Federal Register 52:25942–25953.
EPA. 1987h. U.S. Environmental Protection Agency. Part V. Federal Register 52:25760–25763, 25791.
*EPA. 1987i. Atmospheric persistence of eight air toxics: Project summary. Research Triangle Park, NC: U.S. Environmental Protection Agency, Atmospheric Sciences Research Laboratory. EPA 600/53-87/004. HC/MF PB 87-145306.
*EPA. 1987j. Environmental Protection Agency policy and guidance statement on petitions under the emergency planning and community right-to-know act. U.S. Environmental Protection Agency. Federal Register. 52 FR 107970.
EPA. 1988a. U.S. Environmental Protection Agency. Part II. Federal Register 53:4500–4501.
EPA. 1988b. U.S. Environmental Protection Agency. Part II. Federal Register 53:31138–31142, 31211–31222.
EPA. 1988c. U.S. Environmental Protection Agency. Part IV. Federal Register 53:38642–38654.
*EPA. 1988d. National ambient volatile organic compounds (VOCs): Data base update. Research Triangle Park, NC: US Environmental Protection Agency, Atmospheric Sciences Research Laboratory. EPA/600/3-88/010a.
EPA. 1989a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8-86-032a.
*EPA. 1989b. Measurement of purgeable organic compounds in water by capillary column gas chromatography/mass spectrometry-method 524.2. In: Methods for the determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA/600/4-88/039.
*EPA. 1989c. Measurement of purgeable organic compounds in water by packed column gas chromatography/mass spectrometry-method 524.1. In: Methods for the determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA/600/4-88/039.
*EPA. 1989d. Updated health effects assessment for methylene chloride. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA/600-8-89/092. NTIS no. PB90-142449.
*EPA. 1989e. U.S. Environmental Protection Agency. Part V. Federal Register 54:33426, 33461.
*EPA. 1989f. Volatile halogenated organic compounds in water by purge and trap gas chromatography-method 502.1. In: Methods for the determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA 600/4-88-039.
*EPA. 1989g. Volatile organic compounds in water by purge and trap capillary column gas chromatography with protoionization and electrolytic conductivity detectors in series-method 502.2. In: Methods for the determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA 600/4-88/039.
EPA. 1990a. U.S. Environmental Protection Agency. Part II. Federal Register 55:22520–22536, 22683–22714.
EPA. 1990b. U.S. Environmental Protection Agency. Part II. Federal Register 55:30370–30373, 30386–30387.
*EPA. 1990c. Toxics in the community: National, and local perspectives. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. EPA 560/4-90-017.
*EPA. 1990d. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA 600/8-90/066A.
EPA. 1991. Evaluations of VOC emissions from heated roofing asphalt. Research Triangle Park, NC: U.S. Environmental Protection Agency, Control Technology Center. EPA-600/2-91-061.
EPA. 1992a. Final quantification of toxicological effects for dichloromethane. Washington, DC: U.S. Environmental Protection Agency, Office of Water. NTIS no. PB92-173335.
EPA. 1992b. U.S. Environmental Protection Agency. Part III. Federal Register 57:31789–31790.
EPA. 1993. Locating and estimating air emissions from sources of methylene chloride. U.S. Environmental Protection Agency, Office of Air Quality. EPA 454/R-93-006.
*EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: Office of Research and Development, U.S. Environmental Protection Agency. EPA/600/8-90/066F.
*EPA. 1996a Drinking water regulations and health advisories. U.S. Environmental Protection Agency, Office of Water. http://www.epa.gov/ostwater/tools/dwstds3.html. Accessed on May 20, 1998.
*EPA. 1996b. Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS)method 8260B. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1996c. Aromatic and halogenated volatile by gas chromatography using photoionization and/or electrolytic conductivity detectors-method 8021B. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1996d. Involvement of dichloromethane in the intrinsic Biodegredation of chlorinated ethenes and ethanes. In: Symposium of natural attenuation of chlorinated organics in ground water. U.S. Environmental Protection Agency. EPA\540\R-96\509.
*EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA/630/R-96/012.
EPA. 1998a. Effluent guidelines and standards: General provisions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.
*EPA. 1998b. Exemption from tolerances: Methylene chloride; exemption from the requirement of a tolerance. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.1010.
*EPA. 1998c. Ground-water monitoring list: Appendix IX. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.
*EPA. 1998d. Hazardous waste constituent: Appendix VIII. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.
*EPA. 1998e. Health and safety data reporting: Substances and listed mixtures to which this subpart applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120
*EPA. 1998f. List of hazardous substances and reportable quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1998g. Maximum containment level goals for organic containments. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.50.
*EPA. 1998h. Methods for organic chemical analysis of municipal and industrial wastewater-method 601. Appendix A to 40 Part 136. http://www.epa.gov/ostwater/Tools/guide/methods.html. Accessed on June 2, 1998.
*EPA. 1998i. Methods for organic chemical analysis of municipal and industrial wastewater-method 624. Appendix A to 40 Part 136. Http://www.epa.gov/ostwater/Tools/guide/methods.html. Accessed on June 2, 1998.
*EPA. 1998j. NPDES permit application testing requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122.21.
*EPA. 1998k. Pollutants eligible for a removal credit. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403.
*EPA. 1998l. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.
*EPA 1999a. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA 1999b. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
*EPA 1999c. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33.
*EPA 1999d. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.48.
EPA 1999e. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.6.
*EPA 1999f. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.50.
*EPA 1999g. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.61.
EPA 1999h. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 142.62.
*EPA 1999i. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.1001.
*EPA 1999j. National Recommended Water Quality Criteria- Correction. U. S. Environmental Protection Agency, Office of Water. EPA 822-Z-99-001.
*Estill CF, Spencer AB. 1996. Case study: Control of methylene chloride exposures during furniture stripping. Am Ind Hyg Assoc J 57:43–49.8588552
Ewing BB, Chian ESK, Cook JC, . 1977. Monitoring to detect previously unrecognized pollutants in surface waters. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. EPA 560/6-77-015.
FAO and WHO Working Groups. 1993. Dichloromethane. WHO food additive series 30:135–82.
Farmer PB, Sepai O, Lawrence R, . 1996. Biomonitoring human exposure to environmental carcinogenic chemicals. Mutagenesis 11:363–381.8671761
*FDA. 1985. Cosmetics; proposed ban on the use of methylene chloride as an ingredient of aerosol cosmetic products. Food and Drug Administration. Federal Register 50(243):51551–51559.
*FDA. 1989. Cosmetics; ban on the use of methylene chloride as an ingredient of cosmetic products. Food and Drug Administration. Federal Register 54(124):27328–27342.
FDA. 1997a. Diluents in color additive mixtures for food use exempt from certification. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 73.1.
FDA. 1997b. Food additives permitted for direct addition to food for human consumption: Modified hop extract. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 560.
FDA. 1997c. Indirect food additives: Adhesives and components of coating: Adhesives. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105.
FDA. 1997d. Indirect food additives: Polymers: Polycarbonate resins. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.1580
FDA. 1997e. Requirements for specific cosmetic products. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 700.19.
FDA. 1997f. Secondary direct food additives permitted in food for human consumption: Solvents, lubricants, release agents and related substances. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 173.255.
FDA. 1997g. Food labeling; Statement of identity, nutrition labeling and ingredient labeling of dietary supplements; compliance policy guide, revocation; Correction. Department of Health and Human Services, Food and Drug Administration. Federal Register 62(243): 66275–66277.
*FDA. 1999a. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105.
*FDA. 1999b. Food and Drug Administration. Code of Federal Regulations. 21 CFR 173.255.
*FDA. 1999c. Food and Drug Administration. Code of Federal Regulations. 21 CFR 700.19.
*FDA. 1999d. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.1580.
*FDA. 1999e. Food and Drug Administration. Code of Federal Regulations. 21 CFR 73.1.
*FEDRIP. 1996. Federal Research in Progress. Dialog Information Systems, Inc., Palo Alto, CA.
FEDRIP. 1998. Federal Research in Progress. Dialog Information Systems, Inc., Palo Alto, CA.
*FEDRIP. 1999. Federal Research in Progress. Dialog Information Systems, Inc., Palo Alto, CA. December 1999.
*Ferrario JB, Lawler GC, DeLeon IR, . 1985. Volatile organic pollutants in biota and sediments of Lake Pontchartrain. Bull Environ Contam 34:246–255.
*Fisher J, Mahle D, Bankston L, . 1997. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J 58:425–431.9183837
*Fisher JW, Whittaker TA, Taylor DH, . 1989. Physiologically based pharmacokinetic modeling of the pregnant rat: A multiroute exposure model for trichloroethylene and its metabolite, trichloroacetic acid. Toxicol Appl Pharmacol 99:395–414.2749729
Flury F, Zernik F. 1931. Harmful gases, vapors, fog, smoke, and dust. Berlin: Julius Springer, 311–312.
*Fodor GG, Roscovana G. 1976. [Increased blood-CO-content in humans and animals by incorporated halogenated hydrocarbons.] Zentrabl Bakteriol (Orig B). 162:34–40 (German).
*Fodor GG, Winneke G. 1971. Nervous system disturbances in men and animals experimentally exposed to industrial solvent vapors in England. Proceedings of the 2nd international clean air congress. New York, NY: Academic Press.
*Fodor GG, Prajsnar D, Schlipkoter HW. 1973. Endogenous conformation by incorporated halogenated hydrocarbons of the methane series. Staubreinhalt Luft 33:260–261.
Foley JF, Tuck PD, Ton TT, . 1993. Inhalation exposure to a hepatocarcinogenic concentration of methylene chloride does not induce sustained replicative DNA synthesis in hepatocytes of female B6C3F1 mice. Carcinogenesis 14:811–817.8099314
*Foman SJ. 1966. Body composition of the infant. Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Foman SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Forster HV, Graff S, Hake CL, . 1974. Pulmonary-hematologic studies on humans during exposure to methylene chloride. NIOSH-MCOW-ENVM-MC-74-4.
*Foster JR, Green T, Smith LL, . 1992. Methylene chloride - An inhalation study to investigate pathological and biochemical events occurring in the lungs of mice over an exposure period of 90 days. Fundam Appl Toxicol 18:376–388.1375920
Foster JR, Green T, Smith LL, . 1994. Methylene chloride: An inhalation study to investigate toxicity in the mouse lung using morphological, biochemical and Clara cell culture techniques. Toxicol 91:221–234.
Freedman DL, Gossett JM. 1991. Biodegredation of dichloromethane and its utilization as a growth substrate under methanogenic conditions. Appl Environ Microbiol 57:2847–2857.1746945
Freedman DL, Smith CR, Noguera DR. 1997. Dichloromethane Biodegredation under nitrate-reducing conditions. Water Environ Res 69:115–122.
*Friedlander BR, Hearne FT, Hall S. 1978. Epidemiologic investigation of employees chronically exposed to methylene chloride: Mortality analysis. J Occup Med 20(10):657–666.722350
FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Washington, DC: U.S. Environmental Protection Agency.
*Gargas ML, Burgess RJ, Voisard DE, . 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98:87–99.2929023
*Gargas ML, Clewell HJ, Andersen ME. 1986. Metabolism of inhaled dihalomethanes in vivo: Differentiation of kinetic constants for two independent pathways. Toxicol Appl Pharm 82:211–223.
*Garte S, Crosti F. 1999. A nomenclature system for metabolic gene polymorphisms. In: Vineis P, Malats N, Lang M, . ed. Metabolic polymorphisms and susceptibility to cancer. Lyon, France: International Agency for Research on Cancer, 5–12.
General Electric. 1982. Fourteen day range finding study in rats. Pittsfield, Massachusetts. OTS84003A.
*Ghittori S, Marraccini P, Franco G, . 1993. Methylene chloride exposure in industrial workers. Am Ind Hyg Assoc J 54(1):27–31.8470621
*Gibbs GW, Amsel J, Soden K. 1996. A cohort mortality study of cellulose triacetate-fiber workers exposed to methylene chloride. J Occup Environ Med 38(7):693–697.8823660
Giroux D, Lapointe G, Baril M. 1992. Toxicological index and the presence in the workplace of chemical hazards for workers who breast-feed infants. Amer Ind Hyg Assoc J 53:471–474.1496936
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
*Glatzel W, Tietze K, Gutewort R, . 1987. Interaction of dichloromethane and ethanol in rats: Toxicokinetics and nerve conduction velocity. Alcohol Clin Exp Res 11:450–452.3314558
*Gocke E, King M-T, Eckhardt K, . 1981. Mutagenicity of cosmetic ingredients licensed by European Communities. Mutat Res 90:91–109.6799819
Gold LS, Slone TH, Ames BN. 1998. What do animal cancer tests tell us about human cancer risk?: overview of analysis of the carcinogenic potency database. Drug Metab Rev 30(2):359–404.9606609
Goss K-U. 1997. Conceptual model for the adsorption of organic compounds from the gas phase to liquid and solid surfaces. Environ Sci Technol 31(12):3600–3605.
Gosselin RE, Smith RP, Hodge HC, . 1984. Clinical toxicology of commercial products. 5th ed. Baltimore, MD: Williams and Wilkins, II-161.
*Gossett JM. 1987. Measurement of Henry’s Law constants for C_1_ and C_2_ chlorinated hydrocarbons. Environ Sci Technol 21:202–208.
Gradiski D, Bonnet G, Raoult G, . 1978. [Compared acute pulmonary toxicity of the main chlorinated aliphatic solvents.] Arch Mal Prof Med Trav Secus Soc 39:249. (French).
Graham DR. 1990. Solvent abuse. In: Haddad LM, Winchester JF, ed. Clinical management of poisoning and drug overdose. Philadelphia, PA: W.B. Saunders Company, 1216–1222.
*Graves RJ, Green T. 1996. Mouse liver glutathione S-transferase mediated metabolism of methylene chloride to a mutagen in the CHO/HPRT assay. Mutat Res 367:143–150.8600370
*Graves RJ, Callander RD, Green T. 1994a. The role of formaldehyde and S-chloromethylglutathione in the bacterial mutagenicity of methylene chloride. Mutat Res 320:235–243.7508089
*Graves RJ, Coutts C, Eyton-Jones H, . 1994b. Relationship between hepatic DNA damage and methylene chloride-induced hepaticarcinogenicity in B6C3F1 mice. Carcinogenesis 15(5):991–996.8200106
*Graves RJ, Coutts C, Green T. 1995. Methylene chloride-induced DNA damage: An interspecies comparison. Carcinogenesis 16(8):1919–1926.7634422
*Graves RJ, Trueman P, Jones S, . 1996. DNA sequence analysis of methylene chloride-induced HPRT mutations in Chinese hamster ovary cells: Comparison with the mutation spectrum obtained for 1,2-dibromoethane and formaldehyde. Mutagenesis 11(3):229–233.8671744
*Green T. 1991. Species differences in carcinogenicity: The role of metabolism and pharmacokinetics in risk assessment. Ann Ist Super Sanita 27:595–600.1820731
*Green T. 1997. Methylene chloride induced mouse liver and lung tumours: An overview of the role of mechanistic studies in human safety assessment. Hum Exp Toxicol 16:3–13.9023569
Green T, Nash JA, Mainwaring G, eds. 1986a. Methylene chloride: In vitro metabolism in rat, mouse, and hamster liver and lung fractions and in human liver fractions. ICI Central Toxicology Laboratory, Report no. CTL/R/879, September 22. TSCATS 305692. OTS 0514367. EPA 86-880000289.
*Green T, Provan WM, Collinge DC, . eds. 1986b. Methylene chloride: Interaction with the rat and mouse liver and lung DNA in vivo. ICI Central Toxicology Laboratory, Report no. CTL/R/851, January 22. TSCATS 305690. OTS 0514364. EPA 86-880000286.
*Green T, Proven WM, Nash JA, . eds. 1986c. Methylene chloride (dichloromethane): In vivo inhalation pharmacokinetics and metabolism in F344 rats and B6C3F1 mice. ICI Central Toxicology Laboratory, Report No. CTL/R/880, September 22. TSCATS 305694. NTIS/OTS 0514368. EPA 86-880000290.
*Green T, Provan WM, Collinge DC, . 1988. Macromolecular interactions of inhaled methylene chloride in rats and mice. Toxicol Appl Pharmacol 93:1–10.3353996
Grimsrud EP, Rasmussen RA. 1975. Survey and analysis of halocarbons in the atmosphere by gas chromatography-mass spectrometry. Atmos Environ 9:1014–1017.
Guengerich FP. 1997. Mechanisms of mutagenicity of DNA adducts derived from alkyl and vinyl halides. Jpn J Toxicol Environ Health (Eisei Kagaku) 43(2):69–82.
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington DC: International Life Sciences Institute Press.
Haag WR, Johnson MD, Scofield R. 1996. Direct photolysis of trichloroethene in air: effect of cocontaminants, toxicity of products, and hydrothermal treatment of products. Environ Sci Technol 30:414–421.
*Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. Second edition. Philadelphia, PA: W.B. Saunders Company.
Hakkola J, Pelkonen O, Pasanen M, . 1998. Xenobiotic-metabolizing cytochrome P450 enzymes in the human feto-placental unit: Role in intrauterine toxicity. Crit Rev Toxicol 28(1):35–72.9493761
*Hall AH, Rumack BH. 1990. Methylene chloride exposure in furniture-stripping shops: Ventilation and respirator use practices. J Occup Med 32(1):33–41.2324841
Hall RM, Martinez KF, Jensen PA. 1995. Control of methylene chloride furniture stripping dip tank. Appl Occup Environ Hyg 10:188–195.
*Hallier E, Schroder KR, Asmuth K, . 1994. Metabolism of dichloromethane (methylene chloride to formaldehyde in human erythrocytes: Influence of polymorphism of glutathione transferase theta (GST T1-1). Arch Toxicol 68:423–427.7979958
*Hansch C, Leo A. 1979. Substituent constants for correlation analysis in chemistry and biology. New York, NY: John Wiley and Sons.
*Hardin BD, Manson JM. 1980. Absence of dichloromethane teratogenicity with inhalation exposure to rats. Toxicol Appl Pharmacol 52:22–28.7361312
*Harkov R, Kebbekus B, Bozzelli JW, . 1984. Comparison of selected volatile organic compounds during the summer and winter at urban sites in New Jersey. Sci Total Environ 38:259–274.
*Harkov R, Giante SJ, Bozelli JW, . 1985. Monitoring volatile organic compounds at hazardous and sanitary landfills in New Jersey. J Environ Sci Health A20(5):491–501.
*Harsch D. 1977. Study of halocarbon concentrations in indoor environments. Final report. Report to U.S. Environmental Protection Agency, Office of Research and Development, Washington, DC, by Washington State University, College of Engineering, Pullman, WA. Project 1505. Contract WA-6-99-2922-J.
Hashmi M, Dechert S, Dekant W, . 1994. Bioactivation of [^13^C]dichloromethane in mouse, rat, and human liver cytosol: ^13^C nuclear magnetic resonance spectroscopic studies. Chem Res Toxicol 7:291–296.8075359
Hastings SE. 1984. Written communication (April 24) to T. Knutson, Office of Toxic Substances (TS-793-I), regarding TSCA section 8(d) health and safety study submissions. Stauffer Chemical Company, Westport, Connecticut. OTS84003A.
*Haun CC, Vernot EH, Darmer KI, . 1972. Continuous animal exposure to low levels of dichloromethane. In: Proceedings of the 3^rd^ annual conference on environmental toxicology. Wright Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, 199–208. AMRL-TR-72-130. AD 773766.
*Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1980. Environ Monit Assess 2:249–271.24264296
*HazDat. 1996. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. www.atsdr.cdc.gov/hazdat.html.
HazDat. 1998. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. June 8, 1998. www.atsdr.cdc.gov/hazdat.html.
*HazDat. 1999. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. December 14, 1999. www.atsdr.cdc.gov/hazdat.html.
*HazDat. 2000. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. www.atsdr.cdc.gov/hazdat.html.
*Hearne FT, Grose F, Pifer JW, . 1987. Methylene chloride mortality study: Dose-response characterization and animal model comparison. J Occup Med 29(3):217–228.3559766
*Hearne FT, Pifer JW, Grose F. 1990. Absence of adverse mortality effects in workers exposed to methylene chloride: An update. J Occup Med 32(3):234–240.2319356
HEAST. 1990. Health Effects Assessment Summary Tables. Third quarter FY-1990. Washington, DC: U.S. Environmental Protection Agency.
*Hegi ME, Soderkvist P, Foley JF, . 1993. Characterization of p53 mutations in methylene chloride-induced lung tumors from B6C3F1 mice. Carcinogenesis 14(5):803–810.8504472
*Hegi ME, Devereux TR, Dietrich WF, . 1994. Allelotype analysis of mouse lung carcinomas reveals frequent allelic losses on chromosome 4 and an association between allelic imbalances on chromosome 6 and K-ras activation. Cancer Res 54:6257–6264.7954475
*Heikes DL. 1987. Purge and trap method for determination of volatile halocarbons and carbon disulfide in table-ready foods. J Assoc Off Anal Chem 70:215–226.3571114
Heikes DL, Hopper ML. 1986. Purge and trap method for determination of fumigants in whole grains, milled grain products, and intermediate grain-based foods. J Assoc Off Anal Chem 69:990–998.3542956
*Heineman EF, Cocco P, Gómez MR, . 1994. Occupational exposure to chlorinated aliphatic hydrocarbons and risk of astrocytic brain cancer. Am J Ind Med 26:155–169.7977393
*Helz GR, Hsu RY. 1978. Volatile chloro- and bromocarbons in coastal waters. Limnol Oceanogr 23(5):858–869.
*Heppel LA, Neal PA. 1944. Toxicology of dichloromethane (methylene chloride): II. Its effects upon running activity in the male rat. J Ind Hyg Toxicol 26(1):17–21.
*Heppel LA, Neal PA, Perrin ML, . 1944. Toxicology of dichloromethane (methylene chloride): I. Studies on effects of daily inhalation. J Ind Hyg Toxicol 26(1):8–16.
*Herr DW, Boyes WK. 1997. A comparison of the acute neuroactive effects of dichloromethane, 1,3-dichloropropane, and 1,2-dichlorobenzene on rat flash evoked potentials (FEPs)1,2. Fundam Appl Toxicol 35:31–48.9024671
Hertz-Picciotto I, Neutra RR. 1994. Resolving discrepancies among studies: The influence of dose on effect size. Epidemiology 5:156–163.8172990
Hetrick DM, Jarabek AM, Travis CC. 1991. Sensitivity analysis for physiologically based pharmacokinetic models. J Pharmacokinet Biopharm 19(1):1–20.2023106
Hiatt MH. 1981. Analysis of fish and sediment for volatile priority pollutants. Anal Chem 53:1541–1543.7270902
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoff JT, Wania F, Mackay D, . 1995. Sorption of nonpolar organic vapors by ice and snow. Environ Sci Technol 29:1982–1989.22191345
Hoffmann P, Heinroth K, Richards D, . 1994. Depression of calcium dynamics in cardiac myocytes–a common mechanism of halogenated hydrocarbon anesthetics and solvents. J Mol Cell Cardiol 26:579–589.8072012
Hoffmann P, Muller SP, Heinroth K, . 1996. Calcium dynamics in cardiac myocytes as a target of dichloromethane cardiotoxicity. Arch Toxicol 70:158–163.8825672
*Honma T, Suda M. 1997. Changes in plasma lipoproteins as toxicity markers for carbon tetrachloride, chloroform, and dichloromethane. Ind Health 35:519–531.9348725
Hovorka S, Dohnal V. 1997. Determination of air-water partitioning of volatile halogenated hydrocarbons by the inert gas stripping method. J Chem Eng Data 42:924–933.
*Howard PH, Sage GW, Jarvis WF, . eds. 1990. Handbook of environmental fate and exposure data for organic chemicals. Vol. II. Solvents. Chelsea MI: Lewis Publishers, Inc., 176–183.
Hoyer ME, Keeler GJ, Ball JC. 1992. Detection of oxidative mutagens in an urban air-particulate extract: A preliminary study. Mutat Res 283:295–299.1383803
*HSDB. 1990. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. July 18, 1990.
HSDB. 1998. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. May 11, 1998.
*HSDB. 1999. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
HSIA. 1988. Halogenated Solvents Industry Alliance. Public comments on scientific and technical issues on the draft toxicological profile for methylene chloride. Submitted to Agency for Toxic Substances and Disease Registry (ATSDR), March 8.
*HSIA. 2000. Methylene chloride: 28-day inhalation toxicity study in the rat to assess potential immunotoxicity. 1–82.
Hughes CS. 1985. CEH product review: Chlorinated methanes. In: Chemical economics handbook. Menlo Park, CA: SRI International.
*Hughes NJ, Tracey JA. 1993. A case of methylene chloride (nitromors) poisoning, effects on carboxyhaemoglobin levels. Hum Exp Toxicol 12:159–160.8096715
*IARC. 1986. Dichloromethane. IARC monograph on the evaluation of the carcinogenic risk of chemicals to humans. Some halogenated hydrocarbons and pesticide exposures. Vol. 41. World Health Organization, International Agency for Research on Cancer, Lyon, France, 43–85.
*IARC. 1987. IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Suppl. 7. Overall evaluations of carcinogenicity: An updating of IARC monographs volumes 1 to 42. World Health Organization, International Agency for Research on Cancer, Lyon, France, 29–33, 62.
*ID Dept Health Welfare. 1999. Air pollution control. Idaho Department of Health and Welfare. Rule 16.01.01. http://www.state.id.us/
IJC. 1983. An inventory of chemical substances identified in the Great Lakes ecosystem. Vol. 1. Summary. Report to the Great Lakes Water Quality Board by the International Joint Commission, Windsor, Ontario.
IRIS. 1998. Integrated Risk Information System. U.S. Environmental Protection Agency, Washington, DC. May 11, 1998.
*IRIS. 1999. Integrated Risk Information System. U.S. Environmental Protection Agency, Washington, DC. December 13, 1999.
*IRPTC. 1990. International Register of Potentially Toxic Chemicals. United Nations Environment Programme, Geneva, Switzerland. July, 1990.
James KJ, Stack MA. 1997. The impact of leachate collection on air quality in landfills. Chemosphere 34(8):1713–1721.
Jansson T, Romert L, Magnusson J, . 1991. Genotoxicity testing of extracts of a Swedish moist oral snuff. Mutat Res 261: 101–115.1922153
Jensen AA. 1983. Chemical contaminants in human milk. Residue Rev 89:1–108.6316441
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Jones DL, Burklin CE, Seaman JC, . 1996. Models to estimate volatile organic hazardous air pollutant emissions from municipal sewer systems. J Air Waste Manage Assoc 46:657–666.
*Jones DP, Thor H, Andersson B, . 1978. Detoxification reactions in isolated hepatocytes: Role of gluthathione peroxidase, catalase, and formaldehyde dehydrogenase in reactions relating to N-demethylation by the cytochrome P-450 system. J Biol Chem 253(17):6031–6037.567217
*Jones SM, Boobis AR, Moore GE, . 1992. Expression of CYP2E1 during fetal development: methylation of the CYP2E1 gene in human fetal and adult liver samples. Biochem Pharmacol 43(8):1876–1879.1575782
*Jongen WMF, Lohman PHM, Kottenhagen MJ, . 1981. Mutagenicity testing of dichloromethane in short-term mammalian test systems. Mutat Res 81:203–213.7242542
Jury WA, Winer AM, Spencer WF, . 1987. Transport and transformations of organic chemicals in the soil-air-water ecosystem. Rev Environ Contam Toxicol 99:120–164.
Kadry AM, Skowronski GA, Abdel-Rahman MS. 1995. Evaluation of the use of uncertainty factors in deriving RfDs for some chlorinated compounds. J Toxicol Environ Health 45:83–95.7538596
Kaiser J. 1996. New data help toxicologists home in on assessing risks. Science 272:200.8602503
Kan AT, Tomson MB. 1996. UNIFAC prediction of aqueous and nonaqueous solubilities of chemicals with environmental interest. Environ Sci Technol 30:1369–1376.
*Kanno J, Foley JF, Kari F, . 1993. Effect of methylene chloride inhalation on replicative DNA synthesis in the lungs of female B6C3F_1_ mice. Environ Health Perspec 101(suppl5):271–276.
*Kari FW, Foley JF, Seilkop SK, . 1993. Effect of varying exposure regimens on methylene chloride-induced lung and liver tumors in female B6C3F1 mice. Carcinogenesis 14(5):819–826.8504473
*Karlsson J-E, Rosengren LE, Kjellstrand P, . 1987. Effects of low-dose inhalation of three chlorinated aliphatic organic solvents on deoxyribonucleic acid in gerbil brain. Scand J Work Environ Health 13:453–458.3433047
Kawata K, Tanabe A, Saito S, . 1997. Screening of volatile organic compounds in river sediment. Bull Environ Contam Toxicol 58:893–900.9136651
Keaton BF. 1990. Chlorinated hydrocarbons. In: Haddad LM, Winchester JF, ed. Clinical management of poisoning and drug overdose. Philadelphia, PA: W.B. Saunders Company, 1216–1222.
Kedderis GL. 1997. Extrapolation of in vitro enzyme induction data to humans in vivo. Chem Biol Interact 107:109–121.9402953
*Kelly M. 1988. Case reports of individuals with oligospermia and methylene chloride exposures. Reprod Toxicol 2:13–17.
*Kim C, Manning RO, Brown RP, . 1996b. Use of the vial equilibrium technique for determination of metabolic rate constants for dichloromethane. Toxicol Appl Pharmacol 139:243–251.8806840
Kim NY, Park, SW, Suh JK. 1996a. Two fatal cases of dichloromethane of chloroform poisoning. J Forensic Sci 41: 527–529.8656200
Kim SK, Kim YC. 1996. Effect of a single administration of benzene, toluene or m-xylene on carboxyhaemoglobin elevation and metabolism of dichloromethane in rats. J Appl Toxicol 16:437–444.8889796
*Kim YC. 1997. Dichloromethane potentiation of carbon tetrachloride hepatotoxicity in rats. Fundam Appl Toxicol 35:138–141.9024681
Kim YC, Carlson GP. 1986. The effect of an unusual workshift on chemical toxicity. I. Studies on the exposure of rats and mice to dichloromethane. Fundam Appl Toxicol 6:162–171.3710022
*Kimura ET, Ebert DM, Dodge PW. 1971. Acute toxicity and limits of solvent residue for sixteen organic solvents. Toxicol Appl Pharmacol 19:699–704.5132037
*King JW. 1989. Fundamentals and applications of supercritical fluid extraction in chromatographic science. J Chromatogr 27:355–364.
*Kirschman JC, Brown NM, Coots RH, . 1986. Review of investigations of dichloromethane metabolism and subchronic oral toxicity as the basis for the design of chronic oral studies in rats and mice. Food Chem Toxicol 24(9):943–949.3781441
*Kitchin KT, Brown JL. 1989. Biochemical effects of three carcinogenic chlorinated methanes in rat liver. Teratogenesis Carcinog Mutagen 9:61–69.2567070
*Kjellstrand P, Bjerkemo M, Adler-Maihofer M, . 1986. Effects of methylene chloride on body and organ weight and plasma butyrylcholinesterase activity in mice. Acta Pharmacol Toxicol 59:73–79.
Klecka GM. 1982. Fate and effects of methylene chloride in activated sludge. Appl Environ Microbiol 44:701–707.7138008
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
*Konasewich D, Traversy, WJ, Zar H, . 1978. Status report on organic and heavy metal contaminants in the Lakes Erie, Michigan, Huron, and Superior basins. Great Lake Water Quality Board, 1–14.
Kong ZM, Yu LW, Liu ZT, . 1996. Mutagenicity of organic pollutants and their active components in the Xi River water at Shenyang. Bull Environ Contam Toxicol 56:803–808.8661865
*Kool HJ, vanKreijl CF, Zoetman BCJ. 1982. Toxicology assessment of organic compounds in drinking water. CRC Crit Rev Environ Control 12(4):307–350.
*Kopfler FC, Melton RG, Mullaney JL. . 1977. Human exposure to water pollutants. Adv Environ Sci Technol 8:419–433.
Koppel C, Arndt I, Arendt U, . 1985. Acute tetrachloroethylene poisoning blood elimination kinetics during hyperventilation therapy. Clin Toxicol 23:103–115.
*Koppmann R, Johnen FJ, Plass-Dulmer C, . 1993. Distribution of methylchloride, dichloromethane, trichloroethene and tetrachloroethene over the north and south Atlantic. J Geophys Res 98(D11):20,517–520,526.11539182
Kramers PGN, Mout HCA, Bissumbhar B, . 1991. Inhalation exposure in Drosophila mutagenesis assays: experiments with aliphatic halogenated hydrocarbons, with emphasis on the genetic activity profile of 1,2-dichloroethane. Mutat Res 252:17–33.1996129
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Pelekis M. 1995. Hematotoxic interactions: Occurrence, mechanisms and predictability. Toxicology 105:355–364.8571372
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Krishnan K, Haddad S, Pelekis M. 1995. A simple index for representing the discrepancy between simulations of physiological pharmacokinetic models and experimental data. Toxicol Ind Health 11:413–422.8748422
*KS Dept Health Env. 1998. Ambient air quality standards and air pollution control. Kansas Department of Health and Environment, Kansas Administrative Rules. Rule 28-19. http://www.kdhe.state.ks.us/
KY Dept. for Env. Protect. 1998. Existing Sources: Threshold ambient limits and significant emission levels of toxic pollutants. Kentucky Department for Environmental Protection, Division of Air Quality. 401 KY Admin. Regs. 53:010.
Laham S, Potvin M. 1976. Microdetermination of dichloromethane in blood with a syringeless gas chromatographic injection system. Chemosphere 6:403–411.
*Lanes SF, Cohen A, Rothman KJ, . 1990. Mortality of cellulose fiber production workers. Scand J Work Environ Health 16:247–251.2389131
*Lanes SF, Rothman KJ, Dreyer NA, . 1993. Mortality update of cellulose fiber production workers. Scand J Work Environ Health 19:426–428.8153596
*Lang M, Pelkonen O. 1999. Metabolism of xenobiotics and chemical carcinogenesis. In: Vineis P, Malats N, Lang M, . ed. Metabolic polymorphisms and susceptibility to cancer. Lyon, France: International Agency for Research on Cancer, 13–22.
LaPat-Polasko LT, McCarty PL, Zehnder AJB. 1984. Secondary substrate utilization of methylene chloride by an isolated strain of Pseudomonas. Appl Environ Microbiol 47:825–830.6721491
*LaRegina J, Bozzelli JW, Harkov R, . 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey: An up-to-date review of the present situation. Environ Progr 5(1):18–27.
*Lash AA, Becker CE, So Y, . 1991. Neurotoxic effects of methylene chloride: Are they long lasting in humans? Br J Ind Med 48:418–426.2064980
*Leeder JS, Kearns, GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44:55–77.9057784
Lefevre PA, Ashby J, eds. 1986. Methylene chloride: Induction of S-phase hepatocytes in the mouse after in vivo exposure. ICI Central Toxicology Laboratory, Report no. CTL/R/885, September 22. TSCATS 305696. OTS 0514369. EPA 86-880000286.
Lefevre PA, Ashby J. 1989. Evaluation of dichloromethane as an inducer of DNA synthesis in the B6C3F1 mouse liver. Carcinogenesis 10:1067–1072.2720901
Leiber CS. 1997. Cytochrome P-4502E1: Its physiological and pathological role. Physiol Rev 77(2):517–544.9114822
*Leisinger T, Bader R, Hermann R, . 1994. Microbes, enzymes and genes involved in dichloromethane utilization. Biodegredation 5:237–248.
*Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York NY: Stockton Press, 153–164.
Lewis DFV, Ioannides C, Parke DV. 1998. Cytochromes P450 and species differences in xenobiotic metabolism and activation of carcinogen. Environ Health Perspect 106(10):633–641.9755138
*Lewis RJ. 1996. Sax’s dangerous properties of industrial materials. 9th ed. New York, NY: Van Nostrand Reinhold, 2230–2231.
Liang GB, Ritto CJ, Gellman SH. 1992. Thermodynamic analysis of β-turn formation in pro-ala, progly, and pro-val model peptides in methylene chloride. J Am Chem Soc 114:4440–4442.
*Lide DR. 1994. CRC handbook of chemistry and physics. Boca Raton, FL: CRC Press, 6–57, 15–45.
Liniger B, Sigrist T. 1994. Carboxyhaemoglobinaemia resulting from exposure to dichloromethane with dermatological effects. Hautarzt 45:8–11.8150623
Liteplo RG, Long GW, Meek ME. 1998. Relevance of carcinogenicity bioassays in mice assessing potential health risks associated with exposure to methylene chloride. Hum Exp Toxicol 17:84–87.9506258
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Logemann E, van der Gunther S. 1991. Intoxication with a paint-stripper containing dichloromethane. Arch Kriminol 188:159–166.1799294
Long G, Meek ME, Caldwell I, . 1994. Dichloromethane: Evaluation of risks to health from environmental exposure in Canada. J Environ Sci Health C12:305–318.
*Longo LD. 1977. The biological effects of carbon monoxide on the pregnant woman, fetus, and newborn infant. Am J Obstet Gynecol 129:69–103.561541
Lopez S, Topalian JH, Mitra SK, . 1989. Absorption and desorption of dichloromethane vapor by water drops in air. An experimental test of scavenging theory. J Atmos Chem 8:175–188.
Lundberg I, Ekdahl M, Kronevi T, . 1986. Relative hepatotoxicity of some industrial solvents after intraperitoneal injection or inhalation exposure in rats. Environ Res 40:411–420.3732212
Lynge E, Anttila A, Hemminiki K. 1997. Organic solvents and cancer. Cancer Causes and Control 8:406–419.9498902
*MA Dept. Env. Protect. 1998. Allowable ambient limit (AAL), 24-hour averages. Massachusetts Department of Environmental Protection, Division of Air Quality Control. Mass. Reg. Code Tit. 310, Chapter 6.00.
*MacEwen JD, Vernot EH, Haun CC. 1972. Continuous animal exposure to dichloromethane. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory. AMRL-TR-72-28. AD 746295.
*Mägli A, Messmer M, Leisinger T. 1998. Metabolism of dichloromethane by the strict anaerobe dehalobacterium formicoaceticum. Appl Environ Microbiol 64(2):646–650.16349505
Mahmud M, Kales SN. 1999. Methylene chloride poisoning in a cabinet worker. Environ Health Perspect 107(9):769–772.10464079
Mainwaring GW, Nash J, Davidson M, . 1996a. Isolation of a mouse Theta glutathione S-transferase active with methylene chloride. Biochem J 314:445–448.8670055
*Mainwaring GW, Wiliams SM, Foster JR, . 1996b. The distribution of theta-class gluthione S-transferases in the liver and lung of mouse, rat and human. Biochem J 318:297–303.8761485
*Maltoni C, Cotti G, Perino G, . 1988. Long-term carcinogenicity bioassays on methylene chloride administered by ingestion to Sprague-Dawley rats and Swiss mice and by inhalation to Sprague-Dawley rats^a^. Ann NY Acad Sci 534:352–366.3389665
*Manno M, Rugge M, Cocheo V. 1992. Double fatal inhalation of dichloromethane. Hum Exp Toxicol 11:540–545.1361146
*Mannsville Chemical Products Corporation. 1988. Chemical products synopsis: Methylene chloride. Mannsville Chemical Products Corp., Asbury Park, NJ.
Maronpot RR, Anna CH, Devereux TR, . 1995a. Considerations concerning the murine hepatocarcinogenicity of selected chlorinated hydrocarbons. Prog Clin Biol Res 391:305–323.8532724
*Maronpot RR, Devereux TR, Hegi M, . 1995b. Hepatic and pulmonary carcinogenicity of methylene chloride in mice: A search for mechanisms. Toxicol 102:73–81.
*Marzotko D, Pankow D. 1987. Effect of single dichloromethane administration on the adrenal medulla of male albino rats. Acta Histochem (Jena) 82:177–183.2451390
*Mattsson JL, Albee RR, Eisenbrandt DL. 1990. Neurotoxicologic evaluation of rats after 13 weeks of inhalation exposure to dichloromethane or carbon monoxide^1,2^. Pharmacol Biochem Beh 36:671–681.
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McCarroll NE, Cortina TA, Zieo MJ, . 1983. Evaluation of methylene chloride and vinylidene chloride in mutational assays. Environ Mutagen 5:426–427.
McConnell FE, Solleveld HA, Swenberg JA, . 1986. Guidelines for combining neoplasms for evaluation of rodent carcinogenesis studies. J Natl Can Inst 76:283–289.
*McCulloch A, Midgley PM. 1996. The production and global distribution of emissions of trichloroethane, tetrachloroethene, and dichloromethane over the period 1988-1992. Atmos Environ 30(4):601–606.
*McDougal JN, Jepson GW, Clewell HJ, . 1986. A physiological pharmacokinetic model for dermal absorption of vapors in the rat. Toxicol Appl Pharmacol 85:286–294.3764915
*McKenna MJ, Zempel JA. 1981. The dose-dependent metabolism of [^14^C] methylene chloride following oral administration to rat. Food Cosmet Toxicol 19:73–78.7262735
*McKenna MJ, Saunders JH, Boeckler WH, . 1980. The pharmacokinetics of inhaled methylene chloride in human volunteers [Abstract]. Toxicol Appl Pharm A59.
*McKenna MJ, Zempel JA, Braun WH. 1982. The pharmacokinetics of inhaled methylene chloride in rats. Toxicol Appl Pharmacol 65:1–10.6815830
McRobie DJ, Glover DD, Tracy TS. 1998. Effects of gestational and overt diabetes on human placental cytochromes P450 and glutathione S-transferase. Drug Metab Dispos 26(4):367–371.9531526
*Meister RT, ed. 1989. Farm chemicals handbook. Willoughby, OH: Meister Publishing Company, C193, C344.
*Mennear JH, McConnell EE, Huff JE, . 1988. Inhalation toxicity and carcinogenesis studies of methylene chloride (dichloromethane) in F344/N rats and B6C3F_1_ mice. Ann NY Acad Sci 534:343–351.3389664
*Meyer DJ, Coles B, Pemble SE . 1991. Theta, a new class of glutathione transferases purified from rat and man. Biochem J 274:409–414.1848757
*Meylan WM, Howard PH. 1995. Atom/fragment contribution method for estimating octanol-water partition coefficients. J Pharm Sci 84(1):83–175.7714751
*Michael LC, Pellizzari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22(5):565–570.22195629
Miller JL, Sardo MA, Thompson TL, . 1997. Effect of application solvents on heterotrophic and nitrifying populations in soil microcosms. Environ Toxicol Chem 16(3):447–451.
Miller MS, Juchau MR, Guengerich P, . 1996. Drug metabolic enzymes in developmental toxicology. Fundam Appl Toxicol 34:165–175.8954747
Miller JL, Sardo MA, Thompson TL, . 1997. Effect of application solvents on heterotrophic and nitrifying populations in soil microcosms. Environ Toxicol Chem 16(3):447–451.
Mills WB, Cheng JJ, Droppo JG, . 1997. Multimedia benchmarking analysis for three risk assessment models: RESRAD, MMSOILS, and MEPAS. Risk Anal 17:187–201.9202488
MIS. 1990. Agency for Toxic Substances and Disease Registry, Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. September 24, 1990.
Miyamoto K, Urano K. 1996. Reaction rates and intermediates of chlorinated organic compounds in water and soil. Chemosphere 32(12):2399–2408.
Mokrauer JE, Kosson DS. 1989. Electrophysical sorption of single carbon halogenated solvents onto soil. Environ Prog 8:1–5.
Moody DE. 1981. Correlations among changes in hepatic microsomal components after intoxication with alkyl halides and other hepatotoxins. Mol Pharmacol 20:685–693.6173739
Morgenroth E, Schroeder ED, Chang DPY, . 1996. Nutrient limitation in a compost biofilter degrading hexane. J Air Waste Manage Assoc 46:300–308.
*Morris JB, Smith FA, Garman RH. 1979. Studies on methylene chloride-induced fatty liver. Exp Mol Path 30:386–393.221241
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants. Clin Pharmacokinet 5:485–527.7002417
*Moskowitz S, Sharpio H. 1952. Fatal exposure to methylene chloride vapor. Ind Hyg Occ Med 6:116–123.
Muller S, Weise M, Krug T, . 1991. Adrenergic cardiovascular actions in rats as affected by dichloromethane exposure. Biomed Biochim Acta 50:307–311.1953698
Myers RAM. 1990. Carbon monoxide poisoning. In: Haddad LM, Winchester JF, ed. Clinical management of poisoning and drug overdose. Philadelphia, PA: W.B. Saunders Company, 1216–1222.
*Namkung E, Rittmann BE. 1987. Estimating volatile organic compound emissions from publicly owned treatment works. J Water Pollut Control Fed 59(7):670–678.
*NAS. 1977. Drinking water and health. Washington, DC: National Academy of Sciences. National Academy Press, 743–745.
*NAS. 1978. Scientific and technical assessments of environmental pollutants: Nonfluorinated halomethanes in the environment. Washington, DC: National Academy of Sciences.
NAS. 1980. National Academy of Sciences. Drinking water and health. Vol. 3. Washington, DC: National Academy Press.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology, National Academy of Sciences/National Research Council, Washington, DC: National Academy Press, 15–35.
NATICH. 1989. National Air Toxics Information Clearinghouse: NATICH database report on state, local and EPA air toxics activities. Report to U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. Research Triangle Park, NC, by Radian Corporation, Austin, TX. EPA450/3-89-29.
NCA. 1982. 24-month chronic toxicity and oncogenicity study of methylene chloride in rats. Final report. Vols. I-IV. Report to National Coffee Association by Hazleton Laboratories America, Inc. [Unpublished] 2112–2101.
NCA. 1983. 24-month oncogenicity study of methylene chloride in mice. Final report. Vol. I. Report to National Coffee Association by Hazleton Laboratories America, Inc. [Unpublished] 2112–2106.
*NC Div. Env. Manage. 1998. Toxic air pollutant guidelines. North Carolina Division of Environmental Management, Air Quality Section. NC Admin. Code Tit. 15A, R. 2D.1100.
*Nelson HH, Wiencke JK, Christiani DC, . 1995. Ethnic differences in the prevalence of the homozygous deleted genotype of glutathione S-transferase theta. Carcinogenesis 16:1243–1245.7767992
Newsom JM. 1985. Transport of organic compounds dissolved in ground water. Environmental Monitoring Review 5:28–36.
NFPA. 1978. Fire protection guide for hazardous materials. National Fire Protection Association.
*NIOSH. 1974. Methylene chloride: Development of a biologic standard for the industrial worker by breath analysis. Cincinnati, OH: National Institute of Occupational Safety and Health. NTIS No. PB83-245860. NIOSH-MCOW-ENVM-MC-74-9.
NIOSH. 1976. National Institute for Occupational Safety and Health. Criteria for a recommended standard…occupational exposure to methylene chloride. Cincinnati, OH: U.S. Department of Health, Education and Welfare, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. DHEW publ. no 76-138.
*NIOSH. 1984. Methylene chloride-method 1005. In: NIOSH manual of analytical methods. 3rd ed. Cincinnati, OH: Department of Health and Human Services, National Institute of Occupational Safety and Health. DHHS publ. no. 84-100.
*NIOSH. 1986. Current intelligence bulletin 46 - methylene chloride. Cinncinati, OH: National Institute for Occupational Safety and Health. Department of Health and Human Services. PB 86-114.
NIOSH. 1992. Recommendations for occupational safety health, compendium of policy documents and statements. U.S. Department of Health and Human Services, Centers for Disease Control, National Institute for Occupational Safety and Health, Cincinnati, OH.
NIOSH. 1993. Posthearing comments from the National Institute for Occupational Safety and Health on the Occupational Safety and Health Administration proposed rule on occupational exposure to methylene chloride. NTIS-PB95-200432.
*NIOSH. 1994. Methylene chloride - method no. 1005. In: NIOSH manual of analytical methods. 4^th^ ed. Cincinnati, OH: Department of Health and Human Services, National Institute of Occupational Safety and Health. DHHS publication no. 94-113.
*NIOSH. 1995. Report to Congress on workers’ home contamination study conducted under the workers’ family protection act. Cincinnati, OH: National Institute of Occupational Safety and Health. DHHS publication no. 95-123.
*NIOSH. 1997. National Institute for Occupational Safety and Health pocket guide to chemical hazards. Washington, DC: Department of Health and Human Services, 208-209.PB 97-177604. Pub No. 97-140.
*NIOSH 1999. Methylene chloride. Online pocket guide to chemical hazards. Wysiwyg://58/http://www.cdc.gov/niosh/npg/npg.html (http://www.cdc.gov/niosh/npg/npg.html)
*Nitschke KD, Burek JD, Bell TJ, . 1988a. Methylene chloride: A 2-year inhalation toxicity and oncogenicity study in rats. Fundam Appl Toxicol 11:48–59.3209017
*Nitschke KD, Eisenbrandt DL, Lomax LG, . 1988b. Methylene chloride: Two-generation inhalation reproductive study in rats. Fundam Appl Toxicol 11:60–67.3209018
*NJ Dept Env Protec. 1993. Ground water quality standards. New Jersey Department of Environmental Protection, Division of Water Quality. N.A.J.C. 7:9–6. http://www.state.nj.us/dep/
*NJ Dept. Env. Protect. 1998. Unit risk factors for inhalation. New Jersey Department of Environmental Protection, Air Management. NJ Admin Code Tit. 7, Chapter 7.27, Subchapter 7.
*NOES. 1990. National Occupational Exposure Survey, National Institute of Occupational Safety and Health, Cincinnati, OH. July 16, 1990.
NOHS. 1990. National Occupational Hazard Survey, National Institute of Occupational Safety and Health, Cincinnati, OH. July 16, 1990.
Nordic Chemicals Control Group. 1992. Nordic criteria for reproductive toxicity: Dichloromethane (methylene chloride). 31–33.
Norman WC. 1996a. Exposure to methylene chloride. Science 274:3271.
Norman WC. 1996b. Flawed estimates of methylene chloride exposures. Am J Ind Med 30:504–505.8892559
*Norpoth K, Witting U, Springorum M, . 1974. Induction of microsomal enzymes in the rat liver by inhalation of hydrocarbon solvents. Int Arch Arbeitsmed 33:315–321.4466815
*NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington DC, National Academy Press.
*NTDB. 1998. Dichloromethane. National Trade Data Bank: The Export Connection.
NTP. 1985. National Toxicology Program. 1985. NTP technical report on the toxicology and carcinogenesis studies of dichloromethane in F-344 in rats B6C3F1 mice/inhalation studies). February. NTP-TR-306. Board draft.
*NTP. 1986. National Toxicology Program. NTP technical report on the toxicology and carcinogenesis studies of dichloromethane (methylene chloride) (CAS No. 75-09-2) in F344/N rats and B6C3F_1_ mice (inhalation studies). Research Triangle Park, NC: U.S. Department of Health and Human Services. NTP-TR-306. NIH Pub No. 86-2562.
*NTP. 1989. National Toxicology Program. Dichloromethane (methylene chloride) CAS no. 75-90-2. Fifth annual report on carcinogens: 1989 Summary. Report of the National Institute of Environmental Health Sciences, Research Triangle Park, NC, by Technical Resources, Inc., Rockville, MD, 110-113. NTP 89-239.
NTP. 1998. National Toxicology Program. Dichloromethane (methylene chloride) CAS no. 75-90-2. Eighth annual report on carcinogens: 1998 Summary. Research Triangle Park, NC: National Institute of Environmental Health Sciences.
NTP. 1999. Report on carcinogens. National Toxicology Program. http://ntpserver.niehs.nih.gov/NewHomeRoc/AboutRoC.html.
*NY Dept. Env. Conserv. 1998. High toxicity air contaminants. New York Department of Environmental Conservation, Division of Air Resources. NY Comp. Codes R. & Regs. Tit. 6, Part 257.
Nylen P. 1996. Differing non-additive alterations in different parts of the nervous system of the rat. Food Chem Toxicol 34:1121–1123.9119324
*Oda Y, Yamazaki H, Thier R, . 1996. A new Salmonella typhimurium NM5004 strain expressing rat glutathione S-transferase 5-5: Use in detection of genotoxicity of dihaloalkanes using an SOS/umu test system. Carcinogenesis 17:297–302.
*OHM/TADS. 1998. Oil and Hazardous Materials/Technical Assistance Data System. Baltimore, MD: Chemical Information System, Inc. May 12, 1998.
*OK Dept Env Quality. 1997. Water quality standards. Oklahoma Department of Environmental Quality, Water Resources Board. Chapter 45. Http://www.deq.state.ok.us/
ORVWSC. 1982. Ohio River Valley Water Sanitary Commission. Assessment of water quality conditions. Ohio River Mainstream. 1981–1982. Table 13.
OSHA. 1979. General industry standards. Washington, DC: Occupational Safety and Health Administration, Department of Labor. OSHA 2206. Revised January 1978.
*OSHA. 1986. Occupational Safety and Health Administration. Occupational exposure to methylene chloride. Federal Register 51:42257.
OSHA. 1989. Occupational Safety and Health Administration: Part III. Federal Register 54:2332–2335, 2923, 2959.
OSHA. 1991. Occupational Safety and Health Administration: Part II. Federal Register 56:57036–57139.
*OSHA. 1997. Occupational exposure to methylene chloride. Occupational Safety and Health Administration, Department of Labor. Federal Register 62(7):1494–1600.
*OSHA. 1998a. Methylene chloride; Final rule. Department of Labor, Occupational Safety and Health Administration. Federal Register 63(183): 50712–50732.
*OSHA. 1998b. Substance safety data sheet and technical guidelines for methylene chloride. Occupational Safety and Health Administration, Department of Labor. Code of Federal Regulations. 29 CFR 1910.1052.
*OSHA. 1999. U. S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1052.
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-436.
*Otson R, Doyle EE, Williams DT, . 1983. Survey of selected organics in office air. Bull Environ Contam Toxicol 31:222–229.6616094
*Ott, MG, Skory LK, Holder BB, . 1983a. Health evaluation of employees occupationally exposed to methylene chloride: Clinical laboratory evaluation. Scand J Work Environ Health 9 (Suppl 1):17–25.
*Ott MG, Skory LK, Holder BB, . 1983b. Health evaluation of employees occupationally exposed to methylene chloride: Mortality. Scand J Work Environ Health 9(suppl1):8–16.
*Ott MG, Skory LK, Holder BB, . 1983c. Health evaluation of employees occupationally exposed to methylene chloride: Twenty-four hour electrocardiographic monitoring. Scand J Work Environ Health 9(suppl1):26–30.
*Ott MG, Skory LK, Holder BB, . 1983d. Health evaluation of employees occupationally exposed to methylene chloride: Metabolism data and oxygen half-saturation pressure. Scand J Work Environ Health 9(suppl1):31–38.
Ottenwalder H, Jager R, Thier R, . 1989. Influence of cytochrome P-450 inhibitors on the inhalative uptake of methyl chloride and methylene chloride in male B6C3F1 mice. Arch Toxicol Suppl 13:258–261.2549914
*Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development, Philadelphia, PA, WB Saunders, 22–238.
*Page BD, Charbonneau CF. 1977. Coffee and tea: Gas chromatographic determination of residual methylene chloride and trichloroethylene in decaffeinated instant and ground coffee with electrolytic conductivity and electron capture detection. J Assoc Off Anal Chem 60(3):710–715.858707
*Page BD, Charbonneau CF. 1984. Coffee and tea: Headspace gas chromatographic determination of methylene chloride in decaffeinated tea and coffee, with electrolytic conductivity detection. J Assoc Off Anal Chem 67(4):757–761.6469909
Page BD, Kennedy BPC. 1975. Determination of methylene chloride, ethylene dichloride, and trichloroethylene as solvent residues in spice oleoresins, using vacuum distillation and electron capture gas chromatography. J Assoc Off Anal Chem 58:1062–1068.1158825
*Page BD, Conacher HBS, Salminen J, . 1993. Survey of bottled drinking water sold in Canada. Part 2: Selected volatile organic compounds. J AOAC Int 76(1):26–31.8448439
*Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15(12):1475–1481.
Pankow D, Hoffman P. 1989. Dichloromethane metabolism to carbon monoxide can be induced by isoniazid, acetone and fasting. Arch Toxicol Suppl 13:302–303.2774950
*Pankow D, Jagielki S. 1993. Effect of methanol or modifications of the hepatic glutathione concentration on the metabolism of dichloromethane to carbon monoxide in rats. Hum Exp Toxicol 12:227–231.8100433
Pankow D, Marzotko D. 1987. [To the acute hepatic toxicity of dichloromethane.] Z Gesamte Hyg Ihre Grenzgeb 33:518–519. (German).
*Pankow JF, Rosen ME. 1988. Determination of volatile compounds in water by purging directly to a capillary column with whole column cryotrapping. Environ Sci Technol 22:398–405.
*Pankow D, Kretschmer, Weise M. 1991a. Effect of pyrazole on dichloromethane to carbon monoxide. Arch Toxicol Suppl 14:246–248.1805740
*Pankow D, Matschiner F, Weigmann HJ. 1991b. Influence of aromatic hydrocarbons on the metabolism of dichloromethane to carbon monoxide in rats. Toxicology 68:89–100.1871779
Pankow D, Weise M, Hoffmann P. 1992. Effect of isoniazid or phenobarbital pretreatment on the metabolism of dihalomethanes to carbon monoxide. Pol J Occup Med Environ Health 5:245–250.1490123
Paone DA, Weinreb HG, Bauer MJ, . 1996. A pilot-scale fluid bed reactor for treatment of methlyene chloride process stream. In: Hickey RF, Smith G, ed. Biotechnological industrial waste treatment bioremediation: International symposium on the implementation of biotechnological industrial waste treatment bioremediation. Boca Raton, Florida: Lewis, 143–153.
Park JK, Kim JY, Edil TB. 1996. Mitigation of organic compound movement in landfills by shredded tires. Water Environ Res 68(1):4–10.
Pearson CR, McConnell G. 1975. Chlorinated C_1_ and C_2_ hydrocarbons in the marine environment. Proc R Soc London B 189:305–332.238199
*Pelekis M, Krishnan K. 1997. Assessing the relevance of rodent data on chemical interactions for health risk assessment purposes: A case study with dichloromethane-toluene mixture. Regul Toxicol Pharmacol 25:79–86.9056503
Pelekis M, Poulin P, Krishnan K. 1995. An approach for incorporating tissue composition into physiologically based pharmacokinetic models. Toxicol Ind Health 11:511–522.8677516
*Pelkonen O, Raunio H, Rautio A, . 1999. Xenobiotic-metabolizing enzymes and cancer risk: correspondence between genotype and phenotype. In: Vineis P, Malats N, Lang M, . ed. Metabolic polymorphisms and susceptibility to cancer. Lyon, France: International Agency for Research on Cancer, 77–78.
Pellizzari ED. 1974. Electron capture detection in gas chromatography. J Chromatogr 98:323–361.
Pellizzari ED. 1977. Analysis of organic air pollutants by gas chromatography and mass spectroscopy. U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/2-77-100.
Pellizzari ED. 1978a. Measurement of carcinogenic vapors in ambient atmospheres. U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/7-78-062.
Pellizzari ED. 1978b. Quantification of chlorinated hydrocarbons in previously collected air samples. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. EPA-450/3-78-112.
Pellizzari ED, Bunch JE. 1979. Ambient air carcinogenic vapors: Improved sampling and analytical techniques and field studies. U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/2-79-081.
Pellizzari ED, Erickson MD, Zweidinger RA. 1979. Formulation of a preliminary assessment of halogenated organic compounds in man and environmental media. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. EPA-560/13-179-006.
*Pellizzari ED, Hartwell TD, Harris BSH, . 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28:322–328.7082873
Pemble S, Schroeder KR, Spencer SR, . 1994. Human glutathione S-transferase Theta (GSTT1): cDNA cloning and the characterization of a genetic polymorphism. Biochem J 300:271–276.8198545
*Perocco P, Prodi G. 1981. DNA damage by halokanes in human lymphocytes cultured in vitro. Cancer Lett 13:213–218.6457684
*Peterson JE. 1978. Modeling the uptake, metabolism, and excretion of dichloromethane by man. Am Ind Hyg Assoc J 39:41–47.629207
*Plumb RH. 1987. A comparison of ground water monitoring data from CERCLA and RCRA sites. Ground Water Monit Rev (Fall):94–100.
Post W, Kromhout H, Heederik D, . 1991. Semiquantitative estimates of exposure to methylene chloride and styrene: The influence of quantitative exposure data. Appl Occup Environ Hyg 6:197–204.
*Poulin P, Krishnan K. 1996. Molecular structure-based prediction of the partition coefficients of organic chemicals for physiological pharmacokinetic models. Toxicol Meth 6(3):117–137.
*Poulin P, Krishnan K. 1998. A quantitative structure-toxicokinetic relationship model for highly metabolized chemicals. ATLA 26:45–59.26043283
*Poulin P, Krishnan K. 1999. Molecular structure-based prediction of the toxicokinetics of inhaled vapors in humans. Int J Toxicol 18:7–18.
*Putz VR, Johnson BL, Setzer JV. 1979. A comparative study of the effects of carbon monoxide and methylene chloride on human performance. J Environ Pathol Toxicol 2:97–112.512567
*Raje R, Basso M, Tolen T, . 1988. Evaluation of in vivo mutagenicity of low-dose methylene chloride in mice. J Am Coll Toxicol 7(5):699–703.
*Ramsey JC, Andersen ME. 1984. A physiologically based description of the inhalation pharmacokinetics of styrene in rats and humans. Toxicol Appl Pharmacol 73:159–175.6710512
*Rasheed A, Hines RN, McCarver-May DG. 1997. Variation in induction of human placental CYP2E1: Possible role in susceptibility to fetal alcohol syndrome? Toxicol Appl Pharmacol 144:396–400.9194424
Rasmussen RA, Harsch DE, Sweany PH, . 1977. Determination of atmospheric halocarbons by a temperature programmed gas chromatographic freezeout concentration method. JAPCA 27:579–581.
Rastogi SC. 1994. Regulation of dichloromethane and 1,1,1-trichloroethane in cosmetic products. Sci Total Environ 156:23–25.
Ratney RS, Wegman DH, Elkins HB. 1974. In vivo conversion of methylene chloride to carbon monoxide. Arch Environ Health 28:223–226.4814958
*Rebert CS, Matteucci MJ, Pryor GT. 1989. Acute effects of inhaled dichloromethane on the EEG and sensory-evoked potentials of Fischer-344 rats. Pharmacol Biochem Beh 34:619–629.
*Reitz RH. 1990. Quantitating the production of biological reactive intermediates in target tissues: Example, dichloromethane. In: Witmer CM, . ed. Biological reactives intermediates IV. New York: Plenum Press, 649–655.
*Reitz RH. 1991. Estimating the risk of human cancer associated with exposure to methylene chloride. Ann Ist Super Sanita 27(4):609–614.1820733
*Reitz RH, Smith FA, Andersen ME, . 1988. Use of physiological pharmacokinetics in cancer risk assessments: A study of methylene chloride. In: Paustenbach DJ, ed. The risk assessment of environmental and human health hazards. New York, NY: John Wiley & Sons, Inc., 238–265.
*Reitz RH, Mendrala AL, Guengerich FP. 1989. In vitro metabolism of methylene chloride in human and animal tissues: Use in physiologically based pharmacokinetic models. Toxicol Appl Pharmacol 97:230–246.2922756
*Reitz RH, Hays SM, Gargas ML. 1997. Addressing priority data needs for methylene chloride with physiologically based pharmacokinetic modeling. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Rhomberg L. 1995. Use of quantitative modelling in methylene chloride risk assessment. Toxicol 102:95–114.
Rhone-Poulenc, Inc. 1994. Notice of monitored concentrations of methylene chloride, 1,1,1trichloroethane, benzene, in local wells. TSCATS-441027. NTIS/OTS 0556009.
Rice D. 2000. Parallels between attention deficit hyperactivity disorder and behavioral deficits produced by neurotoxic exposure in monkeys. Environ Health Perspect 108(suppl 3)405–408.10852836
Rice D, Barone S. 2000. Critical periods of vulnerability for the developing nervous system: Evidence from humans and animal models. Environ Health Perspect 108(suppl 3):511–533.10852851
*RI Dept Env Management. 1992. Air toxics. Rhode Island Department of Environmental Management, Divison of Air and Hazardous Materials. Air pollution control regulation No. 22. Http://www.sec.state.ri.us/dem/.
RI Dept. Env. Management. 1998. Acceptable ambient levels. Rhode Island Department of Environmental Management, Division of Air Resources. Http://www.sec.state.ri.us/dem/regs.htm. November 2, 1999.
*Riley EC, Fasset DW, Sutton WL. 1966. Methylene chloride vapor in expired air of human subjects. Am Ind Hyg Assoc J 27:341–348.5967616
Rittman BE, McCarty PL. 1980. Utilization of dichloromethane by suspended and fixed-film bacteria. Appl Environ Microbiol 39:1225–1226.16345585
*Roberts CJC, Marshall FPF. 1976. Recovery after “lethal” quantity of paint remover. Brit Med J (January):20–21.
Robinson E. 1978. Analysis of halocarbons in Antarctica. Report to the National Science Foundation, Washington, DC. Report 78/13-42
Rodkey FL, Collison HA. 1977. Effect of dihalogenated methanes on the in vivo production of carbon monoxide and methane by rats. Toxicol Appl Pharmacol 40:39–47.867431
*Rosengren LE, Kjellstrand P, Aurell A, . 1986. Irreversible effects of dichloromethane on the brain after long term exposure: A quantitative study of DNA and the glial cell marker proteins S-100 and GFA. Br J Ind Med 43:291–299.3707866
*Roth RP, Drew RT, Lo RJ, . 1975. Dichloromethane inhalation, carboxyhemoglobin concentrations, and drug metabolizing enzymes in rabbits. Toxicol Appl Pharmacol 33:427–437.1188941
*Roy WR, Griffin RA. 1985. Mobility of organic solvents in water-saturated soil materials. Environ Geol Water Sci 7(4):241–247.
RTECS. 1998. Registry of Toxic Effects of Chemical Substances. National Library of Medicine, Bethesda, MD. May 11, 1998.
*RTECS. 1999. Registry of Toxic Effects of Chemical Substances. National Library of Medicine, Bethesda, MD.
*Ruch RJ, Crist KA, Klaunig JE. 1989. Effects of culture duration on hydrogen peroxide-induced hepatocyte toxicity. Toxicol Appl Pharm 100:451–464.
Ruelle P, Kesselring UW. 1997. Aqueous solubility prediction of environmentally important chemicals from the mobile order thermodynamics. Chemosphere 34(2):275–298.
*Ruth JH. 1986. Odor thresholds and initation levels of several chemical substances. A review. Am Ind Hyg Assoc J 47:A142–A151.3706135
Sakai T, Miyake K, Kurata M, . 1991. A case of severe hepatic microcirculatory failure with jaundice and fibrosis around the sinusoid caused by long-term exposure of methylene chloride. Nippon Shokakibyo Gakkai Zasshi 88:185–189.2030563
*Sasaki YF, Saga A, Akasaka M, . 1998. Detection of in vivo genotoxicity of haloalkanes and haloalkenes carcinogenic to rodents by the alkaline single cell gel electrophoresis (comet) assay in multiple mouse organs. Mutat Res 419:13–20.9804871
*Savard S, Otson R, Douglas GR. 1992. Mutagenicity and chemical analysis of sequential organic extracts of airborne particulates. Mutat Res 276:101–115.1370100
*Savolainen H, Pfäffli P, Tengén M, . 1977. Biochemical and behavioural effects of inhalation exposure to tetrachloroethylene and dichloromethane. J Neuropath Exp Neurol 36:941–949.925719
*Savolainen H, Kurppa K, Pfäffli P, . 1981. Dose-related effects of dichloromethane on rat brain in short-term inhalation exposure. Chem Biol Interact 34:315–322.6161709
*Sawhney BL. 1989. Movement of organic chemicals through landfill and hazardous waste disposal sites. In: Reactions and movement of organic chemicals in soils. Madison, WI: Soil Science Society of America and American and American Society of Agronomy, 447–474.
*Sax NI, Lewis RJ. 1987. Hawley’s condensed chemical dictionary. 11th ed. New York, NY: Van Nostrand Reinhold Company, 768.
SC Dept. Health & Env. Control. 1998. Toxic air pollutants with maximum allowable concentrations. South Carolina Department of Health & Environmental Control, Bureau of Air Quality. 24A SC Code Ann. Regs. 61-62.5, Standard 8.
Schnaak W, Küchler T, Kujawa M, . 1997. Organic contaminants in sewage sludge and their ecotoxicological significance in the agricultural utilization of sewage sludge. Chemosphere 35(½):5–11.
*Scholz J, Klapperstuck M, Weise M, . 1991. Acute effects of dichloromethane on arrhythmia development during the early phase of myocardial ischemia and reperfusion in the rat. Arch Toxicol Suppl 14:128–131.1805719
*Schröder KR, Hallier E, Meyer DJ. 1996. Purification and characterization of a new glutathione S-transferase, class θ, from human erythrocytes. Arch Toxicol 70:559–566.8831906
Schwartz LJ. 1991. Toxic effects of selected industrial solvents in batch and continuous anaerobic reactors. Appl Biochem Biotech 28/29:297–305.
*Schwetz BA, Leong BKJ, Gehring PJ. 1975. The effect of maternally inhaled trichloroethylene, perchloroethane, methyl chloroform, and methylene chloride on embryonal and fetal development in mice and rats. Toxicol Appl Pharmacol 32:84–96.1135881
*SD Dept Env Natural Resources. 1998. Water hygiene. South Dakota Department of Environment and Natural Resources, Drinking Water Program. Article 74:04. http://www.state.sd.us/state/executive/denr/denr.html
Seilkop SK. 1995. The effect of body weight on tumor incidence and carcinogenicity testing in B6C3F1 mice and F344 rats. Fundam Appl Toxicol 24:247–259.7737436
Selan FM, Evans MA. 1987. The role of microtubules in chlorinated alkane-induced fatty liver. Toxicol Lett 36:117–127.3576642
Selevan SG, Kimmel CA, Mendola P. 2000. Identifying critical windows of exposure for children’s health. Environ Health Perspect 108(suppl 3):451–455.10852844
Semprini L. 1997. Strategies for the aerobic co-metabolism of chlorinated solvents. Curr Opin Biotechnol 8:296–308.9206010
Serota D, Ulland B, Carlborg F. 1984. Hazleton chronic oral study in mice. Food solvents workshop no. 1. Methylene chloride, March 8-9, Bethesda, Maryland. Toxicol Appl Pharmacol 87:185–205.
*Serota DG, Thakur AK, Ulland BM, . 1986a. A two-year drinking-water study of dichloromethane in rodents. I. Rats. Food Chem Toxicol 24(9):951–958.3781442
*Serota DG, Thakur AK, Ulland BM, . 1986b. A two-year drinking-water study of dichloromethane in rodents. II. Mice. Food Chem Toxicol 24(9):959–963.3781443
Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Geiger SR, ed. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Shah JJ, Singh HB. 1988. Distribution of volatile organic chemicals in outdoor and indoor air. Environ Sci Technol 22:1381–1388.22200458
*Sheehan GC, Freedman DL. 1996. High rate treatment of dichloromethane in anoxic and aerobic fluidized bed bioreactors. WEFTEC ’96, The 69th Annual Conference and Exposition of the Water Environment Federation, October 5-9, 1996, Dallas, Texas.
Sheldon T, Richardson CR, Hamilton K, . eds. 1986. Methylene chloride: An evaluation in the mouse micronucleus test. ICI Central Toxicology Laboratory Report No. CTL/P/1603, September 19. TSCATS 305690. OTS 0514366. EPA 86-880000288.
*Sheldon T, Richardson CR, Elliott BM. 1987. Inactivity of methylene chloride in the mouse bone marrow micronucleus assay. Mutagenesis 2(1):57–59.3331695
Shelley ML, Andersen ME, Fisher JW. 1989. A risk assessment approach for nursing infants exposed to volatile organics through the mother’s occupational inhalation exposure. Appl Ind Hyg 4:21–26.
Sherman J, Chin B, Huibers PDT, . 1998. Solvent replacement for green processing. Environ Health Perspect Suppl 106(1):253–271.
*Sherratt PJ, Pulford DJ, Harrison DJ, . 1997. Evidence that human class Theta glutathione S-transferase T1-1 can catalyse the activation of dichloromethane, a liver and lung carcinogen in the mouse: Comparison of the tissue distribution of GST T1-1 with that of classes alpha, mu and pi GST in human. Biochem J 326:837–846.9307035
Sherratt PJ, Manson MM, Thomson AM, . 1998. Increased bioactivation of dihaloalkanes in rat liver due to induction of class theta glutathione s-transferase T1-1. Biochem J 335:619–630.9794803
*Shih RD. 1998. Hydrocarbons. In: Goldfrank LR, Flomenbaum NE, Lewin NA, . ed. Goldfrank’s toxicologic emergencies. Stamford, Connecticut: Appleton & Lange, 1383–1398.
*Shikiya J, Tsou G, Kowalski J, . 1984. Ambient monitoring of selected halogenate hydrocarbons and benzene in the California south coast air basin. Proceedings of the 77th annual meeting of the Air Pollution Control Association, San Francisco, CA, June 24-29, 1984.
Sidebottom H, Franklin J. 1996. The atmospheric fate and impact of hydro-chlorofluorocarbons and chlorinated solvents. Pure Appl Chem 68(9):1757–1769.
*Sikkema J, de Bont JAM, Poolman B. 1995. Mechanisms of membrane toxicity of hydrocarbons. Microbiol Rev 59(2):201–222.7603409
*Simula TP, Glancey MJ, Wolf CR. 1993. Human glutathione S-transferase-expressing Salmonella typhimurium tester strains to study the activation/detoxification of mutagenic compounds: Studies with halogenated compounds, aromatic amines and aflatoxin B_1_. Carcinogenesis 14:1371–1376.8330352
Singh HB. 1977. Atmospheric halocarbons. Evidence in favor of reduced average hydroxyl radical concentrations in the troposphere. Geophys Res Lett 4:101–104.
Singh HB, Salas LJ, Shigeishi H, . 1979. Atmospheric distributions, sources, and sinks of selected halocarbons, hydrocarbons, SF_6_, and N_2_O. Report to U.S. Environmental Protection Agency, Environmental Sciences Research Laboratory, Research Triangle Park, NC, by SRI International, Menlo Park, CA. EPA-600/3-79-107.
*Singh HB, Salas LJ, Smith AJ, . 1981. Measurements of some potentially hazardous organic chemicals in urban environments. Atmos Environ 15:601–612.
*Singh HB, Salas LJ, Stiles RE. 1983. Selected man-made halogenated chemicals in the air and oceanic environment. J Geophy Res 88:3675–3683.
*Singh HB, Salas LJ, Stiles RE, . 1982. Distribution of selected gaseous organic mutagens and suspect carcinogens in ambient air. Environ Sci Technol 16:872–880.22236265
Sinkkonen S, Welling L, Vattulainen A, . 1996. Short chain aliphatic halocarbons and polychlorinated biphenyls in pine needles: effects of metal scrap plant emissions. Chemosphere 32(10):1971–1982.
Sitting M. 1985. Handbook of toxic and hazardous chemicals and carcinogens. 2nd ed. Park Ridge, NY: Noyes Publications, 598–601.
Snodgrass WR. 1992. Physiological and biochemical differences between children and adults as determinants of toxic response to environmental pollutants. In: Guzelian PS, Henry CJ, Olin SS, ed. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press, 35–42.
*Snyder RW, Mishel HS, Christensen GC. 1992a. Pulmonary toxicity following exposure to methylene chloride and its combustion product, phosgene. Chest 101:860–861.1541163
*Snyder RW, Mishel HS, Christensen GC. 1992b. Pulmonary toxicity following exposure to methylene chloride and its combustion product, phosgene. Chest 102:1921.1446539
*Soden KJ. 1993. An evaluation of chronic methylene chloride exposure. J Occup Med 35(3):282–286.8455098
*Soden KJ, Marras G, Amsel J. 1996. Carboxyhemoglobin levels in methylene chloride-exposed employees. J Occup Environ Med 38(4):367–371.8925320
Spivack JL, Shank GK, Nick RJ, . 1996. Biodegredation of methlyene chloride in industrial process wastewater: evaluation of reactor configurations and comparison of a pure hypomicrobial culture with wastewater treatment sludge. In: Hickey RF, Smith G, ed. Biotechnological industrial waste treatment bioremediation: International symposium on the implementation of biotechnological industrial waste treatment bioremediation. Boca Raton, Florida: Lewis, 111–142.
SRI. 1997. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 749.
*SRI. 1999. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 744, 122, 123, 415.
*Staats DA, Fisher JW, Connolly RB. 1991. Gastrointestinal absorption of xenobiotics in physiologically based pharmacokinetic models: A two-compartment description. Drug Metab Dispos 19(1):144–148.1673388
*Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
Stauffer Chemical Company. 1973. Toxicology laboratory report T-4171; Methlyene chloride. Westport, Connecticut. OTS84003A.
Stayner LT, Bailer AJ. 1993. Comparing toxicologic and epidemiologic studies: Methylene chloride–A case study. Risk Anal 13:667–673.8310163
*Steinmetz KL, Green CE, Bakke JP, . 1988. Induction of unscheduled DNA synthesis in primary cultures of rat, mouse, hamster, monkey, and human hepatocytes. Mutat Res 206:91–102.3137465
*Stephens EA, Taylor JA, Kaplan N, . 1994. Ethnic variation in the CYP2E1 gene: Polymorphism analysis of 695 African-Americans and Taiwanese. Pharmacogenetics 4:185–192.7987402
*Stewart RD, Dodd HC. 1964. Absorption of carbon tetrachloride, trichloroethylene, tetrachloroethylene, methylene chloride and 1,1,1-trichloroethane through human skin. Am Ind Hyg Assoc J 25:439–446.14209666
*Stewart RD, Hake CL. 1976. Paint remover hazard. JAMA 235(4):398–401.946084
*Stewart RD, Fischer TN, Hosko MJ, . 1972. Experimental human exposure to methylene chloride. Arch Environ Health 25:342–348.4651547
Storm JE, Rozman KK. 1998. Derivation of an occupational exposure limit (OEL) for methylene chloride based on acute CNS effects and relative potency analysis. Regul Toxicol Pharmacol 27:240–250.9693075
*Stott WT, Dryzga MD, Ramsey JC. 1983. Blood flow distribution in the mouse. J Appl Toxicol 3(6):310–312.6677653
*Stover EL, Kincannon DF. 1983. Biological treatability of specific organic compounds found in chemical industry wastewaters. J Water Pollut Control Fed 55(1):97–109.
*Strange RC, Fryer AA. 1999. The glutathione S-transferases: influence of polymorphism on cancer susceptibility. In: Vineis P, Malats N, Lang M, . ed. Metabolic polymorphisms and susceptibility to cancer. Lyon, France: International Agency for Research on Cancer, 231–249.
*Stubbins MJ, Wolf CR. 1999. Additional polymorphisms and cancer. In: Vineis P, Malats N, Lang M, . ed. Metabolic polymorphisms and susceptibility to cancer. Lyon, France: International Agency for Research on Cancer, 271–301.
Stubin AI, Brosnan TM, Porter KD, . 1996. Organic priority pollutants in New York City municipal wastewaters: 1989-1993. Water Environ Res 68:1037–1044.
*Svirbely JL, Highman B, Alford WF, . 1947. The toxicity and narcotic action of mono-chloro-mono-bromo-methane with special reference to inorganic and volatile bromide in blood, urine and brain. J Ind Hyg Toxicol 29(6):382–389.20271003
*Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85:17–28.
Sylvestre M, Bertrand J-L, Viel G. 1997. Feasibility study for the potential use of biocatalytic systems to destroy chlorofluorocarbons (CFCs). Crit Rev Environ Sci 27(2):87–111.
*Tabak HH, Quave SA, Mashni CI, . 1981. Biodegredability studies with organic priority pollutant compounds. J Water Pollut Control Assoc 53(10):1503–1518.
*Tardif R, Laparé S, Krishnan K, . 1993. Physiologically based modeling of the toxicokinetic interaction between toluene and m-xylene in the rat. Toxicol Appl Pharmacol 120:266–273.8511796
*Taskinen H, Lindbohm M-L, Hemminki K. 1986. Spontaneous abortions among women working in the pharmaceutical industry. Br J Ind Med 43:199–205.3947584
Tateishi T, Nakura H, Asoh M, . 1997. A comparison of hepatic cytochrome P450 protein expression between infancy and postinfancy. Life Sci 61(26):2567–2574.9416779
*Tay P, Tan KT, Sam CT. 1995. Fatal gassing due to methylene chloride–A case report. Singapore Med J 36:444–445.8919167
Teschke K, Ahrens W, Andersen A, . 1999. Occupational exposure to chemical and biological agents in the nonproduction departments of pulp, paper, and paper product mills: an international study. Am Ind Hyg Assoc J 60:73–83.10028618
Testai E, Di Marzio S, di Domenico A, . 1995. An in vitro investigation of the reductive metabolism of chloroform. Arch Toxicol 70:83–88.8773179
Thiebaud H, Merlin G, Alary J, . 1991. Gas chromatographic determination of dichloromethane in the water of model aquatic ecosystems. Analusis 19:208–213.
*Thier R, Foest U, Deutshmann S, . 1991. Distribution of methylene chloride in human blood. Arch Toxicol Suppl 14:254–258.1805743
Thier R, Taylor JB, Pemble SE, . 1993. Expression of mammalian glutathione S-transferase 5-5 in Salmonella typhimurium TA1535 leads to base-pair mutations upon exposure to dihalomethanes. Proc Natl Acad Sci 90:8576–8580.8378332
*Thier R, Wiebel FA, Hinkel A, . 1998. Species difference in the glutathione transferase GSTT1-1 activity towards the model substrates methyl chloride and dichloromethane in liver and kidney. Arch Toxicol 72:622–629.9851677
Thilagar AK, Kumaroo V. 1983. Induction of chromosome damage by methylene chloride in CHO cells. Mutat Res 116:361–367.6835252
*Thilagar AK, Back AM, Kirby PE, . 1984a. Evaluation of dichloromethane in short term in vitro genetic toxicity assays. Environ Mutagen 6:418–419.
Thilagar AK, Kumaroo PV, Clark JJ, . 1984b. Induction of chromosome damage by dichloromethane in cultured human peripheral lymphocytes, CHO cells and mouse lymphoma L5178Y cells. Environ Mutagen 6:422.
Thomas AA, Pinkerton MK, Warden JA. 1972. Effects of low-level dichloromethane exposure on the spontaneous activity of mice. In: Proceedings of the 3rd annual conference on environmental toxicology. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory. AMRL-TR72-130, 185-189.
*Thomas PE, Bandiera S, Maines SL, . 1987. Regulation of cytochrome P-450j, a high-affinity N-nitrosodimethylamine demethylase, in rat hepatic microsomes. Biochemistry 26(8):2280–2289.3113478
Thomas, RG. 1990. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of Chemical Property Estimation Methods. American Chemical Society Washington DC, 2^nd^ Printing. Chapter 15.
Thomas RS, Yang RSH, Morgan DG, . 1996. PBPK modeling/Monte Carlo simulation of methylene chloride kinetic changes in mice in relation to age and acute, subchronic, and chronic inhalation exposure. Environ Health Perspec 104: 858–865.
*Thomas V. 1975. Biological-mathematical modeling of chronic toxicity. Wright Patterson Air Force Base Research Report. AMRL-TR-75-5.
Tiffany-Castiglioni E, Ehrich M, Dees L, . 1999. Bridging the gap between in vitro and in vivo models for neurotoxicology. Toxicol Sci 51:178–183.10543019
*Tomaszewski C. 1998. Carbon monoxide. In: Goldfrank LR, Flomenbaum NE, Lewin NA, . ed. Goldfrank’s toxicologic emergencies. Stamford, Connecticut: Appleton & Lange, 1551–1563.
*Tomenson JA, Bonner SM, Heijne CG, . 1997. Mortality of workers exposed to methylene chloride employed at a plant producing cellulose triacetate film base. Occup Environ Med 54:470–476.9282122
Travis CC, Hattemer-Frey HA, Arms AD. 1988. Relationship between dietary intake of organic chemicals and their concentrations in human adipose tissue and breast milk. Arch Environ Contam Toxicol 17:473–478.3044283
*TRI88. 1990. Toxic chemical release inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
TRI96. 1998. Toxic chemical release inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI97. 1999. Toxic chemical release inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI98. 2000. Toxic chemical release inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Trueman RW, Ashby J. 1987. Lack of UDS activity in the livers of mice and rats exposed to dichloromethane. Environ Mol Mutagen 10:189–195.3691491
Truman RW, Ashby J, eds. 1986. Methylene chloride: In vivo and in vitro unscheduled DNA synthesis studies in the mouse and the rat. ICI Central Toxicology Laboratory, Report no. CTL/P 1444, January 21.
Tsang JSH, Ho YB. 1998. Biodedegredation of halogenated compounds. In: Rama BC, ed. Damaged ecosystem restoration. Singapore: World Scientific, 203–224.
*Ugazio G, Burdino E, Danni O, . 1973. Hepatoxicity and lethality of halogenoalkanes. Biochem Soc Trans 1:968–972.
*USC. 1999. United States Code. 74 USC 7412.
*USITC. 1989. Synthetic organic chemicals: United States production and sales, 1988. Washington, DC: U.S. International Trade Commission. USITC Publication 2219, 15-7, 15-30.
VanHylckama Vlieg JET, De Koning W, Janssen DB. 1996. Transformation kinetics of chlorinated ethenes by methylosinus trichosporium OB3b and detection of unstable epoxides by on-line gas chromatography. Appl Environ Microbiol 62(9):3304–3312.16535402
*Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York: Van Nostrand Reinhold Company, 848–849.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
VIEW Database. 1989. Agency for Toxic Substances and Disease Registry, Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. June 20, 1989.
Vincent R, Poirot P, Subra I. 1994. Occupational exposure to organic solvents during paint stripping and painting operations in the aeronautical industry. Int Arch Occup Environ Health 65:377–380.8034362
Vineis P, Faggiano F. 1991. Epidemiological models and prevention of cancer. Ann Ocol 2:559–563.
Vineis P, Malats N, Lang M, . 1999. Metabolic polymorphisms and susceptibility to cancer. IARC Scientific Publications ed. Lyon, France: International Agency for Research on Cancer,.
Von Oettingen WF, Powell CC, Sharpless NE, . 1949. Relation between the toxic action of chlorinated methanes and their chemical and physicochemical properties. NIH Bulletin 191. Federal Security Agency, U.S. Public Health Service, National Institutes of Health.
*VT Nat. Res. Agency 1998. Hazard ambient air standards: Hazardous air contaminants. Vermont Natural Resources Agency, Department of Environmental Conservation, Air Pollution Control Division. http://www.anr.state.vt.us/dec/air/airtoxic.htm. November 2, 1999.
Vuilleumier S, Leisinger T. 1996. Protein engineering studies of dichloromethane dehalogenase/glutathione S-transferase from Methylophilus sp. strain DM11: Ser12 but not Tyr6 is required for enzyme activity. Eur J Biochem 239:410–417.8706748
Vuilleumier S, Sorribas H, Leisinger T. 1997. Identification of a novel determinant of glutathione affinity in dichloromethane dehalogenases/glutathione S-transferases. Biochem Biophys Res Commun 238:452–456.9299530
*WA Dept. Ecology 1998. Class A toxic air pollutants: With established acceptable source impact levels. Washington Department of Ecology, Air Quality Program. http://www.wa.gov/ecology/leg/laws-etc.html. November 12, 1999.
Waalkes MP, Harvey MJ, Klaassen CD. 1984. Relative in vitro affinity of hepatic metallothionein for metals. Toxicol Lett 20:33–39.6695394
*Walters SM. 1986. Cleanup of samples. In: Zweig G, Sherma J, eds. Analytical methods for pesticides and plant growth regulators. Vol. 15: Principles statistics, and applications. New York, NY: Academic Press Inc., 67–110.
*Wan Y-JY, Poland RE, Lin K-M. 1998. Genetic polymorhism of CYP2E1, ADH2, and ALDH2 in Mexican-Americans. Genetic Testing 2(1):79–83.10464602
Watanabe K, Seno H, Ishii A, . 1997. Capillary gas chromatography with cryogenic oven temperature for headspace samples: analysis of chloroform or methylene chloride in whole blood. Anal Chem 69:5178–5181.9414620
*Weast RC, ed. 1985. CRC handbook of chemistry and physics. 66th ed. Boca Raton, FL: CRC Press Inc., C-349.
*Weinstein RS, Diamond SS. 1972. Hepatotoxicity of dichloromethane (methylene chloride) with continuous inhalation exposure at a low dose level. In: Proceedings of the 3rd annual conference on environmental toxicology. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, 209-220. AMRL-TR-72-130.
Weinstein RS, Boyd DD, Back KC. 1972. Effects of continuous inhalation of dichloromethane in the mouse-morphologic and functional observations. Toxicol Appl Pharmacol 23:660.4118878
Weiss G. 1967. Toxic encephalosis as an occupational hazard with methylene chloride. Zentralbl Arbeitsmed 17:282–285.5614174
Welch L. 1987. Reports of clinical disease secondary to methylene chloride exposure-a collection of 141 cases. Unpublished study. Report to U.S. Environmental Protection Agency, Office of Pesticide and Toxic Substances, Washington, DC.
Welke B, Ettlinger K, Riederer M. 1998. Sorption of volatile organic chemicals in plant surfaces. Environ Sci Technol 32:1099–1104.
*Wells GG, Waldron HA. 1984. Methylene chloride burns. Br J Ind Med 41:420.6743591
*Wells VE, Schrader SM, McCammon CS, . 1989. Letter to the editor. Reprod Toxicol 3:281–282.2520532
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32a:10–18.
*White RF, Proctor SP, Echeverria D, . 1995. Neurobehavioral effects of acute and chronic mixed-solvent exposure in the screen printing industry. Am J Ind Med 28:221–231.8585519
White PA, Rasmusen JB, Blaise C. 1996. Comparing the presence, potency, and potential hazard of genotoxins extracted from a broad range of industrial effluents. Environ Mol Mutagen 27:116–139.8603665
*Whitehead LW, Ball GL, Fine LJ, . 1984. Solvent vapor exposures in booth spray painting and spray glueing, and associated operations. Am Ind Hyg Assoc J 45(11):767–772.6507277
*WHO. 1996. Environmental health criteria 164: Methylene chloride, 2nd ed. World Health Organization, Geneva, Switzerland.
*WI Dept Natural Resources. 1997. Control of hazardous pollutants. Wisconsin Department of Natural Resources. Chs. 400-499 NR 445. http://www.dnr.state.wi.us/org/aw/air/index.htm
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise volume II The elements part A. New York NY: Academic Press.
Wiger R. 1991. Dichloromethane: Summary and evaluation of effects on reproduction. In: Freij L, ed. Effects on reproduction of dichloromethane, n-hexane, and 1,1,1-trichloroethane. Solna, Sweden: Nordic Chemicals Control Group, 9–27.
*Winek CL, Collom WD, Esposito F. 1981. Accidental methylene chloride fatality. Forensic Sci Int 18:165–168.7297968
*Winneke, G. 1974. Behavioral effects of methylene chloride and carbon monoxide as assessed by sensory and psychomotor performance. In: Xintaras C, Johnson BL, de Groot I, eds. Behavioral toxicology: Early detection of occupational hazards. Washington DC: U.S. Department of Health, Education and Welfare, 130–144.
Winneke G. 1981. The neurotoxicity of dichloromethane. Neurobehav Toxicol Teratol 3:391–395.7335138
*Wirkner K, Damme B, Poelchen W, . 1997. Effect of long-term ethanol pretreatment on the metabolism of dichloromethane to carbon monoxide in rats. Toxicol Appl Pharmacol 143:83–88.9073595
Wood PR, Parsons FZ, DeMarco J, . 1981. Introductory study of the biodegredation of the chlorinated methane, ethane, and ethene compounds. Presented at the American Water Works Association Meeting, June.
*Woodrow JE, McChesney MM, Seiber JN. 1988. Determination of methyl bromide in air samples by headspace gas chromatography. Anal Chem 60:509–512.3369700
Woodruff TJ, Axelrad DA, Caldwell J, . 1998. Public health implications of 1990 air toxics concentrations across the United States. Environ Health Perspect 106:245–251.9518474
Workman DJ, Woods SL, Gorby YA, . 1997. Microbial reduction of vitamin B_12_ by shewanella alga strain BrY with subsequent transformation of carbon tetrachloride. Environ Sci Technol 31:2292–2297.
*Wu X, Amos CI, Kemp BL, . 1998. Cytochrome P450 2E1 DraI polymorphisms in lung cancer in minority populations. Cancer Epidemiol Biomarkers Prev 7:13–18.9456237
*Xiao H, Levine SP, Nowak J, . 1993. Analysis of organic vapors in the workplace by remote sensing fourier transform infrared spectroscopy. Am Ind Hyg Assoc J 54(9):545–556.8379497
Yamamoto K, Fukushima M, Kakutani N, . 1997. Volatile organic compounds in urban rivers and their estuaries in Osaka, Japan. Environ Pollut 95(1):135–143.15093482
Yesair DW, Jacques D, Schepis P, . 1977. Dose-related pharmacokinetics of ^14^C methylene chloride in mice. Fed Proc 36:998.
Zeneca Central Toxicology Lab. 1995a. DNA sequence analysis of methylene chloride-induced HPRT mutations in CHO cells: Comparison with the mutation spectrum obtained for 1,2-dibromoethane and formaldehyde. TSCATS-452017. NTIS/OTS 0572586.
Zeneca Central Toxicology Lab. 1995b. Mouse liver glutathione S-transferase mediated metabolism of methylene chloride to a mutagen in the CHO\HPRT assay. TSCATS-452021. NTIS/OTS 0572590.
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zielenska M, Ahmed A, Pienkowska M, . 1993. Mutational specificities of environmental carcinogens in the lacI gene of Escherichia coli. VI: Analysis of methylene chloride-induced mutational distribution in Uvr^+^ and UvrB^−^ strains. Carcinogenesis 14:789–794.
*Zielinska B, Fujita E, Sagebiel J, . 1998. Arizona hazardous air pollutants monitoring program. J Air Waste Manage Assoc 48:1038–1050.
Zoeteman BCJ, Harmsen K, Linders JBHJ, . 1980. Persistant organic pollutants in the river water and ground water of the Netherlands. Chemosphere 9:231–249.
Zwart A, Lommen JGJ, Feron VJ. 1992. Multi-compartment model to study the effect of air-blood and blood-tissue partition coefficients on concentration-time-effect relationships. Arch Toxicol Suppl 15:249–252.1510594