# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding methylene chloride in air, water, and other media are summarized in Table 7-1.

The International Agency for Research on Cancer (IARC) classifies methylene chloride as a Group 2B carcinogen (possibly carcinogenic to humans) (IARC 1987). The Department of Health and Human Services (DHHS) has determined that methylene chloride may reasonably be anticipated to be a carcinogen. The National Institute for Occupational Safety and Health has listed methylene chloride as a possible human carcinogen (NIOSH 1997).

OSHA requires employers of workers who are occupationally exposed to methylene chloride to institute engineering controls and work practices to reduce and maintain employee exposure at or below permissible exposure limits (PEL). The employer must use engineering and work practice controls, if feasible, to reduce exposure to or below an 8-hour TWA of 25 ppm (OSHA 1998a, 1998b). Respirators must be provided and used during the time period necessary to install or implement feasible engineering and work practice controls, or where controls are not yet sufficient. Respirators are also required when the employer determines that compliance with the TWA or PEL is not feasible with engineering or work practice controls, such as maintenance and repair activities, vessel cleaning, or other operations where exposures are intermittent and limited in duration, and in emergencies (OSHA 1987).

The EPA has calculated a chronic oral reference dose (RfD) of 0.06 mg/kg/day for methylene chloride based on a NOAEL of approximately 6 mg/kg/day for rats in a 2-year drinking water bioassay (IRIS 1999; Serota et al. 1986a). The critical effect was liver toxicity. ATSDR has calculated an acute inhalation MRL of 0.6 ppm based on a LOAEL of 300 ppm in an acute study in humans that evaluated the effects of methylene chloride on the central nervous system (Winneke 1974). This MRL supersedes the previous acute inhalation MRL of 3 ppm derived in the 1998 draft for public comment version of this profile. In the new derivation of this MRL, a PBPK model (Reitz et al. 1997) was applied to adjust the dosage yielding an adjusted LOAEL of 60 ppm. An intermediate-duration inhalation MRL of 0.3 ppm was calculated based on a 100-day inhalation study in rats that identified a LOAEL of 25 ppm for liver effects (Haun et al. 1972). A chronic inhalation MRL of 0.3 ppm was calculated based on a NOAEL of 50 ppm for liver effects (Nitschke et al. 1988a). Using a PBPK model for inhalation-to-oral extrapolation of the Winneke (1974) data, an acute oral MRL of 0.2 mg/kg/day was calculated, based on a LOAEL of 16 mg/kg/day for neurological effects (Reitz et al. 1997). This MRL supersedes the previous acute oral MRL of 0.5 mg/kg/day published in the 1998 draft for public comment version of this profile. In the new derivation, the uncertainty factor for human variability was increased from 3 to 10. ATSDR has also calculated a chronic oral MRL of 0.06 mg/kg/day based on a NOAEL of 6 mg/kg/day for liver effects (Serota et al. 1986a). This MRL supersedes the previous chronic oral MRL of 0.2 mg/kg/day published in the 1998 draft for public comment version of this profile. In the new derivation, the uncertainty factor for extrapolation from animals to humans was increased from 3 to 10.

Table 7-1 Regulations and Guidelines Applicable to Methylene Chloride

Agency | Description | Information | References
[underlined: INTERNATIONAL]
IARC | Carcinogenic classification | Group 2B^a^ | IARC 1987
[underlined: NATIONAL]
Regulations:
a. Air:
ACGIH | TLV-TWA | 50 ppm | ACGIH 1999
NIOSH | REL | Lowest feasible concentration | NIOSH 1999
OSHA | PEL 8hr-TWA | 25 ppm | 29 CFR 1910.1052; OSHA 1999
OSHA | STEL determined over a 15minute sampling period | 125 ppm | 29 CFR 1910.1052; OSHA 1999
b. Water:
EPA | MCL applying to community and non-transient, noncommunity water systems | 0.005 mg/L | 40 CFR 141.61; EPA 1999g
EPA | MCLG | Zero | 40 CFR 141.50; EPA 1999f
EPA | Health Advisories | | EPA 1996a
EPA | 1-day (10-kg child) | 10 mg/L
EPA | 10-day (10-kg child) | 2 mg/L
EPA | Longer-term child | ND^b^
EPA | Longer-term adult | ND
EPA | DWEL | 2 mg/L
EPA | Water Quality Criteria | | EPA 1999j
EPA | water + organisms | 4.7 μg/L
EPA | organisms only | 1600 μg/L
c. Food:
EPA | Indirect food additive: ingredient in pesticide formulations as a solvent used on growing crops | No tolerance limit when used as an inert ingredient | 40 CFR 180.1001; EPA 1999i
EPA | Exemption from tolerance for fumigant uses | Yes | 40 CFR 180.1010; EPA 1998b
FDA | Ban on use of methylene chloride in cosmetic products | Yes | 21 CFR 700.19; FDA 1999c
FDA | Methylene chloride present in foods with the following limits: | | 21 CFR 173.255; FDA 1999b
FDA | Spice oleoresins, residue | 30 ppm
FDA | Limit in hops extract | 2.2%
FDA | Hops extract, residue | 5 ppm
FDA | Decaffeinated roasted coffee and soluble coffee extract (instant coffee) | 10 ppm
FDA | Indirect food additive component of adhesives used in food packaging or transporting | Yes | 21 CFR 175.105; FDA 1999a
FDA | Indirect food additive: used in the production of polycarbonate resins which are used for food packaging and transport | Yes | 21 CFR 177.1580; FDA 1999d
FDA | Indirect food additive: used in ink for marking fruits and vegetables | Yes | 21 CFR 73.1; FDA 1999e
d. Other:
ACGIH | Carcinogenic classification Biological Exposure Indices | A3^c^ | ACGIH 1999
ACGIH | Methemoglobin in blood | 1.5% of hemoglobin
EPA | RfD (oral) | 6×10^−2^ mg/kg/day | IRIS 1999
EPA | Carcinogen Classification | Group B2^d^
EPA | Cancer slope factor (q1*) | 7.5×10^−3^ (mg/kg)/day
EPA | Inhalation unit risk | 4.7×10^−7^; 4.7×10^−7^ (μg/m^3^)^−1^
EPA | Reportable quantity for hazardous substances Methylene chloride - designated CERCLA hazardous substance under sections 307(a) of the Clean Water Act and RCRA section 3001 | 1,000 lbs | 40 CFR 302.4; EPA 1999a
EPA | Toxic Chemical Release Reporting—effective date | 1/1/87 | 40 CFR 372.65; EPA 1999b
EPA | Identification and listing as a hazardous waste | Yes | 40 CFR 261.33; EPA 1999c
EPA | List of toxic pollutants designated pursuant to section 307(a)(1) of the Act | Yes | 40 CFR 401.15; EPA 1998h
OSHA | Inhalation Unit Risk | 3.62×10^−3^ (μg/m^3^)^−1^ | OSHA 1997
USC | List of hazardous air pollutants | Yes | 42 USC 7412; USC 1999
USC | Universal treatment standards | | 40 CFR 268.48; EPA 1999d
USC | wastewater | 0.089 mg/L
USC | non-wastewater | 30 mg/L
[underlined: STATE]
Regulations and guidelines:
a. Air:
Idaho | Acceptable ambient concentration for a carcinogen | 2.4×10^−1^ μg/m^3^ | ID Dept Health Welfare 1999
Kansas | Concentration limits for hazardous air emissions | 10 tons/year | KS Dept. Health Env 1998
Massachusetts | Acceptable ambient air concentrations | 0.24 μg/m^3^ (annual) | MA Dept. Env. Protect. 1998
New Jersey | Acceptable ambient air concentrations | 4.7×10^−7^ μg/m^3^ | NJ Dept Env. Protect. 1998
New York | Acceptable ambient air concentrations | 27.0 μg/m^3^ (annual) | NY Dept. Env. Conserv. 1998
North Carolina | Acceptable ambient air concentrations | 2.4×10^−2^ mg/m^3^ (annual) | NC Div. Env. Manage. 1998
Rhode Island | Acceptable ambient air concentrations | 2.0 μg/m^3^ (annual) | RI Dept. Env Management 1992
Vermont | Acceptable ambient air concentrations | 0.02 μg/m^3^ (annual) | VT Nat. Res. Agency 1998
Washington | Acceptable ambient air concentrations | 2.0 μg/m^3^ (annual) | WA Dept. Ecology 1998
Wisconsin | Acceptable emission levels | | WI Dept Natural Resources 1997
Wisconsin | <25 feet | 29 lbs/hr | WI Dept Natural Resources 1997
Wisconsin | 25 feet | 122 lbs/hr | WI Dept Natural Resources 1997
b. Water.
Alabama | Human health criteria for the consumption of: | | AL Dept Env Management 1998
Alabama | water and organism^e^ | 3.4×10−4 μg/L
Alabama | organism only^e^ | 1.48×10−2 μg/L
Alaska | Maximum contaminant level | 0.005 mg/L | AK Dept Env Conserv 1999
New Jersey | Ground water quality | 2 μg/L | NJ Dept Env Protec 1993
Oklahoma | Ground water quality criteria | 10.0 μg/L | OK Dept Env Quality 1997
South Dakota | Maximum contaminant levels—apply to community and non-transient and noncommunity water systems | 0.005 mg/L | SD Dept Env Natural Resources 1998

a Group 2B - The agent is possibly carcinogenic to humans

b ND - Not data

c A3 - Confirmed animal carcinogen with unknown relevance to humans

d B2 - Probable human carcinogen

e The following equations were used to calculate the values as given in the Alabama State laws:

- Consumption of water and organism:
  Concentration (mg / l) = (HBW × RL) / (CPF × [(FCR × BCF) + WCR])
- Consumption of organism only:
  Concentration (mg / l) = (HBW × RL) / (CPF × FCR × BCF)
  - HBW = human body weight, set at 70 kg
  - RL = risk level, set at 1 × 10^−5^
  - CPF = cancer potency factor, 0.0075 (kg-day)/mg
  - FCR = fish consumption rate, set at 0.030 kg/day
  - BCF = bioconcentration factor, 0.9 L/kg
  - WCR = water consumption rate, set at 2 L/day

ACGIH = American Conference of Governmental Industrial Hygienists; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; MCL = maximum contaminant level;MCLG = maximum contaminant level goal; NIOSH = National Institute of Occupational Safety and Health;OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure release; RfD = reference dose; TLV= threshold limit value; TWA = time-weighted average