# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of methylene chloride is located in Table 3-1. Methylene chloride is a halogenated hydrocarbon. It is also commonly known as dichloromethane.

Table 3-1 lists common synonyms, trade names, and other pertinent identification information for methylene chloride.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of methylene chloride is located in Table 3-2.

Methylene chloride is a colorless liquid with a sweet, pleasant odor.

Table 3-1 Chemical Identity of Methylene Chloride

Characteristic | Information | Reference
Chemical Name | Methylene chloride | Lide 1994
Synonyms | Dichloromethane | Lide 1994
Registered trade name(s) | Narkotil; Solaesthin; Solmethine; and others | OHM/TADS 1998
Chemical formula | CH_2_Cl_2_ | Lide 1994
Chemical structure | [image] | Lide 1994
Identification numbers:
CAS | 75-09-2 | Lide 1994
NIOSH RTECS | PA8050000 | RTECS 1999
EPA hazardous waste | U080, F002 | Lewis 1996
OHM/TADS | 7217234 | OHM/TADS 1998
DOT/UN/NA/IMCO shipping | UN1593, IMCO 6.1 | HSDB 1999
HSDB | 66 | HSDB 1999
NCI | C50102 | HSDB 1999

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of Methylene Chloride

Property | Information | Reference
Molecular weight | 84.93 | Lide 1994
Color | Colorless | Lewis 1996
Physical state | Liquid | Lide 1994
Melting point | −95.1 °C | Weast 1985
Boiling point | 40 °C | Lide 1994
Density:
at 25 °C | 1.3182 g/mL | Lide 1994
Vapor density | 2.93 (Air =1) | Verscheuren 1983
Odor | Sweet, pleasant | Verschueren 1983
Odor threshold:
Water | 9.1 ppm | Amoore and Hautala 1983
Air | 540–2,160 mg/m^3^ (160–620 ppm) | Ruth 1986
Solubility:
Water at 20 °C | 20,000 mg/L | Verschueren 1983
at 25 °C | 16,700 mg/L | Verschueren 1983
Organic solvent(s) | Soluble in alcohol, ether, acetone, chloroform, and carbon tetrachloride | Lewis 1996
Partition coefficients:
Log K_ow_ | 1.3 | Hansch and Leo 1979
Log K_oc_ | 1.4 | Roy and Griffin 1982
Vapor pressure:
at 20 °C | 349 mmHg | Verscheuren 1983
at 30 °C | 500 mmHg | Verscheuren 1983
Henry’s law constant | 2.03×10^−3^ atm-m^3^/mol at 25 −C | EPA 1982e
Autoignition temperature | 1,139 F (615 °C) | Lewis 1996
Flashpoint | Nonflammable | Sax and Lewis 1987
Flammability limits | Nonflammable | Sax and Lewis 1987
Coversion factors | 1 mg/m^3^=0.28 ppm | WHO 1996
Coversion factors | 1 ppm=3.53 mg/m^3^ | WHO 1996
Explosive limits | Not explosive | Sax and Lewis 1987