# Systematic Evidence Map (Sem) for Methylene Chloride

## 1 OBJECTIVES

The aim and scope of the systematic evidence map (SEM) are to:

- Conduct literature searches to identify available relevant studies published since the methylene chloride toxicological profile was last published in September 2000, including studies in humans, animals, in vitro models, or in silico.
- Screen literature search results using methods consistent with principles of systematic review to determine if identified studies meet the Populations, Exposures, Comparators, and Outcomes (PECO inclusion criteria) outlined below (see Section 2.1).
- Prepare an interactive literature inventory to provide an overview of the new evidence that meets PECO criteria.
- Perform high-level data review and extraction of studies identified during the updated literature search to determine if any could potentially address key data needs or impact existing minimal risk levels (MRLs) for methylene chloride, as identified in the toxicological profile (ATSDR 2000).

## 2 METHODS

### 2.1 LITERATURE SEARCH STRATEGY

A literature search was conducted to identify studies examining health effects, toxicokinetics, and mechanisms of action for methylene chloride. The PECO criteria used to identify relevant studies examining the health effects of methylene chloride are presented in Table 2-1.

Table 2-1 PECO Criteria for Screening of ATSDR SEM Literature Search Results

PECO element | Evidence
Population | Humans, laboratory mammals, and other animal models of established relevance to human health (e.g., Xenopus embryos); mammalian organs, tissues, and cell lines; and bacterial and eukaryote models of genetic toxicity.
Exposure | In vivo (all routes), ex vivo, and in vitro exposure to the chemical of interest, including mixtures to which the chemical of interest may contribute significantly to exposure or observed effects.
Comparison | Any comparison (across dose, duration, or route) or no comparison for select study types (case reports without controls, acute lethality limit tests without controls).
Outcomes | Any endpoint suggestive of a toxic effect on any bodily system, or mechanistic change associated with such effects. Any endpoint relating to toxicokinetics/dynamics of the chemical within the body.

ATSDR = Agency for Toxic Substances and Disease Registry; PECO = Populations, Exposures, Comparators, and Outcomes; SEM = systematic evidence map

The current literature search was intended to identify studies not included in the existing toxicological profile for methylene chloride (ATSDR 2000); thus, the literature search was restricted to studies published between January 1998 to July 2022 to capture literature published since the search was conducted for the existing profile. The following main databases were searched in July 2022:

- PubMed
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for methylene chloride. The query strings used for the literature search are presented in Appendix A (Table A-1). These query strings are designed to capture all data potentially relevant to the PECO statement as well as additional data potentially relevant to developing a toxicological profile (e.g., chemistry, production, use, environmental fate, etc.).

These additional data studies that are potentially relevant, but do not meet the PECO criteria, will not be included in the SEM but will be tagged for potential future use in profile development.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), National Toxicology Program (NTP), National Technical Reports Library (NTRL), and Regulations.gov websites using the queries presented in Appendix A (Table A-2). Regulatory documents and review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature from these resources, including unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

### 2.2 LITERATURE SCREENING STRATEGY

Two screeners independently conducted a title and abstract screening of the search results using DistillerSR^1^ to identify study references that met the PECO eligibility criteria (see Table 2-1).

References that were included based on PECO eligibility criteria during title and abstract screen were submitted for reference retrieval. For nonlocal retrieval items (e.g., pay-per-citation, etc.), an additional screening step was conducted based on refined PECO criteria with a narrowed focus to capture only key health hazard information and studies that may fill data gaps (Table 2-2). Citations selected for full-text retrieval were limited to English-language, full-length journal articles or study reports at this stage.

Table 2-2 Refined PECO Criteria for Screening of Nonlocal Citations

PECO element | Evidence
Population | Humans or laboratory mammals.
Exposure | Inhalation, oral, or dermal exposure to the chemical of interest, including mixtures that contain a high percentage of the chemical of interest.
Comparison | Any comparison (across dose, duration, or route) or no comparison for select study types (case reports without controls, acute lethality limit tests without controls).
Outcomes | Any endpoint suggestive of a toxic effect on any bodily system or containing information to address data gaps (e.g., PBPK model, toxicokinetics, mechanisms of action, etc.)^a^.

a Data gaps identified in the 2000 toxicological profile for methylene chloride included genotoxicity studies in mammalian cells for which the expression of GSTT1 and/or CYP2E1 isoenzymes are identified, toxicokinetic data for oral and dermal exposures, excretion parameters as functions of concentration, and impact of differences in species sensitivity to specific internal doses by different routes of exposure.

PBPK = physiologically based pharmacokinetic; PECO = Populations, Exposures, Comparators, and Outcomes

References that were included based on title and abstract screening advanced to full-text review using the broad PECO eligibility criteria listed in Table 2-1. Full-text copies of potentially relevant references identified from title and abstract screening were retrieved, embedded in DistillerSR screening forms, and independently assessed by two screeners using DistillerSR to confirm eligibility. If studies were considered PECO relevant based on full-text review, screeners categorized the studies as one of the following study types: health effects studies (human toxicity, animal toxicity) or supporting studies (genotoxicity, mechanistic, toxicokinetic, secondary source). Additionally, studies that did not meet PECO criteria but contained other profile-relevant data were categorized as one of the following study types for potential use during later profile development: chemistry, biomarker, interaction, or susceptible populations.

At both the title/abstract and full-text review levels, any screening conflicts were resolved by discussion between the primary screeners, with consultation by a third screener (if needed) to resolve any remaining disagreements.

### 2.3 HIGH-LEVEL DATA EXTRACTION FOR LITERATURE INVENTORY

References that were categorized as PECO-relevant health effects studies advanced to high-level data extraction in DistillerSR. Information extracted for human toxicity studies included study population, measure of exposure, duration, route, systems evaluated, and whether or not examined systems showed an exposure-related effect. Information extracted for animal toxicity studies included species, strain, animal number and sex, duration, route, number of dose groups, doses/concentrations, systems evaluated, and systems showing an exposure-related effect. Extracted data were exported into Tableau Public^2^ for interactive data visualization.

1 DistillerSR is a web-based systematic review software used to screen studies available at: https://www.evidencepartners.com/products/distillersr-systematic-review-software.

2 Tableau Public is a web-based data visualization software available at https://public.tableau.com.

## 3 RESULTS

### 3.1 LITERATURE SEARCH RESULTS

Literature searches from all bibliographic databases yielded 9,005 unique references (after removal of duplicates). Title and abstract screening identified 8,677 references as not PECO-relevant; of these, 371 were identified as non-PECO profile-relevant items and 48 were nonlocal items identified as not relevant based on refined PECO criteria. After removing not PECO-relevant references, the remaining 328 items proceeded to full-text review. Gray literature search results screened outside of DistillerSR added 14 citations, bringing the total number of citations for full-text review to 342. An additional 85 references were identified as not PECO-relevant during full-text screening; of these, 20 were identified as non-PECO profile-relevant items. The remaining 257 references were identified as PECO-relevant; 33 references included health effects data, 218 references contained other supporting data, and 6 references contained both health effects and supporting data. A summary of the results of the literature search and screening is presented in Figure 3-1.

Figure 3-1 Literature Flow Diagram

ADME = adsorption, distribution, metabolism, and excretion; PBPK = physiologically based pharmacokinetic; PECO = Populations, Exposures, Comparators, and Outcomes

Interactive literature flow diagram can be accessed at: https://public.tableau.com/app/profile/eha.tableau.team/viz/LitFlowDiagram-MethyleneChloride2022/Dashboard

### 3.2 LITERATURE INVENTORY

The literature search and screen identified 27 human and 12 animal health effects studies for methylene chloride; some animal studies included multiple experiments in different species and/or of different durations.

As shown in Figure 3-2 (A: Human Data) and (B: Animal Data), the majority of newly identified studies with toxicity data examined exposure via the inhalation route, with a few oral route studies in animals. 100% (25) of human data gathered focused on the inhalation route, 54% (7) of animal studies focused on the inhalation route, and 46% (6) of animal studies focused on the oral route. The most-studied endpoints include body weight, hepatic, neurological, and cancer. While evidence from human studies is mixed, findings from animal studies are consistent with the existing toxicological profile for methylene chloride (ATSDR 2000), indicating that the nervous system, liver, and kidney are potential toxicity targets of methylene chloride. Additional studies in animals also reported carcinogenic effects.

The current toxicological profile (ATSDR 2000) identified several data needs in the toxicological database for methylene chloride. Very few of the studies identified during the updated literature search address these data needs (see Table 3-1). None of the identified studies are expected to impact the existing inhalation or oral MRLs.

Figure 3-2 Health Effects Studies for Methylene Chloride

*Interactive database can be accessed at: https://public.tableau.com/app/profile/eha.tableau.team/viz/DRAFTSEMDataVisualizationforMethyleneChloride/HealthEffectsOverview

Table 3-1 Data Needs Identified for Methylene Chloride by ATSDR (2000)

Exposure route | Data needs | Studies to potentially address data need
Inhalation | Low-concentration, acute-duration studies evaluating neurological function in animals | None
Inhalation | Studies evaluating immunological function in animals | Warbrick et al. 2003 (no adverse immunological effects)
Oral | Additional low-dose, acute-duration studies in animals | Owumi et al. 2019 and Kim et al. 2011; examined respiratory, hepatic, and/or renal endpoints at ≥150 mg/kg/day
Oral | Low-dose, intermediate-duration studies in animals to provide dose-response data, especially a NOAEL (below the lowest LAOEL of 166 mg/kg-day) | None
Oral | Studies evaluating immunological function in animals | None
Oral | Studies evaluating neurological function in animals | None
Oral | Studies evaluating reproduction and development in animals | None
Oral | Studies evaluating carcinogenicity in animals | NTP 1994 (Note: the primary purpose of the study was to evaluate the impact of different gavage vehicles on tumor development)
Dermal | Acute, intermediate, and chronic (including carcinogenicity) studies in animals | None

ATSDR = Agency for Toxic Substances and Disease Registry; LOAEL = lowest-observed-adverse effect level; NOAEL = no-observed-adverse-effect level

## 4 REFERENCES

### 4.1 CURRENT PROFILE

ATSDR. 2000. Toxicological profile for methylene chloride. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/ToxProfiles/tp14.pdf. August 22, 2022.

### 4.2 HUMAN TOXICITY

Barul C, Fayosse A, Carton M, . 2017. Occupational exposure to chlorinated solvents and risk of head and neck cancer in men: a population-based case-control study in France. Environ Health 16(1):77. 10.1186/s12940-017-0286-5.28738894
Berr C, Vercambre MN, Bonenfant S, . 2010. Occupational exposure to solvents and cognitive performance in the GAZEL cohort: preliminary results. Dement Geriatr Cogn Disord 30(1):12–19. 10.1159/000315498.20606440
Delfino RJ, Gong H, Linn WS, . 2003. Asthma symptoms in Hispanic children and daily ambient exposures to toxic and criteria air pollutants. Environ Health Perspect 111(4):647–656. 10.1289/ehp.5992.12676630
Delfino RJ, Gong H, Linn WS, . 2003. Respiratory symptoms and peak expiratory flow in children with asthma in relation to volatile organic compounds in exhaled breath and ambient air. J Expo Anal Environ Epidemiol 13(5):348–363. 10.1038/sj.jea.7500287.12973363
Dickerson AS, Hansen J, Thompson S, . 2020. A mixtures approach to solvent exposures and amyotrophic lateral sclerosis: a population-based study in Denmark. Eur J Epidemiol 35(3):241–249. 10.1007/s10654-020-00624-5.32193761
El-Zaemey S, Anand TN, Heyworth JS, . 2018. Case-control study to assess the association between colorectal cancer and selected occupational agents using INTEROCC job exposure matrix. Occup Environ Med 75(4):290–295. 10.1136/oemed-2017-104795.29222392
Garcia E, Hurley S, Nelson DO, . 2015. Hazardous air pollutants and breast cancer risk in California teachers: a cohort study. Environ Health 14:14. 10.1186/1476-069X-14-14.25636809
Gold LS, Stewart PA, Milliken K, . 2011. The relationship between multiple myeloma and occupational exposure to six chlorinated solvents. Occup Environ Med 68(6):391–399. 10.1136/oem.2009.054809.20833760
Gong X, Lin Y, Bell ML, . 2018. Associations between maternal residential proximity to air emissions from industrial facilities and low birth weight in Texas, USA. Environ Int 120:181–198. 10.1016/j.envint.2018.07.045.30096612
Hearne FT, Pifer JW. 1999. Mortality study of two overlapping cohorts of photographic film base manufacturing employees exposed to methylene chloride. J Occup Environ Med 41(12):1154–1169. 10.1097/00043764-199912000-00022.10609238
Kumagai S, Kurumatani N, Arimoto A, . 2013. Cholangiocarcinoma among offset colour proofprinting workers exposed to 1,2-dichloropropane and/or dichloromethane. Occup Environ Med 70(7):508–510. 10.1136/oemed-2012-101246.23493378
Lupo PJ, Lee LJ, Okcu MF, . 2012. An exploratory case-only analysis of gene-hazardous air pollutant interactions and the risk of childhood medulloblastoma. Pediatr Blood Cancer 59(4):605–610. 10.1002/pbc.24105.22389292
Makris KC, Voniatis M. 2018. Brain cancer cluster investigation around a factory emitting dichloromethane. Eur J Public Health 28(2):338–343. 10.1093/eurpub/ckx170.29036600
Neta G, Stewart PA, Rajaraman P, . 2012. Occupational exposure to chlorinated solvents and risks of glioma and meningioma in adults. Occup Environ Med 69(11):793–801. 10.1136/oemed-2012-100742.22864249
Niehoff NM, Gammon MD, Keil AP, . 2019. Airborne mammary carcinogens and breast cancer risk in the Sister Study. Environ Int 130:104897. 10.1016/j.envint.2019.06.007.31226564
Ojajarvi A, Partanen T, Ahlbom A, . 2001. Risk of pancreatic cancer in workers exposed to chlorinated hydrocarbon solvents and related compounds: a meta-analysis. Am J Epidemiol 153(9):841–850. 10.1093/aje/153.9.841.11323314
Peters TL, Kamel F, Lundholm C, . 2017. Occupational exposures and the risk of amyotrophic lateral sclerosis. Occup Environ Med 74(2):87–92. 10.1136/oemed-2016-103700.27418175
Roberts AL, Lyall K, Hart JE, . 2013. Perinatal air pollutant exposures and autism spectrum disorder in the children of Nurses’ Health Study II participants. Environ Health Perspect 121(8):978–984. 10.1289/ehp.1206187.23816781
Ruder AM, Yiin JH, Waters MA, . 2013. The Upper Midwest Health Study: gliomas and occupational exposure to chlorinated solvents. Occup Environ Med 70(2):73–80. 10.1136/oemed-2011-100588.23104734
Seidler A, Möhner M, Berger J, . 2007. Solvent exposure and malignant lymphoma: a population-based case-control study in Germany. J Occup Med Toxicol 2:2. 10.1186/1745-6673-2-2.17407545
Swartz MD, Cai Y, Chan W, . 2015. Air toxics and birth defects: a Bayesian hierarchical approach to evaluate multiple pollutants and spina bifida. Environ Health 14:16. 10.1186/1476-069X-14-16.25971584
Talbott EO, Marshall LP, Rager JR, . 2015. Air toxics and the risk of autism spectrum disorder: the results of a population based case-control study in southwestern Pennsylvania. Environ Health 14:80. 10.1186/s12940-015-0064-1.26444407
Talibov M, Auvinen A, Weiderpass E, . 2017. Occupational solvent exposure and adult chronic lymphocytic leukemia: No risk in a population-based case-control study in four Nordic countries. Int J Cancer 141(6):1140–1147. 10.1002/ijc.30814.28571111
Tomenson JA. 2011. Update of a cohort mortality study of workers exposed to methylene chloride employed at a plant producing cellulose triacetate film base. Int Arch Occup Environ Health 84(8):889–897. 10.1007/s00420-011-0621-z.21327981
Weichenthal S, Kulka R, Belisle P, . 2012. Personal exposure to specific volatile organic compounds and acute changes in lung function and heart rate variability among urban cyclists. Environ Res 118:118–123. 10.1016/j.envres.2012.06.005.22776327
Windham GC, Zhang L, Gunier R, . 2006. Autism spectrum disorders in relation to distribution of hazardous air pollutants in the San Francisco Bay area. Environ Health Perspect 114(9):1438–1444. 10.1289/ehp.9120.16966102
Zamyslowska-Szmytke E, Sliwinska-Kowalska M. 2011. Vestibular and balance findings in nonsymptomatic workers exposed to styrene and dichloromethane. Int J Audiol 50(11):815–822. 10.3109/14992027.2011.599872.21929376

### 4.3 ANIMAL TOXICITY

Aiso S, Take M, Kasai T, . 2014. Inhalation carcinogenicity of dichloromethane in rats and mice. Inhal Toxicol 26(8):435–451. 10.3109/08958378.2014.905660.24909451
Andersen ME, Black MB, Campbell JL, . 2017. Combining transcriptomics and PBPK modeling indicates a primary role of hypoxia and altered circadian signaling in dichloromethane carcinogenicity in mouse lung and liver. Toxicol Appl Pharmacol 332:149–158. 10.1016/j.taap.2017.04.002.28392392
Harcourt-Brown NH, Dawson MT, Judd AT, . 2000. Dichloromethane poisoning in a dog: a case report. Vet Rec 146(2):48–49. 10.1136/vr.146.2.48.10678812
Haskell. 1949. Methylene chloride: Toxicity of paint and varnish remover: Progress report. Initial submission: Inhalation toxicity studies of methylene chloride with cover letter dated 10115192. Haskell Laboratory of Industrial Toxicology. Dupont. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. 8EHQ-92-12141. 88920010379. OTS555748. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0555748.xhtml. August 22, 2022.
Hext PM, Foster J, Millward SW, . 1986. Methylene chloride (dichloromethane): Ten day inhalation toxicity study to investigate the effects on rat and mouse liver and lungs. Shell Oil Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. 86880000287. OTS0514365. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0514365.xhtml. August 22, 2022.
Hirata T, Cho YM, Toyoda T, . 2017. Lack of in vivo mutagenicity of 1,2-dichloropropane and dichloromethane in the livers of gpt delta rats administered singly or in combination. J Appl Toxicol 37(6):683–691. 10.1002/jat.3416.27896817
Kim JK, Jung KH, Noh JH, . 2011. Identification of characteristic molecular signature for volatile organic compounds in peripheral blood of rat. Toxicol Appl Pharmacol 250(2):162–169. 10.1016/j.taap.2010.10.009.20955722
NTP. 1994. Comparative toxicology studies of corn oil, safflower oil, and tricaprylin (CAS Nos. 8001-30-7, 8001-23-8, and 538-23-8) in male F344/N rats as vehicles for gavage. National Toxicology Program. Technical Report Series No. 426. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr426.pdf. August 22, 2022.
Owumi SE, Najophe ES. 2019. Dichloromethane and ethanol co-exposure aggravates oxidative stress indices causing hepatic and renal dysfunction in pubertal rats. Toxicology Research and Application 3. 10.1177/2397847319855285.
Owumi SE, Danso OF, Effiong ME, . 2019. Dietary quercetin abrogates hepatorenal oxidative damage associated with dichloromethane exposure in rats. Acta Biochim Pol 66(2):201–206. 10.18388/abp.2018_2771.30958872
Wang H, Chen J, Suda M, . 2019. Acute inhalation co-exposure to 1,2-dichloropropane and dichloromethane cause liver damage by inhibiting mitochondrial respiration and defense ability in mice. J Appl Toxicol 39(2):260–270. 10.1002/jat.3715.30240022
Warbrick EV, Kilgour JD, Dearman RJ, . 2003. Inhalation exposure to methylene chloride does not induce systemic immunotoxicity in rats. J Toxicol Environ Health A 66(13):1207–1219. 10.1080/15287390306410.12851119

## APPENDIX A LITERATURE SEARCH STRATEGIES

Table A-1 Database Query Strings

Database search date | Query string
PubMed 07/2022 | ((75-09-2[rn] AND (1998:3000[mhda] OR 1998:3000[crdt] OR 1998:3000[edat])) AND ((“methylene chloride/toxicity”[mh] OR “methylene chloride/adverse effects”[mh] OR “methylene chloride/poisoning”[mh] OR “methylene chloride/pharmacokinetics”[mh] OR “methylene chloride/antagonists and inhibitors”[mh] OR “methylene chloride/pharmacology”[majr] OR “methylene chloride/blood”[mh] OR “methylene chloride/cerebrospinal fluid”[mh] OR “methylene chloride/urine”[mh]) OR (“methylene chloride”[mh] AND toxicokinetics[mh:noexp]) OR (“methylene chloride/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“methylene chloride”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“methylene chloride”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“methylene chloride”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“methylene chloride”[mh] AND (“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab])))) OR (((“Dichloromethane”[tw] OR “Dichoromethane”[tw] OR “Methane dichloride”[tw] OR “Methylene bichloride”[tw] OR “Methylene chloride”[tw] OR “Methylene dichloride”[tw] OR “Aerothene MM”[tw] OR “Dichlormethan”[tw] OR “F 30 (chlorocarbon)”[tw] OR “Freon 30”[tw] OR “Khladon 30”[tw] OR “Metaclen”[tw] OR “Methaclean U”[tw] OR “Methane, dichloro-”[tw] OR “Narkotil”[tw] OR “R 30 (refrigerant)”[tw] OR “R30 (refrigerant)”[tw] OR “Solaesthin”[tw] OR “Soleana VDA”[tw] OR “Solmethine”[tw]) AND (1998:3000[crdt] OR 1998:3000[edat] OR 1998:3000[dp])) NOT medline[sb])
Toxcenter 07/2022 | FILE ‘TOXCENTER’ ENTERED AT 10:09:37 ON 06 JUL 2022 CHARGED TO COST=EH038.16.02.LB.04; L1 28571 SEA FILE=TOXCENTER 75-09-2; L2 28134 SEA FILE=TOXCENTER L1 NOT TSCATS/FS; L3 19133 SEA FILE=TOXCENTER L2 NOT PATENT/DT; L4 4342 SEA FILE=TOXCENTER L3 AND PY>=2018; L5 13808 SEA FILE=TOXCENTER L3 AND PY>=1998 ACT TOXQUERY/Q; -------; L6 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L7 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L8 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L9 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L10 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L11 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L12 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L13 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L14 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L15 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L16 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L17 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L18 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L19 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L20 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L21 QUE (ENDOCRIN? AND DISRUPT?); L22 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L23 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L24 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L25 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L26 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L27 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L28 QUE (NEPHROTOX? OR HEPATOTOX?); L29 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L30 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L31 QUE L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30; L32 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L33 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L34 QUE L31 OR L32 OR L33; L35 QUE (NONHUMAN MAMMALS)/ORGN; L36 QUE L34 OR L35; L37 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?) L38 QUE L36 OR L37; -------; L39 6866 SEA FILE=TOXCENTER L5 AND L38; L40 6104 SEA FILE=TOXCENTER L5 AND L31; L41 379 SEA FILE=TOXCENTER L40 AND MEDLINE/FS; L42 759 SEA FILE=TOXCENTER L40 AND BIOSIS/FS; L43 4942 SEA FILE=TOXCENTER L40 AND CAPLUS/FS; L44 24 SEA FILE=TOXCENTER L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L45 5697 DUP REM L41 L42 L44 L43 (407 DUPLICATES REMOVED); L*** DEL 379 S L40 AND MEDLINE/FS; L*** DEL 379 S L40 AND MEDLINE/FS; L46 379 SEA FILE=TOXCENTER L45; L*** DEL 759 S L40 AND BIOSIS/FS; L*** DEL 759 S L40 AND BIOSIS/FS; L47 644 SEA FILE=TOXCENTER L45; L*** DEL 4942 S L40 AND CAPLUS/FS; L*** DEL 4942 S L40 AND CAPLUS/FS; L48 4657 SEA FILE=TOXCENTER L45; L*** DEL 24 S L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L*** DEL 24 S L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L49 17 SEA FILE=TOXCENTER L45; L50 5318 SEA FILE=TOXCENTER (L46 OR L47 OR L48 OR L49) NOT MEDLINE/FS; L51 661 SEA FILE=TOXCENTER L50 NOT CAPLUS/FS D SCAN L51; L52 4657 SEA FILE=TOXCENTER L50 AND CAPLUS/FS D SCAN L52

Table A-2 Strategies to Augment the Literature Search

Source | Query and number screened when available
NTP
07/2022 | Limited to: 1990-present, and not dated; “Methylene chloride” “Dichloromethane” “75-09-2” “Methylene dichloride”; “Dichoromethane” “Methane dichloride” “Methylene bichloride” “Methane, dichloro-”; “Dichlormethan” “Aerothene MM” “F 30 (chlorocarbon)” “Freon 30”; “Khladon 30” “Metaclen” “Methaclean U” “Narkotil”; “R 30 (refrigerant)” “R30 (refrigerant)” “Solaesthin” “Soleana VDA”; “Solmethine”
NTRL
07/2022 | Limited to: titles or keywords and 1998-present; “Methylene chloride” OR “Dichloromethane” OR “Dichlormethan” OR “Methylene dichloride” OR “Dichoromethane” OR “Methane dichloride” OR “Methylene bichloride” OR “Methane, dichloro-” OR “Aerothene MM” OR “F 30 (chlorocarbon)” OR “Freon 30” OR “Khladon 30” OR “Metaclen” OR “Methaclean U” OR “Narkotil” OR “R 30 (refrigerant)” OR “R30 (refrigerant)” OR “Solaesthin” OR “Soleana VDA” OR “Solmethine”
Regulations.gov
07/2022 | Limited to: Docket or EPA notices; “Methylene chloride”; 75-09-2; “Dichloromethane”; “Methylene dichloride”; “Methane dichloride”; “Dichoromethane”
Other | Identified throughout the assessment process

## APPENDIX B SUPPLEMENTAL STUDIES

### B.1 CASE REPORTS

Bonfiglioli R, Carnevali L, Di Lello M, . 2014. Bilateral hearing loss after dichloromethane poisoning: a case report. Am J Ind Med 57(2):254–257. 10.1002/ajim.22257.24085714
Cabrera VJ, Farmakiotis D, Aggarwal V, . 2011. Methylene chloride intoxication treated with hyperbaric oxygen therapy. Am J Med 124(5):e3–4. 10.1016/j.amjmed.2010.12.010.
CDC. 2012. Fatal exposure to methylene chloride among bathtub refinishers - United States, 2000-2011. MMWR Morb Mortal Wkly Rep 61(7):119–122.22357403
Chang YL, Yang CC, Deng JF, . 1999. Diverse manifestations of oral methylene chloride poisoning: report of 6 cases. J Toxicol Clin Toxicol 37(4):497–504. 10.1081/clt-100102442.10465248
Chauhan N, Prasad RS. 2021. Methylene chloride burns: a case report and review of literature. Indian J Plast Surg 54(1):94–96. 10.1055/s-0041-1725224.33814750
Delzell E, Beal C, Rodu B, . 1999. A case-series investigation of intracranial neoplasms at a petrochemical research facility. BP Amoco Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. 8EHQ98114311. 8999000264. https://chemview.epa.gov/chemview/proxy?filename=tscats/89990000264_75092_DCDD827AD515 0A8D85256FCE00570DB4.pdf. August 22, 2022.
Dorevitch S, Forst L, Conroy L, . 2002. Toxic inhalation fatalities of US construction workers, 1990 to 1999. J Occup Environ Med 44(7):657–662. 10.1097/00043764-200207000-00012.12134529
Ehler E, Latta J, Eichlerová A, . 2011. Exposure to iodomethane and dichloromethane associated with a confusional state. Neurotoxicology 32(3):307–311. 10.1016/j.neuro.2011.02.003.21329723
Fechner G, Ortmann C, Du Chesne A, . 2001. Fatal intoxication due to excessive dichloromethane inhalation. Forensic Sci Int 122(1):69–72. 10.1016/s0379-0738(01)00468-6.11587869
Goullé JP, Lacroix C, Vaz E, . 1999. Fatal case of dichloromethane poisoning. J Anal Toxicol 23(5):380–383. 10.1093/jat/23.5.380.10488927
Hoang A, Fagan K, Cannon DL, . 2021. Assessment of methylene chloride-related fatalities in the United States, 1980-2018. JAMA Intern Med 181(6):797–805. 10.1001/jamainternmed.2021.1063.
Jacubovich RM, Landau D, Bar Dayan Y, . 2005. Facial nerve palsy after acute exposure to dichloromethane. Am J Ind Med 48(5):389–932. 10.1002/ajim.20215.16254952
Jaffe TA, Boyer EW, Erickson TB, . 2019. Acute and delayed toxicity from co-ingestion of methylene chloride and methanol. Toxicol Commun 3(1):79–84. 10.1080/24734306.2019.1685222.31745533
Kim H. 2008. A case of acute toxic hepatitis after suicidal chloroform and dichloromethane ingestion. Am J Emerg Med 26(9):1073.e3–6. 10.1016/j.ajem.2008.03.050.
Kinoshita M, Sato Y, Nebiki H, . 2019. Occupational cholangiocarcinoma diagnosed 18 years after the end of exposure to 1,2-dichloropropane and dichloromethane at a printing company: a case report. Surg Case Rep 5(1):65. 10.1186/s40792-019-0624-7.31016414
Kobayashi A, Ando A, Tagami N, . 2008. Severe optic neuropathy caused by dichloromethane inhalation. J Ocul Pharmacol Ther 24(6):607–612. 10.1089/jop.2007.0100.19049266
Kubo S, Matsuzaki K, Seki T, . 2015. Severe acute hepatitis in a printing company worker: a case study. J Occup Health 57(1):87–90. 10.1539/joh.14-0122-CS.25410269
Kumagai S. 2014. Two offset printing workers with cholangiocarcinoma. J Occup Health 56(2):164–168. 10.1539/joh.13-0262-cs.24553624
Macisaac J, Harrison R, Krishnaswami J, . 2013. Fatalities due to dichloromethane in paint strippers: a continuing problem. Am J Ind Med 56(8):907–910. 10.1002/ajim.22167.23450690
Mahmud M, Kales SN. 1999. Methylene chloride poisoning in a cabinet worker. Environ Health Perspect 107(9):769–772. 10.1289/ehp.99107769.10464079
Min B, Kim G, Kang T, . 2016. IgA nephropathy in a laboratory worker that progressed to end-stage renal disease: a case report. Ann Occup Environ Med 28:35. 10.1186/s40557-016-0118-z.27504189
NIOSH. 2011. Fatality Assessment and Control Evaluation (FACE) report for California: A paint maker dies from exposure to dichloromethane (methylene chloride) while cleaning a paint tank. FACE-11-CA-009. Cincinnati, OH: National Institute for Occupational Safety and Health. PB2013102990. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2013102990.xhtml. August 22, 2022.
NIOSH. 2012. Fatality Assessment and Control Evaluation (FACE) report for California: A maintenance worker dies from exposure to dichloromethane (methylene chloride) while stripping the floor of a baptismal font in a church. FACE-12-CA-002. Cincinnati, OH: National Institute for Occupational Safety and Health. PB2013101342. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2013101342.xhtml. August 22, 2022.
NIOSH. 2018. Fatality Assessment and Control Evaluation (FACE) report for California: A bathtub refinisher dies from methylene chloride exposure while removing paint from a bathtub, FACE-17-CA-002. PB2018101648. Cincinnati, OH: National Institute for Occupational Safety and Health. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2018101648.xhtml. August 22, 2022.
Ogawa D, Hayashi H, Kitamura F, . 2020. Multiple cholangiocarcinomas in the intrahepatic and extrahepatic biliary tree due to dichloromethane exposure: a case report. Surg Case Rep 6(1):79. 10.1186/s40792-020-00842-9.32318894
Preisser AM, Budnik LT, Hampel E, . 2011. Surprises perilous: toxic health hazards for employees unloading fumigated shipping containers. Sci Total Environ 409(17):3106–3113. 10.1016/j.scitotenv.2011.04.053.21636109
Rague J, Grush J, Buchanan J, . 2021. A case series of chemical dermal injury requiring operative intervention after prolonged dermal methylene chloride exposure. J Med Toxicol 17(2):222–226. 10.1007/s13181-020-00818-z.33403570
Raphael M, Nadiras P, Flacke-Vordos N, . 2002. Acute methylene chloride intoxication-a case report on domestic poisoning. Eur J Emerg Med 9(1):57–59. 10.1097/00063110200203000-00013.11989499
Smith DH. 2006. Methylene chloride inhalation. Nursing (Brux) 36(6):80. 10.1097/00152193-200606000-00054.
Takamura K, Ogi T, Yamamoto M, . 2016. Three simultaneous cases of hypersensitivity pneumonitis and acute lung injury caused by dichloromethane. Respirol Case Rep 4(6):e00193. 10.1002/rcr2.193.28031828
Takeshita H, Mogi K, Yasuda T, . 2000. Postmortem absorption of dichloromethane: a case study and animal experiments. Int J Legal Med 114(1–2):96–100. 10.1007/s004140000141.11197638
Teschke R. 2018. Aliphatic halogenated hydrocarbons: report and analysis of liver injury in 60 patients. J Clin Transl Hepatol 6(4):350–361. 10.14218/jcth.2018.00040.30637211
Tomimaru Y, Kobayashi S, Wada W, . 2015. Intrahepatic cholangiocarcinoma in a worker at an offset color proof-printing company: An autopsy case report. Hepatol Res 45(4):488–493. 10.1111/hepr.12363.24849871
Trullas JC, Nogue S, Miro O, . 2005. Multiorganic involvement after inhalation of isopropyl alcohol and dichloromethane as a form of substance abuse. Revista de Toxicologia 22(3):205–208.
Vetro J, Koutsogiannis Z, Jones DA, . 2012. A case of methylene chloride poisoning due to ingestion of home-distilled alcohol and potential new treatment with ethanol infusion. Crit Care Resusc 14(1):60–63.22404064
Vidal S. 2020. Safety first: a recent case of a dichloromethane injection injury. ACS Cent Sci 6(2):83–86. 10.1021/acscentsci.0c00100.32123724
Yamada K, Kumagai S, Nagoya T, . 2014. Chemical exposure levels in printing workers with cholangiocarcinoma. J Occup Health 56(5):332–338. 10.1539/joh.14-0073-OA.25069896
Yamada K, Kumagai S, Endo G, . 2015. Chemical exposure levels in printing workers with cholangiocarcinoma (second report). J Occup Health 57(3):245–252. 10.1539/joh.14-0239-OA.25739405
Yamada K, Kumagai S, Kubo S, . 2015. Chemical exposure levels in printing and coating workers with cholangiocarcinoma (third report). J Occup Health 57(6):565–571. 10.1539/joh.15-0170-OA.26447094
Zarrabeitia MT, Ortega C, Altuzarra E, . 2001. Accidental dichloromethane fatality: a case report. J Forensic Sci 46(3):726–727.11373017

### B.2 HUMAN, NO EXPOSURE MEASURE

Ahrens W, Merletti F, Mirabelli D, . 2014. Biliary tract cancer in male printers and typesetters in the European rare cancer case-control study. Occup Environ Med 71(8):591–592. 10.1136/oemed-2014-102322.
Arias-Ortiz NE, Icaza-Noguera G, Ruiz-Rudolph P, . 2018. Thyroid cancer incidence in women and proximity to industrial air pollution sources: A spatial analysis in a middle size city in Colombia. Atmos Pollut Res 9(3):464–475. 10.1016/j.apr.2017.11.003.
Banjoko SO, Sridhar Mynapelli KC, Ogunkola IO, . 2007. Methylene chloride exposure and carboxyhemoglobin levels in cabinetmakers. Indian J Occup Environ Med 11(2):56–60. 10.4103/0019-5278.34529.21938216
Barry KH, Zhang Y, Lan Q, . 2011. Genetic variation in metabolic genes, occupational solvent exposure, and risk of non-Hodgkin lymphoma. Am J Epidemiol 173(4):404–413. 10.1093/aje/kwq360.21228414
Beall C, Delzell E, Rodu B, . 2001. Case-control study of intracranial tumors among employees at a petrochemical research facility. J Occup Environ Med 43(12):1103–1113. 10.1097/00043764-200112000-00012.11765681
Blair A, Hartge P, Stewart PA, . 1998. Mortality and cancer incidence of aircraft maintenance workers exposed to trichloroethylene and other organic solvents and chemicals: extended follow up. Occup Environ Med 55(3):161–171. 10.1136/oem.55.3.161.9624267
Brender JD, Shinde MU, Zhan FB, . 2014. Maternal residential proximity to chlorinated solvent emissions and birth defects in offspring: a case-control study. Environ Health 13:96. 10.1186/1476-069X-13-96.25406847
Callahan CL, Stewart PA, Friesen MC, . 2018. Case-control investigation of occupational exposure to chlorinated solvents and non-Hodgkin’s lymphoma. Occup Environ Med 75(6):415–420. 10.1136/oemed-2017-104890.29588333
Chaigne B, Lasfargues G, Marie I, . 2015. Primary Sjögren’s syndrome and occupational risk factors: A case-control study. J Autoimmun 60:80–5. 10.1016/j.jaut.2015.04.004.25963068
Chang YM, Tai CF, Yang SC, . 2005. Cancer incidence among workers potentially exposed to chlorinated solvents in an electronics factory. J Occup Health 47(2):171–180. 10.1539/joh.47.171.15824483
Christensen KY, Vizcaya D, Richardson H, . 2013. Risk of selected cancers due to occupational exposure to chlorinated solvents in a case-control study in Montreal. J Occup Environ Med 55(2):198–208. 10.1097/JOM.0b013e3182728eab.23147555
Fang F, Quinlan P, Ye W, . 2009. Workplace exposures and the risk of amyotrophic lateral sclerosis. Environ Health Perspect 117(9):1387–1392. 10.1289/ehp.0900580.19750102
Garcia-Perez J, Lope V, Lopez-Abente G, . 2015. Ovarian cancer mortality and industrial pollution. Environ Pollut 205:103–110. 10.1016/j.envpol.2015.05.024.26046426
Garcia-Perez J, Lope V, Perez-Gomez B, . 2018. Risk of breast cancer and residential proximity to industrial installations: New findings from a multicase-control study (MCC-Spain). Environ Pollut 237:559–568. 10.1016/j.envpol.2018.02.065.29524878
Garcia-Perez J, Fernandez de Larrea-Baz N, Lope V, . 2020. Residential proximity to industrial pollution sources and colorectal cancer risk: A multicase-control study (MCC-Spain). Environ Int 144:106055. 10.1016/j.envint.2020.106055.32827807
Infante-Rivard C, Siemiatycki J, Lakhani R, . 2005. Maternal exposure to occupational solvents and childhood leukemia. Environ Health Perspect 113(6):787–792. 10.1289/ehp.7707.15929905
Jimenez T, Pollan M, Dominguez-Castillo A, . 2022. Residential proximity to industrial pollution and mammographic density. Sci Total Environ 829:154578. 10.1016/j.scitotenv.2022.154578.35304152
Liu T, Xu QE, Zhang CH, . 2013. Occupational exposure to methylene chloride and risk of cancer: a meta-analysis. Cancer Causes Control 24(12):2037–2049. 10.1007/s10552-013-0283-0.24026192
Mattei F, Guida F, Matrat M, . 2014. Exposure to chlorinated solvents and lung cancer: results of the ICARE study. Occup Environ Med 71(10):681–689. 10.1136/oemed-2014-102182.25015929
Nijem K, Kristensen P, Al-Khatib A, . 2001. Prevalence of neuropsychiatric and mucous membrane irritation complaints among Palestinian shoe factory workers exposed to organic solvents and plastic compounds. Am J Ind Med 40(2):192–198. 10.1002/ajim.1087.11494347
Park AS, Ritz B, Ling C, . 2017. Exposure to ambient dichloromethane in pregnancy and infancy from industrial sources and childhood cancers in California. Int J Hyg Environ Health 220(7):1133–1140. 10.1016/j.ijheh.2017.06.006.28720343
Purdue MP, Stewart PA, Friesen MC, . 2017. Occupational exposure to chlorinated solvents and kidney cancer: a case-control study. Occup Environ Med 74(4):268–274. 10.1136/oemed-2016-103849.27803178
Radican L, Wartenberg D, Rhoads GG, . 2006. A retrospective occupational cohort study of end-stage renal disease in aircraft workers exposed to trichloroethylene and other hydrocarbons. J Occup Environ Med 48(1):1–12. 10.1097/01.jom.0000190300.51629.e0.16404204
Radican L, Blair A, Stewart P, . 2008. Mortality of aircraft maintenance workers exposed to trichloroethylene and other hydrocarbons and chemicals: extended follow-up. J Occup Environ Med 50(11):1306–1319. 10.1097/JOM.0b013e3181845f7f.19001957
Seeherunwong A, Chaiear N, Khuntikeo N, . 2022. The proportion of occupationally related cholangiocarcinoma: a tertiary hospital study in northeastern Thailand. Cancers (Basel) 14(10). 10.3390/cancers14102386.
Sobue T, Utada M, Makiuchi T, . 2015. Risk of bile duct cancer among printing workers exposed to 1,2-dichloropropane and/or dichloromethane. J Occup Health 57(3):230–236. 10.1539/joh.14-0116-OA.25739336

### B.3 OTHER ROUTE TOXICITY

Hoffmann P, Müller SP, Heinroth K, . 1995. Cardiotoxicity of dichloromethane in rats and in cultured rat cardiac myocytes. Toxicol In Vitro 9(4):489–492. 10.1016/0887-2333(95)00019-5.20650117
Honma T, Suda M. 1997. Changes in plasma lipoproteins as toxicity markers for carbon tetrachloride, chloroform, and dichloromethane. Ind Health 35(4):519–531. 10.2486/indhealth.35.519.9348725
Kim SJ, Jung YS, Yoon MY, . 2007. Comparative effects of dimethylsulfoxide on metabolism and toxicity of carbon tetrachloride and dichloromethane. J Appl Toxicol 27(1):25–31. 10.1002/jat.1180.17177172

### B.4 TOXICOKINETICS

Amsel J, Soden KJ, Sielken RL, . 2001. Observed versus predicted carboxyhemoglobin levels in cellulose triacetate workers exposed to methylene chloride. Am J Ind Med 40(2):180–191. 10.1002/ajim.1086.11494346
Andersen ME, Black MB, Campbell JL, . 2017. Combining transcriptomics and PBPK modeling indicates a primary role of hypoxia and altered circadian signaling in dichloromethane carcinogenicity in mouse lung and liver. Toxicol Appl Pharmacol 332:149–158. 10.1016/j.taap.2017.04.002.28392392
Andersen ME, Clewell HJ, Mahle DA, . 1994. Gas uptake studies of deuterium isotope effects on dichloromethane metabolism in female B6C3F1 mice in vivo. Toxicol Appl Pharmacol 128(1):158–65. 10.1006/taap.1994.1193.8079349
Arakawa S, Fujimoto K, Kato A, . 2012. Evaluation of hepatic glutathione transferase Mu 1 and Theta 1 activities in humans and mice using genotype information. Drug Metab Dispos 40(3):497–503. 10.1124/dmd.111.042911.22170331
Barry KH, Zhang Y, Lan Q, . 2011. Genetic variation in metabolic genes, occupational solvent exposure, and risk of non-Hodgkin lymphoma. Am J Epidemiol 173(4):404–413. 10.1093/aje/kwq360.21228414
Basak S, Mills C, El-Masri D, . 2004. Predicting blood:air partition coefficients using theoretical molecular descriptors. Environ Toxicol Pharmacol 16(1–2):45–55. 10.1016/j.etap.2003.09.002.21782693
Beliveau M, Krishnan K. 2005. Molecular structure-based prediction of the steady-state blood concentrations of inhaled organics in rats. Toxicol Mech Methods 15(5):361–366. 10.1080/15376520500195921.20021057
Beliveau M, Tardif R, Krishnan K, . 2003. Quantitative structure-property relationships for physiologically based pharmacokinetic modeling of volatile organic chemicals in rats. Toxicol Appl Pharmacol 189(3):221–232. 10.1016/s0041-008x(03)00129-7.12791307
Boerleider RZ, Olie JD, van Eijkeren JCH, . 2015. Evaluation of three physiologically based pharmacokinetic (PBPK) modeling tools for emergency risk assessment after acute dichloromethane exposure. Toxicol Lett 232(1):21–27. 10.1016/j.toxlet.2014.10.010.25455448
Bois FY. 1999. Analysis of PBPK models for risk characterization. Ann N Y Acad Sci 895:317–337. 10.1111/j.1749-6632.1999.tb08093.x.10676425
Bos PM, Zeilmaker MJ, van Eijkeren, . 2006. Application of physiologically based pharmacokinetic modeling in setting acute exposure guideline levels for methylene chloride. Toxicol Sci 91(2):576–585. 10.1093/toxsci/kfj176.16569727
Chebekoue SF, Krishnan K. 2019. Derivation of internal dose-based thresholds of toxicological concern for occupational inhalation exposure to systemically acting organic chemicals. J Occup Environ Hyg 16(4):308–319. 10.1080/15459624.2019.1568445.30676257
Ciuchta HP, Savell GM, Spiker RC, . 1979. The effect of alcohols and toluene upon methylene chloride-induced carboxyhemoglobin in the rat and monkey. Toxicol Appl Pharmacol 49(2):347–354. 10.1016/0041-008x(79)90259-x.115113
Clewell HJ, Lee TS, Carpenter RL, . 1994. Sensitivity of physiologically based pharmacokinetic models to variation in model parameters: methylene chloride. Risk Anal 14(4):521–531. 10.1111/j.1539-6924.1994.tb00268.x.7972956
Clewell HJ, Gentry PR, Covington TR, . 2004. Evaluation of the potential impact of age- and gender-specific pharmacokinetic differences on tissue dosimetry. Toxicol Sci 79(2):381–393. 10.1093/toxsci/kfh109.15056818
DeJongh J, Verhaar HJ, Hermens JL, . 1998. Role of kinetics in acute lethality of nonreactive volatile organic compounds (VOCs). Toxicol Sci 45(1):26–32. 10.1006/toxs.1998.2496.9848107
Evans MV, Caldwell JC. 2010. Evaluation of two different metabolic hypotheses for dichloromethane toxicity using physiologically based pharmacokinetic modeling for in vivo inhalation gas uptake data exposure in female B6C3F1 mice. Toxicol Appl Pharmacol 244(3):280–290. 10.1016/j.taap.2010.01.018.20153349
Gajjar RM, Miller MA, Kasting GB, . 2013. Evaporation of volatile organic compounds from human skin in vitro. Ann Occup Hyg 57(7):853–865. 10.1093/annhyg/met004.23609116
GE. 1988. Health and safety studies on methylene chloride with attachments and cover letter dated 090688. General Electric Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. 86880000358. OTS0516508. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0516508.xhtml. August 22, 2022.
Gentry PR, Covington TR, Clewell HJ, . 2003. Evaluation of the potential impact of pharmacokinetic differences on tissue dosimetry in offspring during pregnancy and lactation. Regul Toxicol Pharmacol 38(1):1–16. 10.1016/s0273-2300(03)00047-3.12878049
Gisi D, Leisinger T, Vuilleumier S, . 1999. Enzyme-mediated dichloromethane toxicity and mutagenicity of bacterial and mammalian dichloromethane-active glutathione S-transferases. Arch Toxicol 73(2):71–79. 10.1007/s002040050589.10350186
Gisi D, Maillard J, Flanagan JU, . 2001. Dichloromethane mediated in vivo selection and functional characterization of rat glutathione S-transferase theta 1-1 variants. Eur J Biochem 268(14):4001–4010. 10.1046/j.1432-1327.2001.02314.x.11453994
Hoffmann P, Müller SP, Heinroth K, . 1995. Cardiotoxicity of dichloromethane in rats and in cultured rat cardiac myocytes. Toxicol In Vitro 9(4):489–492. 10.1016/0887-2333(95)00019-5.20650117
Holder JW. 2012. Physical and physicochemical factors effecting transport of chlorohydrocarbon gases from lung alveolar air to blood as measured by the causation of narcosis. J Environ Sci Health C Environ Carcinog Ecotoxicol Rev 30(1):42–80. 10.1080/10590501.2012.653888.22458856
Jakubowski M, Czerczak S. 2009. Calculating the retention of volatile organic compounds in the lung on the basis of their physicochemical properties. Environ Toxicol Pharmacol 28(2):311–315. 10.1016/j.etap.2009.05.011.21784021
Jonsson F, Bois F, Johanson G, . 2001. Physiologically based pharmacokinetic modeling of inhalation exposure of humans to dichloromethane during moderate to heavy exercise. Toxicol Sci 59(2):209–218. 10.1093/toxsci/59.2.209.11158713
Jonsson F, Johanson G. 2003. The Bayesian population approach to physiological toxicokinetictoxicodynamic models-an example using the MCSim software. Toxicol Lett 138(1–2):143–150. 10.1016/s0378-4274(02)00369-7.12559698
Kamiya Y, Otsuka S, Miura T, . 2019. Plasma and hepatic concentrations of chemicals after virtual oral administrations extrapolated using rat plasma data and simple physiologically based pharmacokinetic models. Chem Res Toxicol 32(1):211–218. 10.1021/acs.chemrestox.8b00307.30511563
Kim SJ, Jung YS, Yoon MY, . 2007. Comparative effects of dimethylsulfoxide on metabolism and toxicity of carbon tetrachloride and dichloromethane. J Appl Toxicol 27(1):25–31. 10.1002/jat.1180.17177172
Kim SK, Kim YC. 1996. Effect of a single administration of benzene, toluene or m-xylene on carboxyhaemoglobin elevation and metabolism of dichloromethane in rats. J Appl Toxicol 16(5):437–444. 10.1002/(sici)1099-1263(199609)16:5<437::Aid-jat371>3.0.Co;2-2.8889796
Lemasters GK, Lockey JE, Olsen DM, . 1999. Comparison of internal dose measures of solvents in breath, blood and urine and genotoxic changes in aircraft maintenance personnel. Drug Chem Toxicol 22(1):181–200. 10.3109/01480549909029731.10189578
Levitt DG. 2004. Physiologically based pharmacokinetic modeling of arterial - antecubital vein concentration difference. BMC Clin Pharmacol 4:2. 10.1186/1472-6904-4-2.15053829
Mahle DA, Gearhart JM, Grigsby CC, . 2007. Age-dependent partition coefficients for a mixture of volatile organic solvents in Sprague-Dawley rats and humans. J Toxicol Environ Health A 70(20):1745–1751. 10.1080/15287390701458991.17885931
Marino DJ, Clewell HJ, Gentry R, . 2006. Revised assessment of cancer risk to dichloromethane: part I Bayesian PBPK and dose-response modeling in mice. Regul Toxicol Pharmacol 45(1):44–54. 10.1016/j.yrtph.2005.12.007.16442684
Marino DJ, Starr TB. 2007. Probabilistic dose-response modeling: case study using dichloromethane PBPK model results. Regul Toxicol Pharmacol 49(3):285–300. 10.1016/j.yrtph.2007.08.006.17949874
Marino DJ. 2005. Physiologically based pharmacokinetic modeling using Microsoft excel and visual basic for applications. Toxicol Mech Methods 15(2):137–154. 10.1080/15376520590918810.20021074
Nakayama Y, Kishida F, Nakatsuka I, . 2005. Simulation of the toxicokinetics of trichloroethylene, methylene chloride, styrene and n-hexane by a toxicokinetics/toxicodynamics model using experimental data. Environ Sci 12(1):21–32.15793558
Oh SJ, Kim SK, Kim C, . 2002. Role of glutathione in metabolic degradation of dichloromethane in rats. Toxicol Lett 129(1–2):107–114. 10.1016/s0378-4274(01)00523-9.11879980
Olie JD, Bessems JG, Clewell HJ, . 2015. Evaluation of semi-generic PBTK modeling for emergency risk assessment after acute inhalation exposure to volatile hazardous chemicals. Chemosphere 132:47–55. 10.1016/j.chemosphere.2015.02.048.25794648
Olvera-Bello AE, Estrada-Muñiz E, Elizondo G, . 2010. Susceptibility to the cytogenetic effects of dichloromethane is related to the glutathione S-transferase theta phenotype. Toxicol Lett 199(3):218–224. 10.1016/j.toxlet.2010.09.002.20837120
Paixao P, Aniceto N, Gouveia LF, . 2013. Tissue-to-blood distribution coefficients in the rat: Utility for estimation of the volume of distribution in man. Eur J Pharm Sci 50(3–4):526–543. 10.1016/j.ejps.2013.08.020.23994235
Poli D, Manini P, Andreoli R, . 2005. Determination of dichloromethane, trichloroethylene and perchloroethylene in urine samples by headspace solid phase microextraction gas chromatography-mass spectrometry. J Chromatogr B Analyt Technol Biomed Life Sci 820(1):95–102. 10.1016/j.jchromb.2005.03.009.
Poulin P, Krishnan K. 2016. Molecular structure-based prediction of the toxicokinetics of inhaled vapors in humans. Int J Toxicol 18(1):7–18. 10.1080/109158199225756.
Rodriguez CE, Mahle DA, Gearhart JM, . 2007. Predicting age-appropriate pharmacokinetics of six volatile organic compounds in the rat utilizing physiologically based pharmacokinetic modeling. Toxicol Sci 98(1):43–56. 10.1093/toxsci/kfm082.17426107
Schulz TG, Wiebel FA, Thier R, . 2000. Identification of theta-class glutathione S-transferase in liver cytosol of the marmoset monkey. Arch Toxicol 74(3):133–138. 10.1007/s002040050665.10876998
Sherratt PJ, Williams S, Foster J, . 2002. Direct comparison of the nature of mouse and human GST T1-1 and the implications on dichloromethane carcinogenicity. Toxicol Appl Pharmacol 179(2):89–97. 10.1006/taap.2002.9348.11884241
Sweeney LM, Kirman CR, Morgott DA, . 2004. Estimation of interindividual variation in oxidative metabolism of dichloromethane in human volunteers. Toxicol Lett 154(3):201–216. 10.1016/j.toxlet.2004.08.002.15501612
Takeshita H, Mogi K, Yasuda T, . 2000. Postmortem absorption of dichloromethane: a case study and animal experiments. Int J Legal Med 114(1–2):96–100. 10.1007/s004140000141.11197638
Thier R, Wiebel FA, Hinkel A, . 1998. Species differences in the glutathione transferase GSTT1-1 activity towards the model substrates methyl chloride and dichloromethane in liver and kidney. Arch Toxicol 72(10):622–629. 10.1007/s002040050552.9851677
Thomas RS, Yang RS, Morgan DG, . 1996. PBPK modeling/Monte Carlo simulation of methylene chloride kinetic changes in mice in relation to age and acute, subchronic, and chronic inhalation exposure. Environ Health Perspect 104(8):858–865. 10.1289/ehp.96104858.8875160
Trapp S, Bomholtz LM, Legind CN, . 2008. Coupled mother-child model for bioaccumulation of POPs in nursing infants. Environ Pollut 156(1):90–98. 10.1016/j.envpol.2007.12.036.18280018
Valcke M, Haddad S. 2015. Assessing human variability in kinetics for exposures to multiple environmental chemicals: a physiologically based pharmacokinetic modeling case study with dichloromethane, benzene, toluene, ethylbenzene, and m-xylene. J Toxicol Environ Health A 78(7):409–431. 10.1080/15287394.2014.971477.25785556
Watanabe K, Guengerich FP. 2006. Limited reactivity of formyl chloride with glutathione and relevance to metabolism and toxicity of dichloromethane. Chem Res Toxicol 19(8):1091–1096. 10.1021/tx060087n.16918250

### B.5 GENOTOXICITY

Akiba N, Shiizaki K, Matsushima Y, . 2017. Influence of GSH S-transferase on the mutagenicity induced by dichloromethane and 1,2-dichloropropane. Mutagenesis 32(4):455–462. 10.1093/mutage/gex014.28521016
Anderson BE, Zeiger E, Shelby MD, . 1990. Chromosome aberration and sister chromatid exchange test results with 42 chemicals. Environ Mol Mutagen 16 Suppl 18:55–137. 10.1002/em.2850160505.
Brennan RJ, Schiestl RH. 1998. Positive responses to carcinogens in the yeast DEL recombination assay are not due to selection of preexisting spontaneous revertants. Mutat Res 421(1):117–120. 10.1016/s0027-5107(98)00168-7.9748530
Buranarom A, Navasumrit P, Ngaotepprutaram T, . 2021. Dichloromethane increases mutagenic DNA damage and transformation ability in cholangiocytes and enhances metastatic potential in cholangiocarcinoma cell lines. Chem Biol Interact 346:109580. 10.1016/j.cbi.2021.109580.34280354
DeMarini DM, Shelton ML, Warren SH, . 1997. Glutathione S-transferase-mediated induction of GC->AT transitions by halomethanes in Salmonella. Environ Mol Mutagen 30(4):440–447.9435885
Gisi D, Leisinger T, Vuilleumier S, . 1999. Enzyme-mediated dichloromethane toxicity and mutagenicity of bacterial and mammalian dichloromethane-active glutathione S-transferases. Arch Toxicol 73(2):71–79. 10.1007/s002040050589.10350186
Gisi D, Maillard J, Flanagan JU, . 2001. Dichloromethane mediated in vivo selection and functional characterization of rat glutathione S-transferase theta 1-1 variants. Eur J Biochem 268(14):4001–4010. 10.1046/j.1432-1327.2001.02314.x.11453994
Hirata T, Cho YM, Toyoda T, . 2017. Lack of in vivo mutagenicity of 1,2-dichloropropane and dichloromethane in the livers of gpt delta rats administered singly or in combination. J Appl Toxicol 37(6):683–691. 10.1002/jat.3416.27896817
Hu Y, Kabler SL, Tennant AH, . 2006. Induction of DNA-protein crosslinks by dichloromethane in a V79 cell line transfected with the murine glutathione-S-transferase theta 1 gene. Mutat Res 607(2):231–239. 10.1016/j.mrgentox.2006.04.013.16765633
Irvin-Barnwell EA, Benson KM, Lu M, . 2021. Environmental toxins found historically in the polycythemia vera cluster area and their potential for inducing DNA damage. J Environ Anal Toxicol 8(1):1000551. 10.4172/2161-0525.1000551.
Kayser MF, Vuilleumier S. 2001. Dehalogenation of dichloromethane by dichloromethane dehalogenase/glutathione S-transferase leads to formation of DNA adducts. J Bacteriol 183(17):5209–5212. 10.1128/jb.183.17.5209-5212.2001.11489877
Kowalski LA, Laitinen AM, Mortazavi-Asl B, . 2000. In vitro determination of carcinogenicity of sixty-four compounds using a bovine papillomavirus DNA-carrying C3H/10T(1/2) cell line. Environ Mol Mutagen 35(4):300–311.10861948
Kundu B, Richardson SD, Granville CA, . 2004. Comparative mutagenicity of halomethanes and halonitromethanes in Salmonella TA100: structure-activity analysis and mutation spectra. Mutat Res 554(1–2):335–350. 10.1016/j.mrfmmm.2004.05.015.15450430
Lemasters GK, Lockey JE, Olsen DM, . 1999. Comparison of internal dose measures of solvents in breath, blood and urine and genotoxic changes in aircraft maintenance personnel. Drug Chem Toxicol 22(1):181–200. 10.3109/01480549909029731.10189578
Mimaki S, Totsuka Y, Suzuki Y, . 2016. Hypermutation and unique mutational signatures of occupational cholangiocarcinoma in printing workers exposed to haloalkanes. Carcinogenesis 37(8):817–826. 10.1093/carcin/bgw066.27267998
Myhr B, McGregor D, Bowers L, . 1990. L5178Y mouse lymphoma cell mutation assay results with 41 compounds. Environ Mol Mutagen 16 Suppl 18:138–167. 10.1002/em.2850160506.
Olvera-Bello AE, Estrada-Muñiz E, Elizondo G, . 2010. Susceptibility to the cytogenetic effects of dichloromethane is related to the glutathione S-transferase theta phenotype. Toxicol Lett 199(3):218–224. 10.1016/j.toxlet.2010.09.002.20837120
Quintero Ruiz N, Stashenko EE, Fuentes Lorenzo JL, . 2012. The influence of organic solvents on estimates of genotoxicity and antigenotoxicity in the SOS chromotest. Genet Mol Biol 35(2):503–514.22888301
Sasaki YF, Saga A, Akasaka M, . 1998. Detection in vivo genotoxicity of haloalkanes and haloalkenes carcinogenic to rodents by the alkaline single cell gel electrophoresis (comet) assay in multiple mouse organs. Mutat Res 419(1–3):13–20. 10.1016/s1383-5718(98)00114-4.9804871
Stalter D, O’Malley E, von Gunten U, . 2016. Fingerprinting the reactive toxicity pathways of 50 drinking water disinfection by-products. Water Res 91:19–30. 10.1016/j.watres.2015.12.047.26773486
Suzuki T, Yanagiba Y, Suda M, . 2014. Assessment of the genotoxicity of 1,2-dichloropropane and dichloromethane after individual and co-exposure by inhalation in mice. J Occup Health 56(3):205–214. 10.1539/joh.13-0236-OA.24739373
Sykes PJ, Hooker AM, Morley AA, . 1999. Inversion due to intrachromosomal recombination produced by carcinogens in a transgenic mouse model. Mutat Res 427(1):1–9. 10.1016/s0027-5107(99)00084-6.10354496
Watanabe K, Liberman RG, Skipper PL, . 2007. Analysis of DNA adducts formed in vivo in rats and mice from 1,2-dibromoethane, 1,2-dichloroethane, dibromomethane, and dichloromethane using HPLC/accelerator mass spectrometry and relevance to risk estimates. Chem Res Toxicol 20(11):1594–1600. 10.1021/tx700125p.17907789
Wheeler JB, Stourman NV, Their R, . 2001. Conjugation of haloalkanes by bacterial and mammalian glutathione transferases: mono- and dihalomethanes. Chem Res Toxicol 14(8):1118–1127. 10.1021/tx010019v.11511186
Yang F, Zhang J, Chu W, . 2014. Haloactamides versus halomethanes formation and toxicity in chloraminated drinking water. J Hazard Mater 274:156–163. 10.1016/j.jhazmat.2014.04.008.24780857
Zeiger E, Dellarco V. 1990. Mutagenicity of 42 chemicals in Salmonella. Environ Mol Mutagen 16:(Suppl 18):32–54. 10.1002/em.2850160504.
Zeljezic D, Mladinic M, Kopjar N, . 2016. Evaluation of genome damage in subjects occupationally exposed to possible carcinogens. Toxicol Ind Health 32(9):1570–1580. 10.1177/0748233714568478.25653038

### B.6 MECHANISTIC

Andersen ME, Black MB, Campbell JL, . 2017. Combining transcriptomics and PBPK modeling indicates a primary role of hypoxia and altered circadian signaling in dichloromethane carcinogenicity in mouse lung and liver. Toxicol Appl Pharmacol 332:149–158. 10.1016/j.taap.2017.04.002.28392392
Brown-Woodman PD, Hayes LC, Huq F, . 1998. In vitro assessment of the effect of halogenated hydrocarbons: chloroform, dichloromethane, and dibromoethane on embryonic development of the rat. Teratology 57(6):321–333. 10.1002/(sici)1096-9926(199806)57:6<321::Aid-tera5>3.0.Co;2-z.9664640
Buranarom A, Navasumrit P, Ngaotepprutaram T, . 2021. Dichloromethane increases mutagenic DNA damage and transformation ability in cholangiocytes and enhances metastatic potential in cholangiocarcinoma cell lines. Chem Biol Interact 346:109580. 10.1016/j.cbi.2021.109580.34280354
Chan MH, Chen HH, Lin YR, . 2002. Aliphatic chlorinated hydrocarbons alter the contractile responses of tracheal smooth muscle in piglet. J Toxicol Environ Health A 65(3–4):293–304. 10.1080/15287390252800873.11911492
Devereux TR, Anna CH, Foley JF, . 1999. Mutation of beta-catenin is an early event in chemically induced mouse hepatocellular carcinogenesis. Oncogene 18(33):4726–4733. 10.1038/sj.onc.1202858.10467420
Geiss KT, Frazier JM. 2001. QSAR modeling of oxidative stress in vitro following hepatocyte exposures to halogenated methanes. Toxicol In Vitro 15(4–5):557–563. 10.1016/s0887-2333(01)00063-7.11566591
Guerra LR, de Souza AMT, Cortes JA, . 2017. Assessment of predictivity of volatile organic compounds carcinogenicity and mutagenicity by freeware in silico models. Regul Toxicol Pharmacol 91:1–8. 10.1016/j.yrtph.2017.09.030.28970106
Harris SM, Jin Y, Loch-Caruso R, . 2020. Identification of environmental chemicals targeting miscarriage genes and pathways using the comparative toxicogenomics database. Environ Res 184:109259. 10.1016/j.envres.2020.109259.32143025
Hoffmann P, Müller SP, Heinroth K, . 1995. Cardiotoxicity of dichloromethane in rats and in cultured rat cardiac myocytes. Toxicol In Vitro 9(4):489–492. 10.1016/0887-2333(95)00019-5.20650117
Järkelid L, Kjellstrand P, Martinson E, . 1997. Toxicity of 20 chemicals from the MEIC Programme determined by growth inhibition of L-929 fibroblast-like cells. Altern Lab Anim 25(1):55–59.26554350
Johnson FM. 1999. Carcinogenic chemical-response "fingerprint" for male F344 rats exposed to a series of 195 chemicals: implications for predicting carcinogens with transgenic models. Environ Mol Mutagen 34(4):234–245.10618171
Kawasaki Y, Tsuboi C, Yagi K, . 2015. Photoinitiators enhanced 1,2-dichloropropane-induced cytotoxicity in human normal embryonic lung fibroblasts cells in vitro. Environ Sci Pollut Res Int 22(6):4763–4770. 10.1007/s11356-014-3939-8.25501643
Kim SK, Kim YC. 1996. Effect of a single administration of benzene, toluene or m-xylene on carboxyhaemoglobin elevation and metabolism of dichloromethane in rats. J Appl Toxicol 16(5):437–444. 10.1002/(sici)1099-1263(199609)16:5<437::Aid-jat371>3.0.Co;2-2.8889796
Kim SJ, Jung YS, Yoon MY, . 2007. Comparative effects of dimethylsulfoxide on metabolism and toxicity of carbon tetrachloride and dichloromethane. J Appl Toxicol 27(1):25–31. 10.1002/jat.1180.17177172
Kim JK, Jung KH, Noh JH, . 2011. Identification of characteristic molecular signature for volatile organic compounds in peripheral blood of rat. Toxicol Appl Pharmacol 250(2):162–169. 10.1016/j.taap.2010.10.009.20955722
Kim JK, Eun JW, Bae HJ, . 2013. Characteristic molecular signatures of early exposure to volatile organic compounds in rat liver. Biomarkers 18(8):706–715. 10.3109/1354750X.2013.847121.24144218
McDermott C, Heffron JJ. 2013. Toxicity of industrially relevant chlorinated organic solvents in vitro. Int J Toxicol 32(2):136–145. 10.1177/1091581813482006.23559643
Mimaki S, Totsuka Y, Suzuki Y, . 2016. Hypermutation and unique mutational signatures of occupational cholangiocarcinoma in printing workers exposed to haloalkanes. Carcinogenesis 37(8):817–826. 10.1093/carcin/bgw066.27267998
Najera-Martinez M, Garcia-Latorre EA, Reyes-Maldonado E, . 2012. Halomethane-induced cytotoxicity and cell proliferation in human lung MRC-5 fibroblasts and NL20-TA epithelial cells. Inhal Toxicol 24(11):762–773. 10.3109/08958378.2012.716871.22954400
Olvera-Bello AE, Estrada-Muñiz E, Elizondo G, . 2010. Susceptibility to the cytogenetic effects of dichloromethane is related to the glutathione S-transferase theta phenotype. Toxicol Lett 199(3):218–224. 10.1016/j.toxlet.2010.09.002.20837120
Owumi SE, Najophe ES. 2019. Dichloromethane and ethanol co-exposure aggravates oxidative stress indices causing hepatic and renal dysfunction in pubertal rats. Toxicology Research and Application 3. 10.1177/2397847319855285.
Owumi SE, Danso OF, Effiong ME, . 2019. Dietary quercetin abrogates hepatorenal oxidative damage associated with dichloromethane exposure in rats. Acta Biochim Pol 66(2):201–206. 10.18388/abp.2018_2771.30958872
Park SK, Lee MY. 2014. Profiling of the dichloromethane-induced proteome expression changes. J Environ Biol 35(2):377–382.24665765
Pulling LC, Vuillemenot BR, Hutt JA, . 2004. Aberrant promoter hypermethylation of the death-associated protein kinase gene is early and frequent in murine lung tumors induced by cigarette smoke and tobacco carcinogens. Cancer Res 64(11):3844–2848. 10.1158/0008-5472.Can-03-2119.15172992
Ricco G, Tomei MC, Ramadori R, . 2004. Toxicity assessment of common xenobiotic compounds on municipal activated sludge: comparison between respirometry and Microtox. Water Res 38(8):2103–2110. 10.1016/j.watres.2004.01.020.15087191
Sarma SN, Kim YJ, Ryu JC, . 2010. Gene expression profiles of human promyelocytic leukemia cell lines exposed to volatile organic compounds. Toxicology 271(3):122–130. 10.1016/j.tox.2010.03.014.20359517
Seo M, Ikeda K, Okamura T, . 2008. Enhancing effect of chlorinated organic solvents on histamine release and inflammatory mediator production. Toxicology 243(1–2):75–83. 10.1016/j.tox.2007.09.024.18006135
Sherratt PJ, Williams S, Foster J, . 2002. Direct comparison of the nature of mouse and human GST T1-1 and the implications on dichloromethane carcinogenicity. Toxicol Appl Pharmacol 179(2):89–97. 10.1006/taap.2002.9348.11884241
Stalter D, O’Malley E, von Gunten R, . 2016. Fingerprinting the reactive toxicity pathways of 50 drinking water disinfection by-products. Water Res 91:19–30. 10.1016/j.watres.2015.12.047.26773486
Thomas RS, Bao W, Chu TM, . 2009. Use of short-term transcriptional profiles to assess the long-term cancer-related safety of environmental and industrial chemicals. Toxicol Sci 112(2):311–321. 10.1093/toxsci/kfp233.19776212
Thomas R, Thomas RS, Auerbach SS, . 2013. Biological networks for predicting chemical hepatocarcinogenicity using gene expression data from treated mice and relevance across human and rat species. PLoS One 8(5):e63308. 10.1371/journal.pone.0063308.23737943
Vuillemenot BR, Pulling LC, Palmisano WA, . 2004. Carcinogen exposure differentially modulates RAR-ß promoter hypermethylation, an early and frequent event in mouse lung carcinogenesis. Carcinogenesis 25(4):623–629. 10.1093/carcin/bgh038.14656941
Wang H, Chen J, Suda M, . 2019. Acute inhalation co-exposure to 1,2-dichloropropane and dichloromethane cause liver damage by inhibiting mitochondrial respiration and defense ability in mice. J Appl Toxicol 39(2):260–270. 10.1002/jat.3715.30240022
Watanabe K, Guengerich FP. 2006. Limited reactivity of formyl chloride with glutathione and relevance to metabolism and toxicity of dichloromethane. Chem Res Toxicol 19(8):1091–1096. 10.1021/tx060087n.16918250
Yang A, Cardona DL, Barile FA, . 2002. Subacute cytotoxicity testing with cultured human lung cells. Toxicol In Vitro 16(1):33–39. 10.1016/s0887-2333(01)00098-4.11812637
Yang F, Zhang J, Chu W, . 2014. Haloactamides versus halomethanes formation and toxicity in chloraminated drinking water. J Hazard Mater 274:156–163. 10.1016/j.jhazmat.2014.04.008.24780857
Yoshida H, Inoue S, Yoshida K, . 1998. Stimulation of hydrogen peroxide production by drinking water contaminants in HL-60 cells sensitized by retinoic acid. Environ Health Prev Med 3(2):106–112. 10.1007/bf02931793.21432519

### B.7 SECONDARY SOURCE

Anders MW, Andersen ME, Clewell HJ, . 2010. Comment on M.V. Evans and J.C. Caldwell: Evaluation of two different metabolic hypotheses for dichloromethane toxicity using physiologically based pharmacokinetic modeling of in vivo gas uptake data exposure in female B6C3F1 mice, Toxicol Appl Pharmacol 244:280–290. Toxicol Appl Pharmacol 248(1):63–64; author reply 65-67. 10.1016/j.taap.2010.07.012.20153349
Anders MW. 2004. Glutathione-dependent bioactivation of haloalkanes and haloalkenes. Drug Metab Rev 36(3–4):583–594. 10.1081/dmr-200033451.15554237
Armstrong SR, Green LC. 2004. Chlorinated hydrocarbon solvents. Clin Occup Environ Med 4(3):481–496, vi.15325317
ATSDR. 2000. Toxicological profile for methylene chloride. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/ToxProfiles/tp14.pdf. August 22, 2022.
Bale AS, Barone S, Scott CS, . 2011. A review of potential neurotoxic mechanisms among three chlorinated organic solvents. Toxicol Appl Pharmacol 255(1):113–126. 10.1016/j.taap.2011.05.008.21609728
Benbrahim-Tallaa L, Lauby-Secretan B, Loomis D, . 2014. Carcinogenicity of perfluorooctanoic acid, tetrafluoroethylene, dichloromethane, 1,2-dichloropropane, and 1,3-propane sultone. Lancet Oncol 15(9):924–925. 10.1016/s1470-2045(14)70316-x.25225686
Chebekoue SF, Krishnan K. 2017. Derivation of occupational thresholds of toxicological concern for systemically acting noncarcinogenic organic chemicals. Toxicol Sci 160(1):47–56. 10.1093/toxsci/kfx155.29036659
Clewell HJ. 1995. Incorporating biological information in quantitative risk assessment: an example with methylene chloride. Toxicology 102(1–2):83–94. 10.1016/0300-483x(95)03038-h.7482564
Clewell HJ, Gentry PR, Gearhart JM, . 1997. Investigation of the potential impact of benchmark dose and pharmacokinetic modeling in noncancer risk assessment. J Toxicol Environ Health 52(6):475–515. 10.1080/00984109708984077.9397182
Collins JF, Alexeeff GV, Lewis DC, . 2004. Development of acute inhalation reference exposure levels (RELs) to protect the public from predictable excursions of airborne toxicants. J Appl Toxicol 24(2):155–166. 10.1002/jat.967.15052612
Colman J, Rice GE, Wright M, . 2011. Identification of developmentally toxic drinking water disinfection byproducts and evaluation of data relevant to mode of action. Toxicol Appl Pharmacol 254(2):100–126. 10.1016/j.taap.2011.02.002.21296098
Cooper GS, Scott CS, Bale AS, . 2011. Insights from epidemiology into dichloromethane and cancer risk. Int J Environ Res Public Health 8(8):3380–3398. 10.3390/ijerph8083380.21909313
David RM, Clewell HJ, Gentry PR, . 2006. Revised assessment of cancer risk to dichloromethane II. Application of probabilistic methods to cancer risk determinations. Regul Toxicol Pharmacol 45(1):55–65. 10.1016/j.yrtph.2005.12.003.16439044
Dekant W, Jean P, Arts J, . 2021. Evaluation of the carcinogenicity of dichloromethane in rats, mice, hamsters and humans. Regul Toxicol Pharmacol 120:104858. 10.1016/j.yrtph.2020.104858.33387565
Dell LD, Mundt KA, McDonald M, . 1999. Critical review of the epidemiology literature on the potential cancer risks of methylene chloride. Int Arch Occup Environ Health 72(7):429–442. 10.1007/s004200050396.10541908
Dixon D, Herbert RA, Kissling GE, . 2008. Summary of chemically induced pulmonary lesions in the National Toxicology Program (NTP) toxicology and carcinogenesis studies. Toxicol Pathol 36(3):428–439. 10.1177/0192623308315360.18441259
Done R, Stanculescu I, Mandravel CL, . 2009. Actual trends in Threshold Limit Values evaluation: application to halogen containing compounds using multilinear regression method. Revue Roumaine de Chimie 54(9):749–753.
Durrani T, Clapp R, Harrison R, . 2020. Solvent-based paint and varnish removers: a focused toxicologic review of existing and alternative constituents. J Appl Toxicol 40(10):1325–1341. 10.1002/jat.3979.32342556
Elliott EG, Trinh P, Ma X, . 2017. Unconventional oil and gas development and risk of childhood leukemia: Assessing the evidence. Sci Total Environ 576:138–147. 10.1016/j.scitotenv.2016.10.072.27783932
EPA. 2017. Scope of the risk evaluation for methylene chloride (dichloromethane, DCM) CASRN: 75-09-2. U.S. Environmental Protection Agency. EPA740R17006. https://www.regulations.gov/document/EPA-HQ-OPPT-2016-0742-0061. August 22, 2022.
EPA. 2022. Methylene chloride. 5. Unreasonable risk determination. U.S. Environmental Protection Agency. https://www.regulations.gov/document/EPA-HQ-OPPT-2016-0742-0120. August 22, 2022.
Georgakopoulou R, Fiste O, Sergentanis TN, . 2021. Occupational exposure and multiple myeloma risk: an updated review of meta-analyses. J Clin Med 10(18):4179. 10.3390/jcm10184179.34575290
Greim H, Reuter U. 2001. Classification of carcinogenic chemicals in the work area by the German MAK Commission: current examples for the new categories. Toxicology 166(1–2):11–23. 10.1016/s0300-483x(01)00438-3.11518606
Hoffmann S, Kinsner-Ovaskainen A, Prieto P, . 2010. Acute oral toxicity: variability, reliability, relevance and interspecies comparison of rodent LD50 data from literature surveyed for the ACuteTox project. Regul Toxicol Pharmacol 58(3):395–407. 10.1016/j.yrtph.2010.08.004.20709128
IARC. 2017. Dichloromethane. In: Some chemicals used as solvents and in polymer manufacture. Lyon, France: International Agency for Research on Cancer, 110:177–256.
IARC. 1999. Dichloromethane. In: IARC monographs on the evaluation of carcinogenic risks to humans. Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. Lyon, France: International Agency for Research on Cancer. 71 Pt 1(Pt 1):251–315.
Ishii S, Ishii K, Imatanaka, . 2009. Evaluation for skin sensitization based on published literatures (existing information) of major PRTR designated chemical substances in Japan. Regul Toxicol Pharmacol 55(1):43–51. 10.1016/j.yrtph.2009.05.020.19501126
Ishii S, Ishii K, Nakadate, . 2013. Correlation study in skin and eye irritation between rabbits and humans based on published literatures. Food Chem Toxicol 55:596–601. 10.1016/j.fct.2013.02.004.23416141
Jacobs MM, Massey RI, Clapp RW, . 2013. The burden of cancer from organic chemicals. effects of persistent and bioactive organic pollutants on human health. In: Carpenter DO. Effects of persistent and bioactive organic pollutants on human health. Hoboken, NJ: John Wiley & Sons, Inc., 26–56. 10.1002/9781118679654.ch3.
Kafferlein HU, Ruhl R, Bruning T, . 2011. Dichloromethane and paint stripping. Gefahrst Reinhalt Luft 71(6):255–263.
Kirkland D, Aardema M, Henderson L, . 2005. Evaluation of the ability of a battery of three in vitro genotoxicity tests to discriminate rodent carcinogens and non-carcinogens. I. Sensitivity, specificity and relative predictivity. Mutat Res 584(1–2):1–256. 10.1016/j.mrgentox.2005.02.004.15979392
Kirkland D, Aardema M, Muller L, . 2006. Evaluation of the ability of a battery of three in vitro genotoxicity tests to discriminate rodent carcinogens and non-carcinogens II. Further analysis of mammalian cell results, relative predictivity and tumour profiles. Mutat Res 608(1):29–42. 10.1016/j.mrgentox.2006.04.017.16769241
Kubo S, Takemura S, Tanaka S, . 2018. Occupational cholangiocarcinoma caused by exposure to 1,2-dichloropropane and/or dichloromethane. Ann Gastroenterol Surg 2(2):99–105. 10.1002/ags3.12051.29863124
Lam J, Sutton P, Kalkbrenner A, . 2016. A systematic review and meta-analysis of multiple airborne pollutants and autism spectrum disorder. PLoS One 11(9):e0161851. 10.1371/journal.pone.0161851.27653281
Leikauf GD. 2002. Hazardous air pollutants and asthma. Environ Health Perspect 110(Suppl 4):505–526. 10.1289/ehp.02110s4505.12194881
Lewis DF, Ioannides C, Parke DV, . 1998. A combined COMPACT and HazardExpert study of 40 chemicals for which information on mutagenicity and carcinogenicity is known, including the results of human epidemiological studies. Hum Exp Toxicol 17(10):577–586. 10.1177/096032719801701009.9821022
Liss GM, House RA, Wills MC, . 2006. Cranial neuropathy associated with chlorinated solvents. Re: Facial nerve palsy after acute exposure to dichloromethane. Am J Ind Med 49(4):310. 10.1002/ajim.20285.16526064
Liteplo RG, Long GW, Meek ME, . 1998. Relevance of carcinogenicity bioassays in mice in assessing potential health risks associated with exposure to methylene chloride. Hum Exp Toxicol 17(2):84–87. 10.1177/096032719801700202.9506258
Lock EA, Zhang J, Checkoway H, . 2013. Solvents and Parkinson disease: a systematic review of toxicological and epidemiological evidence. Toxicol Appl Pharmacol 266(3):345–355. 10.1016/j.taap.2012.11.016.23220449
Lynge E, Anttila A, Hemminki K, . 1997. Organic solvents and cancer. Cancer Causes Control 8(3):406–419. 10.1023/a:1018461406120.9498902
Lynge E. 1999. Mortality of workers exposed to methylene chloride employed at a plant producing cellulose triacetate film base. Occup Environ Med 56(3):215. 10.1136/oem.56.3.215a.
Norman WC. 1996. Exposure to methylene chloride. Science 274(5286):327.8927983
NTP. 2021. Dichloromethane; CAS No. 75-09-2. Report on carcinogens. 15^th^ ed. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/dichloromethane.pdf. August 22, 2022.
PCI. 2000. Systematic evaluation of potential hazards of solvents. PCI: Paint & Coatings Industry. https://www.pcimag.com/articles/86038-systematic-evaluation-of-the-hazard-potential-of-solvents. August 22, 2022.
Phillips JA. 2018. Methylene chloride. Workplace Health Saf 66(2):108. 10.1177/2165079917736319.29053053
Preston RJ, Williams GM. 2005. DNA-reactive carcinogens: mode of action and human cancer hazard. Crit Rev Toxicol 35(8–9):673–683. 10.1080/10408440591007278.16417034
Rosenman K. 2021. Deaths from methylene chloride exposure: when chemicals used at home or work can kill. JAMA Intern Med 181(6):806–807. 10.1001/jamainternmed.2021.1058.
Ruder AM. 2006. Potential health effects of occupational chlorinated solvent exposure. Ann N Y Acad Sci 1076:207–227. 10.1196/annals.1371.050.17119204
Schlosser PM, Bale AS, Gibbons CF, . 2015. Human health effects of dichloromethane: key findings and scientific issues. Environ Health Perspect 123(2):114–119. 10.1289/ehp.1308030.25325283
Slikker W, Andersen ME, Bogdanffy MS, . 2004. Dose-dependent transitions in mechanisms of toxicity: case studies. Toxicol Appl Pharmacol 201(3):226–294. 10.1016/j.taap.2004.06.027.15582646
Starr TB, Matanoski G, Anders MW, . 2006. Workshop overview: reassessment of the cancer risk of dichloromethane in humans. Toxicol Sci 91(1):20–28. 10.1093/toxsci/kfj145.
Storm JE, Rozman KK. 1998. Derivation of an occupational exposure limit (OEL) for methylene chloride based on acute CNS effects and relative potency analysis. Regul Toxicol Pharmacol 27(3):240–250. 10.1006/rtph.1998.1209.9693075
Veraldi A, Costantini AS, Bolejack V, . 2006. Immunotoxic effects of chemicals: A matrix for occupational and environmental epidemiological studies. Am J Ind Med 49(12):1046–1055. 10.1002/ajim.20364.17036363
Wernke MJ, Schell JD. 2004. Solvents and malignancy. Clin Occup Environ Med 4(3):513–527, vii.15325319

### B.8 CONFERENCE ABSTRACT

Belmont J, Molina E, Lopez A, . 2010. Genotoxic damage, oxidative stress and xenobiotic metabolism changes produced by the exposure of the complex mixture of toluene, chloroform and methylene chloride. Toxicol Lett 196:S165–S166. 10.1016/j.toxlet.2010.03.567.
Kirman CR, Sweeney LM, Morgott DG, . 2003. Estimating interindividual variation in physiologically based pharmacokinetic (PBPK) modeling parameters for dichloromethane metabolism in human volunteers. Toxicol Sci 72(S-1):178.
Rodilla V, Fraser RA, Poupiot J, . 1999. Determination of glutathione S-transferase T1-1 activity towards dichloromethane in human liver and renal cortical cytosol. Hum Exp Toxicol 18(8):534.