# 9 REFERENCES

* Cited in text

Abo-Khatwa N, Hollingworth RM. 1974. Pesticidal chemicals affecting some energy-linked functions of rat liver mitochondria in vitro. Bull Environ Contam Toxicol 12:446–455.4433890
ACGIH. 1986. Documentation of the threshold limit values and biological exposure Indices. 5th ed. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
ACGIH. 1992. Threshold limit values for chemical substances and physical agents and biological exposure indices for 1991 to 1992. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
ACGIH. 1999. Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
ACGIH. 2001. Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
Adams M, Coon FB, Poling CE. 1974. Insecticides in the tissues of four generations of rats fed different dietary fats containing a mixture of chlorinated hydrocarbon insecticides. J Agric Food Chem 22:69–75.4130039
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agarwal SP, Ahmad A. 1978. Effects of pesticides on reproduction in mammals. Pesticides 12:33–38.
AK Dept of Environ Conservation. 1999. Drinking water regulations. Alaska Department of Environmental Conservation. http://www.state.ak.us/local/akpages/ENV.CONSERV/home.htm.
Akingbemi BT, Ge RS, Klinefelter GR, 2000. A metabolite of methoxychlor, 2,2-bis(p-hydroxyphenyl)-1,1,1-trichloroethane, reduces testosterone biosynthesis in rat leydig cells through suppression of steady-state messenger ribonucleic acid levels of the cholesterol side-chain cleavage enzyme. Biol Reprod 62:571–578.10684797
Albright R, Johnson N, Sanderson TW, 1974. Pesticide residues in the top soil of five west Alabama counties. Bull Environ Contam Toxicol 12:378–384.4139997
Alexander M. 1995. How toxic are toxic chemicals in soil. Environ Sci Technol 29(11):2713–2717.22206515
Alexander M. 1997. Environmentally acceptable endpoints in soil. In: Linz DG, Nakles DV, eds. American Academy of Environmental Engineers, Annapolis, MD: 121–147.
Al-jamal JH, Dubin NH. 2000. The effect of raloxifene on the uterine weight response in immature mice exposed to 17β- estradiol, 1,1,1-trichloro-2,2-bis(p-chlorophenyl)ethane, and methoxychlor. Am J Obstet Gynecol 182:1099–1102.10819839
Alm H, Tiemann U, Torner H. 1996. Influence of organochlorine pesticides on development of mouse embryos in vitro. Reprod Toxicol 10:321–326.8829255
Alm H, Torner H, Tiemann U, 1998. Influence of organochlorine pesticides on maturation and post-fertilization development of bovine oocytes in vitro. Reprod Toxicol 12:559–563.9763248
Altman PK, Dittmer DS. 1974. Biological handbooks: Biology data book. Volume III. Second edition. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Altschuh J, Bruggermann R, Santl H, 1999. Henry's law constants for a diverse set of organic chemicals Experimental determination and comparison of estimation methods. Chemosphere 39(11):1871–1887.
AMA. 1988. American Medical Association. Council on Scientific Affairs. Council Report: Cancer risk of pesticides in agricultural workers. J Am Med Assoc 260:959–966.
Amstislavsky SY, Amstislavkaya TG, Eronschenko VP. 1999. Methoxychlor given in the preimplantation period blocks sexual arousal in male mice. Reprod Toxicol 13:405–411.10560590
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. In: Salem H., ed. Animal Test Alternatives. U.S. Army Chemical Research Development and Engineering Center, Aberdeen Proving Ground, Maryland.
Andersen ME, Clewell HJ III, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson RL, DeFoe DL. 1980. Toxicity and bioaccumulation of endrin and methoxychlor in aquatic invertebrates and fish. Environ Pollut 22:111–121.
Anderson SA, Fail PA, McTaggart BT, 1994. Reproductive toxicity of methoxychlor (M) in corn oil to male and female Long-Evans hooded rats using the alternative reproduction test protocol (ART) [Abstract]. Biol Reprod 50(Suppl. 1):101.
APHA. 1992. Organochlorine pesticides. In: Greenburg AE, Clesceri LS, Eaton AD, eds. Standard methods for the examination of water and wastewater. 18th ed. Washington, DC: American Public Health Association, 101–108.
Appel RJ, Eroschenko VP. 1992. Passage of methoxychlor in milk and reproductive organs of nursing female mice; 1. light and scanning electron microscopic observations. Reprod Toxicol 6:223–231.1591479
Ashby J. 1987. Series: current issues in mutagenesis and carcinogenesis. Mutat Res 189:185–187.
Ashby J, Tennant RW. 1991. Definitive relationships among chemical structure, carcinogenicity and mutagenicity for 301 chemicals tested by the U.S. NTP. Mutat Res 257:229–306.1707500
Ashraf-Khorassani M, Houck RK, Levy JM. 1992. Cryogenically cooled adsorbent trap for off-line supercritical fluid extraction. J Chromatogr Sci 30:361–366.
ATSDR. 1989a. Health assessment for FMC Fresno National Priorities List (NPL) site, Fresno, California, Region 9. CERCLIS No. CAD000629998. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 1989b. Agency for Toxic Substances and Disease Registry: Federal Register 54:37618–37634.
ATSDR. 1994. Toxicological profile for DDT, DDE, and DDD. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
Ault JA, Spurgeon TE. 1984. Multiresidue gas chromatographic method for determining organochlorine pesticides in poultry fat: Collaborative study. J Assoc Off Anal Chem 67:284–289.6725198
Baarschers WH, Bharath AI, Elvish J. 1982. The biodegradation of methoxychlor by Klebsiella pneumoniae. Can J Microbiol 28:176–179.7039790
Back AM, Hay C, Caspary WJ. 1987. The mutagenic effect of seven compounds at three genetic loci in L5178Y TK+/- mouse lymphoma cells [Abstract]. Environ Mutagen 9:8.
Bal HS. 1984. Effect of methoxychlor on reproductive systems of the rat (41861). Proc Soc Exp Biol Med 176:187–196.6718363
Barchielli A, Buiatti E, Franchini M, 1982. [Male infertility and exposure to chemical agents: a review.] Med Lav 5:483–495. (Italian).
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Baughman GL, Lassiter RR. 1978. Prediction of environmental pollutant concentration. In: Cairns J, Dickson DL, Maki AW, (eds). Estimating the hazard of chemical substances to aquatic life. American Society for Testing Materials, 657:34–54.
Baughman GL, Paris DF. 1981. Microbial bioconcentration of organic pollutants from aquatic systems a critical review. Crit Rev Microbiol CRC 205–228.
Beck AJ, Wilson SC, Alcock RE, 1995. Kinetic constraints on the loss of organic chemicals form contaminated soils: Implications for soil-quality limits. Crit Rev Environ Sci 25(1):1–43.
Bencic DC, Eroschenko VP, Ingermann RL. 1997. Exposure to the pesticide methoxychlor alters hatching time and larval startle response in the salamander Ambystoma Macrodactylum [Abstract]. Biol Reprod 56(Suppl. 1):148.
Benes V, Sram R. 1969. Mutagenic activity of some pesticides in Drosophila melanogaster. Ind Med 38:50–52.
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Bermingham S. 1996. Effects of pollutants on aquatic hyphomycetes colonizing leaf material in freshwaters. In: Frankland JC, Magan N, Gadd GM, eds. Fungi and environmental change. Cambridge, Great Britain: British Mycological Society, 201–216.
Bernstein ME. 1984. Agents affecting the male reproductive system: Effects of structure on activity. Drug Metab Rev 15:941–996.6396061
Biberhofer J, Stevens RJ. 1987. Organochlorine contaminants in ambient waters of Lake Ontario. Burlington, Ontario: Inland Waters/Land Directorate Canada, 1–11.
Bigsby R, Chapin RE, Daston GP, 1999. Evaluating the effects of endocrine disruptors on endocrine function during development. Environ Health Perspect Suppl 107(4):613–618.
Bintein S, Devillers J. 1994. QSAR for organic chemical sorption in soils and sediments. Chemosphere 28(6):1171–1188.
Bitman J, Cecil HC. 1970. Estrogenic activity of DDT analogs and polychlorinated biphenyls. J Agric Food Chem 18:1108–1112.5483049
Bitman J, Harris SJ, Cecil HC. 1974. The effect of several dietary levels of technical methoxychlor on reproduction in rats. Agricultural Research Service, U.S. Department of Agriculture, Beltsville, Maryland.
Bjorge C, Brunborg G, Scholz T, 1996a. DNA damage in testicular cells in vitro: The response of rat and human cells to known toxicants [Abstract]. Mutat Res 360(3):287–288.
Bjorge C, Brunborg G, Wiger R, 1996b. A comparative study of chemically induced DNA damage in isolated human and rat testicular cells. Reprod Toxicol 10(6):509–519.8946565
Blake CA, Ashiru OA. 1997. Distribution of rat estrous cyclicity by the environmental estrogen 4-tert-octylphenol. Proc Soc Exp Biol Med 216:446–451.9402152
Blizard D, Sueyoshi T, Negishi M. 2001. Mechanism of induction of cytochrome P450 enzymes by the proestrogenic endocrine disruptor pesticide-methoxychlor: Interactions of methoxychlor metabolites with the constitutive androstane receptor system. Drug Metab Dispos 29(6):781–785.11353743
BNA. 2001. Environment and Safety Library on the Web. States and Territories. Bureau of National Affairs, Inc. Washington, D.C. http//www.esweb.bna.com/ (http://www.esweb.bna.com/).
Bomberger DC, Gwinn JL, Mabey WR, 1983. Environmental fate and transport at the terrestrial-atmospheric interface. J Am Chem Soc 10:197–214.
Brandenberger AW, Tee MK, Lee JY, 1997. Tissue distribution of estrogen receptors alpha (ER-α) and beta (ER-β) mRNA in the midgestational human fetus. J Clin Endocrinol Metab 82(10):3509–3512.9329394
Brooks GT. 1980. Perspectives of the chemical fate and toxicity of pesticides. J Environ Sci Health B 15:755–793.7002989
Brown DD, Metcalf RL, Sternberg JG, 1981. Structure-activity relationships of DDT-type analogs based on in vivo toxicity to the sensory nerves of the cockroach, Periplaneta americana L. Pestic Biochem Physiol 15:43–57.
Brown LM, Blair A, Gibson R, 1990. Pesticide exposures and other agricultural risk factors for leukemia among men in Iowa and Minnesota. Cancer Res 50:6585–6591.2208120
Brown MJ, Schultz GS, Hilton FK. 1984. Intrauterine proximity to male fetuses predetermines level of epidermal growth factor in submandibular glands of adult female mice. Endocrinology 115:2318–2323.6333979
Brzozowski AM, Pike A, Dauter Z, 1997. Molecular basis of agonism and antagonism in the oestrogen receptor. Nature 389:753–758.9338790
Budavari S, O'Neil MJ, Smith A, (Eds). 1989. The Merck index. Rahway, NJ, 5913.
Bulger WH, Kupfer D. 1985. Estrogenic activity of pesticides and other xenobiotics on the uterus and male reproductive tract. Thomas JA, , eds. Endocrine Toxicology, New York, NY: Raven Press 1–33.
Bulger WH, Kupfer D. 1989. Characteristics of monooxygenase-mediated covalent binding of methoxychlor in human and rat liver microsomes. Drug Metab Dispos 17:487–494.2573491
Bulger WH, Kupfer D. 1990. Studies on the formation of methoxychlor-protein adduct in rat and human liver microsomes: Is demethylation of methoxychlor essential for cytochrome P450 catalyzed covalent binding? Biochem Pharmacol 40:937–945.2390114
Bulger WH, Feil VJ, Kupfer D. 1985. Role of hepatic monooxygenases in generating estrogenic metabolites from methoxychlor and from its identified contaminants. Mol Pharmacol 27:115–124.3965923
Bulger WH, Muccitelli RM, Kupfer D. 1978a. Interactions of chlorinated hydrocarbon pesticides with the 8S estrogen-binding protein in rat testes. Steroids 32:165–177.715816
Bulger WH, Muccitelli RM, Kupfer D. 1978b. Interactions of methoxychlor, methoxychlor base-soluble contaminant, and 2,2-bis(p-hydroxyphenyl)-1,1,1-trichloroethane with rat uterine estrogen receptor. J Toxicol Environ Health 4:881–893.731734
Bulger WH, Muccitelli RM, Kupfer D. 1978c. Studies on the induction of rat uterine ornithine decarboxylase by DDT analogs. II. Kinetic characteristics of ornithine decarboxylase induced by DDT analogs and estradiol. Pestic Biochem Physiol 8:263–270.
Bulger WH, Muccitelli RM, Kupfer D. 1978d. Studies on the in vivo and in vitro estrogenic activities of methoxychlor and its metabolites. Role of hepatic mono-oxygenase in methoxychlor activation. Biochem Pharmacol 27:2417–2423.728194
Bulger WH, Temple JE, Kupfer D. 1983. Covalent binding of [14C]methoxychlor metabolite(s) to rat liver microsomal components. Toxicol Appl Pharmacol 68:367–374.6857671
Bush PB. 1986. Pesticide residue in feed ingredients. Poult Dig 45:530.
Bush B, Smith RM, Narang AS, 1984. Photoionization conductivity detection limits for environmental pollutants with and without chromophores. Analytical Letters 17:467–474.
CA Dept of Health Services. 2000. Draft, proposed and recently adopted regulations- drinking water. California Department of Health Services, Division of Drinking Water and Environmental Management. http://www.dhs.cahwnet.gov/ps/ddwem/.
Cabral JR, Raitano F, Mollner T, 1979. Acute toxicity of pesticides in hamsters. Toxicol Appl Pharmacol 48:A192.
Cagen SZ, Waechter JM, Dimond SS, 1999. Normal reproductive organ development in CF-1 mice following prenatal exposure to bisphenol A. Toxicol Sci 50:36–44.10445751
Calabrese EJ, Baldwin LA, Kostecki PT, 1997. A toxicologically based weight-of-evidence methodology for the relative ranking of chemicals of endocrine disruption potential. Regul Toxicol Pharmacol 26:36–40.9339477
Camanzo J, Rice CP, Jude DJ, 1987. Organic priority pollutants in nearshore fish from 14 Lake Michigan tributaries and embayments. J Great Lakes Res 13:296–309.
Campoy C, Jimenez M, Olea-Serrano M-F, 2001a. Analysis of organochlorine pesticides in human milk: preliminary results. Early Hum Develop 65(Suppl 2):S183–S190.
Campoy C, Olea-Serrano F, Jimenez M, 2001b. Diet and organochlorine contaminants in women of reproductive age under 40 years old.
Cannon Laboratories. 1976. Acute oral toxicity in rats: Technical methoxychlor. Reading, PA: Cannon Laboratories, Inc.
Carey AE. 1979. Monitoring pesticides in agricultural and urban soils of the United States. Pestic Monit J 13:23–27.492927
Cather SK, Mitchell RH, West PR. 1985. Photodechlorination of methoxychlor induced by hydroquinone: Rearrangement and conjugate formation. Chemosphere 14:27–40.
Caspary WJ, Langenbach R, Penman BW, 1988. The mutagenic activity of selected compounds at the TK locus: rodent vs. human cells. Mutat Res 196:61–81.3292900
CDC/ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary and immune systems. Atlanta, GA: CDC/ATSDR Subcommittee on Biomarkers of Organ Damage and Dysfunction, Centers for Disease Control, Agency for Toxic Substances and Disease Registry. Summary report, August 27, 1990.
Cecil HC, Harris SJ, Bitman J. 1974. Effects of non-persistent pesticides on liver weight, lipids and vitamin A of rats and quail. Bull Environ Contam Toxicol 11:496–499.4215505
Champion WL, Picket KB, Lee J. 1999. Analytical and preparative Chirala chromatography of Chirala pesticides. Division of Environmental Chemistry Preprints of Extended Abstracts 39(2):105–198.
Chan CH, Bruce G, Harrison B. 1994. Wet deposition of organochlorine pesticides and polychlorinated biphenyls to the Great Lakes. J Great Lakes Res 20(3):546–560.
Chang R, Stephens RD. 1985. The application of mass selective detector for the screening of environmental pollutants in toxic waste. The 6th National Conference on Management of Uncontrolled Hazardous Waste Sites, Sampling & Monitoring 102–106.
Chapin RE, Harris MW, Davis BJ, 1997. The effects of perinatal/juvenile methoxychlor exposure on adult rat nervous, immune, and reproductive system function. Fundam Appl Toxicol 40:138–157.9398496
Chedrese PJ, Feyles F. 2001. The diverse mechanism of action of dichlorodiphenyldichloroethylene (DDE) and methoxychlor in ovarian cells in vitro. Reprod Toxicol 15:693–698 11738522
Chen HC, Farese RV Jr. 1999. Steroid hormones: Interactions with membrane-bound receptors. Curr Biol 9(13):R478–R481.10395533
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
CO Dept of Public Health & Environ. 1999. Water quality. Colorado Department of Public Health & Environment. http://www.cdphe.state.co.us/cdphehom.asp.
Coats JR. 1990. Mechanisms of toxic action and structure-activity relationships for organochlorine and synthetic pyrethroid insecticides. Environ Health Perspect 87:255–262.2176589
Coats JR, Metcalf RL, Kapoor IP, 1979. Physical-chemical and biological degradation studies on DDT analogues with altered aliphatic moieties. J Agric Food Chem 27:1016–1022.546944
Coats JR, Williams JW, Chang C. 1989. Structure-activity for uptake and toxicity of DDT-type insecticides utilizing an NMR method for estimating σ*. Environ Toxicol Chem 8:45–52.
Colborn T, Clement C, eds. 1992. Chemically-induced alterations in sexual and functional development: The wildlife-human connection. In: Advances in modern environmental toxicology, Vol. XXI, Princeton, NJ: Princeton Scientific Publishing
Connell D, Markwell R. 1992. Mechanism and prediction of nonspecific toxicity to fish using bioconcentration characteristics. Ecotoxicol Environ Saf 24:247–265.1282870
Cooke PS, Eroschenko VP. 1990. Inhibitory effects of technical grade methoxychlor on development of neonatal male mouse reproductive organs. Biol Reprod 42:585–596.2340338
Cooper RL, Goldman JM, Rehnberg GL. 1986. Pituitary function following treatment with reproductive toxins. Environ Health Perspect 70:177–184.3830104
Cooper RL, Goldman JM, Tyrey L. 1998. The hypothalamus and pituitary as targets for reproductive toxicants. In: Korach KS, ed. Reproductive and developmental toxicology. New York, NY: Marcel Dekker, Inc., 195–210.
Corneliussen PE. 1972. Residues in food and feed: Pesticide residues in total diet samples (VI). Pestic Monit J 5:313–330.4208741
Corrales JJ, Kadohama N, Chai LS, 1981. Fluid imbibition as a factor in estrogen-induced increase of prostatic weight in castrated rats. The Prostate 2:337–358.7329871
Coulston F, Serrone DM. 1969. The comparative approach to the role of nonhuman primates in evaluation of drug toxicity in man: A review. Ann NY Acad Sci 162:681–704.4979576
Cowley SM, Hoare S, Mosselman S, 1997. Estrogen receptors α and β form heterodimers on DNA. J Biol Chem 272(32):19858–19862.9242648
Coye MJ. 1986. The health effects of agricultural production: II. The health of the community. J Public Health Policy 7:340–354.3771784
Cripe CR, Walker WW, Pritchard PH. 1987. A shake-flask test for estimation of biodegradability of toxic organic substances in the aquatic environment. Ecotoxicol Environ Safety 14:239–251.3691377
CRISP. 1993. Computer Retrieval of Information on Scientific Projects, National Institutes of Health, Division of Research Grants, Bethesda, MD. May 13, 1993.
Crockett AB, Wiersma GB, Tai H, 1974. Pesticides in soil: Pesticide residue levels in soils and crops, FY-70. National Soils Monitoring Program (II). Pestic Monit J 8:69–97.4216877
Culik R, Kaplan AM. 1976. Teratogenic study in rats with ethane, 1,1,1-trichloro-2,2-bis/para-methoxyphenyl/-(methoxychlor). Haskell Laboratory Report No. 648–76.
Cummings AM. 1990. Toxicological mechanisms of implantation failure. Fundam Appl Toxicol 15:571–579.2258020
Cummings AM. 1993. Replacement of estrogen by methoxychlor in the artificially-induced decidual cell response in the rat. Life Sci 52:347–352.8421434
Cummings AM. 1997. Methoxychlor as a model for environmental estrogens. Crit Rev Toxicol 27(4):367–379.9263644
Cummings AM, Gray LE. 1987. Methoxychlor affects the decidual cell response of the uterus but not other progestational parameters in female rats. Toxicol Appl Pharmacol 90:330–336.3629607
Cummings AM, Gray LE. 1989. Anti-fertility effect of methoxychlor in female rats: Dose- and time-dependent blockade of pregnancy. Toxicol Appl Pharmacol 97:454–462.2609343
Cummings AM, Laskey J. 1993. Effect of methoxychlor on ovarian steroidogenesis: Role in early pregnancy loss. Reprod Toxicol 7:17–23.
Cummings AM, Laws SC. 2000. Assessment of estrogenicity by using the delayed implanting of rat model and examples. Reprod Toxicol 14:111–117.10825674
Cummings AM, Metcalf JL. 1994. Mechanisms of the stimulation of rat uterine peroxidase activity by methoxychlor. Reprod Toxicol 8(6):477–786.7881199
Cummings AM, Metcalf JL. 1995a. Effects of estrogen, progesterone, and methoxychlor on surgically induced endometriosis in rats. Fundam Appl Toxicol 27:287–290.8529825
Cummings AM, Metcalf JL. 1995b. Methoxychlor regulates rat urine estrogen-induced protein. Toxicol Appl Pharmacol 130:154–160.7839363
Cummings AM, Perreault SD. 1990. Methoxychlor accelerates embryo transport through the rat reproductive tract. Toxicol Appl Pharmacol 102:110–116.2296764
Cunningham AR, Klopman G, Rosenkranz HS. 1997. A dichotomy in the lipophilicity of natural estrogens, xenoestrogens, and phytoestrogens. Environ Health Perspect Suppl 105(3):665–668.
Cupp AS, Skinner MK. 2001. Actions of the endocrine disruptor methoxychlor and its estrogenic metabolite on in vitro embryonic rat seminiferous cord formation and perinatal testis growth. Reprod Toxicol 15:317–326.11390175
Curran PG, DeGroot LJ. 1991. The effect of hepatic enzyme-inducing drugs on thyroid hormones and the thyroid gland. Endocrine Rev 12(2):135–150.2070777
Cutkomp LK, Yap HH, Vea EV, 1971. Inhibition of oligomycin-sensitive (mitochondrial) MG^2+^ ATPase by DDT and selected analogs in fish and insect tissue. Life Sci 10:1201–1209.
Danzo BJ. 1997. Environmental xenobiotics may disrupt normal endocrine function by interfering with the binding of physiological ligands to steroid receptors and binding proteins. Environ Health Perspect 105(3):294–301.9171990
Das S, Thomas p. 1999. Pesticides interfere with the nongenomic action of a progestogen on meiotic maturation by binding to its plasma membrane receptor on fish oocytes. Endocrinology 140(4):1953–1956.10098537
Davies K. 1988. Concentration and dietary intake of selected organochlorines, including PCBs, PCDDs and PCDFs in fresh food composites grown in Ontario, Canada. Chemosphere 17:263–276.
Davies RP, Dobbs AJ. 1984. The prediction of bioconcentration in fish. Water Res 18:1253–1262.
Davis JM, Svendsgaard DJ. 1990. U-Shaped dose-response curves: Their occurrence and implications for risk assessment. J Toxicol Environ Health 30:71–83.2192070
Davison KL, Cox JH. 1976. Methoxychlor effects on hepatic storage of vitamin A in rats. Bull Environ Contam Toxicol 16:145–149.963317
Davison KL, Feil VJ, Lamoureux CH. 1982. Methoxychlor metabolism in goats. J Agric Food Chem 30:130–137.7061764
Davison KL, Lamoureux CH, Feil VJ. 1983. Methoxychlor metabolism in goats. 2. Metabolites in bile and movement through skin. J Agric Food Chem 31:164–166.6826912
DeFranco DB. 1999. Regulation of steroid receptor sub-cellular trafficking. Cell Biochem Biophys 30:1–24.10099820
Degraeve N, Chollet MC. 1984. Evaluation of the mutagenic potential of four commercial mixtures of insecticides. Food Chem Toxicol 22:683–687.6540744
Dehal SS, Kupfer D. 1994. Metabolism of the proestrogenic pesticide methoxychlor by hepatic P450 monooxygenases in rats and humans: Dual pathways involving novel ortho-ring-hydroxylation by CYP2B. Drug Metab Dispos 22(6):937–946.7895613
Deichmann WB, Keplinger M, Sala F, 1967. Synergism among oral carcinogens. IV. The simultaneous feeding of four tumorigens to rats. Toxicol Appl Pharmacol 11:88–103.6056159
De La Riva C, Anadon A. 1991. Organochlorine pesticides in cow's milk from agricultural region in northwestern Spain. Environ Contam Toxicol 46:527–533.
Den Tonkelaar EM, Van Esch GJ. 1974. No-effect levels of organochlorine pesticides based on induction of microsomal liver enzymes in short-term toxicity experiments. Toxicology 2:371–380.4137085
DeRosa C, Richter P, Pohl H, 1998. Environmental exposures that affect the endocrine system: Public health implications. J Toxicol Environ Health B 1:3–26.
DeVault DS. 1985. Contaminants in fish from Great Lakes harbors and tributary mouths. Arch Environ Contam Toxicol 14:587–594.
Dikshith TS S, Raizada RB, Srivastava MK. 1990. Acute and ninety day oral study of methoxychlor in rats. Nat Acad Sci Letters 13(2):67–72.
Dodge JA, Glasebrook AL, Magee DE, 1996. Environmental estrogens: Effects on cholesterol lowering and bone in the ovariectomized rat. J Steroid Biochem Mol Biol 59(2):155–161.9010330
Dommarco R, Di Muccio A, Camoni I, 1987. Organochlorine pesticide and polychlorinated biphenyl residues in human milk from Rome (Italy) and surroundings. Bull Environ Contam Toxicol 39:919–925.3125869
Donovan MP, Schein LG, Thomas JA. 1978. Effects of pesticides on metabolism of steroid hormone by rodent liver microsomes. J Environ Pathol Toxicol 2:447–454.739223
Dougherty CP, Holtz SH, Reinert JC, 2000. Dietary exposures to food contaminants across the United States. Environ Res Sect A 84:170–185.
Driscoll SG, Taylor SH. 1980. Effects of prenatal maternal estrogen on the male urogenital system. Obstet Gynecol 56(5):537–542.7432722
Driss MR, Bouguerra ML. 1987. [Rapid determination of eggs' organochlorine pesticide and PCB residues: Application to a series of falcon eggs.] Analysis 15:361–365. (French)
Duggan RE, Corneliussen PE. 1972. Dietary intake of pesticide chemicals in the United States (III). Pestic Monit J 5:331–341.4133965
Duggan RE, Corneliussen PE, Duggan MB, 1983. Residue monitoring data. Pesticide residue levels in foods in the United States from July 1, 1969 to June 30, 1976. Food and Drug Administration and Association of Official Analytical Chemists, 14–19.
Dunkel VC, Pienta RJ, Sivak A, 1981. Comparative neoplastic transformation responses of Balb/3T3 cells, syrian hamster embryo cells, and rauscher murine leukemia virus-infected fischer 344 rat embryo cells to chemical carcinogens. J Natl Cancer Inst 67:1303–1312.6947113
Dwivedi C, Tabbert J. 1994. Effects of methoxychlor on skin tumor development. Toxicol Lett 74:235–240.7871547
Dzwonkowska A, Hubner H. 1986. Induction of chromosomal aberrations in the Syrian hamster by insecticides tested in vivo. Arch Toxicol 58:152–156.3964078
Earl FL, Miller E, Van Loon EJ. 1973. The teratogenic effects of pesticides and related compounds in beagle dogs and miniature swine. Ind Med Surg 42:32.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
Eitzer BD, Chevalier A. 1999. Landscape care pesticide residues in residential drinking water wells. Bull Environ Contam Toxicol 62:420–427.10094724
Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 1078–1080.
Elsby R, Maggs JL, Ashby J, 2001. Assessment of the effects of metabolism on the estrogenic activity of xenoestrogens: A two-stage approach coupling human liver microsomes and a yeast estrogenicity assay. J Pharmacol Exp Ther 296(2):329–337.11160614
Elswick BA, Janzen DB, Gould JC, 2000. Effects of paternal exposure to low doses of bisphenol A in male offspring of sprague-dawley rats. Abstract:1203: Toxicological Sciences, 39th annual meeting Vol.54, No.1.
EPA. 1976a. Chemical and photochemical transformation of selected pesticides in aquatic systems. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, EPA-600/3–76–067.
EPA. 1976b. Degradation of pesticides by algae. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/3–76-022.
EPA. 1978. Microcosms as ecosystems for testing ecological models. Athens, GA: U.S. Environmental Protection Agency. EPA-600/J-78–166.
EPA. 1980. U.S. Environmental Protection Agency. Part V. Federal Register 45:67350. October 10.
EPA. 1983. U.S. Environmental Protection Agency. Part V. Federal Register 48:14153. April 1.
EPA. 1986a. Quality criteria for water 1986. Washington, DC: U.S. Environmental Protection Agency, Office of Water, EPA 440/5–86-001.
EPA. 1986b. Reference values for risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. ECAO-CIN-477.
EPA. 1987a. U.S. Environmental Protection Agency. Part II. Federal Register. 52:25942–25953.
EPA. 1987b. U.S. Environmental Protection Agency. Methoxychlor health advisory. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
EPA. 1988a. EPA pesticide fact sheets - Methoxychlor no. 187. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. PB89–138531.
EPA. 1988b. Guidance for the reregistration of pesticide products containing methoxychlor as the active ingredient. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs. PB89–138523.
EPA. 1988c. Health advisory for methoxychlor. Washington, DC: U.S. Environmental Protection Agency, Rev Environ Contam Toxicol 104:161–171.
EPA. 1988d. U.S. Environmental Protection Agency. Part II. Federal Register. 53:13382–13393.
EPA. 1989a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8–88/066F.
EPA. 1989b. Method 505. Analysis of organohalide pesticides and commercial polychlorinated biphenyl (PCB) products in water by microextraction and gas chromatography. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory.
EPA. 1989c. U.S. Environmental Protection Agency. Part V. Federal Register 54:33418–33461.
EPA. 1990a. Determination of organochlorine pesticides in indoor air. Method IP-8. In: Compendium of methods for the determination of air pollutants in indoor air. Washington, DC: U.S. Environmental Protection Agency, Atomic Research and Exposure Assessment Laboratory. EPA/600-S4–90/010.
EPA. 1990b. Method 8080A. Organochlorine pesticides and polychlorinated biphenyls by gas chromatography. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory.
EPA. 1990c. Method 8081. Organochlorine pesticides and PCBs as aroclors by gas chromatography: Capillary column technique. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory.
EPA. 1990d. U.S. Environmental Protection Agency. Part II. Federal Register 55:22520–22720.
EPA. 1990e. Nonoccupational pesticide exposure study (NOPES). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA/600/3–90/003.
EPA. 1990f. National pesticide survey. Summary results of EPA's national survey of pesticides in drinking water wells. Washington, DC: U.S. Environmental Protection Agency, Office of Water.
EPA. 1990g. Drinking water criteria document for methoxychlor. Washington, DC: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. ECAO-CIN-425.
EPA. 1990h. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8–88/066F.
EPA. 1991a. Method for the supercritical fluid extraction of soils/sediments. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA/600/S4–90/026.
EPA. 1991b. U.S. Environmental Protection Agency. Part II. Federal Register. 56:3526–3528. January 30.
EPA. 1991c. U.S. Environmental Protection Agency. Part III. Federal Register. 56:7134–7240.
EPA. 1992. National study of chemical residues in fish. U.S. Environmental Protection Agency. Office of Science and Technology, Washington, DC.
EPA. 1994. Estimating exposure to dioxin-like compounds. Vol. II: Properties, sources, occurrence and background exposures. U.S. Environmental Protection Agency. Office of Research and Development, Washington, DC.
EPA. 1996. Drinking water regulations and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA 822-B-96–002.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA/630/R-96/012.
EPA. 1998. Office of Prevention, Pesticides and Toxic Substances (OPPTS), Health Effects Test Guidelines, OPPTS 870.3700, Parental Developmental Toxicity Study (Final Guideline, August 1998).
EPA. 1999a. Chemicals and chemical categories to which this part applies. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 372.65.
EPA. 1999b. Concentration limits. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 264.94.
EPA. 1999c. Determination of reportable quantities. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 117.3.
EPA. 1999d. Discarded commercial chemical products, off-specification species, container residues, and spill residues thereof. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 261.33.
EPA. 1999e. Disposal standards for the receipt of Conditionally Exempt Small Quantity Generator (CESQG) wastes of non-municipal non-hazardous waste disposal units. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 257 Subpart B.
EPA. 1999f. Hazardous waste munitions and explosives storage. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 265 Subpart EE.
EPA. 1999g. Maximum contaminant level goals for organic contaminants. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 141.50.
EPA. 1999h. Maximum contaminant levels for organic contaminants. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 141.61.
EPA. 1999i. Methoxychlor; tolerances for residues. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 180.120.
EPA. 1999j. National Recommended water quality criteria-correction. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA 822-Z-99–001.
EPA. 1999k. Public notification. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 141.32.
EPA. 1999l. Repackaging of agricultural pesticides performed at refilling establishments. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 455 Subpart E.
EPA. 1999m. Tolerances for related pesticide chemicals. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 180.3.
EPA. 1999n. Toxicity characteristics. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 261.24.
EPA. 1999o. Universal treatment standards. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 268.48.
EPA. 2000. Drinking water standards and health advisories. United States Environmental Protection Agency. Office of Water. EPA 822-B-00–001.
EPA. 2001a. Designation, reportable quantities, and notification. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://ecfrback.access.gpo.gov/otcgi/cfr/otfil...=439160&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 03, 2001.
EPA. 2001b. Determination of reportable quantity. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://ecfrback.access.gpo.gov/otcgi/cfr...8&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. September 24, 2001.
EPA. 2001c. Drinking water standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.32(e)(43). http://ecfr.access.gpo.gov/otcgi/cfr/otf...8&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. November 28, 2001.
EPA. 2001d. Groundwater monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX. http://ecfrback.access.gpo.gov/otcgi/cfr/otfilter.cgi...nd&QUERY=49673&RGN=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. September 24, 2001.
EPA. 2001e. Health based limits for exclusion of waste-derived residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, Appendix VII. http://ecfrback.access.gpo.gov/otcgi/cfr...0&RGN=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. September 24, 2001.
EPA. 2001f. Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33(e). http://ecfrback.access.gpo.gov/otcgi/cfr...8&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. September 24, 2001.
EPA. 2001g. Interim primary drinking water standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 265. Appendix III. http://ecfr.access.gpo.gov/otcgi/cfr/otf...7&RGN=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. November 28, 2001.
EPA. 2001h. Land disposal restrictions. Universal treatment standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.48. http://ecfr.access.gpo.gov/otcgi/cfr/otf...1&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. December 05, 2001.
EPA. 2001i. Maximum concentration of constituents for groundwater protection. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264.94. http://ecfr.access.gpo.gov/otcgi/cfr...8&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. November 29, 2001.
EPA. 2001j. Maximum concentration of contaminants for the toxicity characteristic. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.24. http://ecfr.access.gpo.gov/otcgi/cfr...5&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. November 29, 2001.
EPA. 2001k. Maximum contaminant levels (MCL). U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 257. Appendix I. http://ecfr.access.gpo.gov/otcgi/cfr/otf...1&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. November 28, 2001.
EPA. 2001l. Maximum contaminant levels for organic contaminants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.61. http://ecfr.access.gpo.gov/otcgi/cfr/otf...3&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. November 28, 2001.
EPA. 2001m. Maximum contaminant level goals for organic contaminants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.50. http://ecfr.access.gpo.gov/otcgi/cfr/otf...9&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. November 28, 2001.
EPA. 2001n. Methoxyclor; tolerances for residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.120. http://ecfrback.access.gpo.gov/otcgi/cfr...1&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. November 28, 2001.
EPA. 2001o. Radiation protection. Maximum concentration of constituents for groundwater protection. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192. Subpart A. http://ecfr.access.gpo.gov/otcgi/cfr...1&RGN=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. November 29, 2001.
EPA. 2001p. Reference air concentrations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266. Appendix IV. http://ecfr.access.gpo.gov/otcgi/cfr/otf...7&RGN=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. November 28, 2001.
EPA. 2001q. Tolerances for related pesticide chemicals. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.3(e)(4). http://ecfrback.access.gpo.gov/otcgi/cfr...3&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. September 24, 2001.
EPA. 2001r. Toxic chemical release reporting; Community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://ecfrback.access.gpo.gov/otcgi/cfr...4&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. September 24, 2001.
EPA. 2001s. Water programs—designation of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://ecfrback.access.gpo.gov/otcgi/cfr/otfilter.cgi?DB=...TI&QUERY=66703&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. September 24, 2001.
EPA. 2002. EPA suspends registration of certain methoxychlor products. U.S. Environmental Protection Agency. http://www.epa.gov/oppfead1/ch/csb_page/updates/methox.htm
Eroschenko VP. 1991. Ultrastructure of vagina and uterus in young mice after methoxychlor exposure. Reprod Toxicol 5:427–435.1806152
Eroschenko VP, Cooke PS. 1990. Morphological and biochemical alterations in reproductive tracts of neonatal female mice treated with pesticide methoxychlor. Biol Reprod 42:573–583.2340337
Eroschenko VP, Rourke AW. 1992. Stimulatory influences of technical grade methoxychlor and estradiol on protein synthesis in the uterus of the immature mouse. J Occup Med Toxicol 1:307–315.
Eroschenko VP, Abuel-Atta AA, Grober MS. 1995. Neonatal exposures to technical methoxychlor alters ovaries in adult mice. Reprod Toxicol 9(4):379–387.7496094
Eroschenko VP, Johnson TJ, Rourke AW. 2000. Estradiol and pesticide methoxychlor do not exhibit additivity or synergism in the reproductive tract of adult ovariectomized mice. J Toxicol Environ Health A 60:407–421.10933757
Eroschenko VP, Rourke AW, Johnson TJ. 1998. Estradiol and pesticide methoxychlor do not exhibit synergism in the ovariectomized adult mouse [Abstract]. FASEB J 12(5):A1109.
Eroschenko VP, Rourke AW, Sims WA. 1996a. Estradiol or methoxychlor stimulates expression of estrogen receptor (ER) gene in uteri of immature BALB/C mice [Abstract]. FASEB J 10(3):A792.
Eroschenko VP, Swartz WJ, Ford LC. 1997. Decreased superovulation in adult mice following neonatal exposures to technical methoxychlor. Reprod Toxicol 11(6):807–814.9407591
Fail PA, Pearce SW, Anderson SA, 1994. Methoxychlor (M) alters testosterone (T) and LH response to human chorionic gonadotropin (HCG) or gonadotropin-releasing hormone (GNRH) in male Long-Evans hooded rats [Abstract]. Biol Reprod 50(Suppl. 1):106.
Fan AM, Jackson RJ. 1989. Pesticides and food safety. Regul Toxicol Pharmacol 9:158–174.2655038
FDA. 1977. U.S. Food and Drug Administration. Part II. Federal Register 42:14325.
FDA. 1990. Part II. Code of Federal Regulations 21 CFR 103.35. U.S. Food and Drug Administration.
FDA. 1994. Total diet study, 1982–1991; 1992–1994. U.S. Food and Drug Administration
FDA. 1995. Pesticide program: Residue monitoring. J Aoac Int 78(5):119A–142A.
FDA. 1999. Requirements for specific standardized beverages: Bottled water. U.S. Food and Drug Administration. 21 CFR 165.110.
FDA. 2001. Beverages. Bottled water. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://frwebgate.access.gpo.gov/cgi-bin/...PART=165&SECTION=110&YEAR=2001&TYPE=TEXT. November 28, 2001.
FDA Residue Monitoring. 1999. Total Diet Study 1999. http://vm.cfsan.fda.gov.
FEDRIP. 1996. Federal Research In Progress Database. National Technical Information Service, Springfield, VA.
FEDRIP. 1999. Federal Research In Progress Database. National Technical Information Service, Springfield, VA.
FEDRIP. 2000. Federal Research In Progress Database. National Technical Information Service, Springfield, VA.
Fehringer NV, Walters SM. 1986. Evaluation of capillary gas chromatography for pesticide and industrial chemical residue analysis. II. Comparison of quantitative results obtained on capillary and packed columns. J Assoc Off Anal Chem 69:90–93.3949710
Ferguson SA, Scallet AC, Flynn KM, 2000. Developmental neurotoxicity of endocrine disrupters: Focus on estrogens. Neurotoxicology 21(6):947–956.11233764
Fiserova-Bergerova V, Pierce JT, Droz PO. 1990. Dermal absorption potential of industrial chemicals: criteria for skin notation. Am J Ind Med 17:617–635.2337085
Fisher AL, Keasling HH, Schueler FW. 1952. Estrogenic action of some DDT analogues. Proc Soc Exp Biol Med 81:439–441.13027332
Fleming LE, Timmeny W. 1993. Aplastic anemia and pesticides: An etiologic association? J Occup Med 35(11):1106–1116.8295035
Fogel S, Lanicone RL, Sewall AE. 1982. Enhanced biodegradation of methoxychlor in soil under sequential environmental conditions. Appl Environ Microbiol 44:113–121.7125645
Fomon SJ. 1966. Body composition of the infant. Part I: The male reference infant. In: Falkner F, ed. Human Development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Frank R, Braun HE, Ripley BD. 1987a. Residues of insecticides, fungicides, and herbicides in fruit produced in Ontario, Canada, 1980–1984. Bull Environ Contam Toxicol 39:272–279.3663981
Frank R, Braun HE, Ripley BD. 1987b. Residues of insecticides, fungicides, and herbicides on Ontario-Grown vegetables, 1980–1985. J Assoc Off Anal Chem 70:1081–1086.3436903
Fregly MJ, Luttge WG. 1982. Human endocrinology: an interactive text. New York, NY: Elsevier Science Publishing Co., 202.
Frenich AG, Vidal JLM, Frias MM, 2000. Quantitative determination of endocrine-disrupting polychlorinated biphenyls and organochlorinated pesticides in human serum using gas chromatography with electron-capture detection and tandem mass spectrometry. J Mass Spectrom 35:967–975.10972996
FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Washington, DC: Federal-State Toxicology and Regulatory Alliance Committee, Chemical Communication Subcommittee. Report 7, p. 19.
FSTRAC. 1999. Summary of state and federal drinking water standards and guidelines: 1998–1999. Federal State Toxicology and Regulatory Alliance Committee. November 11, 1999.
Fung Y-S, Mak JLL. 2001. Determination of pesticides in drinking water by micellar electrokinetic capillary chromatography. Electrophoresis 22:2260–2269.11504061
Gaido K, Dohme L, Wang F, 1998. Comparative estrogenic activity of wine extracts and organochlorine pesticide residues in food. Environ Health Perspect Suppl 106(6):1347–1351.
Gaido KW, Leonard LS, Maness SC, 1999. Differential interaction of the methoxychlor metabolite 2,2-bis-(p-hydroxyphenyl)-1,1,1-trichloroethane with estrogen receptors α and β. Endocrinology 140(12):5746–5753.10579340
Gaido KW, Maness SC, McDonnell DP, 2000. Interaction of methoxychlor and related compounds with estrogen receptor α and β, and androgen receptor: Structure-activity studies. Mol Pharmacol 58(1):852–858.10999957
Garner RC, Campbell J, Kirkland DJ, 1987. Use of 6-thioguanine-resistance in wild-type mouse lymphoma L5178Y cells for gene mutagen screening. Mutagenesis 2:310–311.
Garrett NE, Stack HF, Waters MD. 1986. Evaluation of the genetic activity profiles of 65 pesticides. Mutat Res 168:301–325.3796654
Gartrell MJ, Craun JC, Podrebarac DS, 1986a. Pesticides, selected elements, and other chemicals in infant and toddler total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69:123–145.3949685
Gartrell MJ, Craun JC, Podrebarac DS, 1986b. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980 - March 1982. J Assoc Off Anal Chem 69:146–161.3949687
*Gellert RJ, Wilson C. 1979. Reproductive function in rats exposed prenatally to pesticides and polychlorinated biphenyls (PCB). Environ Res 18:437–443.92403
Gershbein LL. 1970. Effect of insecticides on rat liver regeneration. Res Commun Chem Pathol Pharmacol 1:740–748.5524274
Ghosh D, Taylor JA, Green JA, 1999. Methoxychlor stimulates estrogen-responsive messenger ribonucleic acids in mouse uterus through a non-estrogen receptor (non-ER)α and non-ERβ mechanism. Endocrinology 140(8):3526–3533.10433208
Giesy JP, Verbrugge DA, Othout RA, 1994. Contaminants in fishes form Great Lakes-influenced sections and above dams of three Michigan Rivers. I: Concentrations of organochlorine insecticides, polychlorinated biphenyls, dioxin equivalents, and mercury. Arch Environ Contam Toxicol 27:202–212.8060164
Gillespie AM, Walters SM. 1986. HPLC silica column fractionation of pesticides and PCB from butterfat. Journal of Liquid Chromatography 9:2111–2141.
Gilliom RJ, Alexander RB, Smith RA. 1985. Pesticides in the nation's rivers, 1975–1980, and implications for future monitoring. U.S. Geological survey water-supply paper 2271.
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Goldman JM, Cooper RL, Rehnberg GL, 1986. Effects of low subchronic doses of methoxychlor on the rat hypothalamic-pituitary reproductive axis. Toxicol Appl Pharmacol 86:474–483.3097876
Golovleva LA, Polyakova AB, Pertsova, 1984. The fate of methoxychlor in soils and transformation by soil microorganisms. J Environ Sci Health B 19:523–538.6491174
Goodrich JA, Lykins BW, Clark RM. 1991. Drinking water from agriculturally contaminated groundwater. J Environ Qual 20:707–717.
Granstrom ML, Ahlert RC, Wiesenfeld J. 1984. The relationships between the pollutants in the sediments and in the water of the Delaware and Raritan Canal. Water Sci Technol 16:375–380.
Grant EL, Mitchell RH, West PR, 1976. Mutagenicity and putative carcinogenicity tests of several polycyclic aromatic compounds associated with impurities of the insecticide methoxychlor. Mutat Res 40:225–228.785248
Gray LE, Ferrell JM, Ostby JS. 1985. Alteration of behavioral sex differentiation by exposure to estrogenic compounds during a critical neonatal period: Effects of zearalenone, methoxychlor, and estradiol in hamsters. Toxicol Appl Pharmacol 80:127–136.3161217
Gray LE, Ostby J, Cooper RL, 1999. The estrogenic and antiandrogenic pesticide methoxychlor alters the reproductive tract and behavior without affecting pituitary size or LH and prolactin secretion in male rats. Toxicol Ind Health 15:37–47.10188190
Gray LE, Ostby JS, Ferrell JM, 1988. Methoxychlor induces estrogen-like alterations of behavior and the reproductive tract in the female rat and hamster: Effects on sex behavior, running wheel activity, and uterine morphology. Toxicol Appl Pharmacol 96:525–540.3206530
Gray LE, Ostby JS, Ferrell JM, 1989. A dose-response analysis of methoxychlor-induced alterations of reproductive development and function in the rat. Fundam Appl Toxicol 12:92–108.2925022
Greco TL, Duello TM, Gorski J. 1993. Estrogen receptors, estradiol, and diethylstilbestrol in early development: The mouse as a model for the study of estrogen receptors and estrogen sensitivity in embryonic development of male and female reproductive tracts. Endocrine Rev 14(1):59–71.8491155
Green JD, Mwatibo JM, Swartz WJ. 1997a. The effects of methoxychlor on early sea urchin development. Environ Res 72:56–64.9012372
Green JD, Swartz WJ, Mwatibo JM. 1997b. HSP expression and alteration of lectin-binding sites in methoxychlor-exposed sea urchin embryos. [Abstract]. FASEB J 11(3):A428.
Greenberg M, Anderson R, Keene J, 1982. Empirical test of the association between gross contamination of wells with toxic substances and surrounding land use. Environ Sci Technol 16:14–19.
Grifoll M, Hammel KE. 1997. Initial steps in the degradation of methoxychlor by the white rot fungus Phanerochaete chrysosporium. Appl Environ Microbiol 63(3):1175–1177.16535547
Grisamore SB, Hile JP, Otten RJ. 1991. Pesticide residues on grain products. Cereal Foods World 36:434–437.
Gunderson EL. 1988. Chemical Contaminants Monitoring: FDA total diet study, April 1982-April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71:1200–1209.3240978
Gunderson EL. 1995a. Dietary intakes of pesticides, selected elements, and other chemicals: FDA total diet study, June 1984-April 1986. J Assoc Off Anal Chem 78:910–920.
Gunderson EL. 1995b. FDA total diet study, July 1986-April 1991, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 78(6):1353–1363.
Gupta C. 2000. Reproductive malformation of the male offspring following maternal exposure to estrogenic chemicals (44516). Proc Soc Exp Biol Med 244(2):61–68.
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haag WR, Yao CC. 1992. Rate constants for reaction of hydroxyl radicals with several drinking water contaminants. Environmental Science and Technology 26:1005–1013.
Haag HB, Finnegan JK, Larson PS, 1950. Comparative chronic toxicity for warm-blooded animals of 2,2-bis-(p-chlorophenyl)-1,1,1-trichloroethane (DDT) and 2,2-bis-(p-methoxyphenyl)-1,1,1-trichloroethane (DMDT, methoxychlor). Arch Int Pharmacodyn 83:491–504.14777600
Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. Second edition. Philadelphia, PA: W.B. Sanders Company, 1084–1085.
Hall DL, Payne LA, Putnam JM, 1997. Effect of methoxychlor in implantation and embryo development in the mouse. Reprod Toxicol 11(5):703–708.9311579
Halsall CJ, Bailey R, Stern GA, 1998. Multi-year observations of organochlorine pesticides in the Arctic atmosphere. Environ Pollut 102:51–62.
Harell M, Shea JJ, Emmett JR. 1978. Bilateral sudden deafness following combined insecticide poisoning. Laryngoscope 88:1348–1351.672367
Harris SJ, Cecil HC, Bitman J. 1974. Effect of several dietary levels of technical methoxychlor on reproduction in rats. J Agric Food Chem 22:969–973.4430807
Hart LG, Fouts JR. 1965. Further studies on the stimulation of hepatic microsomal drug metabolizing enzymes by DDT and its analogs. Arch Exp Pathol Pharmacol 249:486–500.
Haskell Laboratories. 1966. Three-generation study on rats with 2,2-bis(p-methoxyphenyl)-1,1,1-trichloroethane (methoxychlor). Haskell Laboratory Report No. 102–66.
Hawker DW, Connell DW. 1986. Bioconcentration of lipophilic compounds by some aquatic organisms. Ecotoxicol Environ Safety 11:184–197.3709407
HazDat. 1991. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. February 13, 1992.
HazDat. 2000. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
HazDat. 2002. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
Hellawell JM. 1988. Toxic substances in rivers and streams. Environmental Pollution 50:61–85.15092653
Hellou J, Mackay D, Banoub J. 1999. Levels, persistence and bioavailability of organic contaminants present in marine harbor sediments impacted by raw sewage. Chemosphere 38(2):457–473.10901667
*HI Dept of Health. 1999a. Safe drinking water rules. Hawaii Department of Health. http://www.hawaii.gov/health/.
HI Dept of Health. 1999b. Clean water rules. Hawaii Department of Health. http://www.hawaii.gov/health/.
Higginson J, Terracini B, Agthe C. 1976. Nutrition and cancer: Ingestion of foodborne carcinogens. In: Cancer Epidemiology and Prevention. Schottenfeld D, Thomas C, Sprinfield, eds., Springfield, IL, 177–206.
Hodge HC, Elliott AM, Downs WL, 1966. Tests on mice for evaluating carcinogenicity. Toxicol Appl Pharmacol 9:583–596.
Hodge HC, Maynard EA, Blanchet HJ. 1952. Chronic oral toxicity tests of methoxychlor (2,2-di-(p-methoxyphenyl)-1,1,1-trichlorethane) in rats and dogs. J Pharmacol Exp Ther 104:60–66.14908872
Hodge HC, Maynard EA, Thomas JF, 1950. Short-term oral toxicity tests of methoxychlor (2,2 di-(p-methoxy phenyl)-1,1,1-trichlorethane) in rats and dogs. J Pharmacol Exp Ther 99:140–148.15429024
Hodgson E, Levi PE. 1987. A textbook of modern toxicology. New York, NY: Elsevier Science Publishers. 72–73.
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoff RM, Muir DC, Grift NP. 1992. Annual cycle of polychlorinated biphenyls and organohalogen pesticides in air in Southern Ontario. 1. Air concentration data. Environ Sci Technol 26:266–275.
Holoubek I, Houskova L, Seda Z, 1990a. Project TOCOEN. The fate of selected organic pollutants in the environment-IV. Soil, earthworms and vegetation 1988. Toxicol Environ Chem 29:73–83.
Holoubek I, Houskova L, Seda Z, 1990b. Project TOCOEN: The fate of selected organic pollutants in the environment. III. Water and sediments 1988. Toxicol Environ Chem 29:29–35.
Hong J, Pan J, Dong Z, 1987. Regulation of N-nitrosodimethylamine demethylase in rat liver and kidney. Cancer Res 47:5948–5953.3664497
Hooper K, Petreas MX, She J, 1997. Analysis of breast milk to assess exposure to chlorinated contaminants in Kazakstan: PCBs and organochlorine pesticides in southern Kazakstan. Environ Health Perspect 105(11):1250–1254.9370517
Hopper ML. 1991. Analysis of organochlorine pesticide residues using simultaneous injection of two capillary columns with electron capture and electrolytic conductivity detectors. J Assoc Off Anal Chem 74:974–981.1757423
Hopper ML, King JW. 1991. Pesticide and industrial chemical residues: Enhanced supercritical fluid carbon dioxide extraction of pesticides from foods using pelletized diatomaceous earth. J Assoc Off Anal Chem 74:661–666.1917813
Howard PH, ed. 1991. Handbook of environmental fate and exposure data for organic chemicals. Chelsea, MI: Lewis Publishers, Inc. Vol. 3: 502–504.
Howard PH, Boethling RS, Jarvis WF, 1991. Handbook of environmental degradation rates. Chelsea, MI: Lewis Publishers, Inc.
HSDB. 1993. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. May 13, 1993.
HSDB. 2000. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
Hsu RC, Biggs I, Saini NK. 1991. Solid-phase extraction cleanup of halogenated organic pesticides. J Agric Food Chem 39:1658–1666.
IARC. 1979. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Vol. 20: Methoxychlor. World Health Organization, Lyon, France.
IARC. 1987. IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Suppl 7. World Health Organization, International Agency for Research on Cancer, Lyon, France, 66.
IARC. 1998. Methoxyhlor: Summary of data reported and evaluation. World Health Organization, International Agency for Research on Cancer, Lyon France. http://193.51.164.11/htdocs/monographs/vol20/methoxychlor.html.
IARC. 2001. Overall evaluations of carcinogenicity to humans. Group 3: Unclassifiable as to carcinogenicity to humans. International Agency for Research on Cancer. http://193.51.164.11/monoeval/crthgr03.html. November 28, 2001.
Ichinose R, Kurihara N. 1987. Intramolecular deuterium isotope effect and enantiotopic differentiation in oxidative demethylation of Chirala [monomethyl-D_3_]methoxychlor in rat liver microsomes. Biochem Pharmacol 36:3751–3756.3675629
ID Department of Health and Welfare. 1999. http://www.state.id.us/.
IL Environmental Protection Agency. 1999. http://www.epa.state.il.us/.
Ingermann RL, Bencic DC, Eroschenko VP. 1997. Methoxychlor alters hatching and larval startle response in the salamander Ambystoma macrodactylum. Bull Environ Contam Toxicol 59:815–821.9323234
Ingermann RL, Bencic DC, Eroschenko VP. 1999. Methoxychlor effects on hatching and larval startle response in the salamander Ambystoma macrodactulum are independent of its estrogenic actions. Bull Environ Contam Toxicol 62:578–583.10227837
IRIS. 1993. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency.
IRIS. 2000. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency.
IRIS. 2001. Methoxyclor. Integrated Risk Information System. http://www.epa.gov/iris/subst/0369.htm. September 05, 2001.
IRIS. 2002. Methoxyclor. Integrated Risk Information System. http://www.epa.gov/iris/subst/0369.htm. February 26, 2001.
Ivey MC, Ivie GW, Coppock CE, 1983. Methoxychlor residues in milk of cattle treated with marlate^®^ 50 insecticide as a dermal spray. J Dairy Sci 66:943–950.6853805
Jackson C, Lindahl IL, Reynolds P, 1975. Effects of methoxychlor and malathion on semen characteristics of rams. J Anim Sci 40:514–517.234932
Janzen DB, Elswick BA, Welsh F. 2000. The effect of sampling design on the outcome of endocrine, reproductive and developmental toxicity studies. Abstract: 1202: Toxicological Sciences, 39th annual meeting, Vol. 54, No. 1.
Johanson CE. 1980. Permeability and vascularity of the developing brain: cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johnson BT, Kennedy JO. 1973. Biomagnification of p,p'-DDT and methoxychlor by bacteria. Appl Microbiol 26:66–71.4199339
Johnson DC, Sen M, Dey SK. 1991. Differential effects of dichlorodiphenyltrichloroethane analogs, chlordecone, and 2,3,7,8-tetrachlorodibenzo-p-dioxin on establishment of pregnancy in the hypophysectomized rat. Implantation with Xenobiotics, 42–48.
Johnson RD, Manske DD, Podrebarac DS. 1981. Pesticide, metal and other chemical residues in adult total diet samples. XII. Pestic Monit J 15:54–69.7279595
Johnson TJ, Eroschenko VP, Rourke AW. 1998. Estradiol and the pesticide methoxychlor do not exhibit synergism in ovariectomized mice [Abstract]. J Investig Med 46(1):74A.
Jorgensen SE, Halling-Sorensen B. 2000. Editorial: Drugs in the environment. Chemosphere 40:691–699.10705546
Office Kan-Do and Team Pesticides. 1995. Accumulated pesticide and industrial chemical findings from a ten-year study of ready-to-eat foods. J Assoc Off Anal Chem 78:614–631.
Kapoor IP, Metcalf RL, Nystrom RF, 1970. Comparative metabolism of methoxychlor, methiochlor and DDT in mouse, insects, and in a model ecosystem. J Agric Food Chem 18:1145–1152.5483054
Karickhoff SW, Brown DS, Scott TA. 1979. Sorption of hydrophobic pollutants on natural sediments. Water Res 13:241–248.
Kazen C, Bloomer A, Welch R, 1974. Persistence of pesticides on the hands of some occupationally exposed people. Arch Environ Health 29:315–318.4279630
Kelce W, Stone C, Laws S, 1995. Persistent DDT metabolite p,p-DDE is a potent androgen receptor antagonist. Nature 375:581–585.7791873
Kelce W, Lambright C, Gray E, 1997. Vinclozolin and p,p'-DDE alter androgen-dependent gene expression: in vivo confirmation of an androgen receptor-mediated mechanism. Toxicol Appl Pharmacol 142:192–200.9007049
Kelly TJ, Mukund R, Spicer CW, 1994. Concentrations and transformations of hazardous air pollutants. Environ Sci Technol 28:378A–387A.
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Saf 4:26–38.7379718
Keplinger ML, Deichmann WB. 1967. Acute toxicity of combinations of pesticides. Toxicol Appl Pharmacol 10:586–595.6059673
Khera KS, Whalen C, Trivett G. 1978. Teratogenicity studies on linuron, malathion, and methoxychlor in rats. Toxicol Appl Pharmacol 45:435–444.705783
Kincaid Enterprises. 1986. Rabbit teratology study with m ethoxychlor, technical grade. Nitro, WV: Kincaid Enterprises, Inc. MRID No. 0015992.
Kincaid Enterprises. 1992. Written communication (July 29) to Catherine Jewell, ATSDR, regarding current production and use of methoxychlor. Kincaid Enterprises, Inc., Nitro, WV.
Kinsley C, Miele J, Konen C, 1986a. Intrauterine contiguity influences regulatory activity in adult female and male mice. Horm Behav 20:7–12.3957261
Kinsley C, Miele J, Wagner CK, 1986b. Prior intrauterine influences body weight in male and female mice. Horm Behav 20:201–211.3721412
Kishimoto D, Kurihara N. 1996. Effects of cytochrome P450 antibodies on the oxidative demethylation of methoxychlor catalyzed by rat liver microsomal cytochrome P450 isozymes: Isozyme specificity and alteration of enantiotopic selectivity. Pestic Biochem Physiol 56:44–52.
Kishimoto D, Oku A, Kurihara N. 1995. Enantiotopic selectivity of cytochrome P450-catalyzed oxidative demethylation of methoxychlor: Alteration of selectivity depending on isozymes and substrate concentrations. Pestic Biochem Physiol 51:12–19.
Kobayashi H, Rittman BE. 1982. Microbial removal of hazardous organic compounds. Environ Sci Technol 16(3):170A–182A.
Kolpin DW, Barbash FE, Gilliom RJ. 1998. Occurrence of pesticides in shallow groundwater of the United States: Initial results from the national water-quality assessment program. Environ Sci Technol 32:558–566.
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
Konasewich D, Traversy W, Zar H. 1978. Status report on organic and heavy metal contaminants in Lakes Erie, Michigan, Huron and Superior basins, Great Lakes Water Quality Board.
Kraut-Vass A, Thoma J. 1991. Performance of an extraction disk in synthetic organic chemical analysis using gas chromatography-mass spectrometry. J Chromatogr 538:233–240.
Krisfalusi M, Eroschenko VP, Cloud JG. 1997. A comparison of the effects of methoxychlor and estradiol-17B on alevin rainbow trout (Oncorhyncus mykiss) growth, survival, and pigmentation [Abstract]. FASEB J 11(3):A427.
Krisfalusi M, Eroschenko VP, Cloud JG. 1998a. Effects of a proestrogenic pesticide on male juvenile rainbow trout (Oncorhynchus mykiss) growth, survival and sexual differentiation. [Abstract]. FASEB J 12(4):A463.
Krisfalusi M, Eroschenko VP, Cloud JG. 1998b. Exposure of juvenile rainbow trout (Oncorhynchus mykiss) to methoxychlor results in a dose-dependent decrease in growth and survival but does not alter male sexual differentiation. Bull Environ Contam Toxicol 60:659–666.9557208
Krisfalusi M, Eroschenko VP, Cloud JG. 1998c. Methoxychlor and estrasiol-17B affect alevin rainbow trout (Oncorhynchus mykiss) mortality, growth, and pigmentation. Bull Environ Contam Toxicol 61:519–526.9811958
Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Wallace Hayes, ed. Principles and methods of toxicology. 3rd edition, New York, NY: Raven Press, Ltd.
Krishnan K, Andersen ME, Clewell HJ II I, 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Yang RS A, ed. Toxicology of chemical mixtures, New York, NY: Academic Press.
KS Dept of Health & Environ. 1999. Agriculture public health. Kansas Department of Health & Environment. http://www.kdhe.state.ks.us.
Kuiper GGJM, Carlsson B, Grandien K 1997. Comparison of the ligand binding specificity and transcript tissue distribution of estrogen receptors α and β. Endocrinology 138:863–870.9048584
Kuiper GGJM, Enmark E, Pelto-Huikko M 1996. Cloning of a novel estrogen receptor expressed in rat prostate and ovary. Proc Natl Acad Sci USA 93:5925–5930.8650195
Kuiper GGJM, Lemmen JG, Carlsson B, 1998. Interaction of estrogenic chemicals and phytoestrogens with estrogen receptor B. Endocrinology 139(10):4252–4263.9751507
Kulkarni AP, Mailmam RB, Hodgson E. 1975. Cytochrome P-450 optical difference spectra of insecticides. A comparative study. J Agr Food Chem 23:177–183.1133289
Kumar Y, Byrtus G. 1993. Monitoring of methoxychlor residues in the Athabasca River system in northern Alberta after treatment for control of black fly larval populations. Environ Monitor Assess 28(1):15–32.
Kuntz KW, Warry ND. 1983. Chlorinated organic contaminants in water and suspended sediments of the lower Niagara River. J Great Lakes Res 9:241–248.
Kunze FM, Laug EP, Picket CS. 1950. The storage of methoxychlor in the fat of the rat. Proc Soc Exp Biol Med 75:415–416.14808276
Kupfer D. 1991. Interactions of estrogenic pesticides with cytochrome P450. Molecular Aspects of Monooxygenases and Bioactivation of Toxic Compounds 331–344.
Kupfer D, Bulger WH. 1979. A novel in vitro method for demonstrating proestrogens, metabolism of methoxychlor and o,p'DDT by liver microsomes in the presence of uteri and effects on intracellular distribution of estrogen receptors. Life Sci 25:975–984.41991
Kupfer D, Bulger WH. 1987a. Biochemical toxicology of methoxychlor and related chlorinated hydrocarbons. Biochem Toxicol 8:183–215.
Kupfer D, Bulger WH. 1987b. Metabolic activation of pesticides with proestrogenic activity. Fed Proc 46:1864–1869.3556609
Kupfer D, Bulger WH, Nanni FJ. 1986. Characteristics of the active oxygen in covalent binding of the pesticide methoxychlor to hepatic microsomal proteins. Biochem Pharmacol 35:2775–2780.3017361
Kupfer D, Bulger WH, Theoharides AD. 1990. Metabolism of methoxychlor by hepatic P-450 monooxygenases in rat and human. I. Characterization of a novel catechol metabolite. Chem Res Toxicol 3:8–16.2131828
Kupfer D, Li HC, Stresser DM. 1998. Methoxychlor is a prototype endocrine disruptor that inhibits the hepatic steroidal 5a-reductase in catalysis of testosterone transformation into dihydrotestosterone [Abstract]. Abstr Pap Am Chem Soc 216.
Kurata M, Hirose K, Umeda M. 1982. Inhibition of metabolic cooperation in Chinese hamster cells by organochlorine pesticides. Gann 73:217–221.7117752
Kurihara N. 1999. [Metabolism of some selected endocrine-disrupting chemicals]. Radioisotopes 48(5):375–376. (Japanese).
Kurihara N, Oku A. 1991. Effects of added protein (bovine serum albumin) on the rate and enantiotopic selectivity of oxidative O-demethylation of methoxychlor in rat liver microsomes. Pestic Bioch Physiol 40:227–235.
Lacroix D, Sonnier M, Moncino A, 1997. Expression of CYP3A in the human liver, evidence that the shift between CYP3A7 and CYP3A4 occurs immediately after birth. Eur J Biochem 247:625–634.9266706
Lafuente A, Marquez N, Perez-Lorenzo M, 2000. Hormonal disruptions induced by methoxychlor: An environmental xenoestrogen. Toxicol Lett 116(Suppl 1):109.
Lamartiniere CA, Luther MA, Lucier GW, 1982. Altered imprinting of rat liver monoamine oxidase by o-,p'-DDT and methoxychlor. Biochem Pharmacol 31:647–651.7082334
Lamoureux CH, Feil VJ. 1980. Gas chromatographic and mass spectrometric characterization of impurities in technical methoxychlor. J Assoc Off Anal Chem 63:5:1007–1037.
Lane KA, Desantis ME, Eroschenko VP. 1995. Effects of methoxychlor on hypothalamic nuclei of immature female mice [Abstract]. J Investig Med 43(Suppl. 1):146A.
Laskey J, Klinefelter G, Gray LE. 1989. Effects of chronic in vivo methoxychlor exposure on in vitro leydig cell testosterone production. Biol Reprod 40 (Suppl 1).
Laug EP, Kunze FM. 1951. Effect of carbon tetrachloride on toxicity and storage of methoxychlor in the rat. [Abstract] Fed Proc 10:318.
Laws SC, Carey SA, Ferrell JM, 2000. Estrogenic activity of octylphenol, nonylphenol, bisphenol A and methoxychlor in rats. Toxicol Sci 54:154–167.10746942
Leamy LJ, Doster MJ, Huet-Hudson YM. 1999. Effects of methoxychlor on directional and fluctuating asymmetry of mandible characters in mice. Ecotoxicology 8:63–71.
LeBel GL, Williams DT. 1986. Pesticide and industrial chemical residues: Determination of halogenated contaminants in human adipose tissue. J Assoc Off Anal Chem 69:451–458.3722093
Leeder JS, Kearns GL. 1997. Pharmacoginetics in pediatrics: Implications for practice. Pediat Clin North Am 44:55–77.
Lehman AJ. 1952. Chemicals in foods: A report to the Association of Food and Drug Officials on current developments. Part II. Pesticides. Section IV. Biochemistry. Quarterly Bulletin of the Association of Food and Drug Officials of the United States 16(3):85–91.
Lehotay SJ, Anaronson N, Emy P, 1995. Development of a sample preparation technique for supercritical fluid extraction for multiresidue analysis of pesticides in produce. J AOAC Int 78(3):831–840.
Leistra M, Boesten JJ. 1989. Pesticide contamination of groundwater in western Europe. Agric Ecosystem Environ 26:369–389.
Leung H. 1993. Physiologically-based pharmacokinetic modeling. In: Ballantine B, Marro T, Turner T, eds. General and applied toxicology. Vol. I. New York, NY: Stockton Press, 153–164.
Lewis RG, Bond AE, Johnson DE, 1988. Measurement of atmospheric concentration of common household pesticides: A pilot study. Environ Monitor Assess 10:59–73.
Lewis RG, Fortmann RC, Camann DE. 1994. Evaluation of methods for monitoring the potential exposure of small children to pesticides in the residential environment. Arch Environ Contam Toxicol 26:37–46.8110022
Lewis RG, Fortune CR, Willis RD, 1999. Distribution of pesticides and polycyclic aromatic hydrocarbons in house dust as a function of particle size. Environ Health Perspect 107(9):721–726.10464072
Li CF, Bradley RL Jr. 1968. Degradation of chlorinated hydrocarbon pesticides in milk and butteroil by ultraviolet energy. J Dairy Sci 52:27–30.
Li HC, Dehal SS, Kupfer D. 1995. Induction of the hepatic CYP2B and CYP3A enzymes by the proestrogenic pesticide methoxychlor and by DDT in the rat. Effects on methoxychlor metabolism. J Biochem Toxicol 10(1):51–61.7595932
Li HC, Mani C, Kupfer D. 1993. Reversible and time-dependent inhibition of the hepatic cytochrome P450 steroidal hydroxylases by proestrogenic pesticide methoxychlor in rat and human. J Biochem Toxicol 8(4):195–206.8114062
Liao W, Joe T, Cusick WG. 1991. Multiresidue screening method for fresh fruits and vegetables with gas chromatographic/mass spectrometric detection. J Assoc Off Anal Chem 74:554–565.1874703
Lillie RD, Smith MI, Stohlman EF. 1947. Pathologic action of DDT and certain of its analogs and derivatives. Arch Pathol 43:127–142.
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Loeffler K, Peterson R. 1999. Interactive effects of TCDD and p,p'-DDE on male reproductive tract development in in utero and lactationally exposed rats. Toxicol Appl Pharmacol 154:28–39.9882589
Lohninger H. 1994. Estimation of soil partition coefficients of pesticides from their chemical structure. Chemosphere 29(8):1611–1626.
Lopez-Avila V, Benedicto J, Baldin E. 1992. Analysis of classes of compounds of environmental concern: III. Organochlorine pesticides. Journal of High Resolution Chromatography 15:319–328.
Lopez-Avila V, Wesselman R, Edgell K. 1990. Gas chromatographic-electron capture detection method for determination of 29 organochlorine pesticides in finished drinking water: Collaborative study. J Assoc Off Anal Chem 73:276–286.2324039
Luckens MM. 1968. A rapid procedure for the laboratory diagnosis of poisoning by organochlorine insecticides. Ind Med Surg 37:533.
Luczak J. 1969. [Stability of methoxychlor in natural waters.] Rocz Panstw Zakl Hig 20:147–154. (Polish)5803064
MacRae IC. 1989. Microbial metabolism of pesticides and structurally related compounds. Rev Environ Contam Toxicol 109:1–87.2675207
Maddy KT, Edmiston S, Richmond D. 1990. Illness, injuries, and deaths from pesticide exposures in California 1949–1988. Rev Environ Contam Toxicol, 114:58–123.
*Maddy KT, Fong HR, Lowe JA, 1982. A study of well water in selected California communities for residues of 1,3-dichloropropene, chloroallyl alcohol and 49 organophosphate of chlorinated hydrocarbon pesticides. Bull Environ Contam Toxicol 29:354–359.7126926
*Maguire RJ, Kuntz KW, Hale EJ. 1983. Chlorinated hydrocarbons in the surface microlayer of the Niagara River. J Great Lakes Res 9:281–286.
Makela S, Santi R, Martikainen P, 1990. The influence of steroidal and nonsteroidal estrogens on the 5α-reduction of testosterone by the ventral prostate of the rat. J Steroid Biochem 35(2):249–256.2308339
*Maness S, McDonnell D, Gaido K. 1998. Inhibition of androgen receptor-dependent transcriptional activity by DDT isomers and methoxychlor in HepG2 human hepatoma cells. Toxicol Appl Pharmacol 151:135–142.9705896
Manske DD, Johnson RD. 1977. Residues in food and feed: Pesticide and other chemical residues in total diet samples. Pestic Monit J 10:134–148.857241
*Martinez EM, Swartz WJ. 1991. Effects of methoxychlor on the reproductive system of the adult female mouse. 1. Gross and histologic observations. Reprod Toxicol 5:139–147.1807545
*Martinez EM, Swartz WJ. 1992. Effects of methoxychlor on the reproductive system of the adult female mouse. 2. Ultrastructural observations. Reprod Toxicol 6:93–98.1562805
*Maruyama S, Fujimoto N, Yin H, 1999. Growth stimulation of a rat pituitary cell line MtT/E-2 by environmental estrogens in vitro and in vivo. Endocrine Journal 46:513–520.10580743
*Mathur SP, Morley HV. 1978. Incorporation of methoxychlor-14C in model humic acids prepared from hydroquinone. Bull Environ Contam Toxicol 20:268–274.698436
*Matsumura F. 1985. Toxicology of insecticides. New York, NY: Plenum Press.
*Matsumura F, Patil KC. 1969. Adenosine triphosphatase sensitive to DDT in synapses in rat brain. Science 166:121–122.4241326
*Matthews J, Celius T, Halgren R, 2000. Differential estrogen receptor binding of estrogenic substances: a species comparison. J Steroid Biochem Mol Biol 74:223–234.11162928
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Menzie CM. 1972. Fate of pesticides in the environment. Annu Rev Entomol 17:199–222.4550533
*Mes J. 1981. Experiences in human milk analysis for halogenated hydrocarbon residues. Int J Environ Anal Chem 9:283–299.6786993
Metcalf JL, Laws SC, Cummings AM. 1996. Methoxychlor mimics the action of 17β-estradiol on induction of uterine epidermal growth factor receptors in immature female rats. Reprod Toxicol 10(5):393–399.8888411
Metcalf RL. 1976. Organochlorine insecticides, surveys, and prospects. Adv Environ Sci Technol 6:223–285.
Metcalf RL. 1977. Biological fate and transformation of pollutants in water. Environ Sci Technol 8:195–221.
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
Mill T, Mabey W. 1985. Photochemical transformations. In: Environmental exposure from chemicals. Boca Raton, FL: CRC Press, Inc., 1:175–216.
Minyard JP, Roberts WE. 1991. Chemical contaminants monitoring: State findings on pesticide residues in foods-1988 and 1989. J Assoc Off Anal Chem 74:438–452.1874687
Mitchell AD, Caspary WJ. 1987. Concordance of results between in vitro mammalian cell mutagenesis and clastogenesis assays. Eighteenth Annual Meeting of the Environmental Mutagen Society, San Francisco, CA, April 8–12, 1987 [Abstract]. Environ Mutagen 9:74.
Mitchell AD, Rudd CJ, Caspary WJ. 1988. Evaluation of L5178Y mouse lymphoma cell mutagenesis assay: Intralaboratory results for sixty-three coded chemicals tested at SRI International. Environ Mol Mutagen 12:37–101.3416841
Mitchell RH, Mazuch L, Shell B, 1978. Constituents of commercial methoxychlor-III. The mechanism of tetraanisylethylene formation. unsym-Tetraarylethylenes (Ar_2_C=CAr_2_^'^): synthesis from DT class pesticides, and conversion to phenanthrenes and dibenzo[g,p]chrysenes. Can J Chem 56:1246–1252.
Mitsumori K, Onodera H, Yasuhara K, 1999. Modifying effects okf methoxychlor in uterine carcinogenesis model using heterozygous P53 deficient CBA mice treated with N-ethyl-N-nitrosourea. In: Organohalogen Compounds 42:97–99.
Mitsumori K, Shimo T, Onodera H, 2000. Modifying effects of ethinylestradiol but not methoxychlor on N-ethyl-N-nitrosourea-induced uterine carcinogenesis in heterozygous p53-deficient CBA mice. Toxicol Sci 58:43–49.11053539
Modin JC. 1969. Residues in fish, wildlife, and estuaries: Chlorinated hydrocarbon pesticides in California bays and estuaries. Pestic Monit J 3:1–7.5815836
Mohn WW, Tiedje JM. 1992. Microbial reductive dehalogenation. Microbiol Rev 56(3):482–507.1406492
Montesano R, Cabral JR, Wilbourn JD. 1988. Environmental carcinogens: Using pesticides and nitrosamines as paradigms. Ann NY Acad Sci 534:67–73.3291723
Montgomery JH, Welkom LM. 1990. Groundwater chemicals desk reference. Chelsea, MI: Lewis Publishers, Inc., 364–365.
Morgan JM, Hickenbottom JP. 1979. Comparison of selected parameters for monitoring methoxychlor-induced hepatotoxicity. Bull Environ Contam Toxicol 23:275–280.497438
Morrell SL, Fuchs JA, Holtzman JL. 2000. Effect of methoxychlor administration to male rats on hepatic, microsomal iodothyronine 5'-deiodinase, form I. J Pharmacol Exp Ther 294(1):308–312.10871327
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants. Clin Pharmacokin 5:485–527.
Mortelmans K, Haworth S, Lawlor T, 1986. Salmonella mutagenicity tests: II. Results from the testing of 270 chemicals. Environ Mutagen 8:1–119.
Mosselman S, Polman J, Dijkema R. 1996. ER-β: identification and characterization of a novel human estrogen receptor. FEBS Lett 392:49–53.8769313
Mote PL, Grizzle JM, Walford RL, 1990. Age-related down regulation of hepatic cytochrome P_1_-450, P_3_-450, catalase and CuZn-superoxide dismutase RNA. Mech Ageing Dev 53:101–110.1691420
Moubry RJ, Myrdal GR, Halliday HE. 1968. Dieldrin residue in an orchard-dairy area of Wisconsin. Pestic Monit J 2:51–54.5693988
Muir DC, Yarechewski AL. 1984. Degradation of methoxychlor in sediments under various redox conditions. J Environ Sci Health 3:271–295.
Murayama S, Fujimoto N, Yin H, 1999. Growth stimulation of a rat pituitary cell line MtT/E-2 by environmental estrogens in vitro and in vivo. Endocrine Journal 46(4):513–520.10580743
Mwatibo JM, Green JD. 1996. Morphologic and biochemical response of sea urchin embryos to methoxychlor. [Abstract]. Cell 7:121A.
Mwatibo JM, Green JD. 1997. Effects of methoxychlor pre-exposure on sea urchin gametes. Bull Environ Contam Toxicol 58:589–595.9060377
Mwatibo JM, Green JD. 1998. Appearance of new glycoproteins in methoxychlor-exposed sea urchin gastrulae. Bull Environ Contam Toxicol 60(5):791–796.9595197
Mwatibo JM, Swartz WJ, Green JD. 1997. Effects of pre-fertilization exposure to methoxychlor on sea urchin gametes. FASEB J 11(3):A427.
Myhr BC, Caspary WJ. 1988. Evaluation of L5178Y mouse lymphoma cell mutagenesis assay: Intralaboratory results for sixty-three coded chemicals tested at Litton Bionetics, Inc. Environ Mol Mutagen 12:103–194.3416838
Nagel SC, vom Saal FS, Welshons WV. 1999. Developmental effects of estrogenic chemicals are predicted by an in vitro assay incorporating modification of cell uptake by serum. J Steroid Biochem Mol Biol 69:343–357.10419012
Narahashi T, Haas H. 1967. DDT: Interaction with nerve membrane conductance changes. Science 157:1438–1440.6037859
NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
NATICH. 1991. National Air Toxics Information Clearing House: NATICH database report on state, local and EPA air toxic activities. Report to U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. Research Triangle Park, NC, by Radian Corporation, Austin, TX. EPA-450/3–91-018.
NCI. 1978. Bioassay of methoxychlor for possible carcinogenicity. Washington, DC: U.S. Department of Health, Education, and Welfare, Public Health Service, National Cancer Institute. Technical Report Series No. 35.
Newbold RR, Delclos KB. 1999. A comprehensive protocol for the evaluation of potential endocrine disrupting chemicals [Abstract]. Toxicologist 48(Suppl. 1-S):375–376.
Nigg HN, Metcalf RL, Kapoor IP. 1976. DDT and selected analogues as microsomal oxidase inducers in the mouse. Arch Environ Contam Toxicol 3:426–436.
Nimrod AC, Benson WH. 1997. Xenobiotic interaction with and alteration of channel catfish estrogen receptor. Toxicol Appl Pharmacol 147:381–390.9439733
Nimrod AC, Benson WH. 1998. Reproduction and development of Japanese medaka following an early life stage exposure to xenoestrogens. Aquat Toxicol 44:141–156.
NIOSH. 1978. Methoxychlor - method S371. In: NIOSH manual of analytical methods. Vol. 4. Cincinnati, OH: U.S. Department of Health, Education, and Welfare, Public Health Services, Centers for Disease Control, National Institute for Occupational Safety and Health.
NIOSH. 1986. In-depth survey report of H. Nagel and Son. Cincinnati, OH: Centers for Disease Control, National Institute for Occupational Safety and Health.
NIOSH. 1990. National Institute for Occupational Safety and Health. NIOSH pocket guide to chemical hazards. Washington, DC: U.S. Department of Health and Human Services.
NIOSH. 1992a. NIOSH recommendations for occupational safety and health. Compendium of policy documents and statements. Washington, DC: Department of Health and Human Services, 96.
NIOSH. 1992b. National Institute for Occupational Safety and Health, National Occupational Exposure Survey (NOES).
NIOSH. 1995. Report to Congress on workers' home contamination study conducted under the workers' family protection act. Cincinnati, OH: National Institute of Occupational Safety and Health. DHHS publication no. 95–123.
NIOSH. 2000. NIOSH pocket guide to chemical hazards (NPG). Washington, DC: National Institute for Occupational Safety and Health.
NIOSH. 2001. Methoxyclor. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npgd0388.html. November 28, 2001.
NJ Dept Env Protec. 1993. Ground water quality standards. New Jersey Department of Environmental Protection, Division of Water Quality. NAJC. 7:9–6. http://www.state.nj.us/dep/.
Nonneman DJ, Ganjam VK, Welshons WV, 1992. Intrauterine position effects on steroid metabolism and steroid receptors of reproductive organs in male mice. Biol Reprod 47:723–729.1477199
NRC. 1993. Pesticides in the diets of infants and children. National Research Council, Washington DC: National Academy Press.
NTP. 2001. National Toxicology Program. National Toxicology Program’s Report of the Endocrine Disruptors Low Dose Peer Review. http://ntpserver.niehs.nih.gov/htdocs/liason/LowDoseWebPage.html.
O'Brien RD, Elilton BD. 1978. The effect of DDT and its analogs on the fragility of human erythrocytes. Pestic Biochem Phys 9:231–236.
Okazaki K, Koazaki S, Nashimura S, 2001. A repeated 28-day oral dose toxicity study of methoxychlor in rats, based on the ‘enhanced OECD test guideline 407' for screening endocrinedisrupting chemicals. Arch Toxicol 75(9):513–521.11760811
El Okimoto, Nishimura K, Ueno T, 1993. Isotope effects of deuteriated methoxychlor on insecticidal and nerve activities. Comp Biochem Physiol C 106(1): 119–123.
Okumura D, Melnicoe R, Jackson T, 1991. Pesticide residues in food crops analyzed by the California department of food and agriculture in 1989. Rev Environ Contam Toxicol 118:87–151.1992493
Omann GM, Lakowicz JR. 1982. Interactions of chlorinated hydrocarbon insecticides with membranes. Biochim Biophys Acta 684:83–95.7055557
ORNL. 1981. Toxicity of leachates comparison of extraction procedure extracts and landfill leachates. Oak Ridge National Laboratory. ORNL/TM-7563.
OSE1A. 1989. Occupational Safety and Elealth Administration: Part 111. Federal Register 54:2332–2959.
OSEIA. 1993. Occupational Safety and Health Administration: Part V. Federal Register 58:35338 35351.
OSHA. 1999a. Air contaminants. Occupational Safety and Health Administration. 29 CFR 1915.1000.
OSHA. 1999b. Air contaminants. Occupational Safety and Health Administration. 29 CFR 1910.1000.
OSHA. 1999c. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. 29 CFR 1926.55.
OSHA. 2001a. Air contaminants—shipyards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. http://www.sha-slc.gov/OshStd_data/1915_1000.html. September 17, 2001.
OSHA. 2001b. Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.sha-slc.gov/OshStd_data/1910_1000_TABLE_Z.html. September 17, 2001.
OSHA. 2001c. Gases, vapors, fumes, dusts, and mists. Construction industry. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. http://frwebgate.access.gpo.gov/cgi-bin/get-cfr.cgi?TITLE=29&PART=1926&SECTION=55&YEAR=2001&TYPE=TEXT. September 18, 2001.
OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment, U.S. Congress. OTA-BA-436. April 1990.
Ousterhout J, Struck RF, Nelson JA. 1979. Estrogenic properties of methoxychlor metabolites. Toxicology 1:537.
Ousterhout J, Struck RF, Nelson JA. 1981. Estrogenic activities of methoxychlor metabolites. Biochem Pharmacol 30:2869–2871.7317081
Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: Saunders, 222–238.
Pace P, Taylor J, Suntharalingam S, 1997. Human estrogen receptor β binds DNA in a manner similar to and dimerizes with estrogen receptor α. J Biol Chem 272(41):25832–25838.9325313
Palanza P, Morellini F, Parmigiani S, 1999. Prenatal exposure to endocrine disrupting chemicals: effects on behavioral development. Neurosci Biobehav Rev 23:1011–1027.10580314
Palanza P, Parmigiani S, vom Saal FS. 2001. Effects of prenatal exposure to low doses of diethylstilbestrol, o,p’DDT, and methoxychlor on postnatal growth and neurobehavioral development in male and female mice. Horm Behav 40:252–265.11534990
Paris DF, Lewis DL. 1973. Chemical and microbial degradation of ten selected pesticides in aquatic systems. Residue Rev 45:95–124.4196563
Paris DF, Lewis DL. 1976. Accumulation of methoxychlor by microorganisms isolated from aqueous systems. Bull Environ Contam Toxicol 15:24–33.819068
Parmigiani S, vom Saal F, Palanza P. 1998. Social and individual behaviour in mice prenatally exposed to endocrine disrupting chemicals. In: Effects of endocrine disruptors in the environment on neural development and behaviour. Texte-Umweltbundesamt Series # 50. Berlin: Umweltbundesamt, 6–15.
Parrish PR, Dyar EE, Lindberg MA, 1977. Chronic toxicity of methoxychlor, malathion and carbofuran to sheepshead minnows (Cypinodan variegatus). NTIS PB-272101.
Patterson JR. 1991. Reducing solvent consumption in automated gel permeation chromatographic cleanup for pesticide residue analysis: a modified GPC autoprep 1002. J Assoc Off Anal Chem 74:1016–1018.
Perez-Villamil B, Bordiu E, Puente-Cueva M. 1992. Involvement of physiological prolactin levels in growth and prolactin receptor content of prostate glands and testes in developing male rats. J Endocrinol 132:449–459.1564431
Petersen DN, Tkalcevic GT, Koza-Taylor PH, 1998. Identification of estrogen receptor β_2_, a functional varient of estrogen receptor β expressed in normal rat tissues. Endocrinology 139(3):1082–1092.9492041
Petersson DN, Tkalcevic GT, Koza-Taylor PH, 1998. Identification of estrogen receptor β_2_, a functional varient of estrogen receptor β expressed in normal rat tissues. Endocrinology 139(3):1082–1092.9492041
Pettersson K, Grandien K, Kuiper G, 1997. Mouse estrogen receptor β forms estrogen response element-binding heterodimers with estrogen receptor α. Molecular Endocrinology 11:1486–1496.9280064
Petty JD, Poulton BC, Charbonneau CS, 1998. Determination of bioavailable contaminants in the lower Missouri River following the flood of 1993. Environ Sci Technol 32(7):837–842.
Peziol-Laszczynska M, Wozniak D, Oledzka-Slotwinska H. 1978. Study of the influence of liquid insecticides: Foschlor-50 and Metox-30 on histology and enzyme histochemistry of the white mice kidney. Folia Histochem Cytochem 16:165.
Phillips WE, Hatina G. 1972. Effect of dietary organochlorine pesticides on the liver vitamin A content of the weanling rat. Nutr Rep Int 5:357–362.
Pickford DB, Morris ID. 1999. Effects of endocrine-disrupting contaminants on amphibian oogenesis: Methoxychlor inhibits progesterone-induced maturation of xenopus laevis oocytes in vitro. Environ Health Perspect 107(4):285–292.10090707
Pienta RJ. 1980. Transformation of Syrian hamster embryo cells by diverse chemicals and correlation with their reported carcinogenic and mutagenic activities. In: Chemical mutagens. Principles and methods for their detection. de Serres FJ, Hollaender A., eds. New York, NY: Plenum Press, 175–202.
Plumb RH. 1991. The occurrence of appendix IX organic constituents in disposal site ground water. GWMR 157–164.za
Pluta J. 1989. Studies on concentration of halogen derivatives in herbal products from various regions of Poland. Pharmazie 44:222–224.2748709
Polyakova AV, Baskunov BP, Golovleva LA. 1984. Effect of methoxychlor on the soil microflora and its transformation by microorganisms. Mikrobiologiya 53(3):442–449.
Poole DC, Simmon VF, Newell GW. 1977. In vitro mutagenic activity of fourteen pesticides. Toxicol Appl Pharmacol 41:196.
Prasad SS. 1992. Predicting the environmental distribution of compounds with unknown physicochemical properties from known pesticide properties. J AOAC Int 75(5):916–924.
Prins GS, Birch L. 1997. Neonatal estrogen exposure up-regulates estrogen receptor expression in the developing and adult rat prostate lobes. Endocrinology 138(5):1801–1809.9112371
Prins GS, Marmer M, Woodham C, 1998. Estrogen receptor-β messenger ribonucleic acid ontogeny in the prostate of normal and neonatally estrogenized rats. Endocrinology 139(3):874–883.9492016
Probst GS, McMahon RE, Hill LE, 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: A comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3:11–32.7021142
Public Law. 1990. Clean Air Act Amendments of 1990. Public Law 101–541, 101–547.
Pylypiw HM. 1997. Suitability of microwave-assisted extraction for multiresidue pesticide analysis of produce. J. Agric. Food Chem. 45:3522–3528.
Quensen JF, Mueller SA, Jain MK, 1998. Reductive dechlorination of DDE to DDMU in marine sediment microcosms. Science 280:722–724.9563945
Quinto I, Martire G, Vricella G, 1981. Screening of 24 pesticides by Salmonella/microsome assay: mutagenicity of benazolin, metoxuron and paraoxon. Mutat Res 4:265.
Radomski JL, Deichmann WB, MacDonald WE, 1965. Synergism among oral carcinogens. I. Results of the simultaneous feeding of four tumorigens to rats. Toxicol Appl Pharmacol 7:652–656.5866802
Rajfer J, Coffey DS. 1978. Sex steroid imprinting of the immature prostate: Long-term effects. Invest Urol 16(3):186–190.711410
Ratanasavanh D, Beaune P, Morel F, 1991. Intralobular distribution and quantitation of cytochrome P-450 enzymes in human liver as a function of age. Hepatology 13(6):1142–1151.1904834
Reinbold KA, Kapoor IP, Childers WF, 1971. Comparative uptake and biodegradability of DDT and methoxychlor by aquatic organisms. Illinois Natural History Survey Bulletin 30:405.
Respess DS, Carr RL, Cox NM, 1999. Evaluation of the reproductive parameters in rats affected by the interactions of polychlorinated biphenyls and methoxychlor resulting from exposure during development [Abstract]. Toxicologist 48(Suppl. 1-S):374–375.
Reuber MD. 1978. Carcinomas and other lesions of the liver in mice ingesting organochlorine pesticides. Clin Toxicol 13:231–256.216523
Reuber MD. 1979a. Carcinomas of the liver in Osborne-Mendell rats ingesting methoxychlor. Life Sci 24:1367–1372.481087
Reuber MD. 1979b. Interstitial cell carcinomas of the testis in BALB/C male mice ingesting methoxychlor. Cancer Res Clin Oncol 93:173–179.
Reuber MD. 1980. Carcinogenicity and toxicity of methoxychlor. Environ Health Perspect 36:205–219.7000513
Reynolds PJ, Lindahl IL, Cecil HC, 1976. A comparison of DDT and methoxychlor accumulation and depletion in sheep. Bull Environ Contam Toxicol 16:240–247.963329
Rich KJ, Edwards RJ, Foster JR, 1990. Ontogeny of expression and inductibility of hepatic cytochrome P450IA2 in the rat and rabbit. Hum Toxicol 9(5):330.
Richardson EM, Epstein E. 1971. Retention of three insecticides on different size soil particles suspended in water. Soil Sci Soc Am Proc 35:884–887.
Robertson BK, Alexander M. 1998. Sequestration of DDT and dieldrin in soil: disappearance of acute toxicity but not the compounds. Environ Toxicol Chem 17(6):1034–1038.
Rourke AW, Eroschenko VP, Washburn LJ. 1991. Protein secretions in mouse uterus after methoxychlor or estradiol exposure. Reprod Toxicol 5:437–442.1806153
Roy D, Angelini NL, Belsham DD. 1999. Estrogen directly represses gonadotropin-releasing hormone (GnRH) gene expression in estrogen receptor-α (ERα)- and ERβ-expressing GT1–7 GnRH neurons. Endocrinology 140(11):5045–5053.10537130
Roy D, Palangat M, Chen C, 1997. Biochemical and molecular changes at the cellular level in response to exposure to environmental estrogen-like chemicals. J Toxicol Environ Health 50:1–29.9015129
Roy RR, Albert RH, Wilson P, 1995. U.S. Food and Drug Administration pesticide program: Incidence/level monitoring of domestic and imported pears and tomatoes. J AOAC Int 78(4):930–940.7580331
Rudel R. 1997. Predicting health effects of exposures to compounds with estrogenic activity: Methodological issues. Environ Health Perspect 105(Suppl. 3):655–663.9168010
Rudel RA, Brody JG, Spengler JD, 2001. Identification of selected hormonally active agents and animal mammary carcinogens in commercial and residential air and dust samples. J Air Waste Manage Assoc 51(4):499–513.
Sabljic A, Gusten H, Hermens J. 1995. QSAR modeling of soil sorption, improvements and systematics of log K_oc_ vs. log K_ow_ correlations. Chemosphere 31:4489–4514.
Sakabe K, Yoshida T, Furuya H, 1998. Estrogenic xenobiotics increase expression of SS-A/Ro autoantigens in cultured human epidermal cells. Acta Derm Venereol (Stockh) 78:420–423.9833039
Saiki MK, Schmitt CJ. 1986. Organochlorine chemical residues in bluegills and common carp form the irrigated San Joaquin floor, California. Arch Environ Contam Toxicol 15:357–366.
Saleh FY, Lee GF, Butler JS. 1978. Kepone and other selected chlorinated hydrocarbon pesticides and PCBs behavior during hydraulic dredging of the James River near Hopewell, Virginia. J Environ Sci Health A 13:261–294.
Sandhu KS, Randahawa K, Chahal V. 1978. The effect of some herbicides on the rhizosphere microflora in the seed crop of okra Abelmoschius Esculantus. Indian J Ecol 5:61.
Saunders PT K, Fisher JS, Sharpe RM, 1998. Expression of oestrogen receptor beta (ERβ) occurs in multiple cell types, including some germ cells, in the rat testis. J Endocrinol 156:R13–R17.9582517
Sax NI, Lewis RJ. 1989. Dangerous properties of industrial materials, 7th edition. New York, NY: Van Nostrand Reinhold. 1325–1326.
Schattenberg HJ, Hsu JP. 1992. Pesticide residue survey of produce from 1989 to 1991. J AOAC 75:925–933.
Schenck FJ, Calderon L, Saudarg DE. 1996. Florisil solid-phase extraction cartridges for cleanup of organochlorine pesticide residues in foods. J AOAC Int 79(6):1454–1458.8946723
Schlenk D, Stresser DM, McCants JC, 1997. Influence of β-naphthpflavone and methoxychlor pretreatment on the biotransformation and estrogenic activity of methoxychlor in channel catfish (Ictalurus punctatus). Toxicol Appl Pharmacol 145:349–356.9266808
Schmitt CJ, Zajicek JL, Ribick MA. 1985. National pesticide monitoring program: Residues of organochlorine chemicals in freshwater fish, 1980–1981. Arch Environ Contam Toxicol 14:225–260.3920980
Schreiber B, Brink N. 1989. Pesticide toxicity using protozoans as test organisms. Biology and Fertility of Soils 7:289–296.
Schuurmann G, Klein W. 1988. Advances in bioconcentration prediction. Chemosphere 17:1551–1574.
Schwack W. 1988. Photoinduced additions of pesticides to biomolecules. 2. Model reactions of DDT and methoxychlor with methyl oleate. J Agric Food Chem 36:645–648.
SD Department of Environmental and Natural Resources. 1998. http://WWW.STATE.SD.US/STATE/EXECUTIVE/DENR/DENR.HTML.
Seifert M, Haindl S, Hock B. 1999. Development of an enzyme linked receptor assay (ELRA) for estrogens and xenoestrogens. Anal Chim Acta 386:191–199.
Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Shain SA, Shaeffer JC, Boesel RW. 1977. The effect of chronic ingestion of selected pesticides upon rat ventral prostate homeostasis. Toxicol Appl Pharmacol 40:115–130.867426
Sherma J. 1991. Thin layer chromatography of pesticides. J Planar Chromatogr 4:7–14.
Shimada K, Ooe N, Nagohori H, 2001. An in vitro reporter gene assay method incorporating metabolic activation with human and rat S9 or liver microsomes. Biochem Biophys Res Comm 280:85–91.11162482
Shimada T, Yamazaki H, Mimura M, 1994. Interindividual variations in human liver cytochrome P-450 enzymes involved in the oxidation of drugs, carcinogens and toxic chemicals: Studies with liver microsomes of 30 Japanese and 30 Caucasians. J Pharmacol Exp Ther 270:414–423.8035341
Shoeib M, Brice KA, Hoff RM. 1999. Airborne concentrations of toxaphene congeners at Point Petrre (Ontario) using gas-chromatography-electron capture negative ion mass spectometry (GC-ECNIMS). Chemosphere 39(5):849–871.10448561
Sigworth EA. 1965. Identification and removal of herbicides and pesticides. J Am Water Works Assoc 57:1016–1022.
Simmons VF, Poole DC, Riccio ES, 1979. In vitro mutagenicity and genotoxicity assays of 38 pesticides. SRI International, Menlo Park, CA. 1:142–143.
*Sittig M. 1980. Pesticide manufacturing and toxic materials control encyclopedia. Park Ridge, NJ: Noyes Data Corporation 513–515.
*Skaare J, Berge G, Odegaard S, 1982. Excretion of methoxychlor in cow milk following dermal application. Acta Vet Scand 23:16–23.7113866
*Smeets JM W, van Holsteijn I, Giesy JP, 1999. Estrogenic potencies of several environmental pollutants, as determined by vitellogenen induction in a carp hepatocyte assay. Toxicol Sci 50:206–213.10478856
*Smith CN, Payne WR, Mulkey LA, 1981. The persistence and disappearance by washoff and dryfall of methoxychlor from soybean foliage - a preliminary study. J Environ Sci Health B 16(6):777–794.7200103
*Smith MI, Bauer H, Stohlman EF, 1946. The pharmacologic action of certain analogues and derivatives of DDT. J Pharmacol Exp Ther 88:359–365.20279271
Snedaker SC, Araujo RJ, Capin AA, 1999. Organochlorine compounds in subtropical and tropical marine organisms: A meta-analysis. Toxicol Ind Health 15:214–230.10188204
*Sonnier M, Cresteil T. 1998. Delayed ontogenesis of CYP1A2 in the human liver. Eur J Biochem 251:893–898.9490065
*Spalding RF, Junk GA, Richard JJ. 1980. Pesticides in groundwater beneath irrigated farmland in Nebraska, August 1978. Pestic Monit J 14:70–73.7232106
Spicer PE, Kereu RK. 1993. Organochlorine insecticide residues in human breast milk: A survey of lactating mothers form a remote area in Papua New Guinea. Bull Environ Contam Toxicol 50:540–546.8467139
*Stan H. 1989. Application of capillary gas chromatography with mass selective detection to pesticide residue analysis. J Chromatogr 467:85–98.
Stan HJ, Goebel H. 1983. Automated capillary gas chromatographic analysis of pesticide residues in food. J Chromatogr 268:55–69.6630374
*Stanker LH, Watkins B, Vanderlaan M, 1989. Analysis of heptachlor and related cyclodiene insecticides in food products. In: Vanderlaan M, Stanker LH, Watkins BE, , eds. ACS Symposium Series 451. Immunoassays for trace chemical analysis: Monitoring toxic chemicals in humans, food, and the environment. Symposium sponsored by the International Chemical Congress of Pacific Basin Societies, Honolulu, Hawaii, December 17–22, 1989. Washington, DC: American Chemical Society, 108–123.
*Starr HG, Aldrich FD, McDougall WD, 1974. Contribution of household dust to the human exposure to pesticides. Pestic Monit J 8:209–212.4142653
*Stein AA. 1968. Comparative methoxychlor toxicity in dogs, swine, rats, monkeys and man. Ind Med Surg 37:540–541.
Steinberg KK, Garza A, Bueso JA, 1989. Serum pesticide concentrations in farming cooperatives in Honduras. Bull Environ Contam Toxicol 42:643–650.2742993
Stoker TE, Robinette CL, Cooper RL. 1999. Perinatal exposure to estrogenic compounds and the subsequent effects on the prostrate of the adult rat: Evaluation of inflammation in the ventral and lateral lobes. Reprod Toxicol 13:463–472.10613394
Stoltz RL, Pollock GA. 1982. Methoxychlor residues in treated irrigation canal water in Southcentral Idaho. Bull Environ Contam Toxicol 28:473–476.7093544
Strachan WM. 1985. Organic substances in the rainfall of Lake Superior: 1983. Environ Toxicol Chem 4:677–683.
Strachan WM. 1988. Short Communication: Toxic contaminants in rainfall in Canada: 1984. Environ Toxicol Chem 7:871–877.
Strachan WM, Huneault H. 1979. Polychlorinated biphenyls and organochlorine pesticides in Great Lakes precipitation. J Great Lake Res 5:61–68.
Stresser DM, Kupfer D. 1997. Catalytic characteristics of CYP3A4: Requirement for a phenolic function in ortho hydroxylation of estradiol and mono-O-demethylated methoxychlor. Biochem 36:2203–2210.9047321
Stresser DM, Kupfer D. 1998. Human cytochrome P450-catalyzed conversion of the proestrogenic pesticide methoxychlor into an estrogen. Drug Metab Dispos 26(9):868–874.9733665
Stresser DM, Dehal SS, Kupfer D. 1996. Ring hydroxylation of [o-3H]methoxychlor as a probe for liver microsomal CYP2B activity: A potential assay for CYP2B in vivo. Anal Biochem 233:100–107.8789153
Swann RL, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the environmental parameters octonol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:17–28.
Swartz WJ. 1992. Occupational risks of pesticide exposure for females. Final Performance Report PB93–137040.
Swartz WJ, Corkern M. 1992. Effects of methoxychlor treatment of pregnant mice on female offspring on the treated and subsequent pregnancies. Reprod Toxicol 6:431–437.1463923
Swartz WJ, Eroschenko VP. 1995. Reproductive activity of adult mice treated neonatally with methoxychlor (technical grade) [Abstract]. FASEB J 9(3):A550.
Swartz WJ, Eronschenko VP. 1998. Neonatal exposure to technical methoxychlor alters pregnancy outcome in female mice. Reprod Toxicol 12(6):565–573.9875691
Swartz WJ, Vial LJ. 1996. Exposure to methoxychlor early in pregnancy disrupts implantation. FASEB J 10(3):A260.
Swartz WJ, Wink C, Johnson WD. 1993. Response of adult murine uterine epithelium to methoxychlor exposures [Abstract]. Anat Rec 0(Suppl. 1):109.
Swartz WJ, Wink CS, Johnson WD. 1994. Response of adult murine uterine epithelium to 50% methoxychlor. Reprod Toxicol 8(1):81–87.8186629
Szymczynski GA, Waliszewski SM. 1981. Comparison of the content of chlorinated pesticide residues in human semen, testicles and fat tissues. Andrologia 13:250–252.6168217
Szymczynski GA, Waliszewski SM. 1982. A method for the determination of chlorinated pesticides in human semen. J Androl 3:149–150.
Tateishi T, Nakura H, Asoh M, 1997. A comparison of heptic cytochrome P450 protein expression between infancy and postinfancy. Life Sci 61(26):2567–2574.9416779
Tegeris AS, Earl FL, Smalley HE, 1966. Methoxychlor toxicity: Comparative studies in the dog and the swine. Arch Environ Health 13:776–787.4224289
Tessari JD, Winn DT. 1991. Relative retention ratios of 38 chlorinated pesticides and polychlorinated biphenyls on five gas-liquid chromatographic columns. J Chromatogr Sci 29:1–3.
Thomas JA, Donovan MP, Schein LG. 1978. A biochemical basis for insecticide-induced changes in the male reproductive system. Toxicol Appl Pharmacol 45:291.
Thompson TS, Vorster SJ. 2000. Attempted suicide by ingestion of methoxychlor. J Anal Toxicol 24(5):377–380.10926363
Tiemann U, Kuchenmeister U. 1999. Influence of organochlorine pesticides on ATPase activities of microsomal fractions of bovine oviductal and endometrial cells. Toxicol Lett 104:75–81.10048752
Tiemann U, Pohland R. 1999. Inhibitory effects of organochlorine pesticides on intercellular transfer of lucifer yellow in cultured bovine oviductal cells. Reprod Toxicol 13(2):123–130.10213519
Tiemann U, Pohland R, Kuchenmeister U, 1998. Influence of organochlorine pesticides on transmembrane potential, oxidative activity, and ATP-induced calcium release in cultured bovine oviductal cells. Reprod Toxicol 12(5):551–557.9763247
Tiemann U, Schneider F, Tuscherer A. 1996. Effects of organochlorine pesticides on DNA senthesis of cultured oviductal and uterine cells and on estrogen receptor of uterine tissue from heifers. Arch Toxicol 70:490–496.8783812
Timms BG, Petersen SL, vom Saal FS. 1999. Prostate gland growth during development in stimulated in both male and female rat fetuses by intrauterine proximity to female fetuses. J Urol 161:1694–1701.10210442
Toppari J, Larsen JC, Christiansen P, 1996. Male reproductive health and environmental xenoestrogens. Environ Health Perspect Suppl 104(4):741–803.
Trautmann WL, Chesters G, Pionke HB. 1968. Pesticides in soil: Organochlorine insecticide composition of randomly selected soils from nine states. Pestic Monit J 2:93–96.5688483
Treinen KA, Kulkarni AP. 1986. Human placental Ca^2+^-ATPase: In vitro inhibition by DDT homologs. Toxicol Lett 30:223–229.2939596
Treluyer JM, Gueret G, Cheron G, 1997. Developmental expression of CYP2C and CYP2C-dependent activities in the human liver: In-vivo/in-vitro correlation and inducibility. Pharmacogenetics 7:441–452.9429229
TRI90. 1992. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
TRI96. 1998. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
TRI99. 2001. TRI on-site and off-site releases (in pounds), all facilities (of 8) for releasing methoxychlor, U.S., 1998, all industries. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. http://www.epa.gov/triexplorer/chemical.htm.
Tsujita M, Ichikawa Y. 1993. Substrate-binding region of cytochrome P-450_sec_ (P-450 XIA1). Identification and primary structure of the cholesterol binding region in cytochrome P-450_sec_. Biochim Biophys Acta 1161:124–130.8431464
Tullner W. 1961. Uterotrophic action of insecticide methoxychlor. Science 133:647–648.13778585
Tullner WW, Edgcomb JH. 1962. Cystic tubular nephropathy and decrease in testicular weight in rats following oral methoxychlor treatment. J Pharmacol Exp Ther 138:126–130.13994738
Tyl RW. 2000. 53. In:, ed. General and Applied Toxicology. United Kingdom: Macmillan Reference LTD, 1167–1201.
Umegaki K, Ikegami S, Ichikawa T. 1993. [Hepatic DNA damage in mice given organochlorine chemicals]. (Japanese). J Food Hyg Soc Jpn 34:68–73.
USC. 1998. Hazardous air pollutants. U.S. Code: Title 42, section 7412. http://www4.law.cornell.edu/uscode/42/7412.text.html.
USC. 2001. Hazardous air pollutants. United States Code. 42 USC 7412. http://www4.law.cornell.edu/uscode/42/7412.text.html. November 29, 2001.
USDA. 1995. 1992–1993 Pesticide data program databases. United States Department of Agriculture.
USDA. 2000a. Accreditation of chemistry laboratories. United States Department of Agriculture, Food Safety and Inspection Service. 9 CFR 318.21.
USDA. 2000b. Accreditation of chemistry laboratories. United States Department of Agriculture, Food Safety and Inspection Service. 9 CFR 381.153.
USDA. 2000c. Germination standards for vegetable seeds in interstate commerce. United States Department of Agriculture, Agricultural Marketing Service. 7 CFR201.31.
USDA. 2001. Labeling treated seed. United States Department of Agriculture. Code of Federal Regulations. 7 CFR 201.31a(c)(2). http://frwebgate.access.gpo.gov/cgi-bin/...PART=201&SECTION=31a&YEAR=2001&TYPE=TEXT. September 24, 2001.
USDHHS. 1991. Sixth annual report on carcinogens, 1991. Summary. Research Triangle Park, NC: U.S. Department of Health and Human Services, 202–209.
USITC. 1991. Synthetic organic chemicals: United States production and sales, 1990. Washington, DC: U.S. International Trade Commission. USTIC Publication 2470.
Valencia R. 1981. Mutagenesis screening of pesticides using Drosophila. Research Triangle Park, NC: PB81–160848.
Van den Berg KJ, van Raaij GM, Bragt PC, 1991. Interactions of halogenated industrial chemicals with transthyretin and effects on thyroid hormone levels in vivo. Arch Toxicol 65:15–19.2043046
Van Duck PJ, Van de Voorde H. 1976. Biodegredation of methoxychlor and kelthane. Eur J Appl Microbiol 2:277–284.
Veith GD, DeFoe DL, Bergstedt BV. 1979. Measuring and estimating the bioconcentration factor of chemicals in fish. J Fish Res Board Can 36:1040–1048.
Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, 822–824.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Voccia I, Blakely B, Brousseau P, 1999. Immunotoxicity of pesticides: a review. Toxicol Ind Health 15:119–132.10188195
vom Saal FS, 1989. Sexual differentiation in litter-bearing mammals: Influence of sex of adjacent fetuses in utero. J. Anim. Sci. 67:1824–1840.2670873
vom Saal FS, Nagel SC, Palanza P, 1995. Estrogenic pesticides: Binding relative to estradiol in MCF-7 cells and effects of exposure during fetal life on subsequent territorial behaviour in male mice. Toxicol Lett 77:343–350.7618160
vom Saal FS, Timms BG, Montano MM, 1997. Prostate enlargement in mice due to fetal exposure to low doses of estradiol or diethylstilbestrol and opposite effects at high doses. Proc Natl Acad Sci USA 94:2056–2061.9050904
vom Saal FS, Cooke PS, Buchanan DL, 1998. A physiologically based approach to the study of bisphenol A and other estrogenic chemicals on the size of reproductive organs, daily sperm production, and behavior. Toxicol Ind Health 14:239–260.9460178
WA Dept of Ecology. 1998. Controls for new sources of toxic air pollutants. Chapter 173–460 WAC. Washington State Department of Ecology, Air Quality Program. http://www.wa.gov/ecology/air/airhome.html.
Wagner SL. 1990. Pesticide illness surveillance: Review of the national pesticide hazard assessment program. Am J Ind Med 18:307–312.2220836
Wallner WE, Leeling NC, Zabik MJ. 1969. The fate of methoxychlor applied by helicopter for smaller European elm bark beetle control. J Econ Entomol 62:1039–1042.
Walters LM, Rourke AW, Eroschenko VP. 1993. Purified methoxychlor stimulates reproductive tract in immature female mice. Repro Toxicol 7:599–606.
Walters SM. 1990. Clean-up techniques for pesticides in fatty foods. Anal Chim Acta 236:77–82.
Watanabe T, Inoue S, Ogawa S, 1997. Agonistic effect of tamoxifen is dependent on cell type, ERE-promoter context, and estrogen receptor subtype: Functional difference between estrogen receptors α and β. Biochem Biophys Res Commun 236:140–145.9223441
Waters KM, Safe S, Gaido KW. 2001. Differential gene expression in response to methoxychlor and estradiol through ERα, ERβ, and AR in reproductive tissues in female mice. Toxicol Sci 63:47–56.11509743
Waters MD, Simmon VF, Mitchell AD, 1980. An overview of short-term tests for the mutagenic and carcinogenic potential of pesticides. J Environ Sci Health B 15:867–906.7002991
Watters FL, Grussendorf OW. 1969. Toxicity and persistence of lindane and methoxychlor on building surfaces for stored-grain-insect control. J Econ Entomol 62:1101–1106.5810601
Wauchope RD, Buttler TM, Hornsby AG, 1991. The SCS/ARS/CES pesticide properties database for environmental decision-making. Rev Environ Contam Toxicol 123:1–36.
Weikel JH. 1957. The metabolism of methoxychlor (1,1,1 trichloro 2,2-bis (p-Methoxyphenyl)ethane) I. The role of the liver and biliary excretion in the rat. Arch Int Pharmacodyn 110:423–432.13459483
Weikel JH, Laug EP. 1958. The metabolism of methoxychlor (1,1,1-trichloro 2,2 bis p-methoxyphenyl)ethane). II. Effect of hepatotoxins and metabolic inhibitors. Arch Int Pharmacodyn 243–247.
Weisburger EK. 1982. Carcinogenicity tests on pesticides. In: Chambers JE, Yarbrough JD, eds. Effects of chronic exposures to pesticides on animal systems. New York: Raven Press. 165–176.
Weiss LR, Brodie R, Reilly FJ, 1970. Some observations on the comparative toxicity of four organochlorine pesticides after short and prolonged oral administration in rats. [Abstract] Toxicol Appl Pharmacol 17:278.
Welch HE, Muir DC, Billeck BN, 1991. Brown Snow: A long-range transport event in the Canadian Arctic. Environ Sci Technol 25:280–286.
Welch RM, Levin W, Conney AH. 1969. Estrogenic Action of DDT and its analogs. Toxicol Appl Pharmacol 14:358–367.5772860
Welshons WV, Nagel SC, Thayer KA, 1999. Low-dose bioactivity of xenoestrogens in animals: fetal exposure to low doses of methoxychlor and other xenoestrogens increases adult prostrate size in mice. Toxicol Ind Health 15:12–25.10188188
Wenda-Rozewicka L. 1983. Morphometric studies of male gonads from mice receiving insecticides (Metox-30, Sadofos-30 and Foschlor-50). Folia Biol 32:23–34.
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatrics 32a:10–18.
West PR, Cather SK, Branton GR, 1982. High performance liquid chromatographic analysis of impurities and degradation products of methoxychlor. J Assoc Off Anal Chem 65:6:1457–1470.
WHO. 1984. Guidelines for drinking-water quality. Vol. 1. Recommendations. World Health Organization, Geneva, Switzerland, 63, 72.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Felix F, eds. Mineral metabolism: An advanced treatise Volume II, The elements part A. New York: Academic Press.
Wiersma GB, Tai H, Sand PF. 1972. Pesticides in soil: Pesticide residue levels in soils, FY 1969 National Soils Monitoring Program. Pestic Monit J 194–228.4660671
Wills JH. 1969. Effects of chlorinated hydrocarbons on smaller animals as guides in the design of experiments with human volunteers. In: Miller MW, Berg GG, eds. Current research on persistent pesticides chemical fallout, 461–467.
Wolfe NL, Zepp RG, Paris DF, 1977. Methoxychlor and DDT degradation in water: Rates and products. Environ Sci Technol 11:1077–1081.
Wolff MS, Toniolo PG, Lee EW, 1993. Blood levels of organochlorine residues and risk of breast cancer. J Natl Cancer Inst 85:648–652.8468722
Wong YC, White FH, 1991. Morphometric and stereological analysis of the effects of 17β-estradiol on the glandular epithelium of the castrated guinea pig lateral prostate. The Prostate 19:279–297.1754518
Woodard G, Davidow B, Lehman AJ. 1948. Metabolism of chlorinated hydrocarbon insecticides. Industrial Engineering and Chemistry 40:711–712.
Woolley DE. 1995. Organochlorine insecticides: Neurotoxicity and mechanisms of action. In: Chang LW, Dyer RS, eds. Handbook of neurotoxicology. New York, NY: Marcel Dekker, Inc, 475–510.
Wu CH, van den Bercken J, Narahashi T. 1975. The structure activity relationships of DDT analogs in crayfish giant axons. Pestic Biochem Physiol 5:142–149.
Yang HL, Lee QP, Rettie AE, 1994. Functional cytochrome P4503A isoforms in human embryonic tissues: Expression during organogenesis. Mol Pharmacol 46:922–928.7969081
Yao CC, Haag WR. 1991. Rate constants for direct reactions of ozone with several drinking water contaminants. Water Res 25:761–773.
Yess N, Gunderson E, Roy R. 1993. U.S. Food and Drug Administration monitoring of pesticide residues in infant foods and adult foods eaten by infants/children. J Assoc Off Anal Chem 76(3):492–507.
You L, Casanova M, Archibeque-Engle S, 1998. Impaired male sexual development in perinatal Sprague-Dawley and Long-Evans hooded rats exposed in utero and lactationally to p,p'-DDE. Toxicol Sci 45:162–173.9848123
Zaleska-Freljan KI, Wolewicz JT. 1993. Influence of bromfenvinphos alone, and in mixture with methoxychlor, on levels of gamma-glutamyl transpeptidase, ceruloplasmin and cholesterol in the blood plasma of laboratory mice. Pol J Pharmacol Pharm 45:309–316.
Zaleska-Freljan KI, Kosicka B, Zbiegieni B. 1983. The histological changes in some organs of the laboratory mice after intragastrically given bromfenvinphos and mixture of bromfenvinphos with methoxychlor. Pol J Pharmacol Pharm 35:185–193.6622299
Zepp RG, Wolfe NL, Azarraga LV, 1977. Photochemical transformation of the DDT and methoxychlor degredation products, DDE and DMDE, by sunlight. Arch Environ Contam Toxicol 6:305–314.901009
Zepp RG, Wolfe NL, Gordon JA, 1976. Light-induced transformations of methoxychlor in aquatic systems. J Agric Food Chem 24:727–733.956535
Zhao GQ, Holterhus PM, Dammshauser I, 1992. Estrogen-induced morphological and immunohistochemical changes in stroma and epithelium of rat ventral prostate. The Prostate 21:183–199.1437855
Zhou L-X, Dehal SS, Kupfer D, 1995. Cytochrome P450 catalyzed covalent binding of methoxychlor to rat hepatic, microsomal iodothyronine 5'-monodeiodinase, type I: Does exposure to methoxychlor disrupt thyroid hormone metabolism? Arch Biochem Biophys 322(2):390–394.7574712
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Ziem G. 1982. Aplastic anaemia after methoxychlor exposure. Lancet, December 11. 1349.
Zitko V, Stenson G, Hellou J. 1998. Levels of organochlorine and polycyclic aromatic compounds in harp seal beaters (Phoca groenlandica). Sci Total Environ 221:11–29.9810732