# 8 REGULATIONS AND ADVISORIES

Because of methoxychlor’s potential to cause adverse health effects in exposed people, a number of regulations and guidelines have been established by international, federal, and state agencies. The international, national, and state regulations and guidelines regarding methoxychlor in air, water, and other media are summarized in Table 8-1.

In addition to these values, ATSDR and EPA have established additional guidelines to protect people from the adverse health effects from ingesting methoxychlor. ATSDR has withdr awn the previous MRL of 0.02 mg/kg/day for acute-duration exposure derived in the 1994 profile (see Appendix A for further discussion). An intermediate-duration oral MRL of 0.005 mg/kg/day was derived based on the LOAEL of 5 mg/kg/day for accelerated onset of puberty (i.e., precocious vaginal opening) in immature female rats exposed to methoxychlor in utero, during lactation, and after weaning (Chapin et al. 1997). This MRL supercedes the previous MRL of 0.02 mg/kg/day for intermediate-duration exposure derived in the 1994 profile. A chronic-duration oral MRL was not derived. A reference dose (RfD) of 0.005 mg/kg/day was derived (in 1991) by EPA based on the NOEL for maternal toxicity in rabbits dosed during gestational days 7–19 (IRIS 2001; Kincaid Enterprises 1986).

IARC (2001) has classified methoxychlor as a Group 3 carcinogen (not classifiable as to its carcinogenicity to humans) and NCI (1978) concluded that there was insufficient evidence to classify methoxychlor as a carcinogen. Similarly, EPA has classified methoxychlor as a Group D carcinogen, not classifiable as to human carcinogenicity (IRIS 2002).

On January 14, 2000, EPA issued a suspension order to Kincaid Enterprises, Inc. to prevent further manufacture and sale of their methoxychlor products. The order affects the technical product and three products manufactured by Kincaid, but does not directly affect other companies that manufacture methoxychlor products. The order was issued because the registrant failed to submit overdue (per an agreement signed in September of 1998) environmental fate studies. At the time of the writing of this profile, EPA is in the process of issuing a notice of intent to suspend to all companies that use methoxychlor in their products (EPA 2002) (http://www.epa.gov/oppfead1/cb/csb_page/updates/methox.htm).

Table 8-1 Regulations and Guidelines Applicable to Methoxychlor

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | Group 3^a^ | IARC 2001
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air:
ACGIH | TLV (8-hour TWA) | 10 mg/m^3^ | ACGIH 2001
EPA | RAC | 50 μg/m^3^ | EPA 2001p 40CFR266, Appendix IV
NIOSH | REL | Potential occupational carcinogen | NIOSH 2001
| IDLH | 5,000 mg/m^3^
OSHA | PEL (8-hour TWA)—total dust | 15 mg/m^3^ | OSHA 2001b 29CFR1910.1000
| PEL (8-hour TWA) for construction workers—total dust | 15 mg/m^3^ | OSHA 2001c 29CFR1926.55
| PEL (8-hour TWA) for shipyard workers—total dust | 15 mg/m^3^ | OSHA 2001a 29CFR1915.1000
USC | Listed as hazardous air pollutant | | USC 2001 42 USC 7412
b. Water
EPA | Designated as hazardous substance in accordance with Section 311(b)(2)(A) of the Clean Water Act | | EPA 2001s 40CFR116.4
| Drinking water standard | 0.04 ppm | EPA 2001c 40CFR141.32 (e)(43)
| Groundwater monitoring | | EPA 2001d 40CFR264, Appendix IX
| Suggested method | [underlined: PQL] | EPA 2001d 40CFR264, Appendix IX
| 8080 | 2 μg/L | EPA 2001d 40CFR264, Appendix IX
| 8270 | 10 μg/L
EPA | Health advisories | | EPA 2000
| 10-kg child
| 1-day | 0.05 mg/L
| 10-day | 0.05 mg/L
| DWEL^b^ | 0.2 mg/L
| Lifetime | 0.04 mg/L
| Interim primary drinking water standard for owners and operators of hazardous waste TSD facilities—maximum level | 0.1 mg/L | EPA 2001g 40CFR265, Appendix III
| Land disposal restrictions; universal treatment standards | | EPA 2001h 40CFR268.48
| Wastewater concentration | 0.25 mg/L^2^
| Non-wastewater concentration | 0.18 mg/kg^2^
| Maximum concentration of constituents for groundwater protection | 0.1 mg/L | EPA 2001i 40CFR264.94
| MCL—apply to community water systems and non-transient, non-community water systems | 0.04 mg/L | EPA 2001l 40CFR141.61(c)
| MCL—promulgated under the Safe Drinking Water Act | 0.1 mg/L | EPA 2001k 40CFR 257, Appendix I
| MCLG | 0.04 mg/L | EPA 2001m 40CFR141.50(b)
| National recommended water quality criteria | | EPA 1999j
| Freshwater | 0.03 μg/L
| Saltwater | 0.03 μg/L
| Human health for consumption of water and organism | 100 μg/L
| Radiation protection—maximum concentration for groundwater protection | 0.1 mg/L | EPA 2001o 40CFR192, Table 1 to Subpart A
| Reportable quantity of hazardous substance designated pursuant to Section 311 of the Clean Water Act | 1 pound | EPA 2001b 40CFR117.3
c. Food
EPA | Tolerances for residues | 100 ppm | EPA 2001n 40CFR180.120
| Alfalfa, clover, cowpeas, grass for forage, peanut forage, and soybean forage | | EPA 2001n 40CFR180.120
| Apples, apricots, asparagus, beans, beets, blackberries, blueberries, boysenberries, broccoli, brussel sprouts, cabbage, carrots, cauliflower, cherries, collards, corn, cranberries, cucumbers, currants, dewberries, eggplants, gooseberries, grapes, kale, kohlrabi, lettuce, loganberries, melons, mushrooms, nectarines, peaches, peanuts, pears, peas, peppers, pineapples, plums, pumpkins, quinces, radishes, raspberries, rutabagas, spinach, squash, strawberries, summer squash, tomatoes, turnips, youngberries | 14 ppm
| Sweet potatoes and yams from preharvest and postharvest application | 7 ppm
| Fat of meat from cattle, goats, hogs, horses, or sheep | 3 ppm
| Barley, corn, oats, rice, rye, sorghum grain, and wheat from storage-bin treatment | 2 ppm
| Milk fat reflecting negligible residues in milk | 1.25 ppm
| Potatoes and horseradish | 1 ppm
FDA | Beverages—bottled water concentration | 0.04 mg/L | FDA 2001 21CFR165.110
USDA | Federal seed act regulations—not harmful when present at a rate less than the number of ppm indicated | 2 ppm | USDA 2001 7CFR201.31a
d. Other
ACGIH | Carcinogenicity classification | A4^c^ | ACGIH 2001
EPA | Carcinogenicity classification | Group D^d^ | IRIS 2001
| RfD | 5×10^−3^ mg/kg/day
| RfC | Not verifiable
| Health based limits for exclusion of waste-derived residues—concentration limits for residues | 1×10^−1^ mg/kg | EPA 2001e 40CFR266, Appendix VII
| Identification and listing of hazardous waste—hazardous waste number | U247 | EPA 2001f 40CFR261.33(e)
| Maximum concentration of contaminants for toxicity characteristic—regulatory level | 10 mg/L | EPA 2001j 40CFR261.24
| Organic pesticide active ingredient—pesticide code | 34001 | EPA 1999l 40CFR455, Subpart E
| Pesticide class | Chlorinated organic pesticide | EPA 2001q 40CFR180.3(e)(4)
| Reportable quantity of hazardous substance designated pursuant to Section 311(b)(4) of the Clean Water Act and Section 112 of the Clean Air Act | 1 pound | EPA 2001a 40CFR302.4
| Toxic chemical release reporting; community right-to-know—effective date for reporting | 01/01/87 | EPA 2001r 40CFR372.65
[underlined: STATE]
Regulations and Guidelines:
a. Air
Arkansas | RAC | 50 μg/m^3^ | BNA 2001
Idaho | AAC | 0.5 mg/m^3^ | ID Dept. of Health and Welfare 1999
| EL | 0.667 pounds/hour | ID Dept. of Health and Welfare 1999
| OEL | 10 mg/m^3^
Montana | Occupational air contaminant—TLV | 15 mg/m^3^ | BNA 2001
New Hampshire | Regulated toxic air pollutant—OEL | 10 mg/m^3^ | BNA 2001
New York | Dangerous air contaminant—TLV | 15 mg/m^3^ | BNA 2001
South Carolina | RAC | 50 μg/m^3^ | BNA 2001
| Toxic air emissions | | BNA 2001
| Category | 3^e^
| Maximum allowable category concentration | 50 μg/m^3^
Tennessee | RAC | 50 μg/m^3^ | BNA 2001
Texas | Occupational health—TLV | 15 mg/m^3^ | BNA 2001
Vermont | Hazardous air contaminant | | BNA 2001
Washington | Acceptable source impact level, 24-hour average | 33 μg/m^3^ | WA Dept. of Ecology 1998
| Threshold for hazardous air pollutants—threshold level | 0.5 tons/year | BNA 2001
Wyoming | RAC | 50 μg/m^3^ | BNA 2001
b. Water
Alaska | MCL | 0.04 mg/L | AK Dept. of Environ. Conserv. 1999
Arizona | Drinking water standard and guideline | 340 ug/L | FSTRAC 1999
California | MCL | 0.04 mg/L | CA Dept. of Health Services 2000
Colorado | Groundwater organic chemical standard | 40 μg/L | CO Dept. of Public Health and Environ. 1999
Georgia | Groundwater criteria concentration | 0.04 mg/L | BNA 2001
Hawaii | MCL applying to community and non-community, non-transient water systems | 0.04 mg/L | HI Dept. of Health 1999a
Hawaii | Toxic pollutant standard | | HI Dept. of Health 1999b
| Freshwater | | HI Dept. of Health 1999b
| Acute | No standard
| Chronic | 0.03 μg/L
| Saltwater
| Acute | No standard
| Chronic | 0.03 μg/L
| Fish Consumption | No standard
Illinois | Water supply standard | 0.1 mg/L | IL Environ. Protection Agency 1999
Kansas | Water quality standard | | KS Dept. of Health and Environ. 2001
| Aquatic life | | KS Dept. of Health and Environ. 2001
| Acute | Not available | KS Dept. of Health and Environ. 2001
| Chronic | 0.3 μg/L
| Public health
| Food procurement | Not available
| Domestic water supply | 40 μg/L
Maine | Drinking water standard and guideline | 100 μg/L | FSTRAC 1999
Missouri | Water quality standards | | BNA 2001
| Aquatic life | 003 μg/L
| Drinking water supply | 40 μg/L
| Groundwater | 40 μg/L
New Jersey | Groundwater quality criteria | 40 μg/L | NJ Dept. of Environ. Protection 1993
South Dakota | MCL | 0.04 mg/L | SD Dept. of Environ. & Natural Resources 1998
Vermont | Groundwater quality standards | | BNA 2001
| Enforcement standard | 40 μgL
| Preventive action limit | 4 μg/L
Wisconsin | Groundwater quality standards | | BNA 2001
| Enforcement standard | 40 μgL
| Preventive action limit | 4 μg/L
c. Food | No data
d. Other
Arizona | Soil remediation level | | BNA 2001
| Residential | 330 mg/kg
| Non-residential | 3,400 mg/kg
California | Characteristics of toxicity | | BNA 2001
| Regulatory level | 10 mg/L
| STLC | 10 mg/L
| TTLC | 100 wet weight mg/kg

a Group 3: unclassifiable as to its carcinogenicity to humans

b DWEL: A lifetime exposure concentration protective of adverse, non-cancer health effects, that assumes all of the exposure to a contaminant is from drinking water.

c A4: not classifiable as a human carcinogen

d Group D: not classifiable as to human carcinogenicity

e Category 3: High toxicity–those pollutants that may cause chronic effects that result in death or permanent injury after very short exposure to small quantities.

AAC = acceptable ambient concentration; ACGIH = American Conference of Governmental Industrial Hygienists; BNA = Bureau of National Affairs; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EL = emissions screening level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FSTRAC = Federal-State Toxicology and Regulatory Alliance Committee; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; OEL = occupational exposure level; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; PQL = practical quantitation limit; RAC = reference air concentration; ppm = parts per million; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STLC = soluble threshold limit concentration; TLV = threshold limit value; TSD = treatment, storage, and disposal; TTLC = total threshold limit concentration; TWA = time-weighted average; USC = United States Code; USDA = U.S. Department of Agriculture