# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of methoxychlor is located in Table 4-1.

Methoxychlor is produced commercially in the United States as a technical grade containing 88–90% of the pure chemical and 10–12% of impurities consisting of isomers and other reaction products (IARC 1979; Lamoureux and Feil 1980). Twenty-five of these impurities were characterized in studies conducted on technical methoxychlor; evidence for >50 impurities was obtained through gas chromatography/mass spectrometry (GC/MS) (Lamoureux and Feil 1980). Purification of technical grade (nominally 90%) 1,1,1-trichloro-2,2-bis(4-methoxyphenyl)ethane (p,p’-methoxychlor; p,p’-DMDT) by recrystalization gave 76% p,p’-methoxychlor (99.8% pure by normal phase high performance liquid chromatography [HPLC]) and 24% impurities (West et al. 1982). The impurities were found to contain approximately 40 components. The major components were identified (HPLC and GC/MS) using reference standards. Component identities and percent (w/w) in technical grade methoxychlor were found to be as follows: 1,1,1,2-tetrachloro-2-(4-methoxyphenyl)ethane (1.73%), 1,1,1-trichloro-2-(2-methoxy-phenyl)-2-(4-methoxyphenyl)ethane (o,p’-methoxychlor; o,p’-DMDT; 4.03%), 1,1-dichloro-2,2-di(4-methoxyphenyl)ethene (DMDE; 0.39%), a condensation product of p,p’-meth-oxychlor (p,p’-DMDT; 0.48%), a condensation product of o,p’-methoxychlor (o,p’-DMDT; 0.4%), and 1,2,2,2-tetrakis(4-methoxybenzyl)ethene (0.5%). The percentages were calculated relative to the quantity of methoxychlor contained in technical grade material and were found to vary depending upon manufacturing conditions. Another impurity is 1-chloro-1,2,2-tris(4-methoxyphenyl)ethene (chlorotrianisene; TACE), a triphenylethylene derivative, that exhibits estrogenic/anti-estrogenic characteristics. Other impurities include polycylic hydrocarbons (e.g., 3,6-dimethoxy-9,10-bis (p-meth-oxyphenyl)phenanthrene, tetrakis(p-methoxyphenyl)ethylene, and 3,6,11,14-tetramethoxy-dibenzo(g,p)chrysene), which have been studied for mutagenicity and putative carcinogenicity (Grant et al. 1976). The substance, 3,6,11,14-tetramethoxydibenzo(g,p)chrysene, was found to be mutagenic.

Table 4-1 Chemical Identity of Methoxychlor

Characteristic | Information | Reference
Chemical name | Methoxychlor | Howard 1991
Synonym(s) | 2,2-bis(p-methoxyphenyl)-1,1,1-trichoroethane; 1,1,1-trichloro-2,2-bis(4-methoxyphenyl) ethane; methoxy-DDT; 1,1(2,2,2-trichloroethylidene)-bis(4-methoxybenzene) | HSDB 2000
Registered trade name(s) | Marlate^®^; Metox^®^; Prentox^®^; Methoxcide^®^ | EPA 1988b; HSDB 2000; Sittig 1980
Chemical formula | C_16_H_15_Cl_3_O_2_ | Howard 1991
Chemical structure | [image] | EPA 1988c
| 1,1,1-Trichloro-2,2-bis(4-methoxyphenyl)ethane (p,p’-methoxychlor; DMDT)
Identification numbers:
CAS registry | 72-43-5 | Howard 1991
NIOSH RTECS | KJ 3675000 | Sax and Lewis 1989
EPA hazardous waste | U247; D014 | HSDB 2000
OHM/TADS | OHM 7216536 | HSDB 2000
DOT/UN/NA/IMCO shipping | DOT 2761 | Sax and Lewis 1989
| UN 2761 | HSDB 2000
| NA 2761
| IMCO 6.1
HSDB | 1173 | HSDB 2000
NCI | C00497 | HSDB 2000

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substance

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of methoxychlor is located in Table 4-2.

Table 4-2 Physical and Chemical Properties of Methoxychlor

Property | Information | Reference
Molecular weight | 345.65 | Howard 1991
Color | Pale yellow | EPA 1988c
Physical state | Crystalline solid | EPA 1988c
Melting point | 89 °C | HSDB 2000
| 77 C (technical grade)
| No data (decomposes) | Montgomery and Welkom 1990
Density: | 1.41 g/cm^3^ | Montgomery and Welkom 1990
at 25 °C
Odor | Slightly fruity; musty; chlorine-like | HSDB 2000; Sigworth 1965
Odor threshold:
Water 60 °C | 4.7 ppm | Sigworth 1965
Air | No data
Solubility:
Water at 25 °C | 0.045 mg/L
at 15 °C | 0.02 mg/L
at 24 °C | 0.04 mg/L
at 35 °C | 0.095 mg/L
at 45 °C | 0.185 mg/L
Organic solvent(s) | Soluble in chlorinated aromatic solvents, ketonic solvents, ethanol, methylene chloride, methylated naphthalene, carbon tetrachloride, chloroform, xylene, methanol, petroleum ether, benzene | Budavari et al. 1989; EPA 1988a; HSDB 2000; Montgomery and Welkom 1990
Partition coefficients:
Log K_ow_ | 4.68–5.08 | Howard 1991
Log K_oc_ | 4.9 | Montgomery and Welkom 1990
Vapor pressure at 25 °C | 1.4×10^−6^ mmHg (estimated) | Howard 1991
Henry’s law constant:
at 25 °C | 1.6×10^−5^ atm-m^3^/mol (estimated) | Howard 1991
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors^a^ | No data
Explosive limits | No data

a Exists partially in particulate form in air. Conversion factors are only applicable for compounds that are entirely in the vapor phase.