# CHAPTER 8 REFERENCES

Aaseth J, Wallace DR, Vejrup K, . 2020. Methylmercury and developmental neurotoxicity: A global concern. Curr Opin Toxicol 19:80–87. 10.1016/j.cotox.2020.01.005.
Abass K, Huusko A, Knutsen HK, . 2018. Quantitative estimation of mercury intake by toxicokinetic modelling based on total mercury levels in humans. Environ Int 114:1–11. 10.1016/j.envint.2018.02.028.29455008
Abd El-Aziz GS, El-Fark MM, Saleh HA. 2012. The prenatal toxic effect of methylmercury on the development of the appendicular skeleton of rat fetuses and the protective role of vitamin E. Anat Rec 295(6):939–949. 10.1002/ar.22485.
Aberg B, Ekman L, Falk R, . 1969. Metabolism of methyl mercury (^203^Hg) compounds in man. Arch Environ Health 19(4):478–484.5822994
Abiko Y, Katayama Y, Zhao W, . 2021. The fate of methylmercury through the formation of bismethylmercury sulfide as an intermediate in mice. Sci Rep 11(1):17598. 10.1038/s41598-021-96579-y.34475444
ADFG. 1976. Environmental contaminants and parasites in polar bears. Juneau, AK: Alaska Department of Fish and Game. http://www.adfg.alaska.gov/static/home/library/pdfs/wildlife/research_pdfs/76_pbear_contam_lentfer.pdf. January 13, 2021.
ADPH. 1998. The use of traditional foods in a healthy diet in Alaska. Anchorage, AK: Alaska Division of Public Health. http://www.epi.alaska.gov/bulletins/docs/rr1998_01.pdf. January 13, 2021.
af Geijersstam E, Sandborgh-Englund G, Jonsson F, . 2001. Mercury uptake and kinetics after ingestion of dental amalgam. J Dent Res 80(9):1793–1796. 10.1177/00220345010800090401.11926235
Afrifa J, Essien-Baidoo S, Ephraim RKD, . 2017. Reduced eGFR, elevated urine protein and low level of personal protective equipment compliance among artisanal small scale gold miners at Bibiani-Ghana: a cross-sectional study. BMC Public Health 17(1):601. 10.1186/s12889-017-4517-z.28655297
Afrifa J, Ogbordjor WD, Duku-Takyi R. 2018. Variation in thyroid hormone levels is associated with elevated blood mercury levels among artisanal small-scale miners in Ghana. PLoS ONE 13(8):e0203335. 10.1371/journal.pone.0203335.30161259
Agrawal R, Chansouria JP. 1989. Chronic effects of mercuric chloride ingestion on rat adrenocortical function. Bull Environ Contam Toxicol 43(3):481–484. 10.1007/BF01701886.2790255
Agrawal S, Flora G, Bhatnagar P, . 2014. Comparative oxidative stress, metallothionein induction and organ toxicity following chronic exposure to arsenic, lead and mercury in rats. Cell Mol Biol (Noisy-le-grand) 60(2):13–21.
Aguilar A, Borrell A. 1995. Pollution and harbour porpoises in the Eastern North Atlantic: A review. In: Biology of the phocoenids: A collection of papers. Report of the International Whaling Commission, Special issue 16. Cambridge: International Whaling Commission, 231–242.
Ahlqwist M, Bengtsson C, Lapidus L, . 1999. Serum mercury concentration in relation to survival, symptoms, and diseases: Results from the prospective population study of women in Gothenburg, Sweden. Acta Odontol Scand 57(3):168–174. 10.1080/000163599428913.10480284
Ahmad S, Qureshi IH. 1989. Fast mercury removal from industrial effluent. J Radioanal Nucl Chem 130(2):347–352. 10.1007/bf02041354.
Ahmad S, Mahmood R. 2019. Mercury chloride toxicity in human erythrocytes: enhanced generation of ROS and RNS, hemoglobin oxidation, impaired antioxidant power, and inhibition of plasma membrane redox system. Environ Sci Pollut Res Int 26(6):5645–5657. 10.1007/s11356-018-04062-5.30612358
Ai CE, Li CJ, Tsou MC, . 2019. Blood and seminal plasma mercury levels and predatory fish intake in relation to low semen quality. Environ Sci Pollut Res Int 26(19):19425–19433. 10.1007/s11356-019-04592-6.31077049
Airaksinen R, Turunen AW, Rantakokko P, . 2011. Blood concentration of methylmercury in relation to food consumption. Public Health Nutr 14(3):480–489. 10.1017/s1368980010001485.20529404
Akagi H, Malm O, Branches F, . 1995. Human exposure to mercury due to goldmining in the Tapajos River Basin, Amazon, Brazil: Speciation of mercury in human hair, blood and urine. Water Air Soil Pollut 80(1–4):85–94.
Akerstrom M, Barregard L, Lundh T, . 2017. Relationship between mercury in kidney, blood, and urine in environmentally exposed individuals, and implications for biomonitoring. Toxicol Appl Pharmacol 320:17–25. 10.1016/j.taap.2017.02.007.28189652
Albasher G, Alkahtani S, Alarifi S. 2020. Berberine mitigates oxidative damage associated with testicular impairment following mercury chloride intoxication. J Food Biochem 44(9):e13385. 10.1111/jfbc.13385.33460233
Al-Batanony MA, Abdel-Rasul GM, Abu-Salem MA, . 2013. Occupational exposure to mercury among workers in a fluorescent lamp factory, Quisna Industrial Zone, Egypt. Int J Occup Environ Med 4(3):149–156.23860545
Albers JW, Cavender GD, Levine SP, . 1982. Asymptomatic sensorimotor polyneuropathy in workers exposed to elemental mercury. Neurology 32(10):1168–1174. 10.1212/wnl.32.10.1168.6289189
Albers JW, Kallenbach LR, Fine LJ, . 1988. Neurological abnormalities associated with remote occupational elemental mercury exposure. Ann Neurol 24(5):651–659. 10.1002/ana.410240510.2849369
Albert I, Villeret G, Paris A, . 2010. Integrating variability in half-lives and dietary intakes to predict mercury concentration in hair. Regul Toxicol Pharmacol 58(3):482–489. 10.1016/j.yrtph.2010.08.020.20804806
Albores-Garcia D, Acosta-Saavedra LC, Hernandez AJ, . 2016. Early developmental low-dose methylmercury exposure alters learning and memory in periadolescent but not young adult rats. BioMed Res Int 2016:6532108. 10.1155/2016/6532108.26885512
Alfthan GV. 1997. Toenail mercury concentration as a biomarker of methylmercury exposure. Biomarkers 2(4):233–238. 10.1080/135475097231607.23899215
Algahtani MM, Ahmad SF, Alkharashi LA, . 2023. Exposure to methylmercury at juvenile stage worsens autism-like symptoms in adult BTBR T+tf/J mice due to lack of nuclear factor erythroid 2-related factor 2 signaling upregulation in periphery and brain. Toxics 11(6):546. 10.3390/toxics11060546.37368646
Ali Z, Ulrik CS. 2013. Obesity and asthma: A coincidence or a causal relationship? A systematic review. Respir Med 107(9):1287–1300. 10.1016/j.rmed.2013.03.019.23642708
Aligne CA, Auinger P, Byrd RS, . 2000. Risk factors for pediatric asthma. Am J Respir Crit Care Med 162(3):873–877. 10.1164/ajrccm.162.3.9908085.10988098
Allard B, Arsenie I. 1991. Abiotic reduction of mercury by humic substances in aquatic system: An important process for the mercury cycle. Water Air Soil Pollut 56(0):457–464.
Allen BC, Hack CE, Clewell HJ. 2007. Use of Markov Chain Monte Carlo analysis with a physiologically-based pharmacokinetic model of methylmercury to estimate exposures in US women of childbearing age. Risk Anal 27(4):947–959. 10.1111/j.1539-6924.2007.00934.x.17958503
Al-Mazroua HA, Nadeem A, Ansari MA, . 2022. Methylmercury chloride exposure exacerbates existing neurobehavioral and immune dysfunctions in the BTBR T(+) Itpr3(tf)/J mouse model of autism. Immunol Lett 244:19–27. 10.1016/j.imlet.2022.03.001.35259423
Al-Mufti AW, Copplestone JF, Kazantzis G, . 1976. Epidemiology of organomercury poisoning in Iraq. I. Incidence in a defined area and relationship to the eating of contaminated bread. Bull World Health Organ 53(Suppl):23–36.1086164
Al-Saleh I, Al-Doush I. 1997. Mercury content in skin-lightening creams and potential hazards to the health of Saudi women. J Toxicol Environ Health 51(2):123–130. 10.1080/00984109708984016.9176553
Al-Saleh I, Shinwari N, Mashhour A, . 2006. Cadmium and mercury levels in Saudi women and its possible relationship with hypertension. Biol Trace Elem Res 112(1):13–29. 10.1385/bter:112:1:13.16943613
Al-Saleh I, Shinwari N, Mashhour A, . 2011. Heavy metals (lead, cadmium and mercury) in maternal, cord blood and placenta of healthy women. Int J Hyg Environ Health 214(2):79–101. 10.1016/j.ijheh.2010.10.001.21093366
Al-Saleh I, Al-Sedairi A, Elkhatib R. 2012. Effect of mercury (Hg) dental amalgam fillings on renal and oxidative stress biomarkers in children. Sci Total Environ 431:188–196. 10.1016/j.scitotenv.2012.05.036.22683759
Al-Saleh I, Abduljabbar M, Al-Rouqi R, . 2013. Mercury (Hg) exposure in breast-fed infants and their mothers and the evidence of oxidative stress. Biol Trace Elem Res 153(1–3):145–154. 10.1007/s12011-013-9687-7.23661328
Al-Saleh I, Shinwari N, Mashhour A, . 2014. Birth outcome measures and maternal exposure to heavy metals (lead, cadmium and mercury) in Saudi Arabian population. Int J Hyg Environ Health 217(2–3):205–218. 10.1016/j.ijheh.2013.04.009.23735463
Al-Saleh I, Nester M, Abduljabbar M, . 2016. Mercury (Hg) exposure and its effects on Saudi breastfed infant’s neurodevelopment. Int J Hyg Environ Health 219(1):129–141. 10.1016/j.ijheh.2015.10.002.26541552
Al-Saleh I, Al-Rouqi R, Elkhatib R, . 2017. Risk assessment of environmental exposure to heavy metals in mothers and their respective infants. Int J Hyg Environ Health 220(8):1252–1278. 10.1016/j.ijheh.2017.07.010.28869188
Al-Saleh I, Al-Mohawes S, Al-Rouqi R, . 2019. Selenium status in lactating mothers-infants and its potential protective role against the neurotoxicity of methylmercury, lead, manganese, and DDT. Environ Res 176:108562. 10.1016/j.envres.2019.108562.31280027
Altunkaynak ME, Akgul N, Yahyazadeh A, . 2015. A stereological and histopathological study of the effects of exposure of male rat testes to mercury vapor. Biotech Histochem 90(7):529–534. 10.3109/10520295.2015.1024739.25968145
Altunkaynak BZ, Akgul N, Yahyazadeh A, . 2016. Effect of mercury vapor inhalation on rat ovary: Stereology and histopathology. J Obstet Gynaecol Res 42(4):410–416. 10.1111/jog.12911.26787318
Altunkaynak BZ, Akgül N, Yahyazedeh A, . 2019. A stereological study of the effects of mercury inhalation on the cerebellum. Biotech Histochem 94(1):42–47. 10.1080/10520295.2018.1493224.30079771
Amara IE, Elshenawy OH, Abdelrady M, . 2014. Acute mercury toxicity modulates cytochrome P450, soluble epoxide hydrolase and their associated arachidonic acid metabolites in C57B1/6 mouse heart. Toxicol Lett 226(1):53–62. 10.1016/j.toxlet.2014.01.025.24472606
Aminzadeh KK, Etminan M. 2007. Dental amalgam and multiple sclerosis: A systematic review and meta-analysis. J Public Health Dent 67(1):64–66.17436982
Amin-Zaki L, Elhassani S, Majeed MA, . 1974. Intra-uterine methylmercury poisoning in Iraq. Pediatrics 54(5):587–595.4480317
Amin-Zaki L, Elhassani S, Majeed MA, . 1976. Perinatal methylmercury poisoning in Iraq. Am J Dis Child 130(10):1070–1076.973609
Amin-Zaki L, Majeed MA, Clarkson TW, . 1978. Methylmercury poisoning in Iraqi children: Clinical observations over two years. Br Med J 1(6113):613–616.630256
Amin-Zaki L, Majeed MA, Greenwood MR, . 1981. Methylmercury poisoning in the Iraqi suckling infant: a longitudinal study over five years. J Appl Toxicol 1(4):210–214.6892222
Amirhosseini M, Alkaissi H, Hultman PA, . 2021. Autoantibodies in outbred Swiss Webster mice following exposure to gold and mercury. Toxicol Appl Pharmacol 412:115379. 10.1016/j.taap.2020.115379.33358697
An H, Wang B, Li Z, . 2021. Distribution of mercury in serum and blood cells and risk of spontaneous preterm birth: A nested case-control study in China. Ecotoxicol Environ Saf 217:112228. 10.1016/j.ecoenv.2021.112228.33892343
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersson AB. 1979. Mercury in soils. In: Nriagu JO, ed. The biogeochemistry of mercury in the environment. New York, NY: Elsevier/North Holland Biomedical Press, 79–112.
Andersson I, Parkman H, Jernelov A. 1990. The role of sediments as sink or source for environmental contaminants: A case study of mercury and chlorinated organic compounds. Limnologica 20(2):347–360.
Andren AW, Nriagu JO. 1979. The global cycle of mercury. In: Nriagu JO, ed. The biogeochemistry of mercury in the environment. New York, NY: Elsevier/North Holland Biomedical Press, 1–22.
Andreoli V, Sprovieri F. 2017. Genetic aspects of susceptibility to mercury toxicity: An overview. Int J Environ Res Public Health 14:93. 10.3390/ijerph14010093.28106810
Andrew AS, O’Brien KM, Jackson BP, . 2020. Keratinous biomarker of mercury exposure associated with amyotrophic lateral sclerosis risk in a nationwide U.S. study. Amyotroph Lateral Scler Frontotemporal Degener 21(5–6):420–427. 10.1080/21678421.2020.1753777.32329357
Anglen J, Gruninger SE, Chou HN, . 2015. Occupational mercury exposure in association with prevalence of multiple sclerosis and tremor among US dentists. J Am Dent Assoc 146(9):659–668 e651. 10.1016/j.adaj.2015.05.016.26314975
Ansari MS, Miller WJ, Gentry RP, . 1973. Tissue 203 Hg distribution in young Holstein calves after single tracer oral doses in organic and inorganic forms. J Anim Sci 36(2):415–419.4687098
Anwar WA, Gabal MS. 1991. Cytogenetic study in workers occupationally exposed to mercury fulminate. Mutagenesis 6(3):189–192.1881349
Apaydin FG, Bas H, Kalender S, . 2016. Subacute effects of low dose lead nitrate and mercury chloride exposure on kidney of rats. Environ Toxicol Pharmacol 41:219–224. 10.1016/j.etap.2015.12.003.26731605
Arakawa C, Yoshinaga J, Okamura K, . 2006. Fish consumption and time to pregnancy in Japanese women. Int J Hyg Environ Health 209(4):337–344. 10.1016/j.ijheh.2006.02.004.16735138
Araki S, Aono H, Murata K. 1986. Adjustment of urinary concentration to urinary volume in relation to erythrocyte and plasma concentrations: an evaluation of urinary heavy metals and organic substances. Arch Environ Health 41(3):171–177. 10.1080/00039896.1986.9935773.3740957
Arbi S, Oberholzer HM, Van Rooy MJ, . 2017. Effects of chronic exposure to mercury and cadmium alone and in combination on the coagulation system of Sprague-Dawley rats. Ultrastruct Pathol 41(4):275–283. 10.1080/01913123.2017.1327909.28617098
Arito H, Takahashi M. 1991. Effect of methylmercury on sleep patterns in the rat. In: Suzuki T, Imura N, Clarkson TW, eds. Advances in mercury toxicology. New York, NY: Plenum Press, 381–394.
Aschner M, Clarkson TW. 1988. Uptake of methylmercury in the rat brain: Effects of amino acids. Brain Res 462(1):31–39.3179736
Aschner M, Clarkson TW. 1989. Methyl mercury uptake across bovine brain capillary endothelial cells in vitro: The role of amino acids. Pharmacol Toxicol 64(3):293–297. 10.1111/j.1600-0773.1989.tb00650.x.2498864
Aschner M, Eberle NB, Goderie S, . 1990. Methylmercury uptake in rat primary astrocyte cultures: The role of the neutral amino acid transport system. Brain Res 521(1–2):221–228.2207661
Aschner M, Eberle NB, Kimelberg HK. 1991. Interactions of methylmercury with rat primary astrocyte cultures: Methylmercury efflux. Brain Res 554(1–2):10–14.1933294
Aschner M, Syversen T, Souza DO, . 2006. Metallothioneins: Mercury species-specific induction and their potential role in attenuating neurotoxicity. Exp Biol Med 231(9):1468–1473.
Aschner M, Syversen T, Souza DO, . 2007. Involvement of glutamate and reactive oxygen species in methylmercury neurotoxicity. Braz J Med Biol Res 40(3):285–291.17334523
Asgary S, Movahedian A, Keshvari M, . 2017. Serum levels of lead, mercury and cadmium in relation to coronary artery disease in the elderly: A cross-sectional study. Chemosphere 180:540–544. 10.1016/j.chemosphere.2017.03.069.28431391
Ashe WF, Largent EJ, Dutra FR, . 1953. Behavior of mercury in the animal organism following inhalation. AMA Arch Ind Hyg Occup Med 7(1):19–43.13007198
Ashrap P, Watkins DJ, Mukherjee B, . 2020. Maternal blood metal and metalloid concentrations in association with birth outcomes in Northern Puerto Rico. Environ Int 138:105606. 10.1016/j.envint.2020.105606.32179314
Ask K, Akesson A, Berglund M, . 2002. Inorganic mercury and methylmercury in placentas of Swedish women. Environ Health Perspect 110(5):523–526.12003757
ASTER. 1997. ASTER (assessment tools for the evaluation of risk) ecotoxicity profile. Duluth, MN: U.S. Environmental Protection Agency.
Atkinson A, Thompson SJ, Khan AT, . 2001. Assessment of a two-generation reproductive and fertility study of mercuric chloride in rats. Food Chem Toxicol 39(1):73–84. 10.1016/s0278-6915(00)00096-x.11259853
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 1990. Technical assistance to the Tennessee Department of Health and Environment. Mercury exposure study Charleston, Tennessee. Atlanta, GA: Agency for Toxic Substances and Disease Registry. ATDR/HS-91/11. PB91151142. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB91151142.xhtml. January 13, 2021.
ATSDR. 1997. Press release: ATSDR and EPA warn the public about continuing patterns of metallic mercury exposure. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.cdc.gov/media/pressrel/mercury.htm. January 13, 2021.
ATSDR. 2004. Interaction profile for: Persistent chemicals found in fish (chlorinated dibenzo-p-dioxins, hexachlorobenzene, p,p’-DDE, methylmercury, and polychlorinated biphenyls). Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/interactionprofiles/ip-fish/ip01.pdf. December 14, 2020.
ATSDR. 2012. Toxicological profile for cadmium. Agency for Toxic Substances and Disease Registry. PB2013105787. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2013105787.xhtml. March 15, 2021.
ATSDR. 2022. Mercury. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/SPL/resources/index.html. April 1, 2024.
Awata H, Linder S, Mitchell LE, . 2017. Association of dietary intake and biomarker levels of arsenic, cadmium, lead, and mercury among Asian populations in the United States: NHANES 2011-2012. Environ Health Perspect 125(3):314–323. 10.1289/ehp28.27586241
Axelrad DA, Bellinger DC, Ryan LM, . 2007a. Dose-response relationship of prenatal mercury exposure and IQ: An integrative analysis of epidemiologic data. Environ Health Perspect 115(4):609–615. 10.1289/ehp.9303.17450232
Axelrad DA, Bellinger DC, Ryan LM, . 2007b. Supplemental material: Dose-response relationship of prenatal mercury exposure and IQ: An integrative analysis of epidemiologic data. Environ Health Perspect 115 10.1289/ehp.9303.
Axtell CD, Myers GJ, Davidson PW, . 1998. Semiparametric modeling of age at achieving developmental milestones after prenatal exposure to methylmercury in the Seychelles child development study. Environ Health Perspect 106(9):559–564. 10.1289/ehp.106-1533142.
Axtell CD, Cox C, Myers GJ, . 2000. Association between methylmercury exposure from fish consumption and child development at five and a half years of age in the Seychelles Child Development Study: an evaluation of nonlinear relationships. Environ Res 84(2):71–80. 10.1006/enrs.2000.4082.11068920
Aydin N, Karaoglanoglu S, Yigit A, . 2003. Neuropsychological effects of low mercury exposure in dental staff in Erzurum, Turkey. Int Dent J 53(2):85–91.12731695
Bachand PAM, Kraus TEC, Stumpner EB, . 2019. Mercury sequestration and transformation in chemically enhanced treatment wetlands. Chemosphere 217:496–506. 10.1016/j.chemosphere.2018.10.144.30439661
Bache CA, Gutenmann WH, Rutzke M, . 1991. Concentrations of metals in grasses in the vicinity of a municipal refuse incinerator. Arch Environ Contam Toxicol 20(4):538–542. 10.1007/bf01065846.
Baden HP, Goldsmith LA, Fleming B. 1973. A comparative study of the physicochemical properties of human keratinized tissues. Biochim Biophys Acta 322(2):269–278. 10.1016/0005-2795(73)90303-6.4765091
Bae S, Park SJ, Yeum KJ, . 2016. Cut-off values of blood mercury concentration in relation to increased body mass index and waist circumference in Koreans. J Investig Med 64(4):867–871. 10.1136/jim-2015-000039.
Bagheri Hosseinabadi M, Khanjani N, Mobarake MD, . 2020. Neuropsychological effects of long-term occupational exposure to mercury among chloralkali workers. Work 66(3):491–498. 10.3233/wor-203194.32651342
Bagley MP, Schwartz RA, Lambert WC. 1987. Hyperplastic reaction developing within a tattoo. Diagnosis: Granulomatous tattoo reaction, probably to mercuric sulfide (cinnabar). Arch Dermatol 123(11):1557, 1560–1561. 10.1001/archderm.123.11.1557b.
Bakir F, Damluji SF, Amin-Zaki L, . 1973. Methylmercury poisoning in Iraq. Science 181(4096):230–241.4719063
Ballabio C, Jiskra M, Osterwalder S, . 2021. A spatial assessment of mercury content in the European Union topsoil. Sci Total Environ 769:144755. 10.1016/j.scitotenv.2020.144755.33736262
Ballatori N. 2002. Transport of toxic metals by molecular mimicry. Environ Health Perspect 110(Suppl 5):689–694.
Ballatori N, Clarkson TW. 1982. Developmental changes in the biliary excretion of methylmercury and glutathione. Science 216(4541):61–63.7063871
Ballatori N, Clarkson TW. 1984. Inorganic mercury secretion into bile as a low molecular weight complex. Biochem Pharmacol 33(7):1087–1092.6424682
Ballatori N, Clarkson TW. 1985. Biliary secretion of glutathione and of glutathione-metal complexes. Fundam Appl Toxicol 5(5):816–831.4065458
Ballatori N, Truong AT. 1995. Mechanisms of hepatic methylmercury uptake. J Toxicol Environ Health 46(3):343–353. 10.1080/15287399509532040.7473862
Ballatori N, Wang W, Lieberman MW. 1998. Accelerated methylmercury elimination in gamma-glutamyl transpeptidase-deficient mice. Am J Pathol 152(4):1049–1055.9546365
Bangsi D, Ghadirian P, Ducic S, . 1998. Dental amalgam and multiple sclerosis: a case-control study in Montreal, Canada. Int J Epidemiol 27(4):667–671. 10.1093/ije/27.4.667.9758123
Barany E, Bergdahl IA, Bratteby LE, . 2003. Mercury and selenium in whole blood and serum in relation to fish consumption and amalgam fillings in adolescents. J Trace Elem Med Biol 17(3):165–170. 10.1016/s0946-672x(03)80021-4.14968928
Barber TE, Wallis G. 1986. Correction of urinary mercury concentration by specific gravity, osmolality, and creatinine. J Occup Med 28(5):354–359.3712114
Barbone F, Rosolen V, Mariuz M, . 2019. Prenatal mercury exposure and child neurodevelopment outcomes at 18 months: Results from the Mediterranean PHIME cohort. Int J Hyg Environ Health 222(1):9–21. 10.1016/j.ijheh.2018.07.011.30057028
Barboni MT, da Costa MF, Moura AL, . 2008. Visual field losses in workers exposed to mercury vapor. Environ Res 107(1):124–131. 10.1016/j.envres.2007.07.004.17719027
Barboni MT, Feitosa-Santana C, Zachi EC, . 2009. Preliminary findings on the effects of occupational exposure to mercury vapor below safety levels on visual and neuropsychological functions. J Occup Environ Med 51(12):1403–1412. 10.1097/JOM.0b013e3181bca9ea.19952794
Barcelos GR, Grotto D, Serpeloni JM, . 2011. Protective properties of quercetin against DNA damage and oxidative stress induced by methylmercury in rats. Arch Toxicol 85(9):1151–1157. 10.1007/s00204-011-0652-y.21286687
Barcelos GR, Grotto D, Serpeloni JM, . 2012. Bixin and norbixin protect against DNA-damage and alterations of redox status induced by methylmercury exposure in vivo. Environ Mol Mutagen 53(7):535–541. 10.1002/em.21715.22847942
Barkay T, Liebert C, Gillman M. 1989. Environmental significance of the potential for mer(Tn-21)-mediated reduction of Hg^2+^ to Hg^0^ in natural waters. Appl Environ Microbiol 55(5):1196–1202.2547336
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barnes DM, Hanlon PR, Kircher EA. 2003. Effects of inorganic HgCl_2_ on adipogenesis. Toxicol Sci 75(2):368–377. 10.1093/toxsci/kfg195.12883084
Barnett LMA, Cummings BS. 2018. Nephrotoxicity and renal pathophysiology: A contemporary perspective. Toxicol Sci 164(2):379–390. 10.1093/toxsci/kfy159.29939355
Barr RD, Woodger BA, Rees PH. 1973. Levels of mercury in urine correlated with the use of skin lightening creams. Am J Clin Pathol 59(1):36–40. 10.1093/ajcp/59.1.36.4688565
Barregard L. 1993. Biological monitoring of exposure to mercury vapor. Scand J Work Environ Health 19(Suppl 1):45–49.8159972
Barregard L, Sallsten G, Jarvholm B. 1990. Mortality and cancer incidence in chloralkali workers exposed to inorganic mercury. Br J Ind Med 47(2):99–104.2310721
Barregard L, Trachtenberg F, McKinlay S. 2008. Renal effects of dental amalgam in children: The New England children’s amalgam trial. Environ Health Perspect 116(3):394–399. 10.1289/ehp.10504.18335109
Barregard L, Hogstedt B, Schutz A, . 1991. Effects of occupational exposure to mercury vapor on lymphocyte micronuclei. Scand J Work Environ Health 17(4):263–268. 10.5271/sjweh.1704.1925438
Barregard L, Sallsten G, Schutz A, . 1992. Kinetics of mercury in blood and urine after brief occupational exposure. Arch Environ Health 47(3):176–184. 10.1080/00039896.1992.9938347.1596100
Barregard L, Lindstedt G, Schutz A, . 1994a. Endocrine function in mercury exposed chloralkali workers. Occup Environ Med 51(8):536–540. 10.1136/oem.51.8.536.7951778
Barregard L, Horvat M, Schutz A. 1994b. No indication of in vivo methylation of inorganic mercury in chloralkali workers. Environ Res 67(2):160–167. 10.1006/enrs.1994.1071.7982391
Barregard L, Quelquejeu G, Sallsten G, . 1996. Dose-dependent elimination kinetics for mercury in urine: Observations in subjects with brief but high-level exposure. Int Arch Occup Environ Health 68(5):345–348. 10.1007/bf00409421.8832301
Barregard L, Eneström S, Ljunghusen O, . 1997. A study of autoantibodies and circulating immune complexes in mercury-exposed chloralkali workers. Int Arch Occup Environ Health 70(2):101–106. 10.1007/s004200050193.9253638
Barregard L, Horvat M, Mazzolai B, . 2006. Urinary mercury in people living near point sources of mercury emissions. Sci Total Environ 368(1):326–334. 10.1016/j.scitotenv.2005.08.048.16226300
Basta PC, Viana PVS, Vasconcellos ACS, . 2021. Mercury exposure in Munduruku indigenous communities from Brazilian Amazon: Methodological background and an overview of the principal results. Int J Environ Res Public Health 18(17):9222. 10.3390/ijerph18179222.34501811
Bast-Pettersen R, Ellingsen DG, Efskind J, . 2005. A neurobehavioral study of chloralkali workers after the cessation of exposure to mercury vapor. Neurotoxicology 26(3):427–437. 10.1016/j.neuro.2005.03.006.15935213
Basu N, Scheuhammer AM, Rouvinen-Watt K, . 2010. In vitro and whole animal evidence that methylmercury disrupts GABAergic systems in discrete brain regions in captive mink. Comp Biochem Physiol C Toxicol Pharmacol 151(3):379–385. 10.1016/j.cbpc.2010.01.001.20060493
Basu N, Goodrich JM, Head J. 2014. Ecogenetics of mercury: From genetic polymorphisms and epigenetics to risk assessment and decision-making. Environ Toxicol Chem 33(6):1248–1258. 10.1002/etc.2375.24038486
Baswan S, Kasting GB, Li SK, . 2017. Understanding the formidable nail barrier: A review of the nail microstructure, composition and diseases. Mycoses 60(5):284–295. 10.1111/myc.12592.28098391
Bates MN, Fawcett J, Garrett N, . 2004. Health effects of dental amalgam exposure: A retrospective cohort study. Int J Epidemiol 33(4):894–902. 10.1093/ije/dyh164.15155698
Bautista LE, Stein JH, Morgan BJ, . 2009. Association of blood and hair mercury with blood pressure and vascular reactivity. WMJ 108(5):250–252.19743756
BDI. 2011. Great Lakes mercury connections: The extent and effects of mercury pollution in the Great Lakes region. Gorham, ME: Biodiversity Research Institute. https://www.glc.org/library/2011-great-lakes-mercury-connections. January 19, 2021.
Beauchamp G, Kusin S, Elinder CG. 2021. Mercury toxicity. UpToDate. Wolters Kluwer.
Bedir Findik R, Celik HT, Ersoy AO, . 2016. Mercury concentration in maternal serum, cord blood, and placenta in patients with amalgam dental fillings: Effects on fetal biometric measurements. J Matern Fetal Neonatal Med 29(22):3665–3669. 10.3109/14767058.2016.1140737.26898132
Behzadfar L, Hassani S, Feizpour H, . 2020. Effects of mercuric chloride on spatial memory deficit-induced by beta-amyloid and evaluation of mitochondrial function markers in the hippocampus of rats. Metallomics 12(1):144–153. 10.1039/c9mt00161a.31793599
Bell BC, Zhu J, Wei Y. 2023. Urinary concentrations of endocrine-disrupting metals and prevalent breast cancer in US women. Biol Trace Elem Res 201(9):4230–4237. 10.1007/s12011-022-03512-z.36472806
Bellanger M, Pichery C, Aerts D, . 2013. Economic benefits of methylmercury exposure control in Europe: Monetary value of neurotoxicity prevention. Environ Health 12:3. 10.1186/1476-069x-12-3.23289875
Belles M, Albina ML, Sanchez DJ, . 2002. Interactions in developmental toxicology: Effects of concurrent exposure to lead, organic mercury, and arsenic in pregnant mice. Arch Environ Contam Toxicol 42(1):93–98. 10.1007/s002440010296.11706373
Bellinger DC. 2012. Comparing the population neurodevelopmental burdens associated with children’s exposures to environmental chemicals and other risk factors. Neurotoxicology 33(4):641–643. 10.1016/j.neuro.2012.04.003.22525934
Bellinger DC, Trachtenberg F, Barregard L, . 2006. Neuropsychological and renal effects of dental amalgam in children: a randomized clinical trial. JAMA 295(15):1775–1783. 10.1001/jama.295.15.1775.16622139
Bellinger DC, Daniel D, Trachtenberg F, . 2007a. Dental amalgam restorations and children’s neuropsychological function: the New England Children’s Amalgam Trial. Environ Health Perspect 115(3):440–446. 10.1289/ehp.9497.17431496
Bellinger DC, Trachtenberg F, Daniel D, . 2007b. A dose-effect analysis of children’s exposure to dental amalgam and neuropsychological function: the New England Children’s Amalgam Trial. J Am Dent Assoc 138(9):1210–1216. 10.14219/jada.archive.2007.0345.17785386
Bellinger DC, Trachtenberg F, Zhang A, . 2008. Dental amalgam and psychosocial status: the New England Children’s Amalgam Trial. J Dent Res 87(5):470–474. 10.1177/154405910808700504.18434579
Bellinger DC, Devleesschauwer B, O’Leary K, . 2019. Global burden of intellectual disability resulting from prenatal exposure to methylmercury, 2015. Environ Res 170:416–421. 10.1016/j.envres.2018.12.042.30623889
Bellum S, Thuett KA, Grajeda R, . 2007. Coordination deficits induced in young adult mice treated with methylmercury. Int J Toxicol 26(2):115–121. 10.1080/10915810701225190.
Bellum S, Thuett KA, Bawa B, . 2013. The effect of methylmercury exposure on behavior and cerebellar granule cell physiology in aged mice. J Appl Toxicol 33(9):959–969. 10.1002/jat.2786.22886740
Ben-Ozer EY, Rosenspire AJ, McCabe MJ, . 2000. Mercuric chloride damages cellular DNA by a non-apoptotic mechanism. Mutat Res 470(1):19–27.10986472
Bergdahl IA, Ahlqwist M, Barregard L, . 2013. Mercury in serum predicts low risk of death and myocardial infarction in Gothenburg women. Int Arch Occup Environ Health 86(1):71–77. 10.1007/s00420-012-0746-8.22350276
Berglund M, Lind B, Bjornberg KA, . 2005. Inter-individual variations of human mercury exposure biomarkers: a cross-sectional assessment. Environ Health 4:20. 10.1186/1476-069x-4-20.16202128
Bergstrand A, Friberg L, Odeblad E. 1958. Localization of mercury in the kidneys after subcutaneous administration. A study on rabbits with mercuric chloride and phenylmercuric acetate. Arch Ind Health 17(3):253–256.
Berky AJ, Ryde IT, Feingold B, . 2019. Predictors of mitochondrial DNA copy number and damage in a mercury-exposed rural Peruvian population near artisanal and small-scale gold mining: An exploratory study. Environ Mol Mutagen 60(2):197–210. 10.1002/em.22244.30289587
Berlin M, Ullberg S. 1963a. Accumulation and retention of mercury in the mouse. I. An autoradiographic study after a single intravenous injection of mercuric chloride. Arch Environ Health 6:589–601. 10.1080/00039896.1963.10663447.13970883
Berlin M, Ullberg S. 1963b. Accumulation and retention of mercury in the mouse. II. An autoradiographic comparison of phenylmercuric acetate with inorganic mercury. Arch Environ Health 6:602–609. 10.1080/00039896.1963.10663448.13970884
Berlin M, Ullberg S. 1963c. Accumulation and retention of mercury in the mouse. III. An autoradiographic comparison of methylmercuric dicyandiamide with inorganic mercury. Arch Environ Health 6:610–616. 10.1080/00039896.1963.10663449.13970885
Berlin M, Jerksell LG, von Ubisch H. 1966. Uptake and retention of mercury in the mouse brain. A comparison of exposure to mercury vapor and intravenous injection of mercuric salt. Arch Environ Health 12(1):33–42.4951658
Berlin MH, Nordberg GF, Serenius F. 1969a. On the site and mechanism of mercury vapor resorption in the lung. A study in the guinea pig using mercuric nitrate Hg 203. Arch Environ Health 18(1):42–50.5782496
Berlin M, Fazackerley J, Nordberg G. 1969b. The uptake of mercury in the brains of mammals exposed to mercury vapor and to mercuric salts. Arch Environ Health 18(5):719–729.4976543
Berlin M, Carlson J, Norseth T. 1975. Dose-dependence of methylmercury metabolism: A study of distribution: Biotransformation and excretion in the squirrel monkey. Arch Environ Health 30(6):307–313.1137437
Berlin M, Zalups RK, Fowler BA. 2015. Mercury. In: Nordberg GF, Fowler BA, Nordberg M, eds. Handbook on the toxicology of metals. Boston, MA: Academic Press, 1013–1075. 10.1016/B978-0-444-59453-2.00046-9.
Berndt WO, Baggett JM, Blacker A, . 1985. Renal glutathione and mercury uptake by kidney. Fundam Appl Toxicol 5(5):832–839. 10.1016/0272-0590(85)90166-6.4065459
Berthet A, de Batz A, Tardif R, . 2010. Impact of biological and environmental variabilities on biological monitoring--an approach using toxicokinetic models. J Occup Environ Hyg 7(3):177–184. 10.1080/15459620903530052.20063230
Berthoud HR, Garman RH, Weiss B. 1976. Food intake, body weight, and brain histopathology in mice following chronic methylmercury treatment. Toxicol Appl Pharmacol 36(1):19–30. 10.1016/0041-008x(76)90023-5.1273838
Betti C, Davini T, Barale R. 1992. Genotoxic activity of methyl mercury chloride and dimethyl mercury in human lymphocytes. Mutat Res 281(4):255–260.1373219
Beusterien KM, Etzel RA, Agocs MM, . 1991. Indoor air mercury concentrations following application of interior latex paint. Arch Environ Contam Toxicol 21(1):62–64. 10.1007/bf01055557.1898118
Beyrouty P, Stamler CJ, Liu JN, . 2006. Effects of prenatal methylmercury exposure on brain monoamine oxidase activity and neurobehaviour of rats. Neurotoxicol Teratol 28(2):251–259. 10.1016/j.ntt.2005.12.007.16490344
Bhan A, Sarkar NN. 2005. Mercury in the environment: effect on health and reproduction. Rev Environ Health 20(1):39–56.15835497
Bhowmik N, Patra M. 2015. Assessment of genotoxicity of inorganic mercury in rats in vivo using both chromosomal aberration and comet assays. Toxicol Ind Health 31(7):588–594. 10.1177/0748233712469656.23448859
Bilak Ş, Önderci M, Şimşek A. 2019. Evaluation of amalgam-related retinal neurotoxicity with optical coherence tomography findings. Hum Exp Toxicol 38(7):814–822. 10.1177/0960327119842637.30977404
Birch RJ, Bigler J, Rogers JW, . 2014. Trends in blood mercury concentrations and fish consumption among U.S. women of reproductive age, NHANES, 1999-2010. Environ Res 133:431–438. 10.1016/j.envres.2014.02.001.24602558
Birke G, Johnels AG, Plantin LO, . 1972. Studies on humans exposed to methyl mercury through fish consumption. Arch Environ Health 25(2):77–91.5045067
Biro L, Klein WP. 1967. Unusual complications of mercurial (cinnabar) tattoo. Arch Dermatol 96(2):165. 10.1001/archderm.1967.01610020057017.6039153
Bittencourt LO, Dionizio A, Nascimento PC, . 2019. Proteomic approach underlying the hippocampal neurodegeneration caused by low doses of methylmercury after long-term exposure in adult rats. Metallomics 11(2):390–403. 10.1039/c8mt00297e.30525157
Bittencourt LO, Chemelo VS, Aragão WAB, . 2021. From molecules to behavior in long-term inorganic mercury intoxication: Unraveling proteomic features in cerebellar neurodegeneration of rats. Int J Mol Sci 23(1):111. 10.3390/ijms23010111.35008538
Bittencourt LO, Matta PPM, Nascimento PC, . 2022. Deciphering the global proteomic profile involved in methylmercury-induced cerebellar neurodegeneration and motor dysfunction in adult rats. Toxics 10(9):531. 10.3390/toxics10090531.36136496
Bittner AC, Echeverria D, Woods JS, . 1998. Behavioral effects of low-level exposure to Hg^0^ among dental professionals: a cross-study evaluation of psychomotor effects. Neurotoxicol Teratol 20(4):429–439. 10.1016/s0892-0362(98)00006-3.9697969
Bjorkman S. 2004. Prediction of drug disposition in infants and children by means of physiologically based pharmacokinetic (PBPK) modelling: theophylline and midazolam as model drugs. Br J Clin Pharmacol 59(6):691–704. 10.1111/j.1365-2125.2004.02225.x.
Bjorkman L, Sandborgh-Englund G, Ekstrand J. 1997. Mercury in saliva and feces after removal of amalgam fillings. Toxicol Appl Pharmacol 144(1):156–162. 10.1006/taap.1997.8128.9169079
Bjorkman L, Lundekvam BF, Laegreid T, . 2007. Mercury in human brain, blood, muscle and toenails in relation to exposure: an autopsy study. Environ Health 6:30. 10.1186/1476-069x-6-30.17931423
Bjornberg A, Hakanson L, Lundbergh K. 1988. A theory on the mechanisms regulating the bioavailability of mercury in natural waters. Environ Pollut 49(1):53–62.15092673
Bjornberg KA, Vahter M, Petersson-Grawe K, . 2003. Methyl mercury and inorganic mercury in Swedish pregnant women and in cord blood: influence of fish consumption. Environ Health Perspect 111(4):637–641.12676628
Bjornberg KA, Vahter M, Berglund B, . 2005. Transport of methylmercury and inorganic mercury to the fetus and breast-fed infant. Environ Health Perspect 113(10):1381–1385.16203251
Blakley BR, Sisodia CS, Mukkur TK. 1980. The effect of methylmercury, tetraethyl lead, and sodium arsenite on the humoral immune response in mice. Toxicol Appl Pharmacol 52(2):245–254. 10.1016/0041-008x(80)90111-8.6892663
Blanc P, Burnol A, Marty N, . 2018. Methylmercury complexes: Selection of thermodynamic properties and application to the modelling of a column experiment. Sci Total Environ 621:368–375. 10.1016/j.scitotenv.2017.11.259.29190560
Blanchet C, Rochette L. 2008. Qanuippitaa? How are we? Nutrition and food consumption among the Inuit of Nunavik. Quebec: Institut National de Santé Publique du Québec. https://www.inspq.qc.ca/pdf/publications/762_ESI_Nutrition_Report_MA.pdf. January 18, 2021.
Blayney MB, Winn JS, Nierenberg DW. 1997. Handling dimethylmercury. Chem Eng News 75(19):7.
Bloom NS. 1992. On the chemical form of mercury in edible fish and marine invertebrate tissue. Can J Fish Aquat Sci 49(5):1010–1017. 10.1139/f92-113.
Bloom NS, Effler SW. 1990. Seasonal variability in the mercury speciation of Onondaga Lake (New York). Water Air Soil Pollut 53(3–4):251–265. 10.1007/bf00170741.
Bloom MS, Buck Louis GM, Sundaram R, . 2015. Birth outcomes and background exposures to select elements, the Longitudinal Investigation of Fertility and the Environment (LIFE). Environ Res 138:118–129. 10.1016/j.envres.2015.01.008.25707016
Bluhm RE, Bobbitt RG, Welch LW, . 1992. Elemental mercury vapour toxicity, treatment, and prognosis after acute, intensive exposure in chloralkali plant workers. Part I: History, neuropsychological findings and chelator effects. Hum Exp Toxicol 11(3):201–210. 10.1177/096032719201100308.1352115
Blume HP, Brümmer G. 1991. Prediction of heavy metal behavior in soil by means of simple field tests. Ecotoxicol Environ Saf 22(2):164–174. 10.1016/0147-6513(91)90056-u.1769350
Bodaly RAD. 2018. Mercury contamination of the Penobscot River Estuary, Maine, USA. Sci Total Environ 639:1077–1078. 10.1016/j.scitotenv.2018.05.127.29929276
Boersma ER, Lanting CI. 2000. Environmental exposure to polychlorinated biphenyls (PCBs) and dioxins. Consequences for longterm neurological and cognitive development of the child lactation. Adv Exp Med Biol 478:271–287.11065080
Boischio AA, Cernichiari E, Henshel D. 2000. Segmental hair mercury evaluation of a single family along the upper Madeira basin, Brazilian Amazon. Cad Saude Publica 16(3):681–686.11035507
Boogaard PJ, Houtsma AT, Journee HL, . 1996. Effects of exposure to elemental mercury on the nervous system and the kidneys of workers producing natural gas. Arch Environ Health 51(2):108–115. 10.1080/00039896.1996.9936002.8638960
Boomhower SR, Newland MC. 2019. Adolescent methylmercury exposure: Behavioral mechanisms and effects of sodium butyrate in mice. Neurotoxicology 70:33–40. 10.1016/j.neuro.2018.10.011.30385387
Borghese MM, Fisher M, Ashley-Martin J, . 2023. Individual, independent, and joint associations of toxic metals and manganese on hypertensive disorders of pregnancy: Results from the MIREC Canadian pregnancy cohort. Environ Health Perspect 131(4):47014. 10.1289/ehp10825.37079392
Bornhausen M, Musch HR, Greim H. 1980. Operant behavior performance changes in rats after prenatal methylmercury exposure. Toxicol Appl Pharmacol 56(3):305–310. 10.1016/0041-008x(80)90062-9.7222014
Boscolo P, Carmignani M, Giuliano G, . 1989. Peripheral catecholaminergic mechanisms and baroreflex pathways are involved in vascular and cardiac effects of long-term exposure to inorganic mercury in rats. In: Strano A, Novo S, eds. Advances in vascular pathology. Amsterdam: Elsevier Science Publisher, 1061–1066.
Boucher O, Bastien CH, Saint-Amour D, . 2010. Prenatal exposure to methylmercury and PCBs affects distinct stages of information processing: an event-related potential study with Inuit children. Neurotoxicology 31(4):373–384. 10.1016/j.neuro.2010.04.005.20403381
Boucher O, Burden MJ, Muckle G, . 2012a. Response inhibition and error monitoring during a visual go/no-go task in Inuit children exposed to lead, polychlorinated biphenyls, and methylmercury. Environ Health Perspect 120(4):608–615. 10.1289/ehp.1103828.22142904
Boucher O, Jacobson SW, Plusquellec P, . 2012b. Prenatal methylmercury, postnatal lead exposure, and evidence of attention deficit/hyperactivity disorder among Inuit children in Arctic Quebec. Environ Health Perspect 120(10):1456–1461. 10.1289/ehp.1204976.23008274
Boucher O, Muckle G, Jacobson JL, . 2014. Domain-specific effects of prenatal exposure to PCBs, mercury, and lead on infant cognition: Results from the Environmental Contaminants and Child Development Study in Nunavik. Environ Health Perspect 122(3):310–316. 10.1289/ehp.1206323.24441767
Boucher O, Muckle G, Ayotte P, . 2016. Altered fine motor function at school age in Inuit children exposed to PCBs, methylmercury, and lead. Environ Int 95:144–151. 10.1016/j.envint.2016.08.010.27575364
Boujbiha MA, Hamden K, Guermazi F, . 2009. Testicular toxicity in mercuric chloride treated rats: Association with oxidative stress. Reprod Toxicol 28(1):81–89. 10.1016/j.reprotox.2009.03.011.19427169
Boujbiha MA, Hamden K, Guermazi F, . 2011. Impairment of spermatogenesis in rats by mercuric chloride: Involvement of low 17beta-estradiol level in induction of acute oxidative stress. Biol Trace Elem Res 142(3):598–610. 10.1007/s12011-010-8774-2.20820944
Boujbiha MA, Ben Salah G, Ben Feleh A, . 2012. Hematotoxicity and genotoxicity of mercuric chloride following subchronic exposure through drinking water in male rats. Biol Trace Elem Res 148(1):76–82. 10.1007/s12011-012-9342-8.22351102
Bourdineaud JP, Fujimura M, Laclau M, . 2011. Deleterious effects in mice of fish-associated methylmercury contained in a diet mimicking the Western populations’ average fish consumption. Environ Int 37(2):303–313. 10.1016/j.envint.2010.09.003.21035857
Bourgeois M, Dooms-Goossens A, Knockaert D, . 1986. Mercury intoxication after topical application of a metallic mercury ointment. Dermatology 172(1):48–51. 10.1159/000249292.
Bowman KL, Lamborg CH, Agather AM. 2020. A global perspective on mercury cycling in the ocean. Sci Total Environ 710:136166. 10.1016/j.scitotenv.2019.136166.32050358
Boyd ES, Barkay T. 2012. The mercury resistance operon: from an origin in a geothermal environment to an efficient detoxification machine. Front Microbiol 3:349. 10.3389/fmicb.2012.00349.23087676
Branco V, Carvalho C. 2019. The thioredoxin system as a target for mercury compounds. Biochim Biophys Acta Gen Subj 1863(12):129255. 10.1016/j.bbagen.2018.11.007.30447253
Branco V, Ramos P, Canario J, . 2012. Biomarkers of adverse response to mercury: Histopathology versus thioredoxin reductase activity. J Biomed Biotechnol 2012:1–9. 10.1155/2012/359879.21836813
Bressa G, Cima L, Costa P. 1988. Bioaccumulation of mercury in the mushroom Pleurotus ostreatus. Ecotoxicol Environ Saf 16(2):85–89.3234295
Bridges CC, Zalups RK. 2005. Molecular and ionic mimicry and the transport of toxic metals. Toxicol Appl Pharmacol 204(3):274–308. 10.1016/j.taap.2004.09.007.15845419
Bridges CC, Zalups RK. 2010. Transport of inorganic mercury and methylmercury in target tissues and organs. J Toxicol Environ Health B Crit Rev 13(5):385–410. 10.1080/10937401003673750.20582853
Bridges CC, Zalups RK. 2017. Mechanisms involved in the transport of mercuric ions in target tissues. Arch Toxicol 91(1):63–81. 10.1007/s00204-016-1803-y.27422290
Bridges CC, Bauch C, Verrey F, . 2004. Mercuric conjugates of cysteine are transported by the amino acid transporter system b^0,+^: implications of molecular mimicry. J Am Soc Nephrol 15(3):663–673.14978168
Bridges CC, Joshee L, Zalups RK. 2011. MRP2 and the handling of mercuric ions in rats exposed acutely to inorganic and organic species of mercury. Toxicol Appl Pharmacol 251(1):50–58. 10.1016/j.taap.2010.11.015.21134393
Bridges CC, Joshee L, Zalups RK. 2012. Placental and fetal disposition of mercuric ions in rats exposed to methylmercury: Role of Mrp2. Reprod Toxicol 34(4):628–634. 10.1016/j.reprotox.2012.10.001.23059061
Bridges CC, Joshee L, van den Heuvel JJ, . 2013. Glutathione status and the renal elimination of inorganic mercury in the Mrp2^-/-^ mouse. PLoS ONE 8(9):e73559. 10.1371/journal.pone.0073559.24039982
Brosset C, Lord E. 1991. Mercury in precipitation and ambient air: A new scenario. Water Air Soil Pollut 56(0):493–506.
Brown JR, Shockley P. 1982. Serum albumin: structure and characterization of its ligand binding sites. In: Jost PC, Griffith OH, eds. Lipid-protein interactions. Vol. 1. New York, NY: Wiley, Inc., 25–68.
Brown E, Hopper J, Hodges JL, . 1962. Red cell, plasma, and blood volume in healthy women measured by radiochromium cell-labeling and hematocrit. J Clin Invest 41(12):2182–2190. 10.1172/jci104677.14015940
Bryan GW, Langston WJ. 1992. Bioavailability, accumulation and effects of heavy metals in sediments with special reference to United Kingdom estuaries: A review. Environ Pollut 76(2):89–131.15091993
Bryan SE, Guy AL, Hardy KJ. 1974. Metal constituents of chromatin. Interaction of mercury in vivo. Biochemistry 13(2):313–319. 10.1021/bi00699a013.4810055
Bucio L, Garcia C, Souza V, . 1999. Uptake, cellular distribution and DNA damage produced by mercuric chloride in a human fetal hepatic cell line. Mutat Res 423(1–2):65–72.10029678
Buck Louis GM, Sundaram R, Schisterman EF, . 2012. Heavy metals and couple fecundity, the LIFE Study. Chemosphere 87(11):1201–1207. 10.1016/j.chemosphere.2012.01.017.22309709
Buck Louis GM, Smarr MM, Sundaram R, . 2017. Low-level environmental metals and metalloids and incident pregnancy loss. Reprod Toxicol 69:68–74. 10.1016/j.reprotox.2017.01.011.28163209
Budavari S, ed. 1989. Mercury. In: Merck index: an encyclopedia of chemicals, drugs, and biologicals. Rahway, NJ: Merck & Co., Inc., 923–927.
Budtz-Jorgensen E, Grandjean P, Jorgensen PJ, . 2004. Association between mercury concentrations in blood and hair in methylmercury-exposed subjects at different ages. Environ Res 95(3):385–393. 10.1016/j.envres.2003.11.001.15220072
Buhari O, Dayyab FM, Igbinoba O, . 2020. The association between heavy metal and serum cholesterol levels in the US population: National Health and Nutrition Examination Survey 2009-2012. Hum Exp Toxicol 39(3):355–364. 10.1177/0960327119889654.31797685
Bulat P, Dujic I, Potkonjak B, . 1998. Activity of glutathione peroxidase and superoxide dismutase in workers occupationally exposed to mercury. Int Arch Occup Environ Health 71(Suppl):S37–S39.9827878
Bulka CM, Persky VW, Daviglus ML, . 2019. Multiple metal exposures and metabolic syndrome: A cross-sectional analysis of the National Health and Nutrition Examination Survey 2011-2014. Environ Res 168:397–405. 10.1016/j.envres.2018.10.022.30388496
Burbacher TM, Mottet NK. 1988. The long-term physical, behavioral, and sexual maturation of Macaca fascicularis exposed in utero to methylmercury [abstract]. Teratology 37(5):524.
Burbacher TM, Monnett C, Grant KS, . 1984. Methylmercury exposure and reproductive dysfunction in the nonhuman primate. Toxicol Appl Pharmacol 75(1):18–24. 10.1016/0041-008x(84)90071-1.6464019
Burbacher TM, Grant KS, Mayfield DB, . 2005. Prenatal methylmercury exposure affects spatial vision in adult monkeys. Toxicol Appl Pharmacol 208(1):21–28. 10.1016/j.taap.2005.01.011.16164958
Burger J, Cooper K, Gochfeld M. 1992. Exposure assessment for heavy metal ingestion from a sport fish in Puerto Rico: Estimating risk for local fishermen. J Toxicol Environ Health 36(4):355–365. 10.1080/15287399209531644.1507267
Burke J, Hoyer M, Keeler G, . 1995. Wet deposition of mercury and ambient mercury concentrations at a site in the Lake Champlain basin. Water Air Soil Pollut 80:353–362.
Burns DA, Woodruff LG, Bradley PM, . 2014. Mercury in the soil of two contrasting watersheds in the eastern United States. PLoS ONE 9(2):e86855. 10.1371/journal.pone.0086855.24551042
Byczkowski JZ, Lipscomb JC. 2001. Physiologically based pharmacokinetic modeling of the lactational transfer of methylmercury. Risk Anal 21(5):869–882.11798123
Byrns MC, Pennings TM. 2017. Environmental toxicology: Carcinogens and heavy metals. In: Brunton LL, Hilal-Dandan R, Knollman BC, eds. Goodman & Gilman’s: The pharmacological basis of therapeutics. 13^th^ ed. McGraw Hill,
Cagiano R, De Salvia MA, Renna G, . 1990. Evidence that exposure to methyl mercury during gestation induces behavioral and neurochemical changes in offspring of rats. Neurotoxicol Teratol 12(1):23–28. 10.1016/0892-0362(90)90108-o.2156144
Caito SW, Jackson BP, Punshon T, . 2018. Editor’s highlight: Variation in methylmercury metabolism and elimination status in humans following fish consumption. Toxicol Sci 161(2):443–453. 10.1093/toxsci/kfx226.29145616
Cakmak S, Mitchell K, Lukina A, . 2023. Do blood metals influence lipid profiles? Findings of a cross-sectional population-based survey. Environ Res 231(Pt 2):116107. 10.1016/j.envres.2023.116107.37187310
Calamandrei G, Ricceri L, Meccia E, . 2020. Pregnancy exposome and child psychomotor development in three European birth cohorts. Environ Res 181:108856. 10.1016/j.envres.2019.108856.31706595
Calao-Ramos C, Bravo AG, Paternina-Uribe R, . 2021. Occupational human exposure to mercury in artisanal small-scale gold mining communities of Colombia. Environ Int 146:106216. 10.1016/j.envint.2020.106216.33181411
Callan AC, Devine A, Qi L, . 2015. Investigation of the relationship between low environmental exposure to metals and bone mineral density, bone resorption and renal function. Int J Hyg Environ Health 218(5):444–451. 10.1016/j.ijheh.2015.03.010.25857756
Calogero AE, Fiore M, Giacone F, . 2021. Exposure to multiple metals/metalloids and human semen quality: A cross-sectional study. Ecotoxicol Environ Saf 215:112165. 10.1016/j.ecoenv.2021.112165.33773149
Cañadas P, Lantigua Y, Enríquez-de-Salamanca A, . 2021. Ocular surface pathology in patients suffering from mercury intoxication. Diagnostics (Basel) 11(8):1326. 10.3390/diagnostics11081326.34441261
Cannon VT, Barfuss DW, Zalups RK. 2000. Molecular homology and the luminal transport of Hg^2+^ in the renal proximal tubule. J Am Soc Nephrol 11(3):394–402.10703663
Cannon VT, Zalups RK, Barfuss DW. 2001. Amino acid transporters involved in luminal transport of mercuric conjugates of cysteine in rabbit proximal tubule. J Pharmacol Exp Ther 298(2):780–789.11454942
Cantoni O, Costa M. 1983. Correlations of DNA strand breaks and their repair with cell survival following acute exposure to mercury(II) and X-rays. Mol Pharmacol 24(1):84–89.6223207
Cantoni O, Evans RM, Costa M. 1982. Similarity in the acute cytotoxic response of mammalian cells to mercury (II) and X-rays: DNA damage and glutathione depletion. Biochem Biophys Res Commun 108(2):614–619. 10.1016/0006-291x(82)90873-7.7150310
Cantoni O, Christie NT, Robison SH, . 1984a. Characterization of DNA lesions produced by HgCl_2_ in cell culture systems. Chem Biol Interact 49(1–2):209–224.6233017
Cantoni O, Christie NT, Swann A, . 1984b. Mechanism of HgCl_2_ cytotoxicity in cultured mammalian cells. Mol Pharmacol 26(2):360–368.6090887
Canto-Pereira LH, Lago M, Costa MF, . 2005. Visual impairment on dentists related to occupational mercury exposure. Environ Toxicol Pharmacol 19(3):517–522. 10.1016/j.etap.2004.12.015.21783521
Cappelletti S, Piacentino D, Fineschi V, . 2019. Mercuric chloride poisoning: symptoms, analysis, therapies, and autoptic findings. A review of the literature. Crit Rev Toxicol 49(4):329–341. 10.1080/10408444.2019.1621262.31433682
Cardenas A, Roels H, Bernard AM, . 1993. Markers of early renal changes induced by industrial pollutants. I. Application to workers exposed to mercury vapour. Br J Ind Med 50(1):17–27. 10.1136/oem.50.1.17.8431387
Cardenas A, Allard C, Doyon M, . 2016. Validation of a DNA methylation reference panel for the estimation of nucleated cells types in cord blood. Epigenetics 11(11):773–779. 10.1080/15592294.2016.1233091.27668573
Cardenas A, Rifas-Shiman SL, Agha G, . 2017a. Persistent DNA methylation changes associated with prenatal mercury exposure and cognitive performance during childhood. Sci Rep 7(1):288. 10.1038/s41598-017-00384-5.28325913
Cardenas A, Rifas-Shiman SL, Godderis L, . 2017b. Prenatal exposure to mercury: Associations with global DNA methylation and hydroxymethylation in cord blood and in childhood. Environ Health Perspect 125(8):087022. 10.1289/EHP1467.28934725
Carmignani M, Boscolo P. 1984. Cardiovascular homeostasis in rats chronically exposed to mercuric chloride. Arch Toxicol Suppl 7:383–388. 10.1007/978-3-642-69132-4_66.6596006
Carmignani M, Boscolo P, Preziosi P. 1989. Renal ultrastructural alterations and cardiovascular functional changes in rats exposed to mercuric chloride. Arch Toxicol Suppl 13:353–356. 10.1007/978-3-642-74117-3_68.2774959
Carmignani M, Boscolo P, Artese L, . 1992. Renal mechanisms in the cardiovascular effects of chronic exposure to inorganic mercury in rats. Br J Ind Med 49(4):226–232. 10.1136/oem.49.4.226.1571292
Carmona ER, Kossatz E, Creus A, . 2008. Genotoxic evaluation of two mercury compounds in the Drosophila wing spot test. Chemosphere 70(10):1910–1914. 10.1016/j.chemosphere.2007.07.032.17845812
Carneiro MF, Grotto D, Barbosa F. 2014. Inorganic and methylmercury levels in plasma are differentially associated with age, gender, and oxidative stress markers in a population exposed to mercury through fish consumption. J Toxicol Environ Health A 77(1–3):69–79. 10.1080/15287394.2014.865584.24555648
Carocci A, Rovito N, Sinicropi MS, . 2014. Mercury toxicity and neurodegenerative effects. Rev Environ Contam Toxicol 229:1–18. 10.1007/978-3-319-03777-6_1.24515807
Carrasco P, Estarlich M, Iñiguez C, . 2021. Pre and postnatal exposure to mercury and respiratory health in preschool children from the Spanish INMA Birth Cohort Study. Sci Total Environ 782:146654. 10.1016/j.scitotenv.2021.146654.33838378
Carratu MR, Borracci P, Coluccia A, . 2006. Acute exposure to methylmercury at two developmental windows: Focus on neurobehavioral and neurochemical effects in rat offspring. Neuroscience 141(3):1619–1629. 10.1016/j.neuroscience.2006.05.017.16781816
Carratu MR, Coluccia A, Modafferi AM, . 2008. Prenatal methylmercury exposure: Effects on stress response during active learning. Bull Environ Contam Toxicol 81(6):539–542. 10.1007/s00128-008-9557-8.18787750
Carrier G, Bouchard M, Brunet RC, . 2001a. A toxicokinetic model for predicting the tissue distribution and elimination of organic and inorganic mercury following exposure to methyl mercury in animals and humans. II. Application and validation of the model in humans. Toxicol Appl Pharmacol 171(1):50–60. 10.1006/taap.2000.9113.11181111
Carrier G, Brunet RC, Caza M, . 2001b. A toxicokinetic model for predicting the tissue distribution and elimination of organic and inorganic mercury following exposure to methyl mercury in animals and humans. I. Development and validation of the model using experimental data in rats. Toxicol Appl Pharmacol 171(1):38–49. 10.1006/taap.2000.9112.11181110
Carrington CD, Bolger MP. 2002. An exposure assessment for methylmercury from seafood for consumers in the United States. Risk Anal 22(4):689–699.12224743
Carta P, Flore C, Alinovi R, . 2003. Sub-clinical neurobehavioral abnormalities associated with low level of mercury exposure through fish consumption. Neurotoxicology 24(4–5):617–623. 10.1016/s0161-813x(03)00080-9.12900074
Carty AJ, Malone SF. 1979. The chemistry of mercury in biological systems. In: Nriagu JO, ed. The biogeochemistry of mercury in the environment. New York, NY: Elsevier/North Holland Biomedical Press, 433–480.
Casetta I, Invernizzi M, Granieri E. 2001. Multiple sclerosis and dental amalgam: Case-control study in Ferrara, Italy. Neuroepidemiology 20(2):134–137. 10.1159/000054773.11359082
Castano A, Cutanda F, Esteban M, . 2015. Fish consumption patterns and hair mercury levels in children and their mothers in 17 EU countries. Environ Res 141:58–68. 10.1016/j.envres.2014.10.029.25667172
Castiello F, Olmedo P, Gil F, . 2020. Association of urinary metal concentrations with blood pressure and serum hormones in Spanish male adolescents. Environ Res 182:108958. 10.1016/j.envres.2019.108958.31835118
Castoldi AF, Johansson C, Onishchenko N, . 2008. Human developmental neurotoxicity of methylmercury: impact of variables and risk modifiers. Regul Toxicol Pharmacol 51(2):201–214. 10.1016/j.yrtph.2008.01.016.18367301
Castriotta L, Rosolen V, Biggeri A, . 2020. The role of mercury, selenium and the Se-Hg antagonism on cognitive neurodevelopment: A 40-month follow-up of the Italian mother-child PHIME cohort. Int J Hyg Environ Health 230:113604. 10.1016/j.ijheh.2020.113604.32871542
Cavalleri A, Gobba F. 1998. Reversible color vision loss in occupational exposure to metallic mercury. Environ Res 77(2):173–177. 10.1006/enrs.1997.3814.9600811
CDC. 2002. Urine output. Centers for Disease Control and Prevention. https://www.cdc.gov/dengue/training/cme/ccm/page57297.html. December 16, 2020.
CDC. 2011. Understanding thimerosal, mercury, and vaccine safety. Centers for Disease Control and Prevention: https://www.cdc.gov/vaccines/hcp/patient-ed/conversations/downloads/vacsafe-thimerosal-color-office.pdf. December 14, 2020.
CDC. 2013. What to do when mercury spills at school. Centers for Disease Control and Prevention. https://www.atsdr.cdc.gov/dontmesswithmercury/pdfs/mercury-spill-instructions.pdf. December 23, 2021.
CDC. 2015. Mercury-containing objects: In schools and your home. Centers for Disease Control and Prevention. https://www.atsdr.cdc.gov/dontmesswithmercury/pdfs/Mercury-containing-objects-in-schools-and-homes_teachers.pdf. December 20, 2021.
CDC. 2019. Fourth national report on human exposure to environmental chemicals, updated tables, January 2019. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/index.html. December 16, 2020.
CDC. 2020. Timeline of thimerosal in vaccines. Centers for Disease Control and Prevention. https://www.cdc.gov/vaccinesafety/concerns/thimerosal/timeline.html. March 15, 2021.
CDC. 2024. Mercury. Biomonitoring data tables for environmental chemicals. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/data_tables.html. April 4, 2024.
Ceccatelli S, Dare E, Moors M. 2010. Methylmercury-induced neurotoxicity and apoptosis. Chem Biol Interact 188(2):301–308. 10.1016/j.cbi.2010.04.007.20399200
Cediel Ulloa A, Gliga A, Love TM, . 2021. Prenatal methylmercury exposure and DNA methylation in seven-year-old children in the Seychelles Child Development Study. Environ Int 147:106321. 10.1016/j.envint.2020.106321.33340986
Cember H, Gallagher P, Faulkner A. 1968. Distribution of mercury among blood fractions and serum proteins. Am Ind Hyg Assoc J 29(3):233–237. 10.1080/00028896809342994.4173106
Cernichiari E, Toribara TY, Liang L, . 1995. The biological monitoring of mercury in the Seychelles study. Neurotoxicology 16(4):613–628.8714867
Cernichiari E, Myers GJ, Ballatori N, . 2007. The biological monitoring of prenatal exposure to methylmercury. Neurotoxicology 28(5):1015–1022. 10.1016/j.neuro.2007.02.009.17382399
Cesario R, Hintelmann H, Mendes R, . 2017. Evaluation of mercury methylation and methylmercury demethylation rates in vegetated and non-vegetated saltmarsh sediments from two Portuguese estuaries. Environ Pollut 226:297–307. 10.1016/j.envpol.2017.03.075.28390703
Chalmers AT, Argue DM, Gay DA, . 2011. Mercury trends in fish from rivers and lakes in the United States, 1969-2005. Environ Monit Assess 175(1–4):175–191. 10.1007/s10661-010-1504-6.20535551
Chan HM, Egeland GM. 2004. Fish consumption, mercury exposure, and heart diseases. Nutr Rev 62(2):68–72.15080369
Chan PHY, Kwok KM, Chan MHM, . 2021. Prenatal methylmercury exposure is associated with decrease heart rate variability in children. Environ Res 200:111744. 10.1016/j.envres.2021.111744.34310966
Chang JY. 2011. Methylmercury-induced IL-6 release requires phospholipase C activities. Neurosci Lett 496(3):152–156. 10.1016/j.neulet.2011.04.004.21513770
Chang LW, Hartmann HA. 1972. Ultrastructural studies of the nervous system after mercury intoxication. I. Pathological changes in the nerve cell bodies. Acta Neuropathol (Berl) 20(2):122–138. 10.1007/bf00691129.5018222
Chang LW, Mak L, Martin AH. 1974. Effects of methylmercury on the limb regeneration of newts Triturus-viridescens. Anat Rec 178(2):509. 10.1016/0013-9351(76)90091-8.
Chang YC, Yeh CY, Wang JD. 1995. Subclinical neurotoxicity of mercury vapor revealed by a multimodality evoked potential study of chloralkali workers. Am J Ind Med 27(2):271–279. 10.1002/ajim.4700270211.7755016
Chang JW, Chen HL, Su HJ, . 2011. Simultaneous exposure of non-diabetics to high levels of dioxins and mercury increases their risk of insulin resistance. J Hazard Mater 185(2–3):749–755. 10.1016/j.jhazmat.2010.09.084.21087821
Chang JY, Park JS, Shin S, . 2015. Mercury exposure in healthy Korean weaning-age infants: Association with growth, feeding and fish intake. Int J Environ Res Public Health 12(11):14669–14689. 10.3390/ijerph121114669.26593931
Chapman LJ, Sauter SL, Henning RA, . 1990. Differences in frequency of finger tremor in otherwise asymptomatic mercury workers. Br J Ind Med 47(12):838–843. 10.1136/oem.47.12.838.2271392
Charbonneau SM, Munro IC, Nera EA, . 1976. Chronic toxicity of methylmercury in the adult cat. Interim report. Toxicology 5(3):337–349. 10.1016/0300-483x(76)90052-4.1265772
Charette T, Bueno Dalto D, Rosabal M, . 2021. Assessment of in vitro bioaccessibility and in vivo oral bioavailability as complementary tools to better understand the effect of cooking on methylmercury, arsenic, and selenium in tuna. Toxics 9(2):27. 10.3390/toxics9020027.33546146
Charleston JS, Bolender RP, Mottet NK, . 1994. Increases in the number of reactive glia in the visual cortex of Macaca fascicularis following subclinical long-term methyl mercury exposure. Toxicol Appl Pharmacol 129(2):196–206. 10.1006/taap.1994.1244.7992310
Charleston JS, Body RL, Mottet NK, . 1995. Autometallographic determination of inorganic mercury distribution in the cortex of the calcarine sulcus of the monkey Macaca fascicularis following long-term subclinical exposure to methylmercury and mercuric chloride. Toxicol Appl Pharmacol 132(2):325–333. 10.1006/taap.1995.1114.7785060
Charleston JS, Body RL, Bolender RP, . 1996. Changes in the number of astrocytes and microglia in the thalamus of the monkey Macaca fascicularis following long-term subclinical methylmercury exposure. Neurotoxicology 17(1):127–138.8784824
Cheatham C. 2008. Omega-3 fatty acids and the development of cognitive abilities: A review of DHA supplementation studies. CAB Rev Perspect Agric Vet Sci Nutr Nat Resour 3(001):1–15. 10.1079/pavsnnr20083001.
Chehimi L, Roy V, Jeljeli M, . 2012. Chronic exposure to mercuric chloride during gestation affects sensorimotor development and later behaviour in rats. Behav Brain Res 234(1):43–50. 10.1016/j.bbr.2012.06.005.22705860
Chemelo VS, Nascimento PC, Bittencourt LO, . 2022. In utero and lactational exposure to methylmercury elicits physical-chemical and morphological damages in the alveolar bone of offspring rats: The first toxicological findings. Chemosphere 308(Pt 3):136453. 10.1016/j.chemosphere.2022.136453.36122745
Chen L, Li Y. 2019. A review on the distribution and cycling of mercury in the pacific ocean. Bull Environ Contam Toxicol 102(5):665–671. 10.1007/s00128-019-02560-x.30725129
Chen CY, Dionne M, Mayes BM, . 2009. Mercury bioavailability and bioaccumulation in estuarine food webs in the Gulf of Maine. Environ Sci Technol 43(6):1804–1810.19368175
Chen KL, Liu SH, Su CC, . 2012. Mercuric compounds induce pancreatic islets dysfunction and apoptosis in vivo. Int J Mol Sci 13(10):12349–12366. 10.3390/ijms131012349.23202902
Chen A, Kim SS, Chung E, . 2013. Thyroid hormones in relation to lead, mercury, and cadmium exposure in the National Health and Nutrition Examination Survey, 2007-2008. Environ Health Perspect 121(2):181–186. 10.1289/ehp.1205239.23164649
Chen C, Xun P, McClure LA, . 2018. Serum mercury concentration and the risk of ischemic stroke: The REasons for Geographic and Racial Differences in Stroke Trace Element Study. Environ Int 117:125–131. 10.1016/j.envint.2018.05.001.29738916
Chen N, Lin M, Liu N, . 2019a. Methylmercury-induced testis damage is associated with activation of oxidative stress and germ cell autophagy. J Inorg Biochem 190:67–74. 10.1016/j.jinorgbio.2018.10.007.30366167
Chen R, Xu Y, Xu C, . 2019b. Associations between mercury exposure and the risk of nonalcoholic fatty liver disease (NAFLD) in US adolescents. Environ Sci Pollut Res Int 26(30):31384–31391. 10.1007/s11356-019-06224-5.31473923
Chen KH, Yu HC, Chang YC. 2021. Analysis of dental amalgam fillings on primary Sjögren’s syndrome: A population-based case-control study in Taiwan. Medicine (Baltimore) 100(47):e28031. 10.1097/md.0000000000028031.34964800
Chen C, Zhang S, Yang T, . 2023a. Associations between environmental heavy metals exposure and preserved ratio impaired spirometry in the U.S. adults. Environ Sci Pollut Res Int 30(49):108274–108287. 10.1007/s11356-023-29688-y.37749472
Chen Y, Zhao A, Li R, . 2023b. Independent and combined associations of multiple-heavy-metal exposure with lung function: a population-based study in US children. Environ Geochem Health 45(7):5213–5230. 10.1007/s10653-023-01565-0.37097600
Chen T, Li Y, Liu J, . 2023c. The burden of mild intellectual disability attributed to prenatal exposure to methylmercury in China, 2017. Ecotoxicol Environ Saf 254:114748. 10.1016/j.ecoenv.2023.114748.36921496
Cheng J, Fujimura M, Bo D. 2015. Assessing pre/post-weaning neurobehavioral development for perinatal exposure to low doses of methylmercury. J Environ Sci (China) 38:36–41. 10.1016/j.jes.2015.05.027.26702966
Cherian MG, Clarkson TW. 1976. Biochemical changes in rat kidney on exposure to elemental mercury vapor: Effect on biosynthesis of metallothionein. Chem Biol Interact 12(2):109–120. 10.1016/0009-2797(76)90093-4.1248059
Cherian MG, Hursh JB, Clarkson TW, . 1978. Radioactive mercury distribution in biological fluids and excretion in human subjects after inhalation of mercury vapor. Arch Environ Health 33(3):109–114. 10.1080/00039896.1978.10667318.686833
Chernyak YI, Merinova AP. 2017. HSP70 (HSPA1) polymorphisms in former workers with chronic mercury vapor exposure. Int J Occup Med Environ Health 30(1):77–85. 10.13075/ijomeh.1896.00732.28220908
Cheuk DK, Wong V. 2006. Attention-deficit hyperactivity disorder and blood mercury level: a case-control study in Chinese children. Neuropediatrics 37(4):234–240. 10.1055/s-2006-924577.17177150
Chevrier C, Sullivan K, White RF, . 2009. Qualitative assessment of visuospatial errors in mercury-exposed Amazonian children. Neurotoxicology 30(1):37–46. 10.1016/j.neuro.2008.09.012.18992767
Cho KY. 2021. Association of blood mercury levels with the risks of overweight and high waist-to-height ratio in children and adolescents: Data from the Korean National Health and Nutrition Examination Survey. Children (Basel) 8(12):1087. 10.3390/children8121087.34943283
Cho HW, Kim SH, Park MJ. 2020. An association of blood mercury levels and hypercholesterolemia among Korean adolescents. Sci Total Environ 709:135965. 10.1016/j.scitotenv.2019.135965.31927427
Cho GJ, Park HT, Shin JH, . 2012. The relationship between blood mercury level and osteoporosis in postmenopausal women. Menopause 19(5):576–581. 10.1097/gme.0b013e3182377294.22205147
Choi YH, Park SK. 2017. Environmental exposures to lead, mercury, and cadmium and hearing loss in adults and adolescents: KNHANES 2010-2012. Environ Health Perspect 125(6):1–8. 10.1289/ehp565.27384039
Choi AL, Cordier S, Weihe P, . 2008a. Negative confounding in the evaluation of toxicity: the case of methylmercury in fish and seafood. Crit Rev Toxicol 38(10):877–893. 10.1080/10408440802273164.19012089
Choi AL, Budtz-Jorgensen E, Jorgensen PJ, . 2008b. Selenium as a potential protective factor against mercury developmental neurotoxicity. Environ Res 107(1):45–52. 10.1016/j.envres.2007.07.006.17854796
Choi AL, Weihe P, Budtz-Jorgensen E, . 2009. Methylmercury exposure and adverse cardiovascular effects in Faroese whaling men. Environ Health Perspect 117(3):367–372. 10.1289/ehp.11608.19337510
Choi B, Yeum KJ, Park SJ, . 2015. Elevated serum ferritin and mercury concentrations are associated with hypertension; analysis of the fourth and fifth Korea national health and nutrition examination survey (KNHANES IV-2, 3, 2008-2009 and V-1, 2010). Environ Toxicol 30(1):101–108. 10.1002/tox.21899.23929718
Choi J, Bae S, Lim H, . 2017. Mercury exposure in association with decrease of liver function in adults: A longitudinal study. J Prev Med Public Health 50(6):377–385. 10.3961/jpmph.17.099.29207447
Choi S, Lee A, Choi G, . 2022. Free cortisol mediates associations of maternal urinary heavy metals with neonatal anthropometric measures: A cross-sectional study. Toxics 10(4):167. 10.3390/toxics10040167.35448428
Chowdhury R, Ramond A, O’Keeffe LM, . 2018. Environmental toxic metal contaminants and risk of cardiovascular disease: Systematic review and meta-analysis. BMJ 362:k3310. 10.1136/bmj.k3310.30158148
Choy CM, Yeung QS, Briton-Jones CM, . 2002. Relationship between semen parameters and mercury concentrations in blood and in seminal fluid from subfertile males in Hong Kong. Fertil Steril 78(2):426–428. 10.1016/s0015-0282(02)03232-6.12137888
Christensen H, Krogh M, Nielsen M. 1937. Acute mercury poisoning in a respiration chamber. Nature 139(3519):626–627. 10.1038/139626b0.
Christie NT, Cantoni O, Evans RM, . 1984. Use of mammalian DNA repair-deficient mutants to assess the effects of toxic metal compounds on DNA. Biochem Pharmacol 33(10):1661–1670. 10.1016/0006-2952(84)90289-2.6233980
Christie NT, Cantoni O, Sugiyama M, . 1986. Differences in the effects of Hg(II) on DNA repair induced in Chinese hamster ovary cells by ultraviolet or X-rays. Mol Pharmacol 29(2):173–178.3951430
Chung SH, Myong JP. 2016. Are higher blood mercury levels associated with dry eye symptoms in adult Koreans? A population-based cross-sectional study. BMJ Open 6(4):e010985. 10.1136/bmjopen-2015-010985.
Chung SM, Moon JS, Yoon JS, . 2020. The sex-specific effects of blood lead, mercury, and cadmium levels on hepatic steatosis and fibrosis: Korean nationwide cross-sectional study. J Trace Elem Med Biol 62:126601. 10.1016/j.jtemb.2020.126601.32634767
Chung JW, Acharya D, Singh JK, . 2023. Association of blood mercury level with liver enzymes in Korean adults: An analysis of 2015-2017 Korean National Environmental Health Survey. Int J Environ Res Public Health 20(4):3290. 10.3390/ijerph20043290.36833981
Chuu JJ, Hsu CJ, Lin-Shiau SY. 2001a. Abnormal auditory brainstem responses for mice treated with mercurial compounds: Involvement of excessive nitric oxide. Toxicology 162(1):11–22. 10.1016/s0300-483x(01)00348-1.11311454
Chuu JJ, Young YH, Liu SH, . 2001b. Neurotoxicity of mercury sulfide in the vestibular ocular reflex system of guinea pigs. Naunyn Schmiedebergs Arch Pharmacol 364(3):249–258. 10.1007/s002100000279.11521168
Chuu JJ, Liu SH, Lin-Shiau SY. 2007. Differential neurotoxic effects of methylmercury and mercuric sulfide in rats. Toxicol Lett 169(2):109–120. 10.1016/j.toxlet.2006.12.006.17292570
Clarkson TW. 1971. Epidemiological and experimental aspects of lead and mercury contamination of food. Food Cosmet Toxicol 9(2):229–243. 10.1016/0015-6264(71)90308-7.4997818
Clarkson TW. 1989. Mercury. J Am Coll Toxicol 8(7):1291–1295.
Clarkson TW. 1993. Molecular and ionic mimicry of toxic metals. Annu Rev Pharmacol Toxicol 32:545–571.
Clarkson TW. 2006. The three modern faces of mercury. Birth Defects Res A Clin Mol Teratol 76(5):359.
Clarkson T, Rothstein A. 1964. The excretion of volatile mercury by rats injected with mercuric salts. Health Phys 10:1115–1121. 10.1097/00004032-196412000-00032.14244758
Clarkson TW, Shapiro RE. 1971. The absorption of mercury from food, its significance and new methods of removing mercury from the body. In: Proceedings of special symposium on mercury in man’s environment. Ottawa, Canada: The Royal Society of Canada, 124–130.
Clarkson TW, Magos L. 2006. The toxicology of mercury and its chemical compounds. Crit Rev Toxicol 36(8):609–662. 10.1080/10408440600845619.16973445
Clarkson TW, Magos L, Greenwood MR. 1972. The transport of elemental mercury into fetal tissues. Neonatology 21(3–4):239–244. 10.1159/000240512.
Clarkson TW, Amin-Zaki L, Al-Tikriti SK. 1976. An outbreak of methylmercury poisoning due to consumption of contaminated grain. Fed Proc 35(12):2395–2399.964390
Clarkson TW, Friberg L, Hursh JB, . 1988. The prediction of intake of mercury vapor from amalgams. In: Biological monitoring of toxic metals. New York, NY: Plenum Press, 247–264.
Clarkson TW, Magos L, Myers GJ. 2003. The toxicology of mercury--current exposures and clinical manifestations. N Engl J Med 349(18):1731–1737. 10.1056/NEJMra022471.14585942
Clarkson TW, Vyas JB, Ballatori N. 2007. Mechanisms of mercury disposition in the body. Am J Ind Med 50(10):757–764. 10.1002/ajim.20476.17477364
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Clewell HJ, Gearhart JM, Gentry PR, . 1999. Evaluation of the uncertainty in an oral reference dose for methylmercury due to interindividual variability in pharmacokinetics. Risk Anal 19(4):547–558.10765421
Cocking D, King ML, Ritchie L, . 1994. Earthworm bioaccumulation of mercury from contaminated flood plain soils. In: Watras CJ, Huckabee JW, eds. Mercury pollution integration and synthesis. Boca Raton, FL: Lewis Publishers, 381–394.
Cohen JT, Bellinger DC, Shaywitz BA. 2005. A quantitative analysis of prenatal methyl mercury exposure and cognitive development. Am J Prev Med 29(4):353–365. 10.1016/j.amepre.2005.06.007.16242602
Cohen MD, Draxler RR, Artz RS, . 2016. Modeling the global atmospheric transport and deposition of mercury to the Great Lakes. Elementa 4:000118. 10.12952/journal.elementa.000118.
Cole DC, Wainman B, Sanin LH, . 2006. Environmental contaminant levels and fecundability among non-smoking couples. Reprod Toxicol 22(1):13–19. 10.1016/j.reprotox.2005.12.001.16439098
Colon-Rodriguez A, Hannon HE, Atchison WD. 2017. Effects of methylmercury on spinal cord afferents and efferents. A review. Neurotoxicology 60:308–320. 10.1016/j.neuro.2016.12.007.28041893
Coluccia A, Borracci P, Giustino A, . 2007. Effects of low dose methylmercury administration during the postnatal brain growth spurt in rats. Neurotoxicol Teratol 29(2):282–287. 10.1016/j.ntt.2006.10.005.17141469
Copan L, Fowles J, Barreau T, . 2015. Mercury toxicity and contamination of households from the use of skin creams adulterated with mercurous chloride (calomel). Int J Environ Res Public Health 12(9):10943–10954. 10.3390/ijerph120910943.26364641
Cope WG, Wiener JG, Rada RG. 1990. Mercury accumulation in yellow perch in Wisconsin seepage lakes: Relation to lake characteristics. Environ Toxicol Chem 9(7):931–940. 10.1002/etc.5620090711.
Cordier S, Deplan F, Mandereau L, . 1991. Paternal exposure to mercury and spontaneous abortions. Br J Ind Med 48(6):375–381. 10.1136/oem.48.6.375.2064975
Cordier S, Garel M, Mandereau L, . 2002. Neurodevelopmental investigations among methylmercury-exposed children in French Guiana. Environ Res 89(1):1–11. 10.1006/enrs.2002.4349.12051779
Cordier S, Anassour-Laouan-Sidi E, Lemire M, . 2020. Association between exposure to persistent organic pollutants and mercury, and glucose metabolism in two Canadian Indigenous populations. Environ Res 184:109345. 10.1016/j.envres.2020.109345.32172074
Corrêa MG, Bittencourt LO, Nascimento PC, . 2020. Spinal cord neurodegeneration after inorganic mercury long-term exposure in adult rats: Ultrastructural, proteomic and biochemical damages associated with reduced neuronal density. Ecotoxicol Environ Saf 191:110159. 10.1016/j.ecoenv.2019.110159.31962214
Cortés-Gutiérrez EI, Cerda-Flores RM, Gonzalez-Ramirez D, . 2004. Evaluation of the mutagenic and cytotoxic effects of mercurous chloride by the micronuclei technique in golden Syrian hamsters. Mutagenesis 19(3):203–205.15123785
Cortes-Maramba N, Reyes JP, Francisco-Rivera AT, . 2006. Health and environmental assessment of mercury exposure in a gold mining community in Western Mindanao, Philippines. J Environ Manage 81(2):126–134. 10.1016/j.jenvman.2006.01.019.16905240
Cossa D, Gobeil C, Courau P. 1988. Dissolved mercury behaviour in the Saint Lawrence estuary. Estuarine Coastal Shelf Sci 26(2):227–230. 10.1016/0272-7714(88)90052-2.
Costa M, Christie NT, Cantoni O, . 1991. DNA damage by mercury compounds: An overview. In: Suzuki T, Imura N, Clarkson TW, eds. Advances in mercury toxicology. New York, NY: Plenum Press, 255–273.
Counter SA. 2003. Neurophysiological anomalies in brainstem responses of mercury-exposed children of Andean gold miners. J Occup Environ Med 45(1):87–95.12553183
Counter SA, Buchanan LH, Laurell G, . 1998. Blood mercury and auditory neuro-sensory responses in children and adults in the Nambija gold mining area of Ecuador. Neurotoxicology 19(2):185–196.9553955
Counter SA, Buchanan LH, Ortega F. 2006. Neurocognitive screening of mercury-exposed children of Andean gold miners. Int J Occup Environ Health 12(3):209–214. 10.1179/oeh.2006.12.3.209.16967826
Counter SA, Buchanan LH, Ortega F. 2012. Acoustic stapedius muscle reflex in mercury-exposed Andean children and adults. Acta Oto-Laryngologica 132(1):51–63. 10.3109/00016489.2011.617778.22175530
Counter SA, Buchanan LH, Ortega F, . 2002. Elevated blood mercury and neuro-otological observations in children of the Ecuadorian gold mines. J Toxicol Environ Health A 65(2):149–163. 10.1080/152873902753396785.11820503
Cox C, Clarkson TW, Marsh DO, . 1989. Dose-response analysis of infants prenatally exposed to methyl mercury: An application of a single compartment model to single-strand hair analysis. Environ Res 49(2):318–332.2473897
Cragle DL, Hollis DR, Qualters JR, . 1984. A mortality study of men exposed to elemental mercury. J Occup Med 26(11):817–821. 10.1097/00043764-198411000-00011.6502285
Creed JH, Peeri NC, Anic GM, . 2019. Methylmercury exposure, genetic variation in metabolic enzymes, and the risk of glioma. Sci Rep 9(1):10861. 10.1038/s41598-019-47284-4.31350461
Crespo-López ME, Lima de Sa A, Herculano AM, . 2007. Methylmercury genotoxicity: a novel effect in human cell lines of the central nervous system. Environ Int 33(2):141–146. 10.1016/j.envint.2006.08.005.17007929
Crespo-Lopez ME, Costa-Malaquias A, Oliveira EH, . 2016. Is low non-lethal concentration of methylmercury really safe? A report on genotoxicity with delayed cell proliferation. PLoS ONE 11(9):e0162822. 10.1371/journal.pone.0162822.27622704
CRITFC. 1994. A fish consumption survey of the Umatilla, Nez Perce, Yakima and Warm Springs tribes of the Columbia River Basin. Columbia River Inter-Tribal Fish Commission. 1–105. Technical Report 94-3.
Crowe W, Doherty L, Watson G, . 2015. Mercury in hair is inversely related to disease associated damage in systemic lupus erythematosus. Int J Environ Res Public Health 13(1):0075. 10.3390/ijerph13010075.
Crump K, Viren J, Silvers A, . 1995. Reanalysis of dose-response data from the Iraqi methylmercury poisoning episode. Risk Anal 15(4):523–532.7480952
Crump KS, Kjellstrom T, Shipp AM, . 1998. Influence of prenatal mercury exposure upon scholastic and psychological test performance: benchmark analysis of a New Zealand cohort. Risk Anal 18(6):701–713.9972579
Crump KS, Van Landingham C, Shamlaye C, . 2000. Benchmark concentrations for methylmercury obtained from the Seychelles Child Development Study. Environ Health Perspect 108(3):257–263.10706533
Culbreth M, Aschner M. 2016. Dysregulation of glutamate cycling mediates methylmercury-induced neurotoxicity. Adv Neurobiol 13:295–305. 10.1007/978-3-319-45096-4_11.27885634
Czuba M, Mortimer DC. 1980. Stability of methylmercury and inorganic mercury in aquatic plants (Elodea densa). Can J Bot 58(3):316–320.
da Cunha Martins A, Carneiro MFH, Grotto D, . 2018. Arsenic, cadmium, and mercury-induced hypertension: mechanisms and epidemiological findings. J Toxicol Environ Health B Crit Rev 21(2):61–82. 10.1080/10937404.2018.1432025.29446707
da Silva DCB, Bittencourt LO, Baia-da-Silva DC, . 2022. Methylmercury causes neurodegeneration and downregulation of myelin basic protein in the spinal cord of offspring rats after maternal exposure. Int J Mol Sci 23(7):3777. 10.3390/ijms23073777.35409136
Dack K, Wootton RE, Taylor CM, . 2023. Prenatal mercury exposure and infant weight trajectories in a UK observational birth cohort. Toxics 11(1):10. 10.3390/toxics11010010.
Dakeishi M, Nakai K, Sakamoto M, . 2005. Effects of hair treatment on hair mercury-The best biomarker of methylmercury exposure? Environ Health Prev Med 10(4):208–212. 10.1007/bf02897712.21432141
Dallaire R, Dewailly E, Ayotte P, . 2013. Exposure to organochlorines and mercury through fish and marine mammal consumption: associations with growth and duration of gestation among Inuit newborns. Environ Int 54:85–91. 10.1016/j.envint.2013.01.013.23422685
Daneshmand R, Kurl S, Tuomainen TP, . 2016. Associations of serum n-3 and n-6 PUFA and hair mercury with the risk of incident stroke in men: the Kuopio Ischaemic Heart Disease Risk Factor Study (KIHD). Br J Nutr 115(10):1851–1859. 10.1017/S0007114516000982.26991769
Daniel JW, Gage JC, Lefevre PA. 1972. The metabolism of phenylmercury by the rat. Biochem J 129(4):961–967. 10.1042/bj1290961.4655829
Daniels JL, Longnecker MP, Rowland AS, . 2004. Fish intake during pregnancy and early cognitive development of offspring. Epidemiology 15(4):394–402. 10.1097/01.ede.0000129514.46451.ce.15232398
Danielsson BR, Fredriksson A, Dahlgren L, . 1993. Behavioural effects of prenatal metallic mercury inhalation exposure in rats. Neurotoxicol Teratol 15(6):391–396. 10.1016/0892-0362(93)90056-t.8302240
Danscher G, Moller-Madsen B. 1985. Silver amplification of mercury sulfide and selenide: a histochemical method for light and electron microscopic localization of mercury in tissue. J Histochem Cytochem 33(3):219–228. 10.1177/33.3.2579122.2579122
Das RM, Ahmed MK, Oulton MR, . 1997. Methylmercury-induced alterations in lung and pulmonary surfactant properties of adult mice. Chem Phys Lipids 89(2):107–117. 10.1016/s0009-3084(97)00072-8.9369009
Dastoor A, Wilson SJ, Travnikov O, . 2022. Arctic atmospheric mercury: Sources and changes. Sci Total Environ 839:156213. 10.1016/j.scitotenv.2022.156213.35623517
Davidson PW, Meyers GJ, Cox C, . 1995. Longitudinal neurodevelopmental study of Seychellois children following in utero exposure to methylmercury from maternal fish ingestion: Outcomes at 19 and 29 months. Neurotoxicology 16(4):677–688.8714872
Davidson PW, Myers GJ, Cox C, . 1998. Effects of prenatal and postnatal methylmercury exposure from fish consumption on neurodevelopment: Outcomes at 66 months of age in the Seychelles Child Development Study. JAMA 280(8):701–707. 10.1001/jama.280.8.701.9728641
Davidson PW, Myer GJ, Shamlaye C, . 1999. Association between prenatal exposure to methylmercury and developmental outcomes in Seychellois children: effect modification by social and environmental factors. Neurotoxicology 20(5):833–841.10591519
Davidson PW, Myers GJ, Shamlaye C, . 2004. Prenatal exposure to methylmercury and child development: influence of social factors. Neurotoxicol Teratol 26(4):553–559. 10.1016/j.ntt.2004.03.007.15203177
Davidson PW, Myers GJ, Cox C, . 2006a. Methylmercury and neurodevelopment: Longitudinal analysis of the Seychelles child development cohort. Neurotoxicol Teratol 28(5):529–535. 10.1016/j.ntt.2006.06.002.16904865
Davidson PW, Myers GJ, Weiss B, . 2006b. Prenatal methyl mercury exposure from fish consumption and child development: a review of evidence and perspectives from the Seychelles Child Development Study. Neurotoxicology 27(6):1106–1109. 10.1016/j.neuro.2006.03.024.16687174
Davidson PW, Jean Sloane R, Myers GJ, . 2008a. Association between prenatal exposure to methylmercury and visuospatial ability at 10.7 years in the Seychelles Child Development Study. Neurotoxicology 29(3):453–459. 10.1016/j.neuro.2008.02.009.18400302
Davidson PW, Strain JJ, Myers GJ, . 2008b. Neurodevelopmental effects of maternal nutritional status and exposure to methylmercury from eating fish during pregnancy. Neurotoxicology 29(5):767–775. 10.1016/j.neuro.2008.06.001.18590763
Davidson PW, Leste A, Benstrong E, . 2010. Fish consumption, mercury exposure, and their associations with scholastic achievement in the Seychelles Child Development Study. Neurotoxicology 31(5):439–447. 10.1016/j.neuro.2010.05.010.20576509
Davidson PW, Cory-Slechta DA, Thurston SW, . 2011. Fish consumption and prenatal methylmercury exposure: cognitive and behavioral outcomes in the main cohort at 17 years from the Seychelles child development study. Neurotoxicology 32(6):711–717. 10.1016/j.neuro.2011.08.003.21889535
Davis LE. 2000. Unregulated potions still cause mercury poisoning. West J Med 173(1):19.
Davis BJ, Price HC, O’Connor RW, . 2001. Mercury vapor and female reproductive toxicity. Toxicol Sci 59(2):291–296. 10.1093/toxsci/59.2.291.11158722
Davis MA, Gilbert-Diamond D, Karagas MR, . 2014. A dietary-wide association study (DWAS) of environmental metal exposure in US children and adults. PLoS ONE 9(9):e104768. 10.1371/journal.pone.0104768.25198543
de Burbure C, Buchet JP, Leroyer A, . 2006. Renal and neurologic effects of cadmium, lead, mercury, and arsenic in children: evidence of early effects and multiple interactions at environmental exposure levels. Environ Health Perspect 114(4):584–590. 10.1289/ehp.8202.16581550
de Ceaurriz J, Payan JP, Morel G, . 1994. Role of extracellular glutathione and gamma-glutamyltranspeptidase in the disposition and kidney toxicity of inorganic mercury in rats. J Appl Toxicol 14(3):201–206.7916024
de Oliveira Lopes G, Aragão WAB, Bittencourt LO, . 2021. Imaging microstructural damage and alveolar bone loss in rats systemically exposed to methylmercury: first experimental evidence. Biol Trace Elem Res 199(10):3707–3717. 10.1007/s12011-020-02492-2.33409908
de Winter-Sorkina R, Bakker MI, van Donkersgoed G, . 2003. Dietary intake of heavy metals (cadmium, lead and mercury) by the Dutch population. Wageningen, Netherlands: Institute of Food Safety. 1–49. RIVM report 320103001. RIKILT-report 2003.016.
Dean JG, Bosqui FL, Lanouette KH. 1972. Removing heavy metals from waste water. Environ Sci Technol 6(6):518–522. 10.1021/es60065a006.
Debes F, Budtz-Jorgensen E, Weihe P, . 2006. Impact of prenatal methylmercury exposure on neurobehavioral function at age 14 years. Neurotoxicol Teratol 28(5):536–547. 10.1016/j.ntt.2006.02.005.17067778
Debes F, Weihe P, Grandjean P. 2016. Cognitive deficits at age 22 years associated with prenatal exposure to methylmercury. Cortex 74:358–369. 10.1016/j.cortex.2015.05.017.26109549
Decharat S, Phethuayluk P, Maneelok S, . 2014. Determination of mercury exposure among dental health workers in Nakhon Si Thammarat Province, Thailand. J Toxicol 2014:1–8. 10.1155/2014/401012.
Dencker L, Danielsson B, Khayat A, . 1983. Deposition of metals in the embryo and fetus. In: Clarkson TW, Nordberg GG, Sager PR, eds. Reproductive and developmental toxicity of metals. New York, NY: Plenum Press, 607–631.
Denkenberger JS, Fakhraei H, Branfireun B, . 2020. Watershed influences on mercury in tributaries to Lake Ontario. Ecotoxicology 29(10):1614–1626. 10.1007/s10646-019-02157-4.31925621
DeRouen TA, Martin MD, Leroux BG, . 2006. Neurobehavioral effects of dental amalgam in children: A randomized clinical trial. JAMA 295(15):1784–1792. 10.1001/jama.295.15.1784.16622140
Desai G, Niu Z, Luo W, . 2021. Low-level exposure to lead, mercury, arsenic, and cadmium, and blood pressure among 8-17-year-old participants of the 2009-2016 National Health and Nutrition Examination Survey. Environ Res 197:111086. 10.1016/j.envres.2021.111086.33781774
Desjardins RM, Bradbury WC, Seyfried PL. 1988. Effects of metals from mine tailings on the microflora of a marsh treatment system. In: Adams WJ, Chapman GA, Landis WG, eds. Aquatic toxicology and hazard assessment. Vol. 10^th^. Philadelphia, PA: American Society for Testing and Materials, 491–502.
Despres C, Beuter A, Richer F, . 2005. Neuromotor functions in Inuit preschool children exposed to Pb, PCBs, and Hg. Neurotoxicol Teratol 27(2):245–257. 10.1016/j.ntt.2004.12.001.15734276
DeVito SC, Brooks WE. 2013. Mercury. In: Kirk-Othmer encyclopedia of chemical technology. Hoboken, NJ: Wiley, 1–23.
Diamond GL. 1988. Biological monitoring of urine for exposure to toxic metals. In: Clarkson TW, Friberg L, Nordberg GF, ., eds. Biological monitoring of toxic metals. New York, NY: Plenum Press, 515–529.
Dick AL, Sheppard DS, Patterson JE. 1990. Mercury content of Antarctic surface snow: Initial results. Atmos Environ 24A(4):973–978. 10.1016/0960-1686(90)90299-3.
Dickerson EH, Sathyapalan T, Knight R, . 2011. Endocrine disruptor & nutritional effects of heavy metals in ovarian hyperstimulation. J Assist Reprod Genet 28(12):1223–1228. 10.1007/s10815-011-9652-3.22071884
Dieter MP, Luster MI, Boorman GA, . 1983. Immunological and biochemical responses in mice treated with mercuric chloride. Toxicol Appl Pharmacol 68(2):218–228. 10.1016/0041-008x(83)90006-6.6222515
Dieter MP, Boorman GA, Jameson CW, . 1992. Development of renal toxicity in F344 rats gavaged with mercuric chloride for 2 weeks, or 2, 4, 6, 15, and 24 months. J Toxicol Environ Health 36(4):319–340. 10.1080/15287399209531642.1354752
Dieter MP, Goehl TJ, Jameson CW, . 1993. Comparison of the toxicity of citral in F344 rats and B6C3F1 mice when administered by microencapsulation in feed or by corn-oil gavage. Food Chem Toxicol 31(7):463–474. 10.1016/0278-6915(93)90105-8.8340024
Dietrich MO, Mantese CE, Anjos GD, . 2005. Motor impairment induced by oral exposure to methylmercury in adult mice. Environ Toxicol Pharmacol 19(1):169–175. 10.1016/j.etap.2004.07.004.21783473
Ding G, Cui C, Chen L, . 2013. Prenatal low-level mercury exposure and neonatal anthropometry in rural northern China. Chemosphere 92(9):1085–1089. 10.1016/j.chemosphere.2013.01.045.23411084
Diringer SE, Feingold BJ, Ortiz EJ, . 2015. River transport of mercury from artisanal and small-scale gold mining and risks for dietary mercury exposure in Madre de Dios, Peru. Environ Sci Process Impacts 17(2):478–487. 10.1039/c4em00567h.25573610
Discalzi G, Fabbro D, Meliga F, . 1993. Effects of occupational exposure to mercury and lead on brainstem auditory evoked potentials. Int J Psychophysiol 14(1):21–25. 10.1016/0167-8760(93)90080-9.8432676
Dock L, Rissanen RL, Vahter M. 1994. Demethylation and placental transfer of methyl mercury in the pregnant hamster. Toxicology 94(1):131–142. 10.1016/0300-483X(94)90033-7.7801317
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 6, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
DOI. 1985. Mercury. Mineral facts and problems. Washington, DC: U.S. Department of the Interior. 499–508. Bureau of Mines Bulletin 675.
DOI. 1989. Mercury. In: Minerals yearbook. Washington, DC: U.S. Department of the Interior, 705–708.
DOI. 1990. Mercury. In: Minerals yearbook. Washington, DC: U.S. Department of the Interior, 743–747.
DOI. 1991. Mineral commodity summaries, 1991: Mercury. Washington, DC: Department of the Interior.
DOI. 1993. Mineral commodity summaries, 1993: Mercury. Washington, DC: U.S. Department of the Interior.
Dolar SG, Keeney DR, Chesters G. 1971. Mercury accumulation by Myriophyllum spicatum L. Environ Lett 1(3):191–198. 10.1080/00139307109434981.5162597
Dolbec J, Mergler D, Sousa Passos CJ, . 2000. Methylmercury exposure affects motor performance of a riverine population of the Tapajos river, Brazilian Amazon. Int Arch Occup Environ Health 73(3):195–203. 10.1007/s004200050027.10787135
Dolbec J, Mergler D, Larribe F, . 2001. Sequential analysis of hair mercury levels in relation to fish diet of an Amazonian population, Brazil. Sci Total Environ 271(1–3):87–97. 10.1016/s0048-9697(00)00835-4.11346043
Dong Z, Jim RC, Hatley EL, . 2015. A longitudinal study of mercury exposure associated with consumption of freshwater fish from a reservoir in rural south central USA. Environ Res 136:155–162. 10.1016/j.envres.2014.09.029.25460632
Donohue A, Wagner CL, Burch JB, . 2018. Blood total mercury and methylmercury among pregnant mothers in Charleston, South Carolina, USA. J Expo Sci Environ Epidemiol 28(5):494–504. 10.1038/s41370-018-0033-1.29670220
Dore FY, Goulet S, Gallagher A, . 2001. Neurobehavioral changes in mice treated with methylmercury at two different stages of fetal development. Neurotoxicol Teratol 23(5):463–472. 10.1016/s0892-0362(01)00167-2.11711249
Dorea JG, Marques RC, Isejima C. 2012. Neurodevelopment of Amazonian infants: antenatal and postnatal exposure to methyl- and ethylmercury. J Biomed Biotechnol 2012:1–9. 10.1155/2012/132876.21836813
Dorea JG, Marques RC, Abreu L. 2014. Milestone achievement and neurodevelopment of rural Amazonian toddlers (12 to 24 months) with different methylmercury and ethylmercury exposure. J Toxicol Environ Health A 77(1–3):1–13. 10.1080/15287394.2014.861335.24555642
dos Santos AA, Appel Hort M, Culbreth M, . 2016. Methylmercury and brain development: A review of recent literature. J Trace Elem Med Biol 38:99–107. 10.1016/j.jtemb.2016.03.001.26987277
dos Santos Freitas J, da Costa Brito Lacerda EM, da Silva Martins ICV, . 2018. Cross-sectional study to assess the association of color vision with mercury hair concentration in children from Brazilian Amazonian riverine communities. Neurotoxicology 65:60–67. 10.1016/j.neuro.2018.02.006.29428869
dos Santos-Lima C, Mourão DS, Carvalho CF, . 2020. Neuropsychological effects of mercury exposure in children and adolescents of the Amazon region, Brazil. Neurotoxicology 79:48–57. 10.1016/j.neuro.2020.04.004.32335201
dos Santos Chemelo V, Bittencourt LO, Aragão WAB, . 2021. Long-term exposure to inorganic mercury leads to oxidative stress in peripheral blood of adult rats. Biol Trace Elem Res 199(8):2992–3000. 10.1007/s12011-020-02411-5.32997227
Dou Y, Yin Y, Li Z, . 2022. Maternal exposure to metal mixtures during early pregnancy and fetal growth in the Jiangsu Birth Cohort, China. Environ Res 215(Pt 2):114305. 10.1016/j.envres.2022.114305.36096164
Downer MK, Martínez-González MA, Gea A, . 2017. Mercury exposure and risk of cardiovascular disease: a nested case-control study in the PREDIMED (PREvention with MEDiterranean Diet) study. BMC Cardiovasc Disord 17:9. 10.1186/s12872-016-0435-8.28056794
Drake HJ. 1981. Mercury. In: Mark HF, Othmer DF, Overberger CG, eds. Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley and Sons, Inc., 143–156.
Drexler JZ, Alpers CN, Neymark LA, . 2016. A millennial-scale record of Pb and Hg contamination in peatlands of the Sacramento-San Joaquin Delta of California, USA. Sci Total Environ 551–552:738–751. 10.1016/j.scitotenv.2016.01.201.
Druet P, Druet E, Potdevim F, . 1978. Immune type glomerulonephritis induced by HgCl_2_ in the Brown Norway rat. Ann Immunol 129(6):777–792.
Duan W, Xu C, Liu Q, . 2020. Levels of a mixture of heavy metals in blood and urine and all-cause, cardiovascular disease and cancer mortality: A population-based cohort study. Environ Pollut 263(Pt A):114630. 10.1016/j.envpol.2020.114630.33618481
Dunn JD, Clarkson TW, Magos L. 1978. Ethanol-increased exhalation of mercury in mice. Br J Ind Med 35(3):241–244. 10.1136/oem.35.3.241.698140
Dutczak WJ, Ballatori N. 1992. gamma-Glutamyltransferase-dependent biliary-hepatic recycling of methyl mercury in the guinea pig. J Pharmacol Exp Ther 262(2):619–623.1354255
Dutczak WJ, Ballatori N. 1994. Transport of the glutathione-methylmercury complex across liver canalicular membranes on reduced glutathione carriers. J Biol Chem 269(13):9746–9751.8144567
Dutczak WJ, Clarkson TW, Ballatori N. 1991. Biliary-hepatic recycling of a xenobiotic: Gallbladder absorption of methyl mercury. Am J Physiol 260(6 Pt 1):G873–880. 10.1152/ajpgi.1991.260.6.G873.2058675
Dvonch JT, Vette AF, Keeler GJ. 1995. An intensive multi-site pilot study investigating atmospheric mercury in Broward County, Florida. In: Porcella DB, Wheatley B, eds. Mercury as a global pollutant. Proceedings of the third International Conference Whistler, British Columbia, July 10-14, 1994. Boston, MA: Kluwer Academic Publishers, 169–178.
Dyall-Smith DJ, Scurry JP. 1990. Mercury pigmentation and high mercury levels from the use of a cosmetic cream. Med J Aust 153(7):409-410 to 414-405.2215312
Echeverria D, Aposhian HV, Woods JS, . 1998. Neurobehavioral effects from exposure to dental amalgam Hg^0^: new distinctions between recent exposure and Hg body burden. FASEB J 12(11):971–980. 10.1096/fasebj.12.11.971.9707169
Echeverria D, Woods JS, Heyer NJ, . 2005. Chronic low-level mercury exposure, BDNF polymorphism, and associations with cognitive and motor function. Neurotoxicol Teratol 27(6):781–796. 10.1016/j.ntt.2005.08.001.16301096
EFSA. 2012. Scientific Opinion on the risk for public health related to the presence of mercury and methylmercury in food. EFSA J 10(12):2985. 10.2903/j.efsa.2012.2985.
EFSA. 2014. Scientific Opinion on health benefits of seafood (fish and shellfish) consumption in relation to health risks associated with exposure to methylmercury. EFSA J 12(7):3761. 10.2903/j.efsa.2014.3761.
Egwunye J, Cardoso BR, Braat S, . 2023. The role of fingernail selenium in the association between arsenic, lead and mercury and child development in rural Vietnam: a cross-sectional analysis. Br J Nutr 129(9):1589–1597. 10.1017/s0007114522001374.35535482
Ehrenberg RL, Vogt RL, Smith AB, . 1991. Effects of elemental mercury exposure at a thermometer plant. Am J Ind Med 19(4):495–507.2035548
Ehrenstein C, Shu P, Wickenheiser EB, . 2002. Methyl mercury uptake and associations with the induction of chromosomal aberrations in Chinese hamster ovary (CHO) cells. Chem Biol Interact 141(3):259–274.12385723
Eichholz GG, Petelka MF, Kury RL. 1988. Migration of elemental mercury through soil from simulated burial sites. Water Res 22(1):15–20. 10.1016/0043-1354(88)90126-1.
Ekino S, Susa M, Ninomiya T, . 2007. Minamata disease revisited: an update on the acute and chronic manifestations of methyl mercury poisoning. J Neurol Sci 262(1–2):131–144. 10.1016/j.jns.2007.06.036.17681548
Ekstrand J, Nielsen JB, Havarinasab S, . 2010. Mercury toxicokinetics-dependency on strain and gender. Toxicol Appl Pharmacol 243(3):283–291. 10.1016/j.taap.2009.08.026.19732784
El-Badry A, Rezk M, El-Sayed H. 2018. Mercury-induced oxidative stress may adversely affect pregnancy outcome among dental staff: A cohort study. Int J Occup Environ Med 9(3):113–119. 10.15171/ijoem.2018.1181.29995016
Ellingsen DG, Holland RI, Thomassen Y, . 1993. Mercury and selenium in workers previously exposed to mercury vapour at a chloralkali plant. Br J Ind Med 50(8):745–752.8398862
Ellingsen DG, Efskind J, Berg KJ, . 2000a. Renal and immunologic markers for chloralkali workers with low exposure to mercury vapor. Scand J Work Environ Health 26(5):427–435. 10.5271/sjweh.564.11103842
Ellingsen DG, Efskind J, Haug E, . 2000b. Effects of low mercury vapour exposure on the thyroid function in chloralkali workers. J Appl Toxicol 20(6):483–489. 10.1002/1099-1263(200011/12)20:6<483::aid-jat722>3.0.co;2-i.11180271
Ellingsen DG, Bast-Pettersen R, Efskind J, . 2001. Neuropsychological effects of low mercury vapor exposure in chloralkali workers. Neurotoxicology 22(2):249–258. 10.1016/s0161-813x(01)00012-2.11405256
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
El-Sherbeeny AM, Odom JV, Smith JE. 2006. Visual system manifestations due to systemic exposure to mercury. Cutan Ocul Toxicol 25(3):173–183. 10.1080/15569520600860215.16980243
Elsner J. 1991. Tactile-kinesthetic system of rats as an animal model for minimal brain dysfunction. Arch Toxicol 65(6):465–473. 10.1007/BF01977358.1929866
Emeny RT, Korrick SA, Li Z, . 2019. Prenatal exposure to mercury in relation to infant infections and respiratory symptoms in the New Hampshire Birth Cohort Study. Environ Res 171:523–529. 10.1016/j.envres.2019.01.026.30743244
Endo T, Nakaya S, Kimura R, . 1984. Gastrointestinal absorption of inorganic mercuric compounds in vivo and in situ. Toxicol Appl Pharmacol 74(2):223–229.6234682
Endo T, Nakaya S, Kimura R, . 1986. Gastrointestinal absorption of inorganic mercuric compounds in vitro. Toxicol Appl Pharmacol 83(2):187–196.3961808
Endo T, Nakaya S, Kimura R. 1990. Mechanisms of absorption of inorganic mercury from rat small intestine. III. Comparative absorption studies of inorganic mercuric compounds in vitro. Pharmacol Toxicol 66(5):347–353.2371240
Endo T, Nakaya S, Kimura R. 1991. Mechanisms of absorption of inorganic mercury from rat small intestine. IV: Effect of chelating agents and cysteine on absorption of mercuric chloride in situ and in vitro. Pharmacol Toxicol 68(3):171–176.2057447
Engqvist A, Colmsjo A, Skare I. 1998. Speciation of mercury excreted in feces from individuals with amalgam fillings. Arch Environ Health 53(3):205–213. 10.1080/00039899809605697.9814717
Engstrom K, Love TM, Watson GE, . 2016. Polymorphisms in ATP-binding cassette transporters associated with maternal methylmercury disposition and infant neurodevelopment in mother-infant pairs in the Seychelles Child Development Study. Environ Int 94:224–229. 10.1016/j.envint.2016.05.027.27262785
Eom SY, Choi SH, Ahn SJ, . 2014. Reference levels of blood mercury and association with metabolic syndrome in Korean adults. Int Arch Occup Environ Health 87(5):501–513. 10.1007/s00420-013-0891-8.23824410
EPA. 1971. Water quality criteria data book. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1975a. Emission standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61.52.
EPA. 1975b. National emission standards for hazardous air pollutants, emissions standard. U.S. Environmental Protection Agency. Fed Regist 40:48302.
EPA. 1979. Water related environmental fate of 129 priority pollutants, introduction and technical background, metals and inorganics, pesticides and PCBs. Washington, DC: U.S. Environmental Protection Agency. EPA440479029a.
EPA. 1984. Pesticide assessment guidelines: Subdivision F. Hazard evaluation: human and domestic animals. Washington, DC: U.S. Environmental Protection Agency. EPA540984014. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=910129CT.txt. March 15, 2021.
EPA. 1985. Drinking water criteria document for mercury. Washington, DC: U.S. Environmental Protection Agency. EPA600X841781. PB86117827.
EPA. 1992. National study of chemical residues in fish. Volume I. Washington, DC: U.S. Environmental Protection Agency. EPA823R92008a.
EPA. 1998. Hazard standard risk analysis - TSCA section 403: Risk analysis to support standards for lead in paint, dust, and soil. Washington, DC: U.S. Environmental Protection Agency. EPA747R97006. https://www.epa.gov/lead/hazard-standard-risk-analysis-tsca-section-403. January 15, 2021.
EPA. 1999a. Method IO-5: Sampling and analysis for vapor and particle phase mercury in ambient air utilizing cold vapor atomic fluorescence spectrometry (CVAFS). Compendium of methods for the determination of inorganic compounds in ambient air. Cincinnati, OH: U.S. Environmental Protection Agency. EPA625R96010a. https://www.epa.gov/sites/production/files/2015-07/documents/epa-io-5.pdf. January 15, 2021.
EPA. 1999b. National survey of mercury concentrations in fish data base summary 1990-1995. Washington, DC: U.S. Environmental Protection Agency. EPA823R99014.
EPA. 2002a. Method 1631, Revision E: Mercury in water by oxidation, purge and trap, and cold vapor atomic fluorescence spectrometry. Washington, DC: U.S. Environmental Protection Agency. EPA821R02019. https://www.epa.gov/sites/production/files/2015-08/documents/method_1631e_2002.pdf. December 16, 2020.
EPA. 2002b. Task force on ritualistic use of mercury report. Washington, DC: U.S. Environmental Protection Agency. EPA540R01005. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=90100I00.txt. June 24, 2024.
EPA. 2006. Report: EPA is properly addressing the risks of using mercury in rituals. Washington, DC: U.S. Environmental Protection Agency. EPA2006P00031. https://www.epaoig.gov/report-epa-properly-addressing-risks-using-mercury-rituals. June 24, 2024.
EPA. 2008. Regulatory impact analysis of the proposed revisions to the National Ambient Air Quality Standards. U.S. Environmental Protection Agency.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F09004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. August 2, 2019.
EPA. 2011. Exposure factors handbook: 2011 edition. Washington, DC: U.S. Environmental Protection Agency. EPA600R09052F.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018c. About acute exposure guideline levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2019. Air quality system (AQS) data. U.S. Environmental Protection Agency. https://www.epa.gov/aqs/obtaining-aqs-data. December 18, 2020.
EPA. 2020a. Introduction to the 2018 TRI National Analysis. U.S. Environmental Protection Agency. https://www.epa.gov/trinationalanalysis/introduction-2018-tri-national-analysis. December 18, 2020.
EPA. 2020b. Inventory of mercury supply, use, and trade in the United States 2020 report. U.S. Environmental Protection Agency.
EPA. 2021a. CompTox data: Mercuric (II) acetate. U.S. Environmental Protection Agency. https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID4042123#details. May 17, 2021.
EPA. 2021b. CompTox data: Methylmercuric chloride. U.S. Environmental Protection Agency. https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID5020813. May 17, 2021.
EPA. 2021c. CompTox data: Dimethyl mercury. U.S. Environmental Protection Agency. https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID5047742. May 17, 2021.
EPA. 2021d. CompTox data: Phenylmercuric acetate. U.S. Environmental Protection Agency. https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID7021150. May 17, 2021.
EPA. 2021e. CompTox data: Methyl mercury. U.S. Environmental Protection Agency. https://comptox.epa.gov/dashboard/dsstoxdb/results?search=methyl%20mercury. May 17, 2021.
EPA. 2022. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2023. Inventory of mercury supply, use, and trade in the United States 2023 report. U.S. Environmental Protection Agency. https://www.epa.gov/chemicals-under-tsca/epa-publishes-2023-mercury-inventory-report. April 4, 2024.
EPA. 2024. Annual summary data: Mercury. Air quality system (AQS): Concentration by monitor. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. April 4, 2024.
Erfurth EM, Schutz A, Nilsson A, . 1990. Normal pituitary hormone response to thyrotrophin and gonadotrophin releasing hormones in subjects exposed to elemental mercury vapour. Occup Environ Med 47(9):639–644. 10.1136/oem.47.9.639.
Espinoza EO, Mann MJ, Bleasdell B. 1995. Arsenic and mercury in traditional Chinese herbal balls. N Engl J Med 333(12):803–804. 10.1056/nejm199509213331217.
Espinoza EO, Mann M-J, Bleasdell B, . 1996. Toxic metals in selected traditional Chinese medicinals. J Forensic Sci 41(3):453–456. 10.1520/jfs13934j.
Ethier AA, Muckle G, Bastien C, . 2012. Effects of environmental contaminant exposure on visual brain development: A prospective electrophysiological study in school-aged children. Neurotoxicology 33(5):1075–1085. 10.1016/j.neuro.2012.05.010.22683800
Eti S, Weisman R, Hoffman R, . 1995. Slight renal effect of mercury from amalgam fillings. Pharmacol Toxicol 76(1):47–49. 10.1111/j.1600-0773.1995.tb00101.x.7753757
Eto K, Yasutake A, Kuwana T, . 2001. Methylmercury poisoning in common marmosets-a study of selective vulnerability within the cerebral cortex. Toxicol Pathol 29(5):565–573. 10.1080/019262301317226375.11695574
Eto K, Tokunaga H, Nagashima K, . 2002. An autopsy case of Minamata disease (methylmercury poisoning)-pathological viewpoints of peripheral nerves. Toxicol Pathol 30(6):714–722. 10.1080/01926230290166805.12512873
Evans MS, Noguchi GE, Rice CP. 1991. The biomagnification of polychlorinated biphenyls, toxaphene, and DDT compounds in a Lake Michigan offshore food web. Arch Environ Contam Toxicol 20(1):87–93. 10.1007/bf01065333.1899993
Facemire CF, Gross TS, Guillette LJ. 1995. Reproductive impairment in the Florida panther: nature or nurture? Environ Health Perspect 103(Suppl 4):79–86.
Factor-Litvak P, Hasselgren G, Jacobs D, . 2003. Mercury derived from dental amalgams and neuropsychologic function. Environ Health Perspect 111(5):719–723. 10.1289/ehp.5879.12727600
Fagundes BHF, Nascimento PC, Aragão WAB, . 2022. Methylmercury exposure during prenatal and postnatal neurodevelopment promotes oxidative stress associated with motor and cognitive damages in rats: an environmental-experimental toxicology study. Toxicol Rep 9:563–574. 10.1016/j.toxrep.2022.02.014.35392159
Fairey R, Taberski K, Lamerdin S, . 1997. Organochlorines and other environmental contaminants in muscle tissues of sportfish collected from San Francisco Bay. Mar Pollut Bull 34(12):1058–1071. 10.1016/s0025-326x(97)00084-2.
Fan Y, Zhang C, Bu J. 2017. Relationship between selected serum metallic elements and obesity in children and adolescent in the U.S. Nutrients 9(2):104. 10.3390/nu9020104.28165362
Farías P, Hernández-Bonilla D, Moreno-Macías H, . 2022. Prenatal co-exposure to manganese, mercury, and lead, and neurodevelopment in children during the first year of life. Int J Environ Res Public Health 19(20):13020. 10.3390/ijerph192013020.36293596
Farina M, Aschner M. 2017. Methylmercury-induced neurotoxicity: Focus on pro-oxidative events and related consequences. Adv Neurobiol 18:267–286. 10.1007/978-3-319-60189-2_13.28889272
Farris FF, Dedrick RL, Allen PV, . 1993. Physiological model for the pharmacokinetics of methyl mercury in the growing rat. Toxicol Appl Pharmacol 119(1):74–90. 10.1006/taap.1993.1046.8470126
Farris FF, Kaushal A, Strom JG. 2008. Inorganic mercury pharmacokinetics in man: A two-compartment model. Toxicol Environ Chem 90(3):519–533. 10.1080/02772240701602736.
Farzan SF, Howe CG, Chen Y, . 2021. Prenatal and postnatal mercury exposure and blood pressure in childhood. Environ Int 146:106201. 10.1016/j.envint.2020.106201.33129000
Fawer RF, de Ribaupierre Y, Guillemin MP, . 1983. Measurement of hand tremor induced by industrial exposure to metallic mercury. Br J Ind Med 40(2):204–208. 10.1136/oem.40.2.204.6830719
FDA. 2017a. Total diet study: Elements results summary statistics. Market baskets 2006 through 2013. U.S. Food and Drug Administration. https://www.fda.gov/media/77948/download. December 14, 2020.
FDA. 2017b. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.gpo.gov/fdsys/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
FDA. 2018a. CPG sec 578.400 Treated grain seed - mercury residue. U.S. Food and Drug Administration. https://www.fda.gov/regulatory-information/search-fda-guidance-documents/cpg-sec-578400-treated-grain-seed-mercury-residue. November 18, 2020.
FDA. 2018b. CPG sec. 540.600 Fish, shellfish, crustaceans and other aquatic animals - fresh, frozen or processed - methyl mercury. U.S. Food and Drug Administration. https://www.fda.gov/regulatory-information/search-fda-guidance-documents/cpg-sec-540600-fish-shellfish-crustaceans-and-other-aquatic-animals-fresh-frozen-or-processed-methyl. November 18, 2020.
FDA. 2022. Total diet study report: Fiscal years 2018-2020 elements data. U.S. Food and Drug Administration. https://www.fda.gov/food/fda-total-diet-study-tds/fda-total-diet-study-tds-results. April 4, 2024.
FDA. 2023. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. March 14, 2023.
Fehling C, Abdulla M, Brun A, . 1975. Methylmercury poisoning in the rat: a combined neurological, chemical, and histopathological study. Toxicol Appl Pharmacol 33(1):27–37. 10.1016/0041-008x(75)90240-9.169608
Feitosa-Santana C, Bimler DL, Paramei GV, . 2010. Color-space distortions following long-term occupational exposure to mercury vapor. Ophthalmic Physiol Opt 30(5):724–730. 10.1111/j.1475-1313.2010.00764.x.20883360
Feitosa-Santana C, Souza GDS, Sirius EVP, . 2018. Color vision impairment with low-level methylmercury exposure of an Amazonian population - Brazil. Neurotoxicology 66:179–184. 10.1016/j.neuro.2018.01.010.29432854
Feng W, Wang M, Li B, . 2004. Mercury and trace element distribution in organic tissues and regional brain of fetal rat after in utero and weaning exposure to low dose of inorganic mercury. Toxicol Lett 152(3):223–234. 10.1016/j.toxlet.2004.05.001.15331131
Feng L, Zhang C, Liu H, . 2020. Impact of low-level mercury exposure on intelligence quotient in children via rice consumption. Ecotoxicol Environ Saf 202:110870. 10.1016/j.ecoenv.2020.110870.32593806
Ferguson KK, Chin HB. 2017. Environmental chemicals and preterm birth: Biological mechanisms and the state of the science. Curr Epidemiol Rep 4(1):56–71. 10.1007/s40471-017-0099-7.28944158
Ferreira FF, Ammar D, Bourckhardt GF, . 2015. MeHg developing exposure causes DNA double-strand breaks and elicits cell cycle arrest in spinal cord cells. J Toxicol 2015:1–10. 10.1155/2015/532691.
Fiedler N, Udasin I, Gochfeld M, . 1999. Neuropsychological and stress evaluation of a residential mercury exposure. Environ Health Perspect 107(5):343–347.10210689
Fillion M, Mergler D, Sousa Passos CJ, . 2006. A preliminary study of mercury exposure and blood pressure in the Brazilian Amazon. Environ Health 5:29. 10.1186/1476-069x-5-29.17032453
Fischer C, Fredriksson A, Eriksson P. 2008. Coexposure of neonatal mice to a flame retardant PBDE 99 (2,2′,4,4′,5-pentabromodiphenyl ether) and methyl mercury enhances developmental neurotoxic defects. Toxicol Sci 101(2):275–285. 10.1093/toxsci/kfm271.17982161
Fiskesjo G. 1979. Two organic mercury compounds tested for mutagenicity in mammalian cells by use of the cell line V 79-4. Hereditas 90(1):103–109.422393
Fitzgerald WF, Mason RP, Vandal GM. 1991. Atmospheric cycling and air-water exchange of mercury over mid-continental lacustrine regions. Water Air Soil Pollut 56(1):745–767. 10.1007/bf00342314.
Fonfria E, Rodriguez-Farre E, Sunol C. 2001. Mercury interaction with the GABA(A) receptor modulates the benzodiazepine binding site in primary cultures of mouse cerebellar granule cells. Neuropharmacology 41(7):819–833.11684146
Forbes GB, Bruining GJ. 1976. Urinary creatinine excretion and lean body mass. Am J Clin Nutr 29(12):1359–1366. 10.1093/ajcn/29.12.1359.998546
Fossato da Silva DA, Teixeira CT, Scarano WR, . 2011. Effects of methylmercury on male reproductive functions in Wistar rats. Reprod Toxicol 31(4):431–439. 10.1016/j.reprotox.2011.01.002.21262343
Fossato da Silva DA, Barbosa F, Scarano WR. 2012. Oral exposure to methylmercury modifies the prostatic microenvironment in adult rats. Int J Exp Pathol 93(5):354–360. 10.1111/j.1365-2613.2012.00825.x.22974216
Foster P, Gray LE. 2008. Toxic responses of the reproductive system. In: Klaassen CD, ed. Casarett and Doull’s toxicology: The basic science of poisons. New York, NY: The McGraw-Hill Companies, Inc, 761–806.
Foulkes EC. 1993. Metallothionein and glutathione as determinants of cellular retention and extrusion of cadmium and mercury. Life Sci 52(20):1617–1620. 10.1016/0024-3205(93)90042-2.8483390
Foulkes EC, Bergman D. 1993. Inorganic mercury absorption in mature and immature rat jejunum: Transcellular and intercellular pathways in vivo and in everted sacs. Toxicol Appl Pharmacol 120(1):89–95. 10.1006/taap.1993.1090.8511785
Fournie GJ, Saoudi A, Druet P, . 2002. Th2-type immunopathological manifestations induced by mercury chloride or gold salts in the rat: signal transduction pathways, cellular mechanisms and genetic control. Autoimmun Rev 1(4):205–212.12848997
Fowler SW. 1990. Critical review of selected heavy metal and chlorinated hydrocarbon concentrations in the marine environment. Mar Environ Res 29(1):1–64. 10.1016/0141-1136(90)90027-l.
Fox B, Walsh CT. 1982. Mercuric reductase. Purification and characterization of a transposon-encoded flavoprotein containing an oxidation-reduction-active disulfide. J Biol Chem 257(5):2498–2503.6277900
Franco JL, Teixeira A, Meotti FC, . 2006. Cerebellar thiol status and motor deficit after lactational exposure to methylmercury. Environ Res 102(1):22–28. 10.1016/j.envres.2006.02.003.16564521
Franko A, Budihna MV, Dodic-Fikfak M. 2005. Long-term effects of elemental mercury on renal function in miners of the Idrija Mercury Mine. Ann Occup Hyg 49(6):521–527. 10.1093/annhyg/mei022.15964879
Franzblau A, d’Arcy H, Ishak MB, . 2012. Low-level mercury exposure and peripheral nerve function. Neurotoxicology 33(3):299–306. 10.1016/j.neuro.2012.02.009.22370089
Fredriksson A, Dahlgren L, Danielsson B, . 1992. Behavioural effects of neonatal metallic mercury exposure in rats. Toxicology 74(2–3):151–160. 10.1016/0300-483x(92)90135-2.1519238
Fredriksson A, Dencker L, Archer T, . 1996. Prenatal coexposure to metallic mercury vapour and methylmercury produce interactive behavioural changes in adult rats. Neurotoxicol Teratol 18(2):129–134. 10.1016/0892-0362(95)02059-4.8709923
Freire C, Ramos R, Lopez-Espinosa MJ, . 2010. Hair mercury levels, fish consumption, and cognitive development in preschool children from Granada, Spain. Environ Res 110(1):96–104. 10.1016/j.envres.2009.10.005.19909946
Freire MAM, Lima RR, Nascimento PC, . 2020. Effects of methylmercury on the pattern of NADPH diaphorase expression and astrocytic activation in the rat. Ecotoxicol Environ Saf 201:110799. 10.1016/j.ecoenv.2020.110799.32544743
Frentiu T, Pintican BP, Butaciu S, . 2013. Determination, speciation and distribution of mercury in soil in the surroundings of a former chlor-alkali plant: assessment of sequential extraction procedure and analytical technique. Chem Cent J 7(1):178. 10.1186/1752-153x-7-178.24252185
Frenzilli G, Bosco E, Barale R. 2000. Validation of single cell gel assay in human leukocytes with 18 reference compounds. Mutat Res 468(2):93–108.10882888
Fretham SJ, Caito S, Martinez-Finley EJ, . 2012. Mechanisms and modifiers of methylmercury-induced neurotoxicity. Toxicol Res 1(1):32–38. 10.1039/c2tx20010d.
Friberg L, Nordberg F. 1973. Inorganic mercury-a toxicological and epidemiological appraisal. In: Miller MW, Clarkson TW, eds. Mercury, mercurials and mercaptans. Springfield, IL: Charles C. Thomas, 5–22.
Friberg L, Skog E, Wahlberg JE. 1961. Resorption of mercuric chloride and methyl mercury dicyandiamide in guinea-pigs through normal skin and through skin pretreated with acetone, alkylaryl-sulphonate and soap. Acta Derm Venereol 41:40–52.13701881
Friedmann AS, Chen H, Rabuck LD, . 1998. Accumulation of dietary methylmercury in the testes of the adult Brown Norway rat: Impaired testicular and epididymal function. Environ Toxicol Chem 17(5):867–871.
Fruh V, Rifas-Shiman SL, Coull BA, . 2021. Prenatal exposure to a mixture of elements and neurobehavioral outcomes in mid-childhood: Results from Project Viva. Environ Res 201:111540. 10.1016/j.envres.2021.111540.34166661
Frumkin H, Letz R, Williams PL, . 2001. Health effects of long-term mercury exposure among chloralkali plant workers. Am J Ind Med 39(1):1–18. 10.1002/1097-0274(200101)39:1<1::aid-ajim1>3.0.co;2-n.11148011
Fujimura M, Usuki F. 2014. Low in situ expression of antioxidative enzymes in rat cerebellar granular cells susceptible to methylmercury. Arch Toxicol 88(1):109–113. 10.1007/s00204-013-1089-2.23832298
Fujimura M, Usuki F, Sawada M, . 2009. Methylmercury induces neuropathological changes with tau hyperphosphorylation mainly through the activation of the c-jun-N-terminal kinase pathway in the cerebral cortex, but not in the hippocampus of the mouse brain. Neurotoxicology 30(6):1000–1007. 10.1016/j.neuro.2009.08.001.19666049
Fujimura M, Cheng J, Zhao W. 2012. Perinatal exposure to low-dose methylmercury induces dysfunction of motor coordination with decreases in synaptophysin expression in the cerebellar granule cells of rats. Brain Res 1464:1–7. 10.1016/j.brainres.2012.05.012.22587888
Fujita M, Takabatake E. 1977. Mercury levels in human maternal and neonatal blood, hair and milk. Bull Environ Contam Toxicol 18(2):205–209. 10.1007/bf01686068.890156
Fukuda K. 1971. Metallic mercury induced tremor in rabbits and mercury content of the central nervous system. Br J Ind Med 28(3):308–311. 10.1136/oem.28.3.308.5557852
Futatsuka M, Kitano T, Nagano M, . 1992. An epidemiological study with risk analysis of liver diseases in the general population living in a methyl mercury polluted area. J Epidemiol Community Health 46(3):237–240.1645078
Futatsuka M, Kitano T, Shono M, . 2000. Health surveillance in the population living in a methyl mercury-polluted area over a long period. Environ Res 83(2):83–92. 10.1006/enrs.1999.4014.10856180
Futatsuka M, Kitano T, Shono M, . 2005. Long-term follow-up study of health status in population living in methylmercury-polluted area. Environ Sci 12(5):239–282.16308560
Fuyuta M, Fujimoto T, Hirata S. 1978. Embryotoxic effects of methylmercuric chloride administered to mice and rats during organogenesis. Teratology 18(3):353–365. 10.1002/tera.1420180310.741388
Fuyuta M, Fujimoto T, Kiyofuji E. 1979. Teratogenic effects of a single oral administration of methylmercuric chloride in mice. Acta Anat (Basel) 104(3):356–362. 10.1159/000145084.484200
Gale TF. 1974. Embryopathic effects of different routes of administration of mercuric acetate in the hamster. Environ Res 8(2):207–213. 10.1016/0013-9351(74)90052-8.4455507
Galic N, Prpic-Mehiic G, Prester LJ, . 2001. Elimination of mercury from amalgam in rats. J Trace Elem Med Biol 15(1):1–4.11603820
Galiciolli MEA, Pedroso TF, Mesquita M, . 2022. Biochemical parameters of female Wistar rats and their offspring exposed to inorganic mercury in drinking water during the gestational and lactational periods. Toxics 10(11):664. 10.3390/toxics10110664.36355955
Gallagher CM, Meliker JR. 2012. Mercury and thyroid autoantibodies in U.S. women, NHANES 2007-2008. Environ Int 40:39–43. 10.1016/j.envint.2011.11.014.22280926
Gallagher CM, McElroy AE, Smith DM, . 2013. Polychlorinated biphenyls, mercury, and antinuclear antibody positivity, NHANES 2003-2004. Int J Hyg Environ Health 216(6):721–727. 10.1016/j.ijheh.2013.01.004.23419585
Gandhi DN, Panchal GM, Dhull DK. 2013. Influence of gestational exposure on the effects of prenatal exposure to methyl mercury on postnatal development in rats. Cent Eur J Public Health 21(1):30–35. 10.21101/cejph.a3773.23741897
Gao ZY, Li MM, Wang J, . 2018. Blood mercury concentration, fish consumption and anthropometry in Chinese children: A national study. Environ Int 110:14–21. 10.1016/j.envint.2017.08.016.29113684
Gao W, Tong L, Zhao S, . 2022. Exposure to Cadmium, lead, mercury, and arsenic and uric acid levels: Results from NHANES 2007-2016. Biol Trace Elem Res 201(4):1659–1669. 10.1007/s12011-022-03309-0.35809185
Garcia-Fortea P, Cohen-Corcia I, Cordoba-Dona JA, . 2018. Toxic elements in hair and in vitro fertilization outcomes: A prospective cohort study. Reprod Toxicol 77:43–52. 10.1016/j.reprotox.2018.02.001.29438736
Garetano G, Stern AH, Robson M, . 2008. Mercury vapor in residential building common areas in communities where mercury is used for cultural purposes versus a reference community. Sci Total Environ 397(1–3):131–139. 10.1016/j.scitotenv.2008.02.034.18406445
Garí M, Grzesiak M, Krekora M, . 2022. Prenatal exposure to neurotoxic metals and micronutrients and neurodevelopmental outcomes in early school age children from Poland. Environ Res 204(Pt B):112049. 10.1016/j.envres.2021.112049.34520749
Garza-Lombo C, Posadas Y, Quintanar L, . 2018. Neurotoxicity linked to dysfunctional metal ion homeostasis and xenobiotic metal exposure: Redox signaling and oxidative stress. Antioxid Redox Signal 28:1669–1703. 10.1089/ars.2017.7272.29402131
Gavis J, Ferguson JF. 1972. The cycling of mercury through the environment. Water Res 6:989–1008.
Gbemavo MCJ, Bouchard MF. 2021. Concentrations of lead, mercury, selenium, and manganese in blood and hand grip strength among adults living in the United States (NHANES 2011-2014). Toxics 9(8):189. 10.3390/toxics9080189.34437507
Gearhart JM, Clewell HJ, Crump KS, . 1995. Pharmacokinetic dose estimates of mercury in children and dose-response curves of performance tests in a large epidemiological study. Water Air Soil Pollut 80(1–4):49–58.
Geffner ME, Sandler A. 1980. Oral metallic mercury: A folk medicine remedy for gastroenteritis. Clin Pediatr (Phila) 19(6):435–437. 10.1177/000992288001900611.7371357
Geier DA, Carmody T, Kern JK, . 2011. A significant relationship between mercury exposure from dental amalgams and urinary porphyrins: A further assessment of the Casa Pia children’s dental amalgam trial. Biometals 24(2):215–224. 10.1007/s10534-010-9387-0.21053054
Geier DA, Kern JK, Homme KG, . 2019. A cross-sectional study of blood ethylmercury levels and cognitive decline among older adults and the elderly in the United States. J Alzheimers Dis 72(3):901–910. 10.3233/jad-190894.31658062
Genchi G, Sinicropi MS, Carocci A, . 2017. Mercury exposure and heart diseases. Int J Environ Res Public Health 14(1):1–13. 10.3390/ijerph14010074.
Genuis SJ, Birkholz D, Rodushkin I, . 2011. Blood, urine, and sweat (BUS) study: Monitoring and elimination of bioaccumulated toxic elements. Arch Environ Contam Toxicol 61(2):344–357. 10.1007/s00244-010-9611-5.21057782
George CR. 2011. Mercury and the kidney. J Nephrol 24(Suppl 17):S126–132. 10.5301/jn.2011.6486.21614794
George GN, Singh SP, Myers GJ, . 2010. The chemical forms of mercury in human hair: a study using X-ray absorption spectroscopy. J Biol Inorg Chem 15(5):709–715. 10.1007/s00775-010-0638-x.20225071
Gerald AC, Ganapathy S, Zhu J, . 2023. Exposure to endocrine-disrupting metals and serum estrogen levels among US women. Reprod Toxicol 118:108392. 10.1016/j.reprotox.2023.108392.37150308
Ghizoni H, Ventura M, Colle D, . 2018. Effects of perinatal exposure to n-3 polyunsaturated fatty acids and methylmercury on cerebellar and behavioral parameters in mice. Food Chem Toxicol 120:603–615. 10.1016/j.fct.2018.08.004.30086348
Ghosh AK, Sen S, Sharma A, . 1991. Effect of chlorophyllin on mercuric chloride-induced clastogenicity in mice. Food Chem Toxicol 29(11):777–779.1761258
Gilbert SG, Burbacher TM, Rice DC. 1993. Effects of in utero methylmercury exposure on a spatial delayed alternation task in monkeys. Toxicol Appl Pharmacol 123(1):130–136. 10.1006/taap.1993.1229.8236251
Gilbert SG, Rice DC, Burbacher TM. 1996. Fixed interval/fixed ratio performance in adult monkeys exposed in utero to methylmercury. Neurotoxicol Teratol 18(5):539–546.8888018
Gill GA, Guentzel JL, Landing WM, . 1995. Total gaseous mercury measurements in Florida: the FAMS project (1992-1994). In: Porcella DB, Wheatley B, eds. Mercury as a global pollutant. Proceedings of the Third International Conference Whistler, British Columbia, July 10-14, 1994. Boston, MA: Kluwer Academic Publishers, 235–244.
Gilmour CC, Henry EA. 1991. Mercury methylation in aquatic systems affected by acid deposition. Environ Pollut 71(2–4):131–170.15092118
Giménez-Llort L, Ahlbom E, Dare E, . 2001. Prenatal exposure to methylmercury changes dopamine-modulated motor activity during early ontogeny: age and gender-dependent effects. Environ Toxicol Pharmacol 9(3):61–70. 10.1016/s1382-6689(00)00060-0.11167150
Gionfriddo CM, Tate MT, Wick RR, . 2016. Microbial mercury methylation in Antarctic sea ice. Nat Microbiol 1(10):1–12. 10.1038/nmicrobiol.2016.127.
Giovanoli-Jakubczak T, Greenwood MR, Smith JC, . 1974. Determination of total and inorganic mercury in hair by flameless atomic absorption, and of methylmercury by gas chromatography. Clin Chem 20(2):222–229.4813000
Glass GE, Sorensen JA, Schmidt KW, . 1990. New source identification of mercury contamination in the Great Lakes. Environ Sci Technol 24(7):1059–1069. 10.1021/es00077a017.
Glass GE, Sorensen JA, Schmidt KW, . 1991. Mercury deposition and sources for the upper Great Lakes region. Water Air Soil Pollut 56(1):235–249. 10.1007/bf00342274.
Gokoel AR, Zijlmans W, Covert HH, . 2020. Influence of prenatal exposure to mercury, perceived stress, and depression on birth outcomes in Suriname: Results from the MeKiTamara Study. Int J Environ Res Public Health 17(12):4444. 10.3390/ijerph17124444.32575788
Golding J, Gregory S, Emond A, . 2016a. Prenatal mercury exposure and offspring behaviour in childhood and adolescence. Neurotoxicology 57:87–94. 10.1016/j.neuro.2016.09.003.27633321
Golding J, Gregory S, Iles-Caven Y, . 2016b. Associations between prenatal mercury exposure and early child development in the ALSPAC study. Neurotoxicology 53:215–222. 10.1016/j.neuro.2016.02.006.26880023
Golding J, Hibbeln JR, Gregory SM, . 2017. Maternal prenatal blood mercury is not adversely associated with offspring IQ at 8 years provided the mother eats fish: A British prebirth cohort study. Int J Hyg Environ Health 220(7):1161–1167. 10.1016/j.ijheh.2017.07.004.28754500
Golding J, Rai D, Gregory S, . 2018. Prenatal mercury exposure and features of autism: a prospective population study. Mol Autism 9:30. 10.1186/s13229-018-0215-7.29713443
Goldman M, Blackburn P. 1979. The effect of mercuric chloride on thyroid function in the rat. Toxicol Appl Pharmacol 48(1 Pt 1):49–55. 10.1016/s0041-008x(79)80007-1.452043
Gonzalez-Raymat H, Liu G, Liriano C, . 2017. Elemental mercury: Its unique properties affect its behavior and fate in the environment. Environ Pollut 229:69–86. 10.1016/j.envpol.2017.04.101.28577384
Goodrich JM, Wang Y, Gillespie B, . 2013. Methylmercury and elemental mercury differentially associate with blood pressure among dental professionals. Int J Hyg Environ Health 216(2):195–201. 10.1016/j.ijheh.2012.03.001.22494934
Goodsite ME, Outridge PM, Christensen JH, . 2013. How well do environmental archives of atmospheric mercury deposition in the Arctic reproduce rates and trends depicted by atmospheric models and measurements? Sci Total Environ 452–453:196–207. 10.1016/j.scitotenv.2013.02.052.
Gore I, Harding SM. 1987. Sinker lung: Acute metallic mercury poisoning associated with the making of fishing weights. Ala J Med Sci 24(3):267–269.3661892
Gosselin NH, Brunet RC, Carrier G, . 2006. Reconstruction of methylmercury intakes in indigenous populations from biomarker data. J Expo Sci Environ Epidemiol 16(1):19–29. 10.1038/sj.jea.7500433.16007116
Gotelli CA, Astolfi E, Cox C, . 1985. Early biochemical effects of an organic mercury fungicide on infants: “Dose makes the poison”. Science 227(4687):638. 10.1126/science.2857500.2857500
Goulet S, Dore FY, Mirault ME. 2003. Neurobehavioral changes in mice chronically exposed to methylmercury during fetal and early postnatal development. Neurotoxicol Teratol 25(3):335–347. 10.1016/s0892-0362(03)00007-2.12757830
Gouveia N, Buzzo ML, Grossi MGL, . 2019. Occupational exposure to mercury in recycling cooperatives from the metropolitan region of São Paulo, Brazil. Cien Saude Colet 24(4):1517–1526. 10.1590/1413-81232018244.01332017.31066853
Govarts E, Remy S, Bruckers L, . 2016. Combined effects of prenatal exposures to environmental chemicals on birth weight. Int J Environ Res Public Health 13(5):495. 10.3390/ijerph13050495.27187434
Grabo TN. 1997. Unknown toxic exposures. Arts and crafts materials. AAOHN J 45(3):124–130.9146113
Granato TC, Pietz RI, Gschwind J, . 1995. Mercury in soils and crops from fields receiving high cumulative sewage sludge applications: Validation of U.S. EPA’s risk assessment for human ingestion. In: Porcella DB, Wheatley B, eds. Mercury as a global pollutant. Proceedings of the Third International Conference Whistler, British Columbia, July 10-14, 1994. Boston, MA: Kluwer Academic Publishers, 1119–1127.
Grandjean P, Budtz-Jorgensen E. 2007. Total imprecision of exposure biomarkers: implications for calculating exposure limits. Am J Ind Med 50(10):712–719. 10.1002/ajim.20474.17492658
Grandjean P, Yorifuji T. 2012. Mercury. In: Bingham E, Cohrssen B, eds. Patty’s toxicology. New York, NY: Wiley, 213–227.
Grandjean P, Weihe P, White RF. 1995. Milestone development in infants exposed to methylmercury from human milk. Neurotoxicology 16(1):27–33.7603642
Grandjean P, Weihe P, Jorgensen PJ, . 1992. Impact of maternal seafood diet on fetal exposure to mercury, selenium, and lead. Arch Environ Health 47(3):185–195. 10.1080/00039896.1992.9938348.1596101
Grandjean P, Weihe P, White RF, . 1997. Cognitive deficit in 7-year-old children with prenatal exposure to methylmercury. Neurotoxicol Teratol 19(6):417–428. 10.1016/s0892-0362(97)00097-4.9392777
Grandjean P, Weihe P, White RF, . 1998. Cognitive performance of children prenatally exposed to “safe” levels of methylmercury. Environ Res 77(2):165–172. 10.1006/enrs.1997.3804.9600810
Grandjean P, Budtz-Jorgensen E, White RF, . 1999. Methylmercury exposure biomarkers as indicators of neurotoxicity in children aged 7 years. Am J Epidemiol 150(3):301–305. 10.1093/oxfordjournals.aje.a010002.10430235
Grandjean P, Bjerve KS, Weihe P, . 2001. Birthweight in a fishing community: Significance of essential fatty acids and marine food contaminants. Int J Epidemiol 30(6):1272–1278. 10.1093/ije/30.6.1272.11821327
Grandjean P, Budtz-Jorgensen E, Steuerwald U, . 2003. Attenuated growth of breast-fed children exposed to increased concentrations of methylmercury and polychlorinated biphenyls. FASEB J 17(6):699–701. 10.1096/fj.02-0661fje.12586743
Grandjean P, Murata K, Budtz-Jorgensen E, . 2004a. Cardiac autonomic activity in methylmercury neurotoxicity: 14-year follow-up of a Faroese birth cohort. J Pediatr 144(2):169–176. 10.1016/j.jpeds.2003.10.058.14760255
Grandjean P, Budtz-Jorgensen E, Keiding N, . 2004b. Underestimation of risk due to exposure misclassification. Int J Occup Med Environ Health 17(1):131–136.15212216
Grandjean P, Poulsen LK, Heilmann C, . 2010. Allergy and sensitization during childhood associated with prenatal and lactational exposure to marine pollutants. Environ Health Perspect 118(10):1429–1433. 10.1289/ehp.1002289.20562055
Grandjean P, Weihe P, Debes F, . 2014. Neurotoxicity from prenatal and postnatal exposure to methylmercury. Neurotoxicol Teratol 43:39–44. 10.1016/j.ntt.2014.03.004.24681285
Greenwood MR. 1985. Methylmercury poisoning in Iraq. An epidemiological study of the 1971-1972 outbreak. J Appl Toxicol 5(3):148–159.4008862
Gregory S, Iles-Caven Y, Hibbeln JR, . 2016. Are prenatal mercury levels associated with subsequent blood pressure in childhood and adolescence? The Avon prebirth cohort study. BMJ Open 6(10):e012425. 10.1136/bmjopen-2016-012425.
Gregus Z, Stein AF, Klaassen CD. 1987. Effect of inhibition of gamma-glutamyltranspeptidase on biliary and urinary excretion of glutathione-derived thiols and methylmercury. J Pharmacol Exp Ther 242(1):27–32.2886637
Gribble MO, Cheng A, Berger RD, . 2015. Mercury exposure and heart rate variability: A systematic review. Curr Environ Health Rep 2(3):304–314. 10.1007/s40572-015-0053-0.26231507
Grieb TM, Driscoll CT, Gloss SP, . 1990. Factors affecting mercury accumulation in fish in the upper Michigan peninsula. Environ Toxicol Chem 9(7):919–930.
Grieb TM, Fisher NS, Karimi R, . 2020. An assessment of temporal trends in mercury concentrations in fish. Ecotoxicology 29(10):1739–1749. 10.1007/s10646-019-02112-3.31583510
Griffiths C, McGartland A, Miller M. 2007. A comparison of the monetized impact of IQ decrements from mercury emissions. Environ Health Perspect 115(6):841–847. 10.1289/ehp.9797.17589589
Grotto D, de Castro MM, Barcelos GR, . 2009a. Low level and sub-chronic exposure to methylmercury induces hypertension in rats: nitric oxide depletion and oxidative damage as possible mechanisms. Arch Toxicol 83(7):653–662. 10.1007/s00204-009-0437-8.19468715
Grotto D, Barcelos GR, Valentini J, . 2009b. Low levels of methylmercury induce DNA damage in rats: protective effects of selenium. Arch Toxicol 83(3):249–254. 10.1007/s00204-008-0353-3.18754101
Grover P, Banu BS, Devi KD, . 2001. In vivo genotoxic effects of mercuric chloride in rat peripheral blood leucocytes using comet assay. Toxicology 167(3):191–197.11578798
Guallar E, Sanz-Gallardo MI, van’t Veer P, . 2002. Mercury, fish oils, and the risk of myocardial infarction. N Engl J Med 347(22):1747–1754. 10.1056/NEJMoa020157.12456850
Guan T, Wu Z, Xu C, . 2023. The association of trace elements with arthritis in US adults: NHANES 2013-2016. J Trace Elem Med Biol 76:127122. 10.1016/j.jtemb.2022.127122.36525916
Guentzel JL, Landing WM, Gill GA, . 1995. Atmospheric deposition of mercury in Florida: the FAMS project (1992-1994). In: Porcella DB, Huckabee JW, eds. Mercury as a global pollutant. Proceedings of the third International Conference Whistler, British Columbia, July 10-14, 1994. Boston, MA: Kluwer Academic Publishers, 393–402.
Guillamet E, Creus A, Farina M, . 2008. DNA-damage induction by eight metal compounds in TK6 human lymphoblastoid cells: results obtained with the alkaline Comet assay. Mutat Res 654(1):22–28. 10.1016/j.mrgentox.2008.04.005.18534899
Gul N, Khan S, Khan A, . 2016. Quantification of Hg excretion and distribution in biological samples of mercury-dental-amalgam users and its correlation with biological variables. Environ Sci Pollut Res Int 23(20):20580–20590. 10.1007/s11356-016-7266-0.27464660
Gundacker C, Gencik M, Hengstschlager M. 2010. The relevance of the individual genetic background for the toxicokinetics of two significant neurodevelopmental toxicants: mercury and lead. Mutat Res 705(2):130–140. 10.1016/j.mrrev.2010.06.003.20601101
Gundacker C, Graf-Rohrmeister K, Gencik M, . 2021. Gene variants determine placental transfer of perfluoroalkyl substances (PFAS), mercury (Hg) and lead (Pb), and birth outcome: findings from the UmMuKi Bratislava-Vienna Study. Front Genet 12:664946. 10.3389/fgene.2021.664946.34220941
Gunderson EL. 1988. FDA Total Diet Study, April 1982-April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71(6):1200–1209.3240978
Guo BQ, Cai SZ, Guo JL, . 2013. Levels of prenatal mercury exposure and their relationships to neonatal anthropometry in Wujiang City, China. Environ Pollut 182:184–189. 10.1016/j.envpol.2013.07.023.23920315
Guo J, Wu C, Zhang J, . 2020a. Prenatal exposure to mixture of heavy metals, pesticides and phenols and IQ in children at 7 years of age: The SMBCS study. Environ Int 139:105692. 10.1016/j.envint.2020.105692.32251899
Guo J, Wu C, Zhang J, . 2020b. Supplemental material: Prenatal exposure to mixture of heavy metals, pesticides and phenols and IQ in children at 7 years of age: The SMBCS study. Environ Int 139 10.1016/j.envint.2020.105692.
Guo X, Li N, Wang H, . 2022. Combined exposure to multiple metals on cardiovascular disease in NHANES under five statistical models. Environ Res 215(Pt 3):114435. 10.1016/j.envres.2022.114435.36174761
Guo Y, Lv Y, Liu X, . 2023. Association between heavy metal mercury in body fluids and tissues and diabetes mellitus: a systematic review and meta-analysis. Ann Transl Med 11(2):114. 10.21037/atm-22-6404.36819500
Gupchup GV, Zatz J. 1999. Structural characteristics and permeability properties of the human nail: A review. J Cosmet Sci 50(6):363–385.
Gustin K, Tofail F, Mehrin F, . 2017. Methylmercury exposure and cognitive abilities and behavior at 10 years of age. Environ Int 102:97–105. 10.1016/j.envint.2017.02.004.28216013
Gustin K, Barman M, Stråvik M, . 2020. Low-level maternal exposure to cadmium, lead, and mercury and birth outcomes in a Swedish prospective birth-cohort. Environ Pollut 265(Pt B):114986. 10.1016/j.envpol.2020.114986.32585550
Gworek B, Dmuchowski W, Baczewska AH, . 2017. Air contamination by mercury, emissions and transformations-a review. Water Air Soil Pollut 228(4):123. 10.1007/s11270-017-3311-y.28316351
Gyrd-Hansen N. 1981. Toxicokinetics and methyl mercury in pigs. Arch Toxicol 48(2–3):173–181.7295033
Ha M, Kwon HJ, Lim MH, . 2009. Low blood levels of lead and mercury and symptoms of attention deficit hyperactivity in children: A report of the children’s health and environment research (CHEER). Neurotoxicology 30(1):31–36. 10.1016/j.neuro.2008.11.011.19100765
Hadavifar M, Rastakhiz M, Souvizi B, . 2020. Biomonitoring of maternal and fetal exposure to mercury in Sabzevar and its affecting risk factors. J Hazard Mater 388:121781. 10.1016/j.jhazmat.2019.121781.31813691
Haddad JK, Stenberg E. 1963. Bronchitis due to acute mercury inhalation. Report of two cases. Am Rev Respir Dis 88:543–535. .14068440
Halbach S, Clarkson TW. 1978. Enzymatic oxidation of mercury vapor by erythrocytes. Biochim Biophys Acta Enzymol 523(2):522–531. 10.1016/0005-2744(78)90055-4.
Halbach S, Welzl G, Kremers L, . 2000. Steady-state transfer and depletion kinetics of mercury from amalgam fillings. Sci Total Environ 259(1–3):13–21.11032131
Hales CM, Carroll MD, Fryar CD, . 2020. Prevalence of obesity and severe obesity among adults: United States, 2017–2018. Centers for Disease Control and Prevention. NCHS Data Brief No. 360. https://www.cdc.gov/nchs/products/databriefs/db360.htm. March 15, 2021.
Hall LL, Allen PV, Fisher HL, . 1995. The kinetics of intravenously administered inorganic mercury in humans. In: Subramanian KN, Wastney ME, eds. Kinetic models of trace element and mineral metabolism. Boca Raton, FL: CRC Press, 265–280.
Hall BD, Bodaly RA, Fudge RJP, . 1997. Food as the dominant pathway of methylmercury uptake by fish. Water Air Soil Pollut 100(1–2):13–24.
Hallee TJ. 1969. Diffuse lung disease caused by inhalation of mercury vapor. Am Rev Repir Dis 99(3):430–436. 10.1164/arrd.1969.99.3.430.
Hallgren CG, Hallmans G, Jansson JH, . 2001. Markers of high fish intake are associated with decreased risk of a first myocardial infarction. Br J Nutr 86(3):397–404. 10.1079/bjn2001415.11570992
Han DH, Lim SY, Sun BC, . 2009. Mercury exposure and periodontitis among a Korean population: The Shiwha-Banwol environmental health study. J Periodontol 80(12):1928–1936. 10.1902/jop.2009.090293.19961376
Handley J, Todd D, Burrows D. 1993. Mercury allergy in a contact dermatitis clinic in Northern Ireland. Contact Dermatitis 29(5):258–261. 10.1111/j.1600-0536.1993.tb03561.x.8112066
Hapke HJ. 1991. Metals accumulation in the food chain and load of feed and food. In: Merian E, ed. Metals and their compounds in the environment. Weinheim, Germany: VCH, 469–479.
Harada M. 1995. Minamata disease: Methylmercury poisoning in Japan caused by environmental pollution. Crit Rev Toxicol 25(1):1–24. 10.3109/10408449509089885.7734058
Harada M, Nakanishi J, Konuma S, . 1998. The present mercury contents of scalp hair and clinical symptoms in inhabitants of the Minamata area. Environ Res 77(2):160–164. 10.1006/enrs.1998.3837.9600809
Harada M, Akagi H, Tsuda T, . 1999. Methylmercury level in umbilical cords from patients with congenital Minamata disease. Sci Total Environ 234(1–3):59–62.10507148
Harari R, Harari F, Gerhardsson L, . 2012. Exposure and toxic effects of elemental mercury in gold-mining activities in Ecuador. Toxicol Lett 213(1):75–82. 10.1016/j.toxlet.2011.09.006.21925580
Harry GJ, Harris MW, Burka LT. 2004. Mercury concentrations in brain and kidney following ethylmercury, methylmercury and Thimerosal administration to neonatal mice. Toxicol Lett 154(3):183–189. 10.1016/j.toxlet.2004.07.014.15501610
Harsh JB, Doner HE. 1981. Characterization of mercury in a river wash soil. J Environ Qual 10(3):333–337.
Havarinasab S, Hultman P. 2005. Organic mercury compounds and autoimmunity. Autoimmun Rev 4(5):270–275. 10.1016/j.autrev.2004.12.001.15990073
Havarinasab S, Bjorn E, Nielsen JB, . 2007. Mercury species in lymphoid and non-lymphoid tissues after exposure to methyl mercury: correlation with autoimmune parameters during and after treatment in susceptible mice. Toxicol Appl Pharmacol 221(1):21–28. 10.1016/j.taap.2007.02.009.17399758
Hayes AD, Rothstein A. 1962. The metabolism of inhaled mercury vapor in the rat studied by isotope techniques. J Pharmacol Exp Ther 138:1–10.13963562
He K, Xun P, Liu K, . 2013. Mercury exposure in young adulthood and incidence of diabetes later in life: The CARDIA trace element study. Diabetes Care 36(6):1584–1589. 10.2337/dc12-1842.23423697
He J, Zhao Y, Zhu T, . 2021. Mercury chloride impacts on the development of erythrocytes and megakaryocytes in mice. Toxics 9(10):252. 10.3390/toxics9100252.34678948
Heath JC, Abdelmageed Y, Braden TD, . 2009. The effects of chronic mercuric chloride ingestion in female Sprague-Dawley rats on fertility and reproduction. Food Chem Toxicol 47(7):1600–1605. 10.1016/j.fct.2009.04.007.19371768
Heath JC, Abdelmageed Y, Braden TD, . 2012. The effects of chronic ingestion of mercuric chloride on fertility and testosterone levels in male Sprague Dawley rats. J Biomed Biotechnol 2012:1–9. 10.1155/2012/815186.21836813
Heinrich J, Guo F, Trepka MJ. 2017. Brief report: Low-level mercury exposure and risk of asthma in school-age children. Epidemiology 28(1):116–118. 10.1097/ede.0000000000000576.27755278
Hellou J, Fancey LL, Payne JF. 1992. Concentrations of twenty-four elements in bluefin tuna, from the Northwest Atlantic. Chemosphere 24(2):211–218. 10.1016/0045-6535(92)90394-7.
Hernández-Mendoza H, Álvarez-Loredo HE, Romero-Guzmán ET, . 2022. Relationship between serum levels of arsenic, cadmium, and mercury and body mass index and fasting plasma glucose in a Mexican adult population. Biol Trace Elem Res 200:4916–4923. 10.1007/s12011-021-03081-7.35098445
Herr DW, Chanda SM, Graff JE, . 2004. Evaluation of sensory evoked potentials in Long Evans rats gestationally exposed to mercury (Hg0) vapor. Toxicol Sci 82(1):193–206. 10.1093/toxsci/kfh246.15310857
Herrstrom P, Schutz A, Raihle G, . 1995. Dental amalgam, low-dose exposure to mercury, and urinary proteins in young Swedish men. Arch Environ Health 50(2):103–107. 10.1080/00039896.1995.9940886.7786045
Hertz-Picciotto I, Green PG, Delwiche L, . 2010. Blood mercury concentrations in CHARGE Study children with and without autism. Environ Health Perspect 118(1):161–166. 10.1289/ehp.0900736.20056569
Heyer NJ, Echeverria D, Bittner AC, . 2004. Chronic low-level mercury exposure, BDNF polymorphism, and associations with self-reported symptoms and mood. Toxicol Sci 81(2):354–363. 10.1093/toxsci/kfh220.15254338
Hibbeln J, Gregory S, Iles-Caven Y, . 2018. Total mercury exposure in early pregnancy has no adverse association with scholastic ability of the offspring particularly if the mother eats fish. Environ Int 116:108–115. 10.1016/j.envint.2018.03.024.29665469
Hinners T, Tsuchiya A, Stern AH, . 2012. Chronologically matched toenail-Hg to hair-Hg ratio: Temporal analysis within the Japanese community (U.S.). Environ Health 11:81. 10.1186/1476-069x-11-81.23113987
Hirai T, Abe O, Nakamura M, . 2023. Brain structural changes in patients with chronic methylmercury poisoning in Minamata. Brain Res 1805:148278. 10.1016/j.brainres.2023.148278.36775085
Hirano M, Mitsumori K, Maita K, . 1986. Further carcinogenicity study on methylmercury chloride in ICR mice. Nihon Juigaku Zasshi 48(1):127–135. 10.1292/jvms1939.48.127.3959366
Hirzy JW, Connett P, Xiang Q, . 2016. Developmental neurotoxicity of fluoride: A quantitative risk analysis towards establishing a safe daily dose of fluoride for children. Fluoride 49(4 Pt 1):379–400.
Hoet P, Lison D. 1997. A nonoccupational source of mercury intoxication. Clin Chem 43(7):1248.9216470
Hoffman HI, Bradley WG, Chen CY, . 2021. Amyotrophic lateral sclerosis risk, family income, and fish consumption estimates of mercury and omega-3 PUFAs in the United States. Int J Environ Res Public Health 18(9):4528. 10.3390/ijerph18094528.33923256
Högstedt B, Bratt I, Holmen A, . 1988. Frequency and size distribution of micronuclei in lymphocytes stimulated with phytohemagglutinin and pokeweed mitogen in workers exposed to piperazine. Hereditas 109(1):139–142. 10.1111/j.1601-5223.1988.tb00194.x.3192423
Højbjerg S, Nielsen JB, Andersen O. 1992. Effects of dietary lipids on whole-body retention and organ distribution of organic and inorganic mercury in mice. Food Chem Toxicol 30(8):703–708. 10.1016/0278-6915(92)90166-i.1398351
Hollins JG, Willes RF, Bryce FR, . 1975. The whole body retention and tissue distribution of [^203^Hg]methylmercury in adult cats. Toxicol Appl Pharmacol 33(3):438–449.1188942
Hoshino A, Pacheco-Ferreira H, Sanches SG, . 2015. Mercury exposure in a riverside Amazon population, Brazil: A study of the ototoxicity of methylmercury. Int Arch Otorhinolaryngol 19(2):135–140. 10.1055/s-0034-1544115.25992169
Houston MC. 2011. Role of mercury toxicity in hypertension, cardiovascular disease, and stroke. J Clin Hypertens (Greenwich) 13(8):621–627. 10.1111/j.1751-7176.2011.00489.x.21806773
Howard W, Leonard B, Moody W, . 1991. Induction of chromosome changes by metal compounds in cultured CHO cells. Toxicol Lett 56(1–2):179–186.2017776
Howe CG, Nozadi SS, Garcia E, . 2022. Prenatal metal(loid) mixtures and birth weight for gestational age: A pooled analysis of three cohorts participating in the ECHO program. Environ Int 161:107102. 10.1016/j.envint.2022.107102.35081493
Hsu YC, Chang CW, Lee HL, . 2016. Association between history of dental amalgam fillings and risk of Parkinson’s disease: A population-based retrospective cohort study in Taiwan. PLoS ONE 11(12):e0166552. 10.1371/journal.pone.0166552.27906991
Hu G, Jin M, Lin X, . 2010. Mercury distribution in neonatal rat brain after intrauterine methylmercury exposure. Environ Toxicol Pharmacol 29(1):7–11. 10.1016/j.etap.2009.08.006.21787575
Hu Y, Chen L, Wang C, . 2016. Prenatal low-level mercury exposure and infant neurodevelopment at 12 months in rural northern China. Environ Sci Pollut Res Int 23(12):12050–12059. 10.1007/s11356-016-6395-9.26965274
Hu XF, Eccles KM, Chan HM. 2017. High selenium exposure lowers the odds ratios for hypertension, stroke, and myocardial infarction associated with mercury exposure among Inuit in Canada. Environ Int 102:200–206. 10.1016/j.envint.2017.03.002.28279481
Hu XF, Singh K, Chan HM. 2018. Mercury exposure, blood pressure, and hypertension: a systematic review and dose-response meta-analysis. Environ Health Perspect 126(7):076002. 10.1289/ehp2863.30073953
Hu XF, Lowe M, Chan HM. 2021. Mercury exposure, cardiovascular disease, and mortality: A systematic review and dose-response meta-analysis. Environ Res 193:110538. 10.1016/j.envres.2020.110538.33285155
Huang LS, Cox C, Wilding GE, . 2003. Using measurement error models to assess effects of prenatal and postnatal methylmercury exposure in the Seychelles Child Development Study. Environ Res 93(2):115–122.12963395
Huang LS, Cox C, Myers GJ, . 2005. Exploring nonlinear association between prenatal methylmercury exposure from fish consumption and child development: evaluation of the Seychelles Child Development Study nine-year data using semiparametric additive models. Environ Res 97(1):100–108. 10.1016/j.envres.2004.05.004.15476739
Huang LS, Myers GJ, Davidson PW, . 2007. Is susceptibility to prenatal methylmercury exposure from fish consumption non-homogeneous? Tree-structured analysis for the Seychelles Child Development Study. Neurotoxicology 28(6):1237–1244. 10.1016/j.neuro.2007.08.009.17942158
Huang CF, Liu SH, Hsu CJ, . 2011. Neurotoxicological effects of low-dose methylmercury and mercuric chloride in developing offspring mice. Toxicol Lett 201(3):196–204. 10.1016/j.toxlet.2010.12.016.21195143
Huang LS, Cory-Slechta DA, Cox C, . 2018. Analysis of nonlinear associations between prenatal methylmercury exposure from fish consumption and neurodevelopmental outcomes in the Seychelles main cohort at 17 years. Stoch Environ Res Risk Assess 32(4):893–904. 10.1007/s00477-017-1451-7.30323714
Hughes JA, Annau Z. 1976. Postnatal behavioral effects in mice after prenatal exposure to methylmercury. Pharmacol Biochem Behav 4(4):385–391. 10.1016/0091-3057(76)90052-6.935210
Hui LL, Chan MHM, Lam HS, . 2016. Impact of fetal and childhood mercury exposure on immune status in children. Environ Res 144(Pt A):66–72. 10.1016/j.envres.2015.11.005.26562044
Hultman P, Enestrom S. 1986. Localization of mercury in the kidney during experimental acute tubular necrosis studied by the cytochemical Silver Amplification method. Br J Exp Pathol 67(4):493–503.3741775
Hultman P, Johansson U. 1991. Strain differences in the effect of mercury on murine cell-mediated immune reactions. Food Chem Toxicol 29(9):633–638. 10.1016/0278-6915(91)90146-x.1937295
Hultman P, Enestrom S. 1992. Dose-response studies in murine mercury-induced autoimmunity and immune-complex disease. Toxicol Appl Pharmacol 113(2):199–208. 10.1016/0041-008x(92)90115-9.1532866
Hultman P, Nielsen JB. 2001. The effect of dose, gender, and non-H-2 genes in murine mercury-induced autoimmunity. J Autoimmun 17(1):27–37. 10.1006/jaut.2001.0521.11488635
Hultman P, Enestrom S, von Schenck H. 1985. Renal handling of inorganic mercury in mice. The early excretion phase following a single intravenous injection of mercuric chloride studied by the Silver Amplification method. Virchows Arch B Cell Pathol Incl Mol Pathol 49(3):209–224.2865844
Hurley JP, Watras CJ, Bloom NS. 1991. Mercury cycling in a northern Wisconsin seepage lake: The role of particulate matter in vertical transport. Water Air Soil Pollut 56(1):543–551. 10.1007/bf00342298.
Hursh JB. 1985. Partition coefficients of mercury (203Hg) vapor between air and biological fluids. J Appl Toxicol 5(5):327–332. 10.1002/jat.2550050512.4056310
Hursh JB, Clarkson TW, Cherian MG, . 1976. Clearance of mercury (Hg-197, Hg-203) vapor inhaled by human subjects. Arch Environ Health 31:302–309.999343
Hursh JB, Greenwood MR, Clarkson TW, . 1980. The effect of ethanol on the fate of mercury vapor inhaled by man. J Pharmacol Exp Ther 214(3):520–527.7400960
Hursh JB, Clarkson TW, Miles EF, . 1989. Percutaneous absorption of mercury vapor by man. Arch Environ Health 44(2):120–127. 10.1080/00039896.1989.9934385.2494955
Hwang GW, Lee JY, Ryoke K, . 2011. Gene expression profiling using DNA microarray analysis of the cerebellum of mice treated with methylmercury. J Toxicol Sci 36(3):389–391.21628967
Hytten F. 1985. Blood volume changes in normal pregnancy. Clin Haematol 14(3):601–612.
IARC. 1993. Mercury and mercury compounds. In: IARC monographs on the evaluation of carcinogenic risks to humans. Volume 58. Beryllium, cadmium, mercury, and exposures in the glass manufacturing industry. Lyon, France: International Agency for Research on Cancer, 239–345. https://publications.iarc.fr/76. November 11, 2020.
ICRP. 1980. Metabolic data for mercury. In: Limits for intakes of radionuclides by workers. Oxford, England: Pergamon Press, 59–63.
ICRP. 1981. Report of the task group on reference man. New York, NY: International Commission on Radiological Protection. ICRP Publication 23.
ICRP. 1994. Human respiratory tract model for radiological protection. International Commission on Radiological Protection. ICRP Publication 66.
Iesato K, Wakashin M, Wakashin Y, . 1977. Renal tubular dysfunction in Minamata disease. Detection of renal tubular antigen and beta-2-microglobin in the urine. Ann Intern Med 86(6):731–737. 10.7326/0003-4819-86-6-731.68693
Igata A. 1993. Epidemiological and clinical features of Minamata disease. Environ Res 63(1):157–169.8404770
Iglesias P, Carrero JJ, Díez JJ. 2012. Gonadal dysfunction in men with chronic kidney disease: Clinical features, prognostic implications and therapeutic options. J Nephrol 25(1):31–42. 10.5301/jn.2011.8481.21748720
IJC. 2015. Atmospheric deposition of mercury in the Great Lakes basin. Washington, DC: International Joint Commission: Canada and United States. https://legacyfiles.ijc.org/tinymce/uploaded/documents/Atmospheric-Deposition-of-Mercury-in-the-Great-Lakes-Basin-December-2015.pdf. December 14, 2020.
Ikegaya K, Nokihara K, Yasuhara T. 2010. Characterization of sulfhydryl heterogeneity in human serum albumin and recombinant human serum albumin for clinical use. Biosci Biotechnol Biochem 74(11):2232–2236. 10.1271/bbb.100423.21071845
Ilback NG. 1991. Effects of methyl mercury exposure on spleen and blood natural killer (NK) cell activity in the mouse. Toxicology 67(1):117–124. 10.1016/0300-483x(91)90169-2.2017762
Ilback NG, Sundberg J, Oskarsson A. 1991. Methyl mercury exposure via placenta and milk impairs natural killer (NK) cell function in newborn rats. Toxicol Lett 58(2):149–158. 10.1016/0378-4274(91)90169-7.1949074
Ilback N-G, Frisk P, Tallkvist J, . 2008. Gastrointestinal uptake of trace elements are changed during the course of a common human viral (Coxsackievirus B3) infection in mice. J Trace Elem Med Biol 22(2):120–130. 10.1016/j.jtemb.2007.12.001.18565424
IMERC. 2015. IMERC fact sheet: Mercury use in batteries. Interstate Mercury Education and Reduction Clearinghouse.
Inoue S, Yorifuji T, Tsuda T, . 2012. Short-term effect of severe exposure to methylmercury on atherosclerotic heart disease and hypertension mortality in Minamata. Sci Total Environ 417–418:291–293. 10.1016/j.scitotenv.2011.11.076.
Inouye M, Kajiwara Y. 1988. Developmental disturbances of the fetal brain in guinea-pigs caused by methylmercury. Arch Toxicol 62(1):15–21. 10.1007/BF00316251.3190452
Inouye M, Murao K, Kajiwara Y. 1985. Behavioral and neuropathological effects of prenatal methylmercury exposure in mice. Neurobehav Toxicol Teratol 7(3):227–232.4033863
Inouye M, Kajiwara Y, Hirayama K. 1986. Dose- and sex-dependent alterations in mercury distribution in fetal mice following methylmercury exposure. J Toxicol Environ Health 19(3):425–435. 10.1080/15287398609530940.3772988
IRIS. 1987. Phenylmercuric acetate. CASRN 62-38-4. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0089_summary.pdf. November 10, 2020.
IRIS. 1995a. Mercury, elemental. CASRN 7439-97-6. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0370_summary.pdf. November 10, 2020.
IRIS. 1995b. Mercuric chloride (HgCl2). CASRN 7487-94-7. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0692_summary.pdf. November 10, 2020.
IRIS. 2001. Methylmercury (MeHg). CASRN 22967-92-6. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0073_summary.pdf. November 10, 2020.
Ishihara N. 2000. Excretion of methyl mercury in human feces. Arch Environ Health 55(1):44–47. 10.1080/00039890009603384.10735519
Ishihara Y, Itoh K, Oguro A, . 2019. Neuroprotective activation of astrocytes by methylmercury exposure in the inferior colliculus. Sci Rep 9(1):13899. 10.1038/s41598-019-50377-9.31554907
Ishitobi H, Stern S, Thurston SW, . 2010. Organic and inorganic mercury in neonatal rat brain after prenatal exposure to methylmercury and mercury vapor. Environ Health Perspect 118(2):242–248. 10.1289/ehp.0900956.20123608
Ismail OI, El-Meligy MMS. 2021. Could vitamin C protect against mercuric chloride induced lung toxicity in the offspring rat: A histological and immunohistochemical study. Ultrastruct Pathol 45(3):197–211. 10.1080/01913123.2021.1954118.34315326
Iverson F, Hierlihy SL. 1974. Biotransformation of methyl mercury in the guinea pig. Bull Environ Contam Toxicol 11(1):85–91.4433786
Iverson F, Downie RH, Paul C, . 1973. Methyl mercury: acute toxicity, tissue distribution and decay profiles in the guinea pig. Toxicol Appl Pharmacol 24(4):545–554.4713481
Iwai-Shimada M, Satoh H, Nakai K, . 2015. Methylmercury in the breast milk of Japanese mothers and lactational exposure of their infants. Chemosphere 126:67–72. 10.1016/j.chemosphere.2014.12.086.25723533
Iwata T, Sakamoto M, Feng X, . 2007. Effects of mercury vapor exposure on neuromotor function in Chinese miners and smelters. Int Arch Occup Environ Health 80(5):381–387. 10.1007/s00420-006-0144-1.17021844
Iwata T, Takaoka S, Sakamoto M, . 2016. Characteristics of hand tremor and postural sway in patients with fetal-type Minamata disease. J Toxicol Sci 41(6):757–763. 10.2131/jts.41.757.27853104
Jackson LW, Zullo MD, Goldberg JM. 2008. The association between heavy metals, endometriosis and uterine myomas among premenopausal women: National Health and Nutrition Examination Survey 1999-2002. Hum Reprod 23(3):679–687. 10.1093/humrep/dem394.18192673
Jackson LW, Howards PP, Wactawski-Wende J, . 2011. The association between cadmium, lead and mercury blood levels and reproductive hormones among healthy, premenopausal women. Hum Reprod 26(10):2887–2895. 10.1093/humrep/der250.21778284
Jacobson JL, Muckle G, Ayotte P, . 2015. Relation of prenatal methylmercury exposure from environmental sources to childhood IQ. Environ Health Perspect 123(8):827–833. 10.1289/ehp.1408554.25757069
Jagiello G, Lin JS. 1973. An assessment of the effects of mercury on the meiosis of mouse ova. Mutat Res 17(1):93–99. 10.1016/0027-5107(73)90257-1.4682605
Jain RB. 2017. Trends in and factors affecting the observed levels of urinary inorganic and total blood mercury among US children, adolescents, adults, and senior citizens over 2005-2012. Environ Toxicol Pharmacol 56:268–281. 10.1016/j.etap.2017.09.003.29055217
Jalili C, Kazemi M, Taheri E, . 2020a. Exposure to heavy metals and the risk of osteopenia or osteoporosis: a systematic review and meta-analysis. Osteoporos Int 31(9):1671–1682. 10.1007/s00198-020-05429-6.32361950
Jalili C, Akhshi N, Rashidi I, . 2020b. Harmine protects mercuric chloride kidney-induced injury by antioxidant activity in male mice: a biochemical and histological study. Res Pharm Sci 15(6):541–550. 10.4103/1735-5362.301339.33828597
Jan AT, Ali A, Haq Q. 2011. Glutathione as an antioxidant in inorganic mercury induced nephrotoxicity. J Postgrad Med 57(1):72–77. 10.4103/0022-3859.74298.21206114
Janse van Rensburg M, van Rooy MJ, Bester MJ, . 2020. Ultrastructural alterations of whole blood by copper, manganese and mercury metal mixtures using a chronic in vivo model of coagulation. Environ Toxicol Pharmacol 75:103314. 10.1016/j.etap.2019.103314.31881365
Janssen SE, Riva-Murray K, DeWild JF, . 2019. Chemical and physical controls on mercury source signatures in stream fish from the northeastern United States. Environ Sci Technol 53(17):10110–10119. 10.1021/acs.est.9b03394.31390861
Jao-Tan C, Pope E. 2006. Cutaneous poisoning syndromes in children: A review. Curr Opin Pediatr 18(4):410–416. 10.1097/01.mop.0000236391.49086.34.16914996
Jarosinska D, Horvat M, Sallsten G, . 2008. Urinary mercury and biomarkers of early renal dysfunction in environmentally and occupationally exposed adults: a three-country study. Environ Res 108(2):224–232. 10.1016/j.envres.2008.06.005.18684440
Jedrychowski W, Jankowski J, Flak E, . 2006. Effects of prenatal exposure to mercury on cognitive and psychomotor function in one-year-old infants: epidemiologic cohort study in Poland. Ann Epidemiol 16(6):439–447. 10.1016/j.annepidem.2005.06.059.16275013
Jedrychowski W, Perera F, Jankowski J, . 2007. Fish consumption in pregnancy, cord blood mercury level and cognitive and psychomotor development of infants followed over the first three years of life: Krakow epidemiologic study. Environ Int 33(8):1057–1062. 10.1016/j.envint.2007.06.001.17643489
Jensen TK, Grandjean P, Jorgensen EB, . 2005. Effects of breast feeding on neuropsychological development in a community with methylmercury exposure from seafood. J Expo Anal Environ Epidemiol 15(5):423–430. 10.1038/sj.jea.7500420.15674318
Jenssen D, Ramel C. 1980. The micronucleus test as part of a short-term mutagenicity test program for the prediction of carcinogenicity evaluated by 143 agents tested. Mutat Res 75:191–202.7366601
Jenssen MT, Brantsaeter AL, Haugen M, . 2012. Dietary mercury exposure in a population with a wide range of fish consumption-self-capture of fish and regional differences are important determinants of mercury in blood. Sci Total Environ 439:220–229. 10.1016/j.scitotenv.2012.09.024.23069934
Jeon J, Morris JS, Park K. 2021. Toenail mercury levels positively correlate with obesity and abdominal obesity among Korean adults. J Trace Elem Med Biol 64:126678. 10.1016/j.jtemb.2020.126678.33249372
Jeong KS, Park H, Ha E, . 2017. High maternal blood mercury level is associated with low verbal IQ in children. J Korean Med Sci 32(7):1097–1104. 10.3346/jkms.2017.32.7.1097.28581265
Jeppesen C, Valera B, Nielsen NO, . 2015. Association between whole blood mercury and glucose intolerance among adult Inuit in Greenland. Environ Res 143(Pt A):192–197. 10.1016/j.envres.2015.10.013.26497629
Jin X, Chan HM, Lok E, . 2008. Dietary fats modulate methylmercury-mediated systemic oxidative stress and oxidative DNA damage in rats. Food Chem Toxicol 46(5):1706–1720. 10.1016/j.fct.2008.01.015.18295952
Jin R, Zhu X, Shrubsole MJ, . 2018. Associations of renal function with urinary excretion of metals: Evidence from NHANES 2003-2012. Environ Int 121(Pt 2):1355–1362. 10.1016/j.envint.2018.11.002.30442456
Jin T, Park EY, Kim B, . 2021. Association between blood mercury concentration and prevalence of borderline hypercholesterolemia among adolescents: The Korea National Health and Nutrition Examination Survey (KNHANES) 2010-2013 and 2016. Toxics 9(10):242. 10.3390/toxics9100242.34678938
Jindal M, Garg GR, Mediratta PK, . 2011. Protective role of melatonin in myocardial oxidative damage induced by mercury in murine model. Hum Exp Toxicol 30(10):1489–1500. 10.1177/0960327110391685.21138989
Jo S, Woo HD, Kwon HJ, . 2015. Estimation of the biological half-life of methylmercury using a population toxicokinetic model. Int J Environ Res Public Health 12(8):9054–9067. 10.3390/ijerph120809054.26264017
Johansson C, Castoldi AF, Onishchenko N, . 2007. Neurobehavioural and molecular changes induced by methylmercury exposure during development. Neurotox Res 11(3–4):241–260.17449462
Johnson DL, Braman RS. 1974. Distribution of atmospheric mercury species near ground. Environ Sci Technol 8(12):1003–1009.
Johnsson C, Schutz A, Sallsten G. 2005. Impact of consumption of freshwater fish on mercury levels in hair, blood, urine, and alveolar air. J Toxicol Environ Health A 68(2):129–140. 10.1080/15287390590885992.15762551
Jonker D, Woutersen RA, van Bladeren PJ, . 1993. Subacute (4-wk) oral toxicity of a combination of four nephrotoxins in rats: comparison with the toxicity of the individual compounds. Food Chem Toxicol 31(2):125–136. 10.1016/0278-6915(93)90126-j.8449457
Jonsson F, Sandborgh-Englund G, Johanson G. 1999. A compartmental model for the kinetics of mercury vapor in humans. Toxicol Appl Pharmacol 155(2):161–168. 10.1006/taap.1998.8585.10053170
Joo SH, Seo S, Cho MH, . 2022. Environmental exposure to lead, mercury, and cadmium is not associated with abnormal kidney function in Korean adolescents. Pediatr Nephrol 37(3):625–631. 10.1007/s00467-021-05215-4.34448022
Joselow MM, Ruiz R, Goldwater LJ. 1968. Absorption and excretion of mercury in man. XIV. Salivary excretion of mercury and its relationship to blood and urine mercury. Arch Environ Health 17(1):39–43.
Joshi D, Kumar MD, Kumar SA, . 2014. Reversal of methylmercury-induced oxidative stress, lipid peroxidation, and DNA damage by the treatment of N-acetyl cysteine: a protective approach. J Environ Pathol Toxicol Oncol 33(2):167–182.24941299
Juárez BI, Portillo-Salazar H, Gonzalez-Amaro R, . 2005. Participation of N-methyl-D-aspartate receptors on methylmercury-induced DNA damage in rat frontal cortex. Toxicology 207(2):223–229. 10.1016/j.tox.2004.09.007.15596253
Julvez J, Debes F, Weihe P, . 2010. Sensitivity of continuous performance test (CPT) at age 14 years to developmental methylmercury exposure. Neurotoxicol Teratol 32(6):627–632. 10.1016/j.ntt.2010.08.001.20699117
Julvez J, Smith GD, Golding J, . 2013. Prenatal methylmercury exposure and genetic predisposition to cognitive deficit at age 8 years. Epidemiology 24(5):643–650. 10.1097/EDE.0b013e31829d5c93.23903878
Julvez J, Davey Smith G, Ring S, . 2019. A birth cohort study on the genetic modification of the association of prenatal methylmercury with child cognitive development. Am J Epidemiol 188(10):1784–1793. 10.1093/aje/kwz156.31241132
Julvez J, Lopez-Vicente M, Warembourg C, . 2021. Early life multiple exposures and child cognitive function: A multi-centric birth cohort study in six European countries. Environ Pollut 284:117404. 10.1016/j.envpol.2021.117404.34077897
Jung RC, Aaronson J. 1980. Death following inhalation of mercury vapor at home. West J Med 132(6):539–543.7405205
Jung SJ, Lee SH. 2019. Association between three heavy metals and dry eye disease in Korean adults: Results of the Korean National Health and Nutrition Examination Survey. Korean J Ophthalmol 33(1):26–35. 10.3341/kjo.2018.0065.30746909
Jung W, Kim Y, Lihm H, . 2019. Associations between blood lead, cadmium, and mercury levels with hyperuricemia in the Korean general population: A retrospective analysis of population-based nationally representative data. Int J Rheum Dis 22(8):1435–1444. 10.1111/1756-185x.13632.31215160
Juric AK, Batal M, David W, . 2017. A total diet study and probabilistic assessment risk assessment of dietary mercury exposure among First Nations living on-reserve in Ontario, Canada. Environ Res 158:409–420. 10.1016/j.envres.2017.06.025.28689032
Kagi JHR, Vasak M, Lerch K, . 1984. Structure of mammalian metallothionein. Environ Health Perspect 54:93. 10.2307/3429795.6329671
Kajiwara Y, Yasutake A, Adachi T, . 1996. Methylmercury transport across the placenta via neutral amino acid carrier. Arch Toxicol 70(5):310–314.8852703
Kajiwara Y, Yasutake A, Hirayama K. 1997. Strain difference in methylmercury transport across the placenta. Bull Environ Contam Toxicol 59(5):783–787.9323229
Kakita A, Wakabayashi K, Su M, . 2000. Intrauterine methylmercury intoxication. Consequence of the inherent brain lesions and cognitive dysfunction in maturity. Brain Res 877(2):322–330. 10.1016/s0006-8993(00)02717-7.10986347
Kalač P, Burda J, Stakova I. 1991. Concentrations of lead, cadmium, mercury and copper in mushrooms in the vicinity of a lead smelter. Sci Total Environ 105:109–119. 10.1016/0048-9697(91)90333-a.1925517
Kalish BT, Rifas-Shiman SL, Wright RO, . 2014. Associations of prenatal maternal blood mercury concentrations with early and mid-childhood blood pressure: a prospective study. Environ Res 133:327–333. 10.1016/j.envres.2014.06.004.25019468
Kamycheva E, Goto T, Camargo CA. 2017. Blood levels of lead and mercury and celiac disease seropositivity: the US National Health and Nutrition Examination Survey. Environ Sci Pollut Res Int 24(9):8385–8391. 10.1007/s11356-017-8545-0.28185175
Kanematsu N, Hara M, Kada T. 1980. Rec assay and mutagenicity studies on metal compounds. Mutat Res 77:109–116.6769036
Kang MS, Jeong JY, Seo JH, . 2006. Methylmercury-induced toxicity is mediated by enhanced intracellular calcium through activation of phosphatidylcholine-specific phospholipase C. Toxicol Appl Pharmacol 216(2):206–215. 10.1016/j.taap.2006.04.016.16854443
Kang P, Shin HY, Kim KY. 2021. Association between dyslipidemia and mercury exposure in adults. Int J Environ Res Public Health 18(2):775. 10.3390/ijerph18020775.33477628
Kanluen S, Gottlieb CA. 1991. A clinical pathologic study of four adult cases of acute mercury inhalation toxicity. Arch Pathol Lab Med 115(1):56–60.1987914
Karatela S, Ward N, Paterson J. 2019. Mercury exposure in mother-children pairs in a seafood eating population: Body burden and related factors. Int J Environ Res Public Health 16(12):2238. 10.3390/ijerph16122238.31242636
Karita K, Iwata T, Maeda E, . 2018. Assessment of cardiac autonomic function in relation to methylmercury neurotoxicity. Toxics 6:38. 10.3390/toxics6030038.30036985
Kawahara D, Oshima H, Kosugi H, . 1993. Further epidemiologic study of occupational contact dermatitis in the dental clinic. Contact Dermatitis 28(2):114–115. 10.1111/j.1600-0536.1993.tb03357.x.8458206
Kawasaki Y, Ikeda Y, Yamamoto T, . 1986. Long-term toxicity study of methylmercury chloride in monkeys. J Food Hyg Soc Jpn 27(5):528–552.
Ke T, Gonçalves FM, Gonçalves CL, . 2019. Post-translational modifications in MeHg-induced neurotoxicity. Biochim Biophys Acta Mol Basis Dis 1865(8):2068–2081. 10.1016/j.bbadis.2018.10.024.30385410
Keeler GJ, Hoyner ME, Lamborg CH. 1994. Measurements of atmospheric mercury in the Great Lakes basin. In: Watras CJ, Huckabee JW, eds. Mercury pollution integration and synthesis. Boca Raton, FL: Lewis Publishers, 231–241.
Kelly TJ, Czuczwa JM, Sticksel PR, . 1991. Atmospheric and tributary inputs of toxic substances to Lake Erie. J Great Lakes Res 17(4):504–516. 10.1016/s0380-1330(91)71386-5.
Kendricks DR, Newland MC. 2021. Selective dopaminergic effects on attention and memory in male mice exposed to Methylmercury during adolescence. Neurotoxicol Teratol 87:107016. 10.1016/j.ntt.2021.107016.34274440
Kendricks DR, Boomhower SR, Newland MC. 2020a. Methylmercury, attention, and memory: baseline-dependent effects of adult d-amphetamine and marginal effects of adolescent methylmercury. Neurotoxicology 80:130–139. 10.1016/j.neuro.2020.07.009.32726658
Kendricks DR, Boomhower SR, Arnold MA, . 2020b. Adolescent methylmercury exposure alters short-term remembering, but not sustained attention, in male Long-Evans rats. Neurotoxicology 78:186–194. 10.1016/j.neuro.2020.03.009.32199988
Kendricks DR, Bhattacharya S, Reed MN, . 2022. Impacts of neonatal methylmercury on behavioral flexibility and learning in spatial discrimination reversal and visual signal detection tasks. Neurotoxicology 93:9–21. 10.1016/j.neuro.2022.08.013.36055519
Kern JK, Geier DA, Homme KG, . 2020. Examining the evidence that ethylmercury crosses the blood-brain barrier. Environ Toxicol Pharmacol 74:103312. 10.1016/j.etap.2019.103312.31841767
Kerper LE, Ballatori N, Clarkson TW. 1992. Methylmercury transport across the blood-brain barrier by an amino acid carrier. Am J Physiol 262(5 Pt 2):R761–765. 10.1152/ajpregu.1992.262.5.R761.1590471
Kerry A, Welbourn PM, Prucha B, . 1991. Mercury methylation by sulphate-reducing bacteria from sediments of an acid stressed lake. Water Air Soil Pollut 56(1):565–575. 10.1007/bf00342300.
Kershaw TG, Clarkson TW, Dhahir PH. 1980. The relationship between blood levels and dose of methylmercury in man. Arch Environ Health 35(1):28–36.7189107
Khan MA, Wang F. 2009. Mercury-selenium compounds and their toxicological significance: Toward a molecular understanding of the mercury-selenium antagonism. Environ Toxicol Chem 28(8):1567–1577. 10.1897/08-375.1.19374471
Khan MF, Wang H. 2020. Environmental exposures and autoimmune diseases: contribution of gut microbiome. Front Immunol 10:3094. 10.3389/fimmu.2019.03094.31998327
Khan AT, Atkinson A, Graham TC, . 2001. Uptake and distribution of mercury in rats after repeated administration of mercuric chloride. J Environ Sci Health A Tox Hazard Subst Environ Eng 36(10):2039–2045.11759913
Khan AT, Atkinson A, Graham TC, . 2004. Effects of inorganic mercury on reproductive performance of mice. Food Chem Toxicol 42(4):571–577. 10.1016/j.fct.2003.10.018.15019180
Khayat A, Dencker L. 1983. Whole body and liver distribution of inhaled mercury vapor in the mouse: Influence of ethanol and aminotriazole pretreatment. J Appl Toxicol 3(2):66–74. 10.1002/jat.2550030203.6886298
Khayat A, Dencker L. 1984. Organ and cellular distribution of inhaled metallic mercury in the rat and marmoset monkey (Callithrix jacchus): Influence of ethyl alcohol pretreatment. Acta Pharmacol Toxicol 55(2):145–152. 10.1111/j.1600-0773.1984.tb01977.x.
Khera KS. 1973. Reproductive capability of male rats and mice treated with methyl mercury. Toxicol Appl Pharmacol 24:167–177. 10.1016/0041-008x(73)90136-1.4696301
Khera KS, Tabacova SA. 1973. Effects of methylmercuric chloride on the progeny of mice and rats treated before or during gestation. Food Cosmet Toxicol 11(2):245–254. 10.1016/s0015-6264(73)80491-2.4197780
Khera KS, Iverson F, Hierlihy L, . 1974. Toxicity of methylmercury in neonatal cats. Teratology 10(1):69–76. 10.1002/tera.1420100110.4855228
Khoury ED, Souza Gda S, da Costa CA, . 2015. Somatosensory psychophysical losses in inhabitants of riverside communities of the Tapajos River Basin, Amazon, Brazil: Exposure to methylmercury is possibly involved. PLoS ONE 10(12):e0144625. 10.1371/journal.pone.0144625.26658153
Kim Y, Lee BK. 2012. Associations of blood lead, cadmium, and mercury with estimated glomerular filtration rate in the Korean general population: Analysis of 2008-2010 Korean National Health and Nutrition Examination Survey data. Environ Res 118:124–129. 10.1016/j.envres.2012.06.003.22749111
Kim K, Park H. 2023. Association of mercury exposure with the serum high-sensitivity C-reactive protein level in Korean adults. Front Public Health 11:1062741. 10.3389/fpubh.2023.1062741.37056650
Kim CY, Nakai K, Kasanuma Y, . 2000. Comparison of neurobehavioral changes in three inbred strains of mice prenatally exposed to methylmercury. Neurotoxicol Teratol 22(3):397–403. 10.1016/s0892-0362(99)00077-x.10840183
Kim SH, Johnson VJ, Sharma RP. 2003. Oral exposure to inorganic mercury alters T lymphocyte phenotypes and cytokine expression in BALB/c mice. Arch Toxicol 77(11):613–620. 10.1007/s00204-003-0497-0.12928768
Kim BM, Lee BE, Hong YC, . 2011. Mercury levels in maternal and cord blood and attained weight through the 24 months of life. Sci Total Environ 410–411:26–33. 10.1016/j.scitotenv.2011.08.060.
Kim RB, Kim BG, Kim YM, . 2013a. Association between low-level mercury exposure and neurobehavioral functions in Korean adults living in a coastal city. Environ Health Toxicol 28:e2013015. 10.5620/eht.2013.28.e2013015.24303351
Kim H, Kim KN, Hwang JY, . 2013b. Relation between serum folate status and blood mercury concentrations in pregnant women. Nutrition 29(3):514–518. 10.1016/j.nut.2012.08.012.23274092
Kim YN, Kim YA, Yang AR, . 2014. Relationship between blood mercury level and risk of cardiovascular diseases: Results from the fourth Korea National Health and Nutrition Examination Survey (KNHANES IV) 2008-2009. Prev Nutr Food Sci 19(4):333–342. 10.3746/pnf.2014.19.4.333.25580399
Kim KN, Bae S, Park HY, . 2015a. Low-level mercury exposure and risk of asthma in school-age children. Epidemiology 26(5):733–739. 10.1097/ede.0000000000000351.26154023
Kim NH, Hyun YY, Lee KB, . 2015b. Environmental heavy metal exposure and chronic kidney disease in the general population. J Korean Med Sci 30(3):272–277. 10.3346/jkms.2015.30.3.272.25729249
Kim KN, Park SJ, Choi B, . 2015c. Blood mercury and insulin resistance in nondiabetic Koreans (KNHANES 2008-2010). Yonsei Med J 56(4):944–950. 10.3349/ymj.2015.56.4.944.26069115
Kim JH, Lee KH, Hong SC, . 2015d. Association between serum mercury concentration and leukocyte differential count in children. Pediatr Hematol Oncol 32(2):109–114. 10.3109/08880018.2013.853222.24274666
Kim YH, Shim JY, Seo MS, . 2016a. Relationship between blood mercury concentration and bone mineral density in Korean men in the 2008-2010 Korean National Health and Nutrition Examination Survey. Korean J Fam Med 37(5):273–278. 10.4082/kjfm.2016.37.5.273.27688860
Kim SA, Kwon Y, Kim S, . 2016b. Assessment of dietary mercury intake and blood mercury levels in the Korean population: Results from the Korean National Environmental Health Survey 2012-2014. Int J Environ Res Public Health 13(9):13090877. 10.3390/ijerph13090877.
Kim BM, Chen MH, Chen PC, . 2017. Path analysis of prenatal mercury levels and birth weights in Korean and Taiwanese birth cohorts. Sci Total Environ 605–606:1003–1010. 10.1016/j.scitotenv.2017.06.151.
Kim Y, Ha EH, Park H, . 2018. Prenatal mercury exposure, fish intake and neurocognitive development during first three years of life: Prospective cohort mothers and Children’s environmental health (MOCEH) study. Sci Total Environ 615:1192–1198. 10.1016/j.scitotenv.2017.10.014.29751424
Kim B, Shah S, Park HS, . 2020a. Adverse effects of prenatal mercury exposure on neurodevelopment during the first 3 years of life modified by early growth velocity and prenatal maternal folate level. Environ Res 191:109909. 10.1016/j.envres.2020.109909.32871452
Kim KW, Sreeja SR, Kwon M, . 2020b. Association of blood mercury level with the risk of depression according to fish intake level in the general Korean population: Findings from the Korean National Health and Nutrition Examination Survey (KNHANES) 2008-2013. Nutrients 12(1):189. 10.3390/nu12010189.31936641
Kim SS, Meeker JD, Aung MT, . 2020c. Urinary trace metals in association with fetal ultrasound measures during pregnancy. Environ Epidemiol 4(2):e075. 10.1097/ee9.0000000000000075.32201854
Kim DW, Ock J, Moon KW, . 2021a. Association between Pb, Cd, and Hg exposure and liver injury among Korean adults. Int J Environ Res Public Health 18(13):6783. 10.3390/ijerph18136783.34202682
Kim MJ, Kim S, Choi S, . 2021b. Association of exposure to polycyclic aromatic hydrocarbons and heavy metals with thyroid hormones in general adult population and potential mechanisms. Sci Total Environ 762:144227. 10.1016/j.scitotenv.2020.144227.33373756
Kim DW, Ock J, Moon KW, . 2022a. Association between heavy metal exposure and dyslipidemia among Korean adults: From the Korean National Environmental Health Survey, 2015-2017. Int J Environ Res Public Health 19(6):3181. 10.3390/ijerph19063181.35328872
Kim K, Argos M, Persky VW, . 2022b. Associations of exposure to metal and metal mixtures with thyroid hormones: Results from the NHANES 2007-2012. Environ Res 212(Pt C):113413. 10.1016/j.envres.2022.113413.35537494
King G. 1954. Acute pneumonitis due to accidental exposure to mercury vapor. Ariz Med 11:335.13189795
Kirk JL, Lehnherr I, Andersson M, . 2012. Mercury in Arctic marine ecosystems: sources, pathways and exposure. Environ Res 119:64–87. 10.1016/j.envres.2012.08.012.23102902
Kirkpatrick M, Benoit J, Everett W, . 2015. The effects of methylmercury exposure on behavior and biomarkers of oxidative stress in adult mice. Neurotoxicology 50:170–178. 10.1016/j.neuro.2015.07.001.26151194
Kishi R, Hashimoto K, Shimizu S, . 1978. Behavioral changes and mercury concentrations in tissues of rats exposed to mercury vapor. Toxicol Appl Pharmacol 46(3):555–566. 10.1016/0041-008x(78)90303-4.746548
Kjellstrom T, Kennedy P, Wallis S, . 1986. Physical and mental development of children with prenatal exposure to mercury from fish. Stage I: Preliminary tests at age 4. Solna, Sweden: National Swedish Environmental Board. Report 3080.
Kjellstrom T, Kennedy P, Wallis S, . 1989. Physical and mental development of children with prenatal exposure to mercury from fish. Stage 2: Interviews and psychological tests at age 6. Solna, Sweden: National Swedish Environmental Protection Board. Report 3642.
Kobal AB, Horvat M, Prezelj M, . 2004. The impact of long-term past exposure to elemental mercury on antioxidative capacity and lipid peroxidation in mercury miners. J Trace Elem Med Biol 17(4):261–274. 10.1016/s0946-672x(04)80028-2.15139389
Kobayashi S, Kishi R, Saijo Y, . 2019. Association of blood mercury levels during pregnancy with infant birth size by blood selenium levels in the Japan Environment and Children’s Study: A prospective birth cohort. Environ Int 125:418–429. 10.1016/j.envint.2019.01.051.30743147
Kobayashi S, Itoh S, Miyashita C, . 2022. Impact of prenatal exposure to mercury and selenium on neurodevelopmental delay in children in the Japan environment and Children’s study using the ASQ-3 questionnaire: A prospective birth cohort. Environ Int 168:107448. 10.1016/j.envint.2022.107448.35964534
Koch P, Bahmer FA. 1999. Oral lesions and symptoms related to metals used in dental restorations: a clinical, allergological, and histologic study. J Am Acad Dermatol 41(3 Pt 1):422–430. 10.1016/s0190-9622(99)70116-7.10459117
Koh AS, Simmons-Willis TA, Pritchard JB, . 2002. Identification of a mechanism by which the methylmercury antidotes N-acetylcysteine and dimercaptopropanesulfonate enhance urinary metal excretion: transport by the renal organic anion transporter-1. Mol Pharmacol 62(4):921–926.12237339
Kohler CC, Heidinger RC, Call T. 1990. Levels of PCBs and trace metals in crab orchard lake sediment, benthos, zooplankton and fish. Carbondale, IL: University of South Illinois. HWRICRR-043.
Koller LD, Exon JH, Arbogast B. 1977. Methylmercury: Effect on serum enzymes and humoral antibody. J Toxicol Environ Health 2(5):1115–1123. 10.1080/15287397709529509.864783
Komsta-Szumska E, Chmielnicka J, Piotrowski JK. 1976. Binding of inorganic mercury by subcellar fractions and proteins of rat kidneys. Arch Toxicol 37(1):57–66. 10.1007/bf00353355.1036908
Koopsamy Naidoo SV, Bester MJ, Arbi S, . 2019. Oral exposure to cadmium and mercury alone and in combination causes damage to the lung tissue of Sprague-Dawley rats. Environ Toxicol Pharmacol 69:86–94. 10.1016/j.etap.2019.03.021.30981014
Kopec AD, Kidd KA, Fisher NS, . 2019. Spatial and temporal trends of mercury in the aquatic food web of the lower Penobscot River, Maine, USA, affected by a chlor-alkali plant. Sci Total Environ 649:770–791. 10.1016/j.scitotenv.2018.08.203.30176487
Kort SAR, Wickliffe J, Shankar A, . 2022. The association between mercury and lead exposure and liver and kidney function in pregnant Surinamese women enrolled in the Caribbean Consortium for Research in Environmental and Occupational Health (CCREOH) environmental epidemiologic cohort study. Toxics 10(10):584. 10.3390/toxics10100584.36287864
Kosta L, Byrne AR, Zelenko V. 1975. Correlation between selenium and mercury in man following exposure to inorganic mercury. Nature 254(5497):238–239. 10.1038/254238a0.1113885
Kostial K, Kargačin B, Landeka M. 1984. Influence of dietary ingredients on the body retention of strontium, cadmium and mercury in suckling rats. Toxicol Lett 23(2):163–168. 10.1016/0378-4274(84)90121-8.6506091
Kostial K, Kello D, Jugo S, . 1978. Influence of age on metal metabolism and toxicity. Environ Health Perspect 25:81–86. 10.1289/ehp.782581.720306
Kostial K, Restek-Samarzija N, Blanusa M, . 1997. Racemic-2,3-dimercaptosuccinic acid for inorganic mercury mobilization in rats. J Appl Toxicol 17(1):71–74.9048230
Kostyniak PJ. 1983. Pharmacokinetics of methylmercury in sheep. J Appl Toxicol 3(1):35–38.6875174
Krabbenhoft DP, Babiarz CL. 1992. The role of groundwater transport in aquatic mercury cycling. Water Resour Res 28(12):3119–3128. 10.1029/92wr01766.
Krystek P, Favaro P, Bode P, . 2012. Methyl mercury in nail clippings in relation to fish consumption analysis with gas chromatography coupled to inductively coupled plasma mass spectrometry: a first orientation. Talanta 97:83–86. 10.1016/j.talanta.2012.03.065.22841050
Kvestad I, Vabø S, Kjellevold M, . 2018. Fatty fish, hair mercury and cognitive function in Norwegian preschool children: Results from the randomized controlled trial FINS-KIDS. Environ Int 121(Pt 2):1098–1105. 10.1016/j.envint.2018.10.022.30360881
Laine J, Kalimo K, Happonen RP. 1997. Contact allergy to dental restorative materials in patients with oral lichenoid lesions. Contact Dermatitis 36(3):141–146. 10.1111/j.1600-0536.1997.tb00396.x.9145263
Lam HS, Kwok KM, Chan PH, . 2013. Long term neurocognitive impact of low dose prenatal methylmercury exposure in Hong Kong. Environ Int 54:59–64. 10.1016/j.envint.2013.01.005.23416249
Langolf GD, Chaffin DB, Henderson R, . 1978. Evaluation of workers exposed to elemental mercury using quantitative tests of tremor and neuromuscular functions. Am Ind Hyg Assoc J 39(12):976–984. 10.1080/0002889778507898.742601
Langworth S, Kölbeck KG, Akesson A. 1988. Mercury exposure from dental fillings. II. Release and absorption. Swed Dent J 12(1–2):71–72.3164919
Langworth S, Almkvist O, Soderman E, . 1992a. Effects of occupational exposure to mercury vapour on the central nervous system. Occup Environ Med 49(8):545–555. 10.1136/oem.49.8.545.
Langworth S, Elinder CG, Sundquist KG, . 1992b. Renal and immunological effects of occupational exposure to inorganic mercury. Br J Ind Med 49(6):394–401. 10.1136/oem.49.6.394.1606025
Larsen JO, Brændgaard H. 1995. Structural preservation of cerebellar granule cells following neurointoxication with methyl mercury: A stereological study of the rat cerebellum. Acta Neuropathol 90:251–256. 10.1007/BF00296508.8525798
Larsen TJ, Jørgensen ME, Larsen CVL, . 2018. Whole blood mercury and the risk of cardiovascular disease among the Greenlandic population. Environ Res 164:310–315. 10.1016/j.envres.2018.03.003.29554622
Lash LH, Jones DP. 1985. Uptake of the glutathione conjugate S-(1,2-dichlorovinyl)glutathione by renal basal-lateral membrane vesicles and isolated kidney cells. Mol Pharmacol 28(3):278–282.3839897
Laue HE, Moroishi Y, Jackson BP, . 2020. Nutrient-toxic element mixtures and the early postnatal gut microbiome in a United States longitudinal birth cohort. Environ Int 138:105613. 10.1016/j.envint.2020.105613.32142916
Lauwerys R, Bonnier C, Evrard P, . 1987. Prenatal and early postnatal intoxication by inorganic mercury resulting from the maternal use of mercury containing soap. Hum Toxicol 6(3):253–256. 10.1177/096032718700600316.3596613
Lebel J, Mergler D, Lucotte M, . 1996. Evidence of early nervous system dysfunction in Amazonian populations exposed to low-levels of methylmercury. Neurotoxicology 17(1):157–167.8784826
Lebel J, Mergler D, Branches F, . 1998. Neurotoxic effects of low-level methylmercury contamination in the Amazonian Basin. Environ Res 79(1):20–32.9756677
Lecavalier PR, Chu I, Villeneuve D, . 1994. Combined effects of mercury and hexachlorobenzene in the rat. J Environ Sci Health B 29(5):951–961. 10.1080/03601239409372911.8089432
Lederman SA, Jones RL, Caldwell KL, . 2008. Relation between cord blood mercury levels and early child development in a World Trade Center cohort. Environ Health Perspect 116(8):1085–1091. 10.1289/ehp.10831.18709170
Lee Y, Iverfeldt A. 1991. Measurement of methylmercury and mercury in run-off, lake and rain waters. Water Air Soil Pollut 56(1):309–321. 10.1007/bf00342279.
Lee JH, Han DH. 1995. Maternal and fetal toxicity of methylmercuric chloride administered to pregnant Fischer 344 rats. J Toxicol Environ Health 45(4):415–425. 10.1080/15287399509532005.7643429
Lee E, Park HK, Kim HJ. 1996. Adjustment of urinary mercury in health risk assessment of mercury. J Korean Med Sci 11(4):319–325. 10.3346/jkms.1996.11.4.319.8878800
Lee CH, Lin RH, Liu SH, . 1997. Distinct genotoxicity of phenylmercury acetate in human lymphocytes as compared with other mercury compounds. Mutat Res 392(3):269–276.9294027
Lee BE, Hong YC, Park H, . 2010. Interaction between GSTM1/GSTT1 polymorphism and blood mercury on birth weight. Environ Health Perspect 118(3):437–443. 10.1289/ehp.0900731.20194072
Lee H, Kim Y, Sim CS, . 2014. Associations between blood mercury levels and subclinical changes in liver enzymes among South Korean general adults: analysis of 2008-2012 Korean national health and nutrition examination survey data. Environ Res 130:14–19. 10.1016/j.envres.2014.01.005.24525240
Lee S, Yoon JH, Won JU, . 2016. The association between blood mercury levels and risk for overweight in a general adult population: Results from the Korean National Health and Nutrition Examination Survey. Biol Trace Elem Res 171(2):251–261. 10.1007/s12011-015-0530-1.26458904
Lee MR, Lim YH, Lee BE, . 2017a. Blood mercury concentrations are associated with decline in liver function in an elderly population: a panel study. Environ Health 16(1):17. 10.1186/s12940-017-0228-2.28257627
Lee S, Tan YM, Phillips MB, . 2017b. Estimating methylmercury intake for the general population of South Korea using physiologically based pharmacokinetic modeling. Toxicol Sci 159(1):6–15. 10.1093/toxsci/kfx111.28903490
Lee DH, Keum N, Hu FB, . 2017c. Development and validation of anthropometric prediction equations for lean body mass, fat mass and percent fat in adults using the National Health and Nutrition Examination Survey (NHANES) 1999–2006. Br J Nutr 118(10):858–866. 10.1017/s0007114517002665.29110742
Lee SH, Choi B, Park SJ, . 2017d. The cut-off value of blood mercury concentration in relation to insulin resistance. J Obes Metab Syndr 26(3):197–203. 10.7570/jomes.2017.26.3.197.31089517
Lee TW, Kim DH, Ryu JY. 2019. The effects of exposure to lead, cadmium and mercury on follicle-stimulating hormone levels in men and postmenopausal women: data from the Second Korean National Environmental Health Survey (2012-2014). Ann Occup Environ Med 31:e21. 10.35371/aoem.2019.31.e21.31620298
Lee S, Cho SR, Jeong I, . 2020a. Mercury exposure and associations with hyperlipidemia and elevated liver enzymes: A nationwide cross-sectional survey. Toxics 8(3):47. 10.3390/toxics8030047.32630237
Lee S, Hong YC, Park H, . 2020b. Combined effects of multiple prenatal exposure to pollutants on birth weight: The Mothers and Children’s Environmental Health (MOCEH) study. Environ Res 181:108832. 10.1016/j.envres.2019.108832.31810591
Leggett RW, Munro NB, Eckerman KF. 2001. Proposed revision of the ICRP model for inhaled mercury vapor. Health Phys 81(4):450–455.11569640
Leistevuo J, Leistevuo T, Helenius H, . 2001. Dental amalgam fillings and the amount of organic mercury in human saliva. Caries Res 35(3):163–166. 10.1159/000047450.11385194
Leong CC, Syed NI, Lorscheider FL. 2001. Retrograde degeneration of neurite membrane structural integrity of nerve growth cones following in vitro exposure to mercury. Neuroreport 12(4):733–737.11277574
Lescord GL, Johnston TA, Branfireun BA, . 2018. Percentage of methylmercury in the muscle tissue of freshwater fish varies with body size and age and among species. Environ Toxicol Chem 37(10):2682–2691. 10.1002/etc.4233.30024049
Letz R, Gerr F, Cragle D, . 2000. Residual neurologic deficits 30 years after occupational exposure to elemental mercury. Neurotoxicology 21(4):459–474.11022856
Leung TY, Choy CM, Yim SF, . 2001. Whole blood mercury concentrations in sub-fertile men in Hong Kong. Aust N Z J Obstet Gynaecol 41(1):75–77. 10.1111/j.1479-828x.2001.tb01298.x.11284652
Levey AS, Stevens LA, Schmid CH, . 2009. A new equation to estimate glomerular filtration rate. Ann Intern Med 150(9):604. 10.7326/0003-4819-150-9-200905050-00006.19414839
Levine SP, Cavender GD, Langolf GD, . 1982. Elemental mercury exposure: Peripheral neurotoxicity. Occup Environ Med 39(2):136–139. 10.1136/oem.39.2.136.
Lewis RJ. 1993. Mercury. In: Hawley’s condensed chemical dictionary. 12^th^ ed. New York, NY: John Wiley & Sons, Inc., 739–741, 743–745, 901.
Li W, Wang WX. 2019. In vivo oral bioavailability of fish mercury and comparison with in vitro bioaccessibility. Sci Total Environ 683:648–658. 10.1016/j.scitotenv.2019.05.290.31150885
Li Y, Zhang B, Yang L, . 2013. Blood mercury concentration among residents of a historic mercury mine and possible effects on renal function: a cross-sectional study in southwestern China. Environ Monit Assess 185(4):3049–3055. 10.1007/s10661-012-2772-0.22791021
Li P, Du B, Chan HM, . 2015. Human inorganic mercury exposure, renal effects and possible pathways in Wanshan mercury mining area, China. Environ Res 140:198–204. 10.1016/j.envres.2015.03.033.25863593
Li S, Baiyun R, Lv Z, . 2019a. Exploring the kidney hazard of exposure to mercuric chloride in mice: Disorder of mitochondrial dynamics induces oxidative stress and results in apoptosis. Chemosphere 234:822–829. 10.1016/j.chemosphere.2019.06.096.31247492
Li H, Lin X, Zhao J, . 2019b. Intestinal methylation and demethylation of mercury. Bull Environ Contam Toxicol 102(5):597–604. 10.1007/s00128-018-2512-4.30515547
Li P, Yin R, Du B, . 2020. Kinetics and metabolism of mercury in rats fed with mercury contaminated rice using mass balance and mercury isotope approach. Sci Total Environ 736:139687. 10.1016/j.scitotenv.2020.139687.32485364
Li W, Li X, Su J, . 2023. Associations of blood metals with liver function: Analysis of NHANES from 2011 to 2018. Chemosphere 317:137854. 10.1016/j.chemosphere.2023.137854.36649900
Liang JH, Pu YQ, Liu ML, . 2023. Joint effect of whole blood metals exposure with dyslipidemia in representative US adults in NHANES 2011-2020. Environ Sci Pollut Res Int 30(42):96604–96616. 10.1007/s11356-023-28903-0.37578581
Liberda EN, Tsuji LJ, Martin ID, . 2014. The complexity of hair/blood mercury concentration ratios and its implications. Environ Res 134:286–294. 10.1016/j.envres.2014.08.007.25194499
Lilis R, Miller A, Lerman Y. 1985. Acute mercury poisoning with severe chronic pulmonary manifestations. Chest 88(2):306–309. 10.1378/chest.88.2.306.4017688
Lim HS, Lee HH, Kim TH, . 2016. Relationship between heavy metal exposure and bone mineral density in Korean adult. J Bone Metab 23(4):223–231. 10.11005/jbm.2016.23.4.223.27965944
Lin YS, Ginsberg G, Caffrey JL, . 2014a. Association of body burden of mercury with liver function test status in the U.S. population. Environ Int 70:88–94. 10.1016/j.envint.2014.05.010.24908642
Lin YS, Ginsberg G, Lin JW, . 2014b. Mercury exposure and omega-3 fatty acid intake in relation to renal function in the US population. Int J Hyg Environ Health 217(4–5):465–472. 10.1016/j.ijheh.2013.09.004.24189320
Lin PD, Cardenas A, Rifas-Shiman SL, . 2023. Non-essential and essential trace element mixtures and kidney function in early pregnancy - A cross-sectional analysis in project viva. Environ Res 216(Pt 4):114846. 10.1016/j.envres.2022.114846.36402181
Lindberg SE, Turner RR, Meyers TP, . 1991. Atmospheric concentrations and deposition of Hg to a deciduous forest at Walker Branch Watershed, Tennessee, USA. Water Air Soil Pollut 56(1):577–594. 10.1007/bf00342301.
Lindberg SE, Owens JG, Stratton WJ. 1994. Application of throughfall methods to estimate dry deposition of mercury. In: Watras CJ, Huckabee JW, eds. Mercury pollution integration and synthesis. Boca Raton, FL: Lewis Publishers, 261–271.
Lindqvist O, Johansson K, Bringmark L, . 1991. Mercury in the Swedish environment - Recent research on causes, consequences and corrective methods. Water Air Soil Pollut 55(1–2):xi–261. 10.1007/bf00542429.
Liu T, Zhang M, Guallar E, . 2019. Trace minerals, heavy metals, and preeclampsia: Findings from the Boston Birth Cohort. J Am Heart Assoc 8(16):e012436. 10.1161/jaha.119.012436.31426704
Liu J, Portnoy J, Um P, . 2021a. Blood lead and mercury levels are associated with low resting heart rate in community adolescent boys. Int J Hyg Environ Health 233:113685. 10.1016/j.ijheh.2020.113685.33556713
Liu M, Song J, Jiang Y, . 2021b. A case-control study on the association of mineral elements exposure and thyroid tumor and goiter. Ecotoxicol Environ Saf 208:111615. 10.1016/j.ecoenv.2020.111615.33396135
Liu Y, Zhang C, Qin Z, . 2022. Analysis of threshold effect of urinary heavy metal elements on the high prevalence of nephrolithiasis in men. Biol Trace Elem Res 200(3):1078–1088. 10.1007/s12011-021-02740-z.34263420
Liu Q, Hu S, Fan F, . 2023. Association of blood metals with serum sex hormones in adults: A cross-sectional study. Environ Sci Pollut Res Int 30(26):69628–69638. 10.1007/s11356-023-27384-5.37140863
Livardjani F, Ledig M, Kopp P, . 1991. Lung and blood superoxide dismutase activity in mercury vapor exposed rats: Effect of N-acetylcysteine treatment. Toxicology 66(3):289–295. 10.1016/0300-483x(91)90200-k.2011853
Llop S, Guxens M, Murcia M, . 2012. Prenatal exposure to mercury and infant neurodevelopment in a multicenter cohort in Spain: study of potential modifiers. Am J Epidemiol 175(5):451–465. 10.1093/aje/kwr328.22287639
Llop S, Lopez-Espinosa MJ, Murcia M, . 2015. Synergism between exposure to mercury and use of iodine supplements on thyroid hormones in pregnant women. Environ Res 138:298–305. 10.1016/j.envres.2015.02.026.25749125
Loan A, Leung JW, Cook DP, . 2023. Prenatal low-dose methylmercury exposure causes premature neuronal differentiation and autism-like behaviors in a rodent model. iScience 26(3):106093. 10.1016/j.isci.2023.106093.36843845
Lodenius M, Autio S. 1989. Effects of acidification on the mobilization of cadmium and mercury from soils. Arch Environ Contam Toxicol 18(1–2):261–267. 10.1007/bf01056212.
Lohren H, Bornhorst J, Galla H-J, . 2015. The blood–cerebrospinal fluid barrier – first evidence for an active transport of organic mercury compounds out of the brain. Metallomics 7(10):1420–1430. 10.1039/c5mt00171d.26267314
Lomonte C, Doronila AI, Gregory D, . 2010. Phytotoxicity of biosolids and screening of selected plant species with potential for mercury phytoextraction. J Hazard Mater 173(1–3):494–501. 10.1016/j.jhazmat.2009.08.112.19775810
Long LH, Cattanach J. 1961. Antoine vapour-pressure equations and heats of vaporization for the dimethyls of zinc, cadmium and mercury. J Inorg Nucl Chem 20(3–4):340–342. 10.1016/0022-1902(61)80285-6.
Lopez AM, Fitzsimmons JN, Adams HM, . 2022. A time-series of heavy metal geochemistry in sediments of Galveston Bay estuary, Texas, 2017-2019. Sci Total Environ 806(Pt 3):150446. 10.1016/j.scitotenv.2021.150446.34599961
Louopou RC, Trottier H, Arbuckle TE, . 2020. Dental amalgams and risk of gestational hypertension in the MIREC study. Pregnancy Hypertens 21:84–89. 10.1016/j.preghy.2020.04.015.32447273
Love TM, Thurston SW, Davidson PW. 2017. Finding vulnerable subpopulations in the Seychelles Child Development Study: Effect modification with latent groups. Stat Methods Med Res 26(2):809–822. 10.1177/0962280214560044.25512145
Lovejoy HB, Bell ZG, Vizena TR. 1973. Mercury exposure evaluations and their correlation with urine mercury excretions. 4. Elimination of mercury by sweating. J Occup Med 15(7):590–591.4711652
Lozano M, Murcia M, Soler-Blasco R, . 2021. Exposure to mercury among 9-year-old children and neurobehavioural function. Environ Int 146:106173. 10.1016/j.envint.2020.106173.33096466
Lu Z, Ma Y, Gao L, . 2018. Urine mercury levels correlate with DNA methylation of imprinting gene H19 in the sperm of reproductive-aged men. PLoS ONE 13(4):e0196314. 10.1371/journal.pone.0196314.29698523
Lu YT, Qi WZ, Wang S, . 2020. Toxicity and risk assessment of mercury exposures from cinnabar and Baizi Yangxin Pills based on pharmacokinetic and tissue distribution studies. J Ethnopharmacol 250:112489. 10.1016/j.jep.2019.112489.31866510
Lu K, Liu T, Wu X, . 2023. Association between serum iron, blood lead, cadmium, mercury, selenium, manganese and low cognitive performance in old adults from National Health and Nutrition Examination Survey (NHANES): a cross-sectional study. Br J Nutr 130(10):1743–1753. 10.1017/s0007114523000740.36941743
Luecke RH, Wosilait WD, Pearce BA, . 1994. A physiologically based pharmacokinetic computer model for human pregnancy. Teratology 49(2):90–103. 10.1002/tera.1420490205.8016750
Luecke RH, Wosilait WD, Pearce BA, . 1997. A computer model and program for xenobiotic disposition during pregnancy. Comput Methods Programs Biomed 53(3):201–224.9230455
Lukacinova A, Benacka R, Sedlakova E, . 2012. Multigenerational lifetime low-dose exposure to heavy metals on selected reproductive parameters in rats. J Environ Sci Health A Tox Hazard Subst Environ Eng 47(9):1280–1287. 10.1080/10934529.2012.672132.22540652
Lukina AO, Fisher M, Khoury C, . 2021. Temporal variation of total mercury levels in the hair of pregnant women from the Maternal-Infant Research on Environmental Chemicals (MIREC) study. Chemosphere 264(Pt 1):128402. 10.1016/j.chemosphere.2020.128402.33022505
Lundgren KD, Swensson Å, Ulfvarson U. 1967. Studies in humans on the distribution of mercury in the blood and the excretion in urine after exposure to different mercury compounds. Scand J Clin Lab Invest 20(2):164–166. 10.3109/00365516709076937.
Lyman SN, Cheng I, Gratz LE, . 2020. An updated review of atmospheric mercury. Sci Total Environ 707:135575. 10.1016/j.scitotenv.2019.135575.31784172
Ma J, Zhang H, Zheng T, . 2022. Exposure to metal mixtures and hypertensive disorders of pregnancy: A nested case-control study in China. Environ Pollut 306:119439. 10.1016/j.envpol.2022.119439.35550130
Ma Y, Liang C, Wang Z, . 2023. Association between prenatal metals exposure and blood pressure in 5-6 years children: A birth cohort study. Environ Res 219:114974. 10.1016/j.envres.2022.114974.36463992
Mabille V, Roels H, Jacquet P, . 1984. Cytogenetic examination of leucocytes of workers exposed to mercury vapour. Int Arch Occup Environ Health 53(3):257–260. 10.1007/bf00398818.6706421
MacDonald JS, Harbison RD. 1977. Methyl mercury-induced encephalopathy in mice. Toxicol Appl Pharmacol 39(2):195–205. 10.1016/0041-008x(77)90153-3.847752
Mackert JR, Berglund A. 1997. Mercury exposure from dental amalgam fillings: Absorbed dose and the potential for adverse health effects. Crit Rev Oral Biol Med 8(4):410–436.9391753
MacPherson S, Arbuckle TE, Fisher M. 2018. Adjusting urinary chemical biomarkers for hydration status during pregnancy. J Expo Sci Environ Epidemiol 28(5):481–493. 10.1038/s41370-018-0043-z.29880833
MacSween K, Stupple G, Aas W, . 2022. Updated trends for atmospheric mercury in the Arctic: 1995-2018. Sci Total Environ 837:155802. 10.1016/j.scitotenv.2022.155802.35550896
Maeda E, Murata K, Kumazawa Y, . 2019. Associations of environmental exposures to methylmercury and selenium with female infertility: A case-control study. Environ Res 168:357–363. 10.1016/j.envres.2018.10.007.30384229
Magos L. 1967. Mercury-blood interaction and mercury uptake by the brain after vapor exposure. Environ Res 1(4):323–337.5602290
Magos L, Clarkson TW. 2006. Overview of the clinical toxicity of mercury. Ann Clin Biochem 43(Pt 4):257–268. 10.1258/000456306777695654.16824275
Magos L, Halbach S, Clarkson TW. 1978. Role of catalase in the oxidation of mercury vapor. Biochem Pharmacol 27(9):1373–1377. 10.1016/0006-2952(78)90122-3.567993
Magos L, Clarkson TW, Hudson AR. 1989. The effects of dose of elemental mercury and first-pass circulation time on exhalation and organ distribution of inorganic mercury in rats. Biochim Biophys Acta 991(1):85–89. 10.1016/0304-4165(89)90032-9.2713425
Mahaffey KR, Clickner RP, Jeffries RA. 2009. Adult women’s blood mercury concentrations vary regionally in the United States: association with patterns of fish consumption (NHANES 1999-2004). Environ Health Perspect 117(1):47–53. 10.1289/ehp.11674.19165386
Mahour K, Saxena PN. 2009. Assessment of haematotoxic potential of mercuric chloride in rat. J Environ Biol 30(5 Suppl):927–928.20143731
Mailhes JB. 1983. Methylmercury effects on Syrian hamster metaphase II oocyte chromosomes. Environ Mutagen 5(5):679–686.6617598
Malqui H, Anarghou H, Ouardi FZ, . 2018. Continuous exposure to inorganic mercury affects neurobehavioral and physiological parameters in mice. J Mol Neurosci 66(2):291–305. 10.1007/s12031-018-1176-1.30251082
Mansour MM, Dyer NC, Hoffman LH, . 1974. Placental transfer of mercuric nitrate and methyl mercury in the rat. Am J Obstet Gynecol 119(4):557–562. 10.1016/0002-9378(74)90220-8.4841448
Manzolli ES, Serpeloni JM, Grotto D, . 2015. Protective effects of the flavonoid chrysin against methylmercury-induced genotoxicity and alterations of antioxidant status, in vivo. Oxid Med Cell Longev 2015:1–7. 10.1155/2015/602360.
Mao X, Chen C, Xun P, . 2019. Effects of seafood consumption and toenail mercury and selenium levels on cognitive function among American adults: 25 y of follow up. Nutrition 61:77–83. 10.1016/j.nut.2018.11.002.30703573
Maqbool F, Niaz K, Hassan FI, . 2017. Immunotoxicity of mercury: Pathological and toxicological effects. J Environ Sci Health C Environ Carcinog Ecotoxicol Rev 35(1):29–46. 10.1080/10590501.2016.1278299.28055311
Maqbool F, Bahadar H, Hassani S, . 2019. Biochemical evidence on the potential role of methyl mercury in hepatic glucose metabolism through inflammatory signaling and free radical pathways. J Cell Biochem 120(9):16195–16205. 10.1002/jcb.28899.31081130
Marien K, Patrick GM. 2001. Exposure analysis of five fish-consuming populations for overexposure to methylmercury. J Expo Anal Environ Epidemiol 11(3):193–206. 10.1038/sj.jea.7500160.11477517
Marinho JS, Lima MO, de Oliveira Santos EC, . 2014. Mercury speciation in hair of children in three communities of the Amazon, Brazil. BioMed Res Int 2014:1–9. 10.1155/2014/945963.
Marques RC, Garrofe Dorea J, Rodrigues Bastos W, . 2007. Maternal mercury exposure and neuro-motor development in breastfed infants from Porto Velho (Amazon), Brazil. Int J Hyg Environ Health 210(1):51–60. 10.1016/j.ijheh.2006.08.001.17011234
Marques RC, Bernardi JV, Dórea JG, . 2013a. Mercury transfer during pregnancy and breastfeeding: hair mercury concentrations as biomarker. Biol Trace Elem Res 154(3):326–332. 10.1007/s12011-013-9743-3.23836367
Marques RC, Bernardi JV, Dórea JG, . 2013b. Fish consumption during pregnancy, mercury transfer, and birth weight along the Madeira River Basin in Amazonia. Int J Environ Res Public Health 10(6):2150–2163. 10.3390/ijerph10062150.23759951
Marques RC, Moreira Mde F, Bernardi JV, . 2013c. Breast milk lead concentrations of mothers living near tin smelters. Bull Environ Contam Toxicol 91(5):549–554. 10.1007/s00128-013-1093-5.24068462
Marques RC, Bernardi JV, Abreu L, . 2015. Neurodevelopment outcomes in children exposed to organic mercury from multiple sources in a tin-ore mine environment in Brazil. Arch Environ Contam Toxicol 68(3):432–441. 10.1007/s00244-014-0103-x.25425160
Marsh DO, Clarkson TW, Cox C, . 1987. Fetal methylmercury poisoning: Relationship between concentration in single strands of maternal hair and child effects. Arch Neurol 44(10):1017–1022.2443112
Martin MD, McCann T, Naleway C, . 1996. The validity of spot urine samples for low-level occupational mercury exposure assessment and relationship to porphyrin and creatinine excretion rates. J Pharmacol Exp Ther 277(1):239–244.8613926
Maserejian NN, Trachtenberg FL, Assmann SF, . 2008. Dental amalgam exposure and urinary mercury levels in children: The New England Children’s Amalgam Trial. Environ Health Perspect 116(2):256–262. 10.1289/ehp.10440.18288327
Mason RP, Reinfelder JR, Morel FM. 1995. Bioaccumulation of mercury and methylmercury. In: Porcella DB, Wheatley B, eds. Proceedings of the third international Conference Whistler, British Columbia, July 10-14, 1994. Boston, MA: Kluwer Academic Publishers, 915–921.
Mason RP, Reinfelder JR, Morel FM. 1996. Uptake, toxicity, and trophic transfer of mercury in a coastal diatom. Environ Sci Technol 30(6):1835–1845.
Mathiesen T, Ellingsen DG, Kjuus H. 1999. Neuropsychological effects associated with exposure to mercury vapor among former chloralkali workers. Scand J Work Environ Health 25(4):342–350. 10.5271/sjweh.444.10505660
Matsumoto N, Spindle A. 1982. Sensitivity of early mouse embryos to methylmercury toxicity. Toxicol Appl Pharmacol 64(1):108–117.7112574
Matsuo N, Suzuki T, Akagi H. 1989. Mercury concentration in organs of contemporary Japanese. Arch Environ Health 44(5):298–303.2817960
Matthews NH, Koh M, Li WQ, . 2019. A prospective study of toenail trace element levels and risk of skin cancer. Cancer Epidemiol Biomarkers Prev 28(9):1534–1543. 10.1158/1055-9965.EPI-19-0214.31217167
McClam M, Liu J, Fan Y, . 2023. Associations between exposure to cadmium, lead, mercury and mixtures and women’s infertility and long-term amenorrhea. Arch Public Health 81(1):161. 10.1186/s13690-023-01172-6.37626359
McGrother CW, Dugmore C, Phillips MJ, . 1999. Multiple sclerosis, dental caries and fillings: a case-control study. Br Dent J 187(5):261–264. 10.1038/sj.bdj.4800255.10520544
McKean SJ, Bartell SM, Hansen RL, . 2015. Prenatal mercury exposure, autism, and developmental delay, using pharmacokinetic combination of newborn blood concentrations and questionnaire data: a case control study. Environ Health 14:62. 10.1186/s12940-015-0045-4.26198445
McKelvey W, Jeffery N, Clark N, . 2011. Population-based inorganic mercury biomonitoring and the identification of skin care products as a source of exposure in New York City. Environ Health Perspect 119(2):203–209. 10.1289/ehp.1002396.20923743
McKelvey W, Alex B, Chernov C, . 2018. Tracking declines in mercury exposure in the New York City adult population, 2004-2014. J Urban Health 95(6):813–825. 10.1007/s11524-018-0269-z.30117056
McKeown-Eyssen GE, Ruedy J, Neims A. 1983. Methyl mercury exposure in northern Quebec. II. Neurologic findings in children. Am J Epidemiol 118(4):470–479. 10.1093/oxfordjournals.aje.a113652.6637974
McSorley EM, Yeates AJ, Mulhern MS, . 2018. Associations of maternal immune response with MeHg exposure at 28 weeks’ gestation in the Seychelles Child Development Study. Am J Reprod Immunol 80(5):e13046. 10.1111/aji.13046.30295973
McSorley EM, van Wijngaarden E, Yeates AJ, . 2020. Methylmercury and long chain polyunsaturated fatty acids are associated with immune dysregulation in young adults from the Seychelles child development study. Environ Res 183:109072. 10.1016/j.envres.2019.109072.32007747
MDN. 2020. Mercury deposition network data. National Atmospheric Deposition Program. http://nadp.slh.wisc.edu/MDN/. December 16, 2020.
Meador JP, Varanasi U, Robisch PA, . 1993. Toxic metals in pilot whales (Globicephala melaena) from strandings in 1986 and 1990 on Cape Cod, Massachusetts. Can J Fish Aquat Sci 50(12):2698–2706.
Medina Pérez OM, Flórez-Vargas O, Rincón Cruz G, . 2021. Glutathione-related genetic polymorphisms are associated with mercury retention and nephrotoxicity in gold-mining settings of a Colombian population. Sci Rep 11(1):8716. 10.1038/s41598-021-88137-3.33888803
Meeker JD, Rossano MG, Protas B, . 2008. Cadmium, lead, and other metals in relation to semen quality: Human evidence for molybdenum as a male reproductive toxicant. Environ Health Perspect 116(11):1473–1479. 10.1289/ehp.11490.19057699
Meili M. 1991. The coupling of mercury and organic matter in the biogeochemical cycle - towards a mechanistic model for the boreal forest zone. Water Air Soil Pollut 56(1):333–347. 10.1007/bf00342281.
Meili M, Iverfeldt A, Håkanson L. 1991. Mercury in the surface water of Swedish forest lakes - concentrations, speciation and controlling factors. Water Air Soil Pollut 56(1):439–453. 10.1007/bf00342290.
Mendiola J, Moreno JM, Roca M, . 2011. Relationships between heavy metal concentrations in three different body fluids and male reproductive parameters: a pilot study. Environ Health 10(1):6. 10.1186/1476-069X-10-6.21247448
Mergler D. 2002. Review of neurobehavioral deficits and river fish consumption from the Tapajos (Brazil) and St. Lawrence (Canada). Environ Toxicol Pharmacol 12(2):93–99. 10.1016/s1382-6689(02)00027-3.21782628
Mergler D, Belanger S, Larribe F, . 1998. Preliminary evidence of neurotoxicity associated with eating fish from the Upper St. Lawrence River Lakes. Neurotoxicology 19(4–5):691–702.9745930
Miao J, Feng S, Dou S, . 2023. Association between mercury exposure and lung function in young adults: A prospective cohort study in Shandong, China. Sci Total Environ 878:162759. 10.1016/j.scitotenv.2023.162759.36907407
Mierle G. 1990. Aqueous inputs of mercury to Precambrian shield lakes in Ontario. Environ Toxicol Chem 9(7):843–851. 10.1002/etc.5620090704.
Miettinen JK, Rahola T, Hattula T, . 1971. Elimination of 203-Hg-methylmercury in man. Ann Clin Res 3(2):116–122.4997252
Migliore L, Cocchi L, Nesti C, . 1999. Micronuclei assay and FISH analysis in human lymphocytes treated with six metal salts. Environ Mol Mutagen 34(4):279–284.10618176
Milioni ALV, Nagy BV, Moura ALA, . 2017. Neurotoxic impact of mercury on the central nervous system evaluated by neuropsychological tests and on the autonomic nervous system evaluated by dynamic pupillometry. Neurotoxicology 59:263–269. 10.1016/j.neuro.2016.04.010.27090823
Miller JM, Chaffin DB, Smith RG. 1975. Subclinical psychomotor and neuromuscular changes in workers exposed to inorganic mercury. Am Ind Hyg Assoc J 36(10):725–733. 10.1080/0002889758507331.1180206
Miller CT, Zawidzka Z, Nagy E, . 1979. Indicators of genetic toxicity in leucocytes and granulocytic precursors after chronic methylmercury ingestion by cats. Bull Environ Contam Toxicol 21(3):296–303.444719
Miller C, Karimi R, Silbernagel S, . 2018. Mercury, omega-3 fatty acids, and seafood intake are not associated with heart rate variability or QT interval. Arch Environ Occup Health 73(4):251–257. 10.1080/19338244.2017.1315360.28379067
Milne J, Christophers A, Silva PD. 1970. Acute mercurial pneumonitis. Occup Environ Med 27(4):334–338. 10.1136/oem.27.4.334.
Mínguez-Alarcón L, Afeiche MC, Williams PL, . 2018. Hair mercury (Hg) levels, fish consumption and semen parameters among men attending a fertility center. Int J Hyg Environ Health 221(2):174–182. 10.1016/j.ijheh.2017.10.014.29102416
Mínguez-Alarcón L, Williams PL, Souter I, . 2021. Hair mercury levels, intake of omega-3 fatty acids and ovarian reserve among women attending a fertility center. Int J Hyg Environ Health 237:113825. 10.1016/j.ijheh.2021.113825.34388609
Minyard JP, Roberts EW. 1991. State findings on pesticide residues in foods-1988 and 1989. J AOAC Int 74(3):438–452. 10.1093/jaoac/74.3.438.
Miskimmin BM. 1991. Effect of natural levels of dissolved organic carbon doc on methyl mercury formation and sediment-water partitioning. Bull Environ Contam Toxicol 47(5):743–750.1813090
Miskimmin BM, Rudd JW, Kelly CA. 1992. Influence of dissolved organic carbon, pH, and microbial respiration rates on mercury methylation and demethylation in lake water. Can J Fish Aquat Sci 49(1):17–22.
Mitsumori K, Maita K, Saito T, . 1981. Carcinogenicity of methylmercury chloride in ICR mice: Preliminary note on renal carcinogenesis. Cancer Lett 12(4):305–310. 10.1016/0304-3835(81)90172-5.7306934
Mitsumori K, Hirano M, Ueda H, . 1990. Chronic toxicity and carcinogenicity of methylmercury chloride in B6C3F1 mice. Fundam Appl Toxicol 14(1):179–190. 10.1016/0272-0590(90)90243-d.2307316
Miyakawa T, Sumiyoshi S, Deshimaru M. 1974. Late changes in sciatic nerve of rats after a small dose of methyl methylmercury sulfide. Acta Neuropathol (Berl) 30(1):33–41. 10.1007/BF00685320.4446959
Miyake Y, Tanaka K, Yasutake A, . 2011. Lack of association of mercury with risk of wheeze and eczema in Japanese children: the Osaka Maternal and Child Health Study. Environ Res 111(8):1180–1184. 10.1016/j.envres.2011.07.003.21807364
Miyashita C, Saijo Y, Ito Y, . 2021. Association between the concentrations of metallic elements in maternal blood during pregnancy and prevalence of abdominal congenital malformations: The Japan Environment and Children’s study. Int J Environ Res Public Health 18(19):10103. 10.3390/ijerph181910103.34639405
Miyazaki J, Ikehara S, Tanigawa K, . 2023. Prenatal exposure to selenium, mercury, and manganese during pregnancy and allergic diseases in early childhood: The Japan Environment and Children’s study. Environ Int 179:108123. 10.1016/j.envint.2023.108123.37595534
Mocevic E, Specht IO, Marott JL, . 2013. Environmental mercury exposure, semen quality and reproductive hormones in Greenlandic Inuit and European men: a cross-sectional study. Asian J Androl 15(1):97–104. 10.1038/aja.2012.121.23223027
Mohamed MK, Burbacher TM, Mottet NK. 1987. Effects of methyl mercury on testicular functions in Macaca fascicularis monkeys. Pharmacol Toxicol 60(1):29–36. 10.1111/j.1600-0773.1987.tb01715.x.3562387
Mohammad Abu-Taweel G, Al-Fifi Z. 2021. Protective effects of curcumin towards anxiety and depression-like behaviors induced mercury chloride. Saudi J Biol Sci 28(1):125–134. 10.1016/j.sjbs.2020.09.011.33424289
Mokrzan EM, Kerper LE, Ballatori N, . 1995. Methylmercury-thiol uptake into cultured brain capillary endothelial cells on amino acid system L. J Pharmacol Exp Ther 272(3):1277–1284.7891344
Møller L, Kristensen TS. 1992. Blood lead as a cardiovascular risk factor. Am J Epidemiol 136(9):1091–1100. 10.1093/oxfordjournals.aje.a116574.1462969
Monastero RN, Karimi R, Nyland JF, . 2017. Mercury exposure, serum antinuclear antibodies, and serum cytokine levels in the Long Island Study of Seafood Consumption: A cross-sectional study in NY, USA. Environ Res 156:334–340. 10.1016/j.envres.2017.03.037.28390301
Montgomery KS, Mackey J, Thuett K, . 2008. Chronic, low-dose prenatal exposure to methylmercury impairs motor and mnemonic function in adult C57/B6 mice. Behav Brain Res 191(1):55–61. 10.1016/j.bbr.2008.03.008.18436314
Moody RP, Joncas J, Richardson M, . 2009. Contaminated soils (II): In vitro dermal absorption of nickel (Ni-63) and mercury (Hg-203) in human skin. J Toxicol Environ Health A 72(8):551–559. 10.1080/15287390802706322.19267315
Moon S. 2013. Association of lead, mercury and cadmium with diabetes in the Korean population: the Korea National Health and Nutrition Examination Survey (KNHANES) 2009-2010. Diabet Med 30(4):e143–148. 10.1111/dme.12103.23278294
Moon S. 2017. Association between blood mercury level and visceral adiposity in adults. Diabetes Metab J 41(2):96–98. 10.4093/dmj.2017.41.2.96.28447437
Moon SH, Kang Y, Park KM. 2017. A one-dimensional Hg(II) coordination polymer based on bis-(pyridin-3-ylmeth-yl)sulfane. Acta Crystallogr E Crystallogr Commun 73(Pt 12):1871–1874. 10.1107/s205698901701619x.29250405
Moon MK, Lee I, Lee A, . 2022. Lead, mercury, and cadmium exposures are associated with obesity but not with diabetes mellitus: Korean National Environmental Health Survey (KoNEHS) 2015-2017. Environ Res 204(Pt A):111888. 10.1016/j.envres.2021.111888.34403664
Morcillo MA, Santamaria J. 1995. Whole-body retention, and urinary and fecal excretion of mercury after subchronic oral exposure to mercuric chloride in rats. Biometals 8(4):301–308.7580050
Mordukhovich I, Wright RO, Hu H, . 2012. Associations of toenail arsenic, cadmium, mercury, manganese, and lead with blood pressure in the normative aging study. Environ Health Perspect 120(1):98–104. 10.1289/ehp.1002805.21878420
Moreira EL, de Oliveira J, Dutra MF, . 2012. Does methylmercury-induced hypercholesterolemia play a causal role in its neurotoxicity and cardiovascular disease? Toxicol Sci 130(2):373–382. 10.1093/toxsci/kfs252.22903822
Morgan DL, Chanda SM, Price HC, . 2002. Disposition of inhaled mercury vapor in pregnant rats: Maternal toxicity and effects on developmental outcome. Toxicol Sci 66(2):261–273. 10.1093/toxsci/66.2.261.11896293
Mori T, Sato K, Kusaka Y, . 2007. Positive patch test for mercury possibly from exposure to amalgam. Environ Health Prev Med 12(4):172–177. 10.1007/bf02897987.21432061
Mori N, Yamamoto M, Tsukada E, . 2012. Comparison of in vivo with in vitro pharmacokinetics of mercury between methylmercury chloride and methylmercury cysteine using rats and Caco2 cells. Arch Environ Contam Toxicol 63(4):628–636. 10.1007/s00244-012-9800-5.22932937
Morris GE. 1960. Dermatoses from phenylmercuric salts. Arch Environ Health 1:53–55.14424324
Morrissette J, Takser L, St-Amour G, . 2004. Temporal variation of blood and hair mercury levels in pregnancy in relation to fish consumption history in a population living along the St. Lawrence River. Environ Res 95(3):363–374. 10.1016/j.envres.2003.12.007.15220070
Morrow PE, Gibb FR, Johnson LA. 1964. Clearance of insoluble dust from the lower respiratory tract. Health Phys 10(8):543–555. 10.1097/00004032-196408000-00003.14203885
Mortada WL, Sobh MA, El-Defrawy MM, . 2002. Mercury in dental restoration: is there a risk of nephrotoxicity? J Nephrol 15(2):171–176.12018634
Mortimer DC. 1985. Freshwater aquatic macrophytes as heavy metal monitors - the Ottawa River experience. Environ Monit Assess 5(3):311–324.24258036
Mottet NK, Body RL, Wilkens V, . 1987. Biologic variables in the hair uptake of methylmercury from blood in the macaque monkey. Environ Res 42(2):509–523.3569185
Mousavi A. 2015. Mercury(I) chloride in vivo oxidation: a thermodynamic study. Main Group Metal Chem 38(3–4):121–124. 10.1515/mgmc-2015-0012.
Moussa H, Hachfi L, Trimeche M, . 2010. Accumulation of mercury and its effects on testicular functions in rats intoxicated orally by methylmercury. Andrologia 43(1):23–27. 10.1111/j.1439-0272.2009.01003.x.21219378
Movassagh H, Halchenko Y, Sampath V, . 2021. Maternal gestational mercury exposure in relation to cord blood T cell alterations and placental gene expression signatures. Environ Res 201:111385. 10.1016/j.envres.2021.111385.34129869
Mozaffarian D. 2009. Fish, mercury, selenium and cardiovascular risk: current evidence and unanswered questions. Int J Environ Res Public Health 6(6):1894–1916. 10.3390/ijerph6061894.19578467
Mozaffarian D, Rimm EB. 2006. Fish intake, contaminants, and human health: Evaluating the risks and the benefits. JAMA 296(15):1885–1899. 10.1001/jama.296.15.1885.17047219
Mozaffarian D, Shi P, Morris JS, . 2011. Mercury exposure and risk of cardiovascular disease in two U.S. cohorts. N Engl J Med 364(12):1116–1125. 10.1056/NEJMoa1006876.21428767
Mozaffarian D, Shi P, Morris JS, . 2012. Mercury exposure and risk of hypertension in US men and women in 2 prospective cohorts. Hypertension 60(3):645–652. 10.1161/hypertensionaha.112.196154.22868395
Mozaffarian D, Shi P, Morris JS, . 2013. Methylmercury exposure and incident diabetes in U.S. men and women in two prospective cohorts. Diabetes Care 36(11):3578–3584. 10.2337/dc13-0894.24026556
Muckle G, Dewailly E, Ayotte P. 1998. Prenatal exposure of Canadian children to polychlorinated biphenyls and mercury. Can J Public Health 89:S20–S25.9654788
Muckle G, Ayotte P, Dewailly EE, . 2001. Prenatal exposure of the northern Québec Inuit infants to environmental contaminants. Environ Health Perspect 109(12):1291–1299. 10.1289/ehp.011091291.11748038
Muir DCG, Wagemann R, Hargrave BT, . 1992. Arctic marine ecosystem contamination. Sci Total Environ 122(1–2):75–134. 10.1016/0048-9697(92)90246-o.1514106
Mulder KM, Kostyniak PJ. 1985a. Effect of L-(alpha S,5S)-alpha-amino-3-chloro-4,5-dihydro-5-isoxazoleacetic acid on urinary excretion of methylmercury in the mouse. J Pharmacol Exp Ther 234(1):156–160.4009498
Mulder KM, Kostyniak PJ. 1985b. Involvement of glutathione in the enhanced renal excretion of methyl mercury in CFW Swiss mice. Toxicol Appl Pharmacol 78(3):451–457.2864752
Muldoon MF, Ryan CM, Yao JK, . 2014. Long-chain omega-3 fatty acids and optimization of cognitive performance. Mil Med 179(11S):95–105. 10.7205/milmed-d-14-00168.25373092
Mumtaz MM, Ray M, Crowell SR, . 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, . 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Munthe J, McElroy WJ. 1992. Some aqueous reactions of potential importance in the atmospheric chemistry of mercury. Atmos Environ 26A(4):553–557.
Murata K, Weihe P, Renzoni A, . 1999a. Delayed evoked potentials in children exposed to methylmercury from seafood. Neurotoxicol Teratol 21(4):343–348.10440477
Murata K, Weihe P, Araki S, . 1999b. Evoked potentials in Faroese children prenatally exposed to methylmercury. Neurotoxicol Teratol 21(4):471–472.10440491
Murata K, Budtz-Jorgensen E, Grandjean P. 2002. Benchmark dose calculations for methylmercury-associated delays on evoked potential latencies in two cohorts of children. Risk Anal 22(3):465–474.12088226
Murata K, Weihe P, Budtz-Jorgensen E, . 2004a. Delayed brainstem auditory evoked potential latencies in 14-year-old children exposed to methylmercury. J Pediatr 144(2):177–183. 10.1016/j.jpeds.2003.10.059.14760257
Murata K, Sakamoto M, Nakai K, . 2004b. Effects of methylmercury on neurodevelopment in Japanese children in relation to the Madeiran study. Int Arch Occup Environ Health 77(8):571–579. 10.1007/s00420-004-0542-1.15688249
Murcia M, Ballester F, Enning AM, . 2016. Prenatal mercury exposure and birth outcomes. Environ Res 151:11–20. 10.1016/j.envres.2016.07.003.27448728
Myers GJ, Marsh DO, Davidson PW, . 1995. Main neurodevelopmental study of Seychellois children following in utero exposure to methylmercury from a maternal fish diet: outcome at six months. Neurotoxicology 16(4):653–664.8714870
Myers GJ, Davidson PW, Shamlaye CF, . 1997. Effects of prenatal methylmercury exposure from a high fish diet on developmental milestones in the Seychelles Child Development Study. Neurotoxicology 18(3):819–829.9339828
Myers GJ, Davidson PW, Palumbo D, . 2000. Secondary analysis from the Seychelles Child Development Study: the child behavior checklist. Environ Res 84(1):12–19. 10.1006/enrs.2000.4085.10991778
Myers GJ, Davidson PW, Cox C, . 2003. Prenatal methylmercury exposure from ocean fish consumption in the Seychelles child development study. Lancet 361(9370):1686–1692. 10.1016/s0140-6736(03)13371-5.12767734
Myers GJ, Thurston SW, Pearson AT, . 2009. Postnatal exposure to methyl mercury from fish consumption: a review and new data from the Seychelles Child Development Study. Neurotoxicology 30(3):338–349. 10.1016/j.neuro.2009.01.005.19442817
Myers GJ, Davidson PW, Shamlaye C, . 2020. The Seychelles Child Development Study of methyl mercury from fish consumption: analysis of subscales from the Child Behaviour Checklist at age 107 months in the main cohort. Neurotoxicology 81:331–338. 10.1016/j.neuro.2020.09.025.35623358
NADP. 2024. AMNet: Atmospheric mercury data. National Atmospheric Deposition Program. http://nadp.slh.wisc.edu/data/AMNet/. April 4, 2024.
Nagahara N. 2011. Catalytic site cysteines of thiol enzyme: Sulfurtransferases. J Amino Acids 2011:1–7. 10.4061/2011/709404.
Nagano M, Yasutake A, Miura K. 2010. Demethylation of methylmercury in human neuroblastoma, glioblastoma and liver cells. J Health Sci 56(3):326–330. 10.1248/jhs.56.326.
Nagar RN, Bhattacharya L. 2001. Effect of mercuric chloride on testicular activities in mice, Musculus albinus. J Environ Biol 22(1):15–18.11480345
Nakada Y, Adachi T. 1999. Effect of experimentally induced renal failure on testicular testosterone synthesis in rats. Arch Androl 43(1):37–45. 10.1080/014850199262715.10445103
Nakai S, Machida I. 1973. Genetic effect of organic mercury on yeast. Mutat Res 21(6):348.
Nakamura M, Hachiya N, Murata KY, . 2014. Methylmercury exposure and neurological outcomes in Taiji residents accustomed to consuming whale meat. Environ Int 68:25–32. 10.1016/j.envint.2014.03.005.24685489
Nakamura M, Tatsuta N, Murata K, . 2023. Neurodevelopmental associations of prenatal and postnatal methylmercury exposure among first-grade children in the Kinan region, Japan. Environ Res 235:116688. 10.1016/j.envres.2023.116688.37467938
Nan Y, Yang J, Yang J, . 2024. Associations between individual and combined metal exposures in whole blood and kidney function in U.S. adults aged 40 years and older. Biol Trace Elem Res 202(3):850–865. 10.1007/s12011-023-03722-z.37291467
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
Nascimento S, Goethel G, Gauer B, . 2018. Exposure to environment chemicals and its possible role in endocrine disruption of children from a rural area. Environ Res 167:488–498. 10.1016/j.envres.2018.07.039.30142624
Nascimento TS, Pinto DV, Dias RP, . 2022. Chronic methylmercury intoxication induces systemic inflammation, behavioral, and hippocampal amino acid changes in C57Bl6J adult mice. Int J Mol Sci 23(22):13837. 10.3390/ijms232213837.36430321
Nater EA, Grigal DF. 1992. Regional trends in mercury distribution across the Great Lakes states, north central USA. Nature 358(6382):139–141. 10.1038/358139a0.
Neghab M, Choobineh A, Hassan Zadeh J, . 2011. Symptoms of intoxication in dentists associated with exposure to low levels of mercury. Ind Health 49(2):249–254.21173523
NESCAUM. 1998. Northeast states and eastern Canadian provinces - mercury study - a framework for action. Boston, MA: Northeast States for Coordinated Air Use Management.
Newland MC, Reile PA. 1999. Blood and brain mercury levels after chronic gestational exposure to methylmercury in rats. Toxicol Sci 50(1):106–116. 10.1093/toxsci/50.1.106.10445759
Newland MC, Rasmussen EB. 2000. Aging unmasks adverse effects of gestational exposure to methylmercury in rats. Neurotoxicol Teratol 22(6):819–828. 10.1016/s0892-0362(00)00107-0.11120387
Newland MC, Warfvinge K, Berlin M. 1996. Behavioral consequences of in utero exposure to mercury vapor: Alterations in lever-press durations and learning in squirrel monkeys. Toxicol Appl Pharmacol 139(2):374–386. 10.1006/taap.1996.0178.8806855
Newland MC, Reile PA, Langston JL. 2004. Gestational exposure to methylmercury retards choice in transition in aging rats. Neurotoxicol Teratol 26(2):179–194. 10.1016/j.ntt.2003.12.004.15019952
Newton D, Fry FA. 1978. The retention and distribution of radioactive mercuric oxide following accidental inhalation. Ann Occup Hyg 21(1):21–32.418722
Ngim CH, Foo SC, Boey KW, . 1992. Chronic neurobehavioural effects of elemental mercury in dentists. Br J Ind Med 49(11):782–790. 10.1136/oem.49.11.782.1463679
Nguyen HD. 2023. Cadmium, lead, and mercury interactions on obstructive lung function in pre- and postmenopausal women. Environ Sci Pollut Res Int 30(29):73485–73496. 10.1007/s11356-023-27503-2.37191746
Nguyen HD, Oh H, Hoang NHM, . 2022. Environmental science and pollution research role of heavy metal concentrations and vitamin intake from food in depression: a national cross-sectional study (2009-2017). Environ Sci Pollut Res Int 29(3):4574–4586. 10.1007/s11356-021-15986-w.34414543
Nielsen JB. 1992. Toxicokinetics of mercuric chloride and methylmercuric chloride in mice. J Toxicol Environ Health 37(1):85–122. 10.1080/15287399209531659.1522616
Nielsen JB, Andersen O. 1990. Disposition and retention of mercuric chloride in mice after oral and parenteral administration. J Toxicol Environ Health 30(3):167–180. 10.1080/15287399009531420.2366256
Nielsen JB, Andersen O. 1991. Methyl mercuric chloride toxicokinetics in mice. I: Effects of strain, sex, route of administration and dose. Pharmacol Toxicol 68(3):201–207.2057451
Nielsen JB, Hultman P. 1998. Strain dependence of steady-state retention and elimination of mercury in mice after prolonged exposure to mercury(II) chloride. Analyst 123(1):87–90.9581026
Nielsen JB, Hultman P. 2002. Mercury-induced autoimmunity in mice. Environ Health Perspect 110(Suppl 5):877–881. 10.1289/ehp.02110s5877.12426151
Nielsen JB, Andersen HR, Andersen O, . 1991. Mercuric chloride-induced kidney damage in mice: Time course and effect of dose. J Toxicol Environ Health 34(4):469–483. 10.1080/15287399109531583.1960762
Nielsen JB, Andersen HL, Sorensen JA, . 1992. Localization of gastrointestinal deposition of mercuric chloride studied in vivo. Pharmacol Toxicol 70(4):262–267.1608910
Nielsen AB, Davidsen M, Bjerregaard P. 2012. The association between blood pressure and whole blood methylmercury in a cross-sectional study among Inuit in Greenland. Environ Health 11:44. 10.1186/1476-069x-11-44.22747793
Nielsen SJ, Kit BK, Aoki Y, . 2014. Seafood consumption and blood mercury concentrations in adults aged ≥20 y, 2007-2010. Am J Clin Nutr 99(5):1066–1070. 10.3945/ajcn.113.077081.24522443
Nielsen-Kudsk F. 1965a. Absorption of mercury vapour from the respiratory tract in man. Acta Pharmacol Toxicol 23(2):250–262. 10.1111/j.1600-0773.1965.tb03592.x.
Nielsen-Kudsk F. 1965b. The influence of ethyl alcohol on the absorption of mercury vapour from the lungs in man. Acta Pharmacol Toxicol 23(2):263–274. 10.1111/j.1600-0773.1965.tb03593.x.
Nielsen-Kudsk F. 1973. Biological oxidation of elemental mercury. In: Miller MW, Clarkson TW, eds. Mercury, mercurials and mercaptans. Springfield, IL: Charles C. Thomas, 355.
Nierenberg DW, Nordgren RE, Chang MB, . 1998. Delayed cerebellar disease and death after accidental exposure to dimethylmercury. N Engl J Med 338(23):1672–1676. 10.1056/nejm199806043382305.9614258
Nikolaychuk PA. 2016. Is calomel truly a poison and what happens when it enters the human stomach? A study from the thermodynamic viewpoint. Main Group Metal Chem 39(1–2):41–47. 10.1515/mgmc-2015-0040.
Nilsen FM, Tulve NS. 2020. A systematic review and meta-analysis examining the interrelationships between chemical and non-chemical stressors and inherent characteristics in children with ADHD. Environ Res 180:108884. 10.1016/j.envres.2019.108884.31706600
NIOSH. 1994a. Mercury (organo) alkyl compounds (as Hg). Immediately dangerous to life or health concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/idlh/merc-hg.html. November 12, 2020.
NIOSH. 1994b. Mercury compounds [except (organo) alkyls] (as Hg). Immediately dangerous to life or health concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/idlh/7439976.html. November 12, 2020.
NIOSH. 2010. NIOSH backgrounder: Alice’s Mad Hatter & work-related illness. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/updates/upd-03-04-10.html. January 5, 2022.
NIOSH. 2019a. Mercury (organo) alkyl compounds (as Hg). NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0384.html. November 12, 2020.
NIOSH. 2019b. Mercury compounds [except (organo) alkyls] (as Hg). NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0383.html. November 12, 2020.
NJDEP. 2007. Cultural uses of mercury in New Jersey - year 2 mercury vapor in residential buildings - Comparison of communities that use mercury for cultural purposes with a reference community. Trenton, NJ: New Jersey Department of Environmental Protection. https://www.nj.gov/dep/dsr/research/mercury-cultural-yr2.pdf. May 17, 2021.
NLM. 2020. PubChem compound summary: Mercury. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/Mercury. January 11, 2021.
Noisel N, Bouchard M, Carrier G, . 2011. Comparison of a toxicokinetic and a questionnaire-based approach to assess methylmercury intake in exposed individuals. J Expo Sci Environ Epidemiol 21(3):328–335. 10.1038/jes.2010.33.20502494
Nolen GA, Buchler EV, Geil RG, . 1972. Effects of trisodium nitrotriacetate on cadmium and methylmercury toxicity and teratogenicity in rats. Toxicol Appl Pharmacol 23(2):222–223. 10.1016/0041-008x(72)90186-x.5074572
Nonaka H, Nakada T, Iijima M, . 2011. Metal patch test results from 1990-2009. J Dermatol 38(3):267–271. 10.1111/j.1346-8138.2010.00980.x.21342229
Nordberg GF, Serenius F. 1969. Distribution of inorganic mercury in the guinea pig brain. Acta Pharmacol Toxicol (Copenh) 27:269–283.5394744
Nordenhall K, Dock L, Vahter M. 1998. Cross-fostering study of methyl mercury retention, demethylation and excretion in the neonatal hamster. Pharmacol Toxicol 82(3):132–136.9553991
Nordhagen HP, Ellingsen DG, Kjuus H. 1994. Production and surveillance of mercury exposure over 40 years at a chloralkali plant. Ann Occup Hyg 38(5):777–788. 10.1093/annhyg/38.5.777.7978992
Nordlind K, Liden S. 1992. Patch test reactions to metal salts in patients with oral mucosal lesions associated with amalgam restorations. Contact Dermatitis 27(3):157–160. 10.1111/j.1600-0536.1992.tb05245.x.1451460
Nørgaard JO, Møller-Madsen B, Hertel N, . 1989. Silver enhancement of tissue mercury: Demonstration of mercury in autometallographic silver grains from rat kidneys. J Histochem Cytochem 37(10):1545–1547. 10.1177/37.10.2778309.2778309
Norseth T. 1971. Biotransformation of methyl mercuric salts in the mouse studied by specific determination of inorganic mercury. Acta Pharmacol Toxicol (Copenh) 29(4):375–384. 10.1111/j.1600-0773.1971.tb00597.x.5109981
Norseth T, Clarkson TW. 1970. Studies on the biotransformation of 203Hg-labeled methyl mercury chloride in rats. Arch Environ Health 21(6):717–727.5478557
NTP. 1993. Toxicology and carcinogenesis studies of mercuric chloride (CAS no. 7487-94-7) in F344/N rats and B6C3F1 mice (gavage studies). Research Triangle Park, NC: National Toxicology Program. NTP TR 408. NIH publication no. 91-3139.
NTP. 1997. Chemical repository (Radian Corporation August 29, 1991) phenylmercuric acetate. National Toxicology Program.
NTP. 2016. Substances listed in the fourteenth report on carcinogens. 14^th^ Report on carcinogens. National Toxicology Program. https://ntp.niehs.nih.gov/whatwestudy/assessments/cancer/roc/index.html. January 19, 2021.
NTP. 2021. CASRN index. In: Report on carcinogens. 15^th^ ed. National Toxicology Program, https://ntp.niehs.nih.gov/go/roc15. January 10, 2022.
Nunes PBO, Ferreira MKM, Ribeiro Frazão D, . 2022. Effects of inorganic mercury exposure in the alveolar bone of rats: an approach of qualitative and morphological aspects. PeerJ 10:e12573. 10.7717/peerj.12573.35127276
Nyanza EC, Dewey D, Manyama M, . 2020. Maternal exposure to arsenic and mercury and associated risk of adverse birth outcomes in small-scale gold mining communities in Northern Tanzania. Environ Int 137:105450. 10.1016/j.envint.2019.105450.32014788
Nyanza EC, Bernier FP, Martin JW, . 2021. Effects of prenatal exposure and co-exposure to metallic or metalloid elements on early infant neurodevelopmental outcomes in areas with small-scale gold mining activities in Northern Tanzania. Environ Int 149:106104. 10.1016/j.envint.2020.106104.32948351
Nyland JF, Wang SB, Shirley DL, . 2011. Fetal and maternal immune responses to methylmercury exposure: a cross-sectional study. Environ Res 111(4):584–589. 10.1016/j.envres.2011.02.010.21396635
Nylander M, Friberg L, Lind B. 1987. Mercury concentrations in the human brain and kidneys in relation to exposure from dental amalgam fillings. Swed Dent J 11(5):179–187.3481133
Oberly TJ, Piper CE, McDonald DS. 1982. Mutagenicity of metal salts in the L51784 mouse lymphoma assay. J Toxicol Environ Health 9(3):367–376.7097791
O’Donoghue JL, Watson GE, Brewer R, . 2020. Neuropathology associated with exposure to different concentrations and species of mercury: A review of autopsy cases and the literature. Neurotoxicology 78:88–98. 10.1016/j.neuro.2020.02.011.32092311
Ohno T, Sakamoto M, Kurosawa T, . 2007. Total mercury levels in hair, toenail, and urine among women free from occupational exposure and their relations to renal tubular function. Environ Res 103(2):191–197. 10.1016/j.envres.2006.06.009.16890218
Oken E, Radesky JS, Wright RO, . 2008. Maternal fish intake during pregnancy, blood mercury levels, and child cognition at age 3 years in a US cohort. Am J Epidemiol 167(10):1171–1181. 10.1093/aje/kwn034.18353804
Oken E, Rifas-Shiman SL, Amarasiriwardena C, . 2016. Maternal prenatal fish consumption and cognition in mid childhood: Mercury, fatty acids, and selenium. Neurotoxicol Teratol 57:71–78. 10.1016/j.ntt.2016.07.001.27381635
Okubo H, Nakayama SF. 2023. Periconceptional maternal diet quality influences blood heavy metal concentrations and their effect on low birth weight: the Japan Environment and Children’s Study. Environ Int 173:107808. 10.1016/j.envint.2023.107808.36827813
Oliveira RB, Gomes-Leal W, do-Nascimento JL, . 1998. Methylmercury intoxication and histochemical demonstration of NADPH-diaphorase activity in the striate cortex of adult cats. Braz J Med Biol Res 31(9):1157–1161.9876283
Oliveira RB, Malm O, Guimaraes JR. 2001. Distribution of methylmercury and inorganic mercury in neonate hamsters dosed with methylmercury during fetal life. Environ Res 86(1):73–79. 10.1006/enrs.2001.4220.11386744
Oliveira CS, Oliveira VA, Ineu RP, . 2012. Biochemical parameters of pregnant rats and their offspring exposed to different doses of inorganic mercury in drinking water. Food Chem Toxicol 50(7):2382–2387. 10.1016/j.fct.2012.04.046.22580302
Oliveira CS, Joshee L, Zalups RK, . 2015. Disposition of inorganic mercury in pregnant rats and their offspring. Toxicology 335:62–71. 10.1016/j.tox.2015.07.006.26196528
Oliveira CS, Oliveira VA, Costa LM, . 2016. Inorganic mercury exposure in drinking water alters essential metal homeostasis in pregnant rats without altering rat pup behavior. Reprod Toxicol 65:18–23. 10.1016/j.reprotox.2016.06.013.27338755
Oliveira C, Joshee L, George H, . 2017. Oral exposure of pregnant rats to toxic doses of methylmercury alters fetal accumulation. Reprod Toxicol 69:265–275. 10.1016/j.reprotox.2017.03.008.28341569
Oliveira AN, Pinheiro AM, Belém-Filho IJA, . 2018. Unravelling motor behaviour hallmarks in intoxicated adolescents: methylmercury subtoxic-dose exposure and binge ethanol intake paradigm in rats. Environ Sci Pollut Res Int 25(22):21937–21948. 10.1007/s11356-018-2235-4.29797195
Oliveira RAA, Pinto BD, Rebouças BH, . 2021. Neurological impacts of chronic methylmercury exposure in Munduruku indigenous adults: Somatosensory, motor, and cognitive abnormalities. Int J Environ Res Public Health 18(19):10270. 10.3390/ijerph181910270.34639574
Olson BH, Cayless SM, Ford S, . 1991. Toxic element contamination and the occurrence of mercury-resistant bacteria in Hg-Contaminated soil, sediments, and sludges. Arch Environ Contam Toxicol 20(2):226–233. 10.1007/bf01055908.
Omanwar S, Fahim M. 2015. Mercury exposure and endothelial dysfunction: An interplay between nitric oxide and oxidative stress. Int J Toxicol 34(4):300–307. 10.1177/1091581815589766.26060268
Omanwar S, Saidullah B, Ravi K, . 2014. Vasorelaxant effects of mercury on rat thoracic aorta: the nitric oxide signaling mechanism. Hum Exp Toxicol 33(9):904–910. 10.1177/0960327113512341.24347300
Omata S, Sakimura K, Ishii T, . 1978. Chemical nature of a methylmercury complex with a low molecular weight in the liver cytosol of rats exposed to methylmercury chloride. Biochem Pharmacol 27(12):1700–1702.697910
Omata S, Kasama H, Hasegawa H, . 1986. Species difference between rat and hamster in tissue accumulation of mercury after administration of methylmercury. Arch Toxicol 59(4):249–254.3827592
Ondovcik SL, Tamblyn L, McPherson JP, . 2012. Oxoguanine glycosylase 1 (OGG1) protects cells from DNA double-strand break damage following methylmercury (MeHg) exposure. Toxicol Sci 128(1):272–283. 10.1093/toxsci/kfs138.22523232
Onishchenko N, Karpova N, Sabri F, . 2008. Long-lasting depression-like behavior and epigenetic changes of BDNF gene expression induced by perinatal exposure to methylmercury. J Neurochem 106(3):1378–1387. 10.1111/j.1471-4159.2008.05484.x.18485098
Ontario Ministry of the Environment. 1991. Relationship of mercury levels in sportfish with lake sediment and water quality variables. Toronto, Ontario: Ontario Environmental Research Program. PIBS 1261. https://archive.org/details/RELATIONSHIPOFME00WREN08121.ome/page/n1/mode/2up. January 19, 2021.
Orenstein ST, Thurston SW, Bellinger DC, . 2014. Prenatal organochlorine and methylmercury exposure and memory and learning in school-age children in communities near the New Bedford Harbor Superfund site, Massachusetts. Environ Health Perspect 122(11):1253–1259. 10.1289/ehp.1307804.25062363
Orlando MS, Dziorny AC, Harrington D, . 2014. Associations between prenatal and recent postnatal methylmercury exposure and auditory function at age 19 years in the Seychelles Child Development Study. Neurotoxicol Teratol 46:68–76. 10.1016/j.ntt.2014.10.003.25462959
Orlando MS, Love T, Harrington D, . 2023. The association of auditory function measures with low-level methylmercury from oceanic fish consumption and mercury vapor from amalgam: The Seychelles Child Development Study Nutrition 1 Cohort. Neurotoxicology 95:46–55. 10.1016/j.neuro.2022.12.010.36621469
Ortega HG, Lopez M, Salvaggio JE, . 1997a. Lymphocyte proliferative response and tissue distribution of methylmercury sulfide and chloride in exposed rats. J Toxicol Environ Health 50(6):605–616. 10.1080/15287399709532058.15279033
Ortega HG, Lopez M, Takaki A, . 1997b. Neuroimmunological effects of exposure to methylmercury forms in the Sprague-Dawley rats. Activation of the hypothalamic-pituitary-adrenal axis and lymphocyte responsiveness. Toxicol Ind Health 13(1):57–66. 10.1177/074823379701300105.9098950
OSHA. 2005. Memorandum: PEL for inorganic mercury. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/standardinterpretations/1996-09-03-0. November 19, 2020.
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1000.pdf. August 28, 2022.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-55.pdf. August 28, 2022.
Oskarsson A, Palminger Hallen I, Sundberg J. 1995. Exposure to toxic elements via breast milk. Analyst 120(3):765–770.7741226
Oskarsson A, Schütz A, Skerfving S, . 1996. Total and inorganic mercury in breast milk and blood in relation to fish consumption and amalgam fillings in lactating women. Arch Environ Health 51(3):234–241. 10.1080/00039896.1996.9936021.8687245
Osol A. 1980. Mercury. In: Remington’s pharmaceutical sciences. 16^th^ ed. Easton, PA: Mack Publishing Co., 1106.
Ostlund K. 1969. Studies on the metabolism of methyl mercury and dimethyl mercury in mice. Acta Pharmacol Toxicol (Copenh) 27(1):5–132.
Ou L, Chen L, Chen C, . 2014. Associations of methylmercury and inorganic mercury between human cord blood and maternal blood: a meta-analysis and its application. Environ Pollut 191:25–30. 10.1016/j.envpol.2014.04.016.24792881
Ou L, Chen C, Chen L, . 2015. Low-level prenatal mercury exposure in north China: an exploratory study of anthropometric effects. Environ Sci Technol 49(11):6899–6908. 10.1021/es5055868.25936461
Ou L, Wang H, Chen C, . 2018. Physiologically based pharmacokinetic (PBPK) modeling of human lactational transfer of methylmercury in China. Environ Int 115:180–187. 10.1016/j.envint.2018.03.018.29574338
Ouddane B, Monperrus M, Kadlecova M, . 2015. Mercury methylation and demethylation in highly contaminated sediments from the Deule River in Northern France using species-specific enriched stable isotopes. Environ Sci Process Impacts 17(1):145–155. 10.1039/c4em00398e.25421488
Oulhote Y, Shamim Z, Kielsen K, . 2017a. Children’s white blood cell counts in relation to developmental exposures to methylmercury and persistent organic pollutants. Reprod Toxicol 68:207–214. 10.1016/j.reprotox.2016.08.001.27497749
Oulhote Y, Debes F, Vestergaard S, . 2017b. Aerobic fitness and neurocognitive function scores in young Faroese adults and potential modification by prenatal methylmercury exposure. Environ Health Perspect 125(4):677–683. 10.1289/ehp274.27611346
Oulhote Y, Coull B, Bind MA, . 2019. Joint and independent neurotoxic effects of early life exposures to a chemical mixture: A multi-pollutant approach combining ensemble learning and g-computation. Environ Epidemiol 3(5):e063. 10.1097/ee9.0000000000000063.32051926
Packull-McCormick S, Ashley-Martin J, Singh K, . 2023. Prenatal and concurrent blood mercury concentrations and associations with IQ in Canadian preschool children. Environ Res 233:116463. 10.1016/j.envres.2023.116463.37343750
Palumbo DR, Cox C, Davidson PW, . 2000. Association between prenatal exposure to methylmercury and cognitive functioning in Seychellois children: a reanalysis of the McCarthy Scales of Children’s Ability from the main cohort study. Environ Res 84(2):81–88. 10.1006/enrs.2000.4095.11068921
Pamphlett R, Coote P. 1998. Entry of low doses of mercury vapor into the nervous system. Neurotoxicology 19(1):39–47.9498219
Pamphlett R, Kum-Jew S. 2001. Mercury vapor uptake into the nervous system of developing mice. Neurotoxicol Teratol 23(2):191–196.11348837
Pamphlett R, Kum Jew S. 2019. Mercury is taken up selectively by cells involved in joint, bone, and connective tissue disorders. Front Med (Lausanne) 6:168. 10.3389/fmed.2019.00168.31380381
Pamphlett R, Kum Jew S, Cherepanoff S. 2019. Mercury in the retina and optic nerve following prenatal exposure to mercury vapor. PLoS ONE 14(8):e0220859. 10.1371/journal.pone.0220859.31390377
Pamphlett R, Bishop DP. 2022. Mercury is present in neurons and oligodendrocytes in regions of the brain affected by Parkinson’s disease and co-localises with Lewy bodies. PLoS ONE 17(1):e0262464. 10.1371/journal.pone.0262464.35015796
Pan Z, Guo Y, Xiang H, . 2020. Effects of lead, mercury, and cadmium co-exposure on children’s pulmonary function. Biol Trace Elem Res 194(1):115–120. 10.1007/s12011-019-01772-w.31227986
Pandalai SL, Morgan BW. 2011. Case files of the Emory University Medical Toxicology Fellowship: inhalational mercury toxicity from a traditional Vietnamese product. J Med Toxicol 7(4):295–305. 10.1007/s13181-011-0180-4.22072090
Papadopoulou E, Botton J, Caspersen IH, . 2021. Maternal seafood intake during pregnancy, prenatal mercury exposure and child body mass index trajectories up to 8 years. Int J Epidemiol 50(4):1134–1146. 10.1093/ije/dyab035.33713119
Papp A, Nagymajtenyi L, Vezer T. 2005. Subchronic mercury treatment of rats in different phases of ontogenesis: functional effects on the central and peripheral nervous system. Food Chem Toxicol 43(1):77–85. 10.1016/j.fct.2004.08.014.15582198
Parajuli RP, Goodrich JM, Chan LHM, . 2018. Genetic polymorphisms are associated with exposure biomarkers for metals and persistent organic pollutants among Inuit from the Inuvialuit Settlement Region, Canada. Sci Total Environ 634:569–578. 10.1016/j.scitotenv.2018.03.331.29635199
Park H, Kim K. 2011. Association of blood mercury concentrations with atopic dermatitis in adults: a population-based study in Korea. Environ Res 111(4):573–578. 10.1016/j.envres.2011.02.003.21342690
Park JD, Zheng W. 2012. Human exposure and health effects of inorganic and elemental mercury. J Prev Med Public Health 45(6):344–352. 10.3961/jpmph.2012.45.6.344.23230464
Park S, Lee BK. 2013. Body fat percentage and hemoglobin levels are related to blood lead, cadmium, and mercury concentrations in a Korean Adult Population (KNHANES 2008-2010). Biol Trace Elem Res 151(3):315–323. 10.1007/s12011-012-9566-7.23238610
Park S, Choi NK. 2016. Associations of blood heavy metal levels with intraocular pressure. Ann Epidemiol 26(8):546–550 e541. 10.1016/j.annepidem.2016.07.002.27497680
Park K, Seo E. 2017. Toenail mercury and dyslipidemia: Interaction with selenium. J Trace Elem Med Biol 39:43–49. 10.1016/j.jtemb.2016.07.005.27908422
Park J, Kim Y. 2021. Associations of blood heavy metals with uric acid in the Korean general population: analysis of data from the 2016-2017 Korean National Health and Nutrition Examination Survey. Biol Trace Elem Res 199(1):102–112. 10.1007/s12011-020-02152-5.32342340
Park IH, Park KM, Lee SS. 2010. Preparation and characterisation of divalent hard and soft metal (M = Ca, Co, Cu, Zn, Cd, Hg and Pb) complexes of 1,10-dithia-18-crown-6: structural versatility. Dalton Trans 39(40):9696–9704. 10.1039/c0dt00696c.20830403
Park SK, Lee S, Basu N, . 2013. Associations of blood and urinary mercury with hypertension in U.S. adults: the NHANES 2003-2006. Environ Res 123:25–32. 10.1016/j.envres.2013.02.003.23472608
Park JS, Ha KH, He K, . 2017. Association between blood mercury level and visceral adiposity in adults. Diabetes Metab J 41(2):113–120. 10.4093/dmj.2017.41.2.113.28029015
Park KC, Kim KS, Jung BS, . 2022. Hair methylmercury levels are inversely correlated with arterial stiffness. Atherosclerosis 357:14–19. 10.1016/j.atherosclerosis.2022.08.003.36037758
Parkin Kullmann JA, Pamphlett R. 2018. A comparison of mercury exposure from seafood consumption and dental amalgam fillings in people with and without amyotrophic lateral sclerosis (ALS): An international online case-control study. Int J Environ Res Public Health 15(12):2874. 10.3390/ijerph15122874.30558238
Parks JM, Smith JC. 2016. Modeling mercury in proteins. Methods Enzymol 578:103–122. 10.1016/bs.mie.2016.05.041.27497164
Parks JW, Curry C, Romani D, . 1991. Young northern pike, yellow perch and crayfish as bioindicators in a mercury contaminated watercourse. Environ Monit Assess 16(1):39–73. 10.1007/bf00399593.24241775
Passos CJ, Da Silva DS, Lemire M, . 2008. Daily mercury intake in fish-eating populations in the Brazilian Amazon. J Expo Sci Environ Epidemiol 18(1):76–87. 10.1038/sj.jes.7500599.17805232
Pastor-Idoate S, Coco-Martin RM, Zabalza I, . 2021. Long-term visual pathway alterations after elemental mercury poisoning: report of a series of 29 cases. J Occup Med Toxicol 16(1):49. 10.1186/s12995-021-00341-z.34772411
Patel E, Reynolds M. 2013. Methylmercury impairs motor function in early development and induces oxidative stress in cerebellar granule cells. Toxicol Lett 222(3):265–272. 10.1016/j.toxlet.2013.08.002.23948120
Patel TA, Rao MV. 2015. Ameliorative effect of certain antioxidants against mercury induced genotoxicity in peripheral blood lymphocytes. Drug Chem Toxicol 38(4):408–414. 10.3109/01480545.2014.975354.25645230
Patel TA, Rao MV. 2018. Antigenotoxic effect of melatonin against mercuric chloride in human peripheral blood lymphocytes. Toxicol Ind Health 34(11):778–786. 10.1177/0748233718795747.30278831
Patel NB, Xu Y, McCandless LC, . 2019. Very low-level prenatal mercury exposure and behaviors in children: the HOME Study. Environ Health 18(1):4. 10.1186/s12940-018-0443-5.30626382
Pedersen GA, Mortensen GK, Larsen EH. 1994. Beverages as a source of toxic trace element intake. Food Addit Contam 11(3):351–363. 10.1080/02652039409374234.7926169
Penna S, Pocino M, Marval MJ, . 2009. Modifications in rat testicular morphology and increases in IFN-gamma serum levels by the oral administration of subtoxic doses of mercuric chloride. Syst Biol Reprod Med 55(2):69–84. 10.1080/19396360802562678.19462287
Perharic L, Shaw D, Colbridge M, . 1994. Toxicological problems resulting from exposure to traditional remedies and food supplements. Drug Saf 11(4):284–294. 10.2165/00002018-199411040-00006.7848547
Periard D, Beqiraj B, Hayoz D, . 2015. Associations of baroreflex sensitivity, heart rate variability, and initial orthostatic hypotension with prenatal and recent postnatal methylmercury exposure in the Seychelles Child Development Study at age 19 years. Int J Environ Res Public Health 12(3):3395–3405. 10.3390/ijerph120303395.25807149
Perry HM, Erlanger MW. 1974. Metal-induced hypertension following chronic feeding of low doses of cadmium and mercury. J Lab Clin Med 83(4):541–547.4817779
Pesch HJ, Bloss S, Schubert J, . 1992. The mercury, cadmium and lead content of cigarette tobacco: Comparative analytical-statistical studies in 1987 and 1991 employing Zeeman-AAS. Fresenius J Anal Chem 343(1):152–153. 10.1007/bf00332087.
Peters S, Broberg K, Gallo V, . 2021. Blood metal levels and amyotrophic lateral sclerosis risk: a prospective cohort. Ann Neurol 89(1):125–133. 10.1002/ana.25932.33068316
Petersson K, Dock L, Soderling K, . 1991. Distribution of mercury in rabbits subchronically exposed to low levels of radiolabeled methyl mercury. Pharmacol Toxicol 68(6):464–468.1891441
Petruccioli L, Turillazzi P. 1991. Effect of methylmercury on acetylcholinesterase and serum cholinesterase activity in monkeys, Macaca fascicularis. Bull Environ Contam Toxicol 46(5):769–773. 10.1007/BF01689966.2039873
Phelps RW, Clarkson TW, Kershaw TG, . 1980. Interrelationships of blood and hair mercury concentrations in a North American population exposed to methylmercury. Arch Environ Health 35(3):161–168.7189997
Philibert A, Fillion M, Mergler D. 2020. Mercury exposure and premature mortality in the Grassy Narrows First Nation community: a retrospective longitudinal study. Lancet Planet Health 4(4):e141–e148. 10.1016/s2542-5196(20)30057-7.32353294
Philibert A, Fillion M, Da Silva J, . 2022. Past mercury exposure and current symptoms of nervous system dysfunction in adults of a First Nation community (Canada). Environ Health 21(1):34. 10.1186/s12940-022-00838-y.35292021
Pierrehumbert G, Droz PO, Tardif R, . 2002. Impact of human variability on the biological monitoring of exposure to toluene, phenol, lead, and mercury: II. Compartmental based toxicokinetic modelling. Toxicol Lett 134(1–3):165–175. 10.1016/s0378-4274(02)00186-8.12191875
Piikivi L. 1989. Cardiovascular reflexes and low long-term exposure to mercury vapour. Int Arch Occup Environ Health 61(6):391–395. 10.1007/bf00381030.2744870
Piikivi L, Hänninen H. 1989. Subjective symptoms and psychological performance of chlorine-alkali workers. Scand J Work Environ Health 15(1):69–74. 10.5271/sjweh.1880.2922591
Piikivi L, Ruokonen A. 1989. Renal function and long-term low mercury vapor exposure. Arch Environ Health 44(3):146–149. 10.1080/00039896.1989.9935878.2787621
Piikivi L, Hanninen H, Martelin T, . 1984. Psychological performance and long-term exposure to mercury vapors. Scand J Work Environ Health 10(1):35–41. 10.5271/sjweh.2365.6740275
Pilones K, Tatum A, Gavalchin J. 2009. Gestational exposure to mercury leads to persistent changes in T-cell phenotype and function in adult DBF1 mice. J Immunotoxicol 6(3):161–170. 10.1080/15476910903084021.19678760
Pingree SD, Simmonds PL, Rummel KT, . 2001. Quantitative evaluation of urinary porphyrins as a measure of kidney mercury content and mercury body burden during prolonged methylmercury exposure in rats. Toxicol Sci 61(2):234–240.11353132
Piotrowski JK, Trojanowska B, Sapota A. 1974a. Binding of cadmium and mercury by metallothionein in the kidneys and liver of rats following repeated administration. Arch Toxicol 32(4):351–360. 10.1007/bf00330118.4480036
Piotrowski JK, Trojanowska B, Wisniewska-Knypl JM, . 1974b. Mercury binding in the kidney and liver of rats repeatedly exposed to mercuric chloride: induction of metallothionein by mercury and cadmium. Toxicol Appl Pharmacol 27(1):11–19. 10.1016/0041-008x(74)90169-0.4853165
Piotrowski JK, Szymanska JA, Skrzypinska-Gawrysiak M, . 1992. Intestinal absorption of inorganic mercury in rat. Pharmacol Toxicol 70(1):53–55.1594537
Polevoy C, Arbuckle TE, Oulhote Y, . 2020. Prenatal exposure to legacy contaminants and visual acuity in Canadian infants: a maternal-infant research on environmental chemicals study (MIREC-ID). Environ Health 19(1):14. 10.1186/s12940-020-0567-2.32028962
Pollack AZ, Schisterman EF, Goldman LR, . 2011. Cadmium, lead, and mercury in relation to reproductive hormones and anovulation in premenopausal women. Environ Health Perspect 119(8):1156–1161. 10.1289/ehp.1003284.21543284
Pollack AZ, Mumford SL, Wactawski-Wende J, . 2013. Bone mineral density and blood metals in premenopausal women. Environ Res 120:76–81. 10.1016/j.envres.2012.06.001.23122770
Pollack AZ, Mumford SL, Mendola P, . 2015. Kidney biomarkers associated with blood lead, mercury, and cadmium in premenopausal women: a prospective cohort study. J Toxicol Environ Health A 78(2):119–131. 10.1080/15287394.2014.944680.25424620
Poma K, Kirsch-Volders M, Susanne C. 1981. Mutagenicity study on mice given mercuric chloride. J Appl Toxicol 1(6):314–316. 10.1002/jat.2550010609.6224841
Ponce RA, Bloom NS. 1991. Effect of pH on the bioaccumulation of low level, dissolved methylmercury by rainbow trout (Oncorhynchus mykiss). Water Air Soil Pollut 56(0):631–640.
Pope Q, Rand MD. 2021. Variation in methylmercury metabolism and elimination in humans: physiological pharmacokinetic modeling highlights the role of gut biotransformation, skeletal muscle, and hair. Toxicol Sci 180(1):26–37. 10.1093/toxsci/kfaa192.33481013
Popescu HI, Negru L, Lancranjan I. 1979. Chromosome aberrations induced by occupational exposure to mercury. Arch Environ Health 34(6):461–463. 10.1080/00039896.1979.10667450.518128
Porcella DB. 1994. Mercury in the environment: Biogeochemistry. In: Watras CJ, Huckabee JW, eds. Mercury pollution integration and synthesis. Boca Raton, FL: Lewis Publishers, 3–19.
Poreba R, Skoczynska A, Gac P, . 2012. Left ventricular diastolic function in workers occupationally exposed to mercury vapour without clinical presentation of cardiac involvement. Toxicol Appl Pharmacol 263(3):368–373. 10.1016/j.taap.2012.07.012.22820423
Post EM, Yang MG, King JA, . 1973. Behavioral changes of young rats force-fed methyl mercury chloride. Proc Soc Exp Biol Med 143(4):1113–1116. 10.3181/00379727-143-37480.4743689
Pouzaud F, Ibbou A, Blanchemanche S, . 2010. Use of advanced cluster analysis to characterize fish consumption patterns and methylmercury dietary exposures from fish and other sea foods among pregnant women. J Expo Sci Environ Epidemiol 20(1):54–68. 10.1038/jes.2009.2.19293844
Purohit AR, Rao MV. 2014. Mitigative role of melatonin and alpha-tocopherol against mercury-induced genotoxicity. Drug Chem Toxicol 37(2):221–226. 10.3109/01480545.2013.838774.24195647
Puty B, Leão LKR, Crespo-Lopez ME, . 2019. Association between methylmercury environmental exposure and neurological disorders: A systematic review. J Trace Elem Med Biol 52:100–110. 10.1016/j.jtemb.2018.12.001.30732869
Pyle DM, Mather TA. 2003. The importance of volcanic emissions for the global atmospheric mercury cycle. Atmos Environ 37(36):5115–5124. 10.1016/j.atmosenv.2003.07.011.
Rabenstein DL, Isab AA, Reid RS. 1982. A proton nuclear magnetic resonance study of the binding of methylmercury in human erythrocytes. Biochim Biophys Acta 720(1):53–64.7059615
Raeeszadeh M, Moradi M, Ayar P, . 2021. The antioxidant effect of Medicago sativa L. (Alfalfa) ethanolic extract against mercury chloride (HgCl2) toxicity in rat liver and kidney: An in vitro and in vivo study. Evid Based Complement Alternat Med 2021:8388002. 10.1155/2021/8388002.34484406
Rafiee A, Delgado-Saborit JM, Sly PD, . 2020. Environmental chronic exposure to metals and effects on attention and executive function in the general population. Sci Total Environ 705:135911. 10.1016/j.scitotenv.2019.135911.31838411
Raffee LA, Alawneh KZ, Alassaf RA, . 2021. Effects of elemental mercury vapor inhalation on arterial blood gases, lung histology, and interleukin-1 expression in pulmonary tissues of rats. ScientificWorldJournal 2021:4141383. 10.1155/2021/4141383.34629987
Rahola T, Aaran RK, Miettinen JK. 1972. Half-time studies of mercury and cadmium by whole-body counting. Assess Radioactiv Contam March:553–562.
Rahola T, Hattula T, Korolainen A, . 1973. Elimination of free and protein-bound ionic mercury 203Hg2+ in man. Ann Clin Res 5(4):214–219.4203781
Rajaee M, Sanchez BN, Renne EP, . 2015. An investigation of organic and inorganic mercury exposure and blood pressure in a small-scale gold mining community in Ghana. Int J Environ Res Public Health 12(8):10020–10038. 10.3390/ijerph120810020.26308023
Rajanna B, Hobson M. 1985. Influence of mercury on uptake of (3H)dopamine and (3H)norepinephrine by rat brain synaptosomes. Toxicol Lett 27:7–14.2997949
Ralston NVC, Raymond LJ. 2018. Mercury’s neurotoxicity is characterized by its disruption of selenium biochemistry. Biochim Biophys Acta Gen Subj 1862:2405–2416. 10.1016/j.bbagen.2018.05.009.29753115
Ralston NV, Ralston CR, Blackwell JL, . 2008. Dietary and tissue selenium in relation to methylmercury toxicity. Neurotoxicology 29(5):802–811. 10.1016/j.neuro.2008.07.007.18761370
Ramalingam V, Vimaladevi V, Rajeswary S, . 2003. Effect of mercuric chloride on circulating hormones in adult albino rats. J Environ Biol 24(4):401–404.15248653
Ramelow GJ, Webre CL, Mueller CS, . 1989. Variations of heavy metals and arsenic in fish and other organisms from the Calcasieu River and Lake, Louisiana. Arch Environ Contam Toxicol 18(6):804–818. 10.1007/bf01160294.2619321
Ramirez GB, Cruz MC, Pagulayan O, . 2000. The Tagum study I: analysis and clinical correlates of mercury in maternal and cord blood, breast milk, meconium, and infants’ hair. Pediatrics 106(4):774–781.11015522
Ramirez GB, Pagulayan O, Akagi H, . 2003. Tagum study II: follow-up study at two years of age after prenatal exposure to mercury. Pediatrics 111(3):e289–295.12612286
Rand MD, Conrad K, Marvin E, . 2020. Developmental exposure to methylmercury and resultant muscle mercury accumulation and adult motor deficits in mice. Neurotoxicology 81:1–10. 10.1016/j.neuro.2020.07.007.32735808
Rao MV, Chinoy NJ, Suthar MB, . 2001. Role of ascorbic acid on mercuric chloride-induced genotoxicity in human blood cultures. Toxicol in Vitro 15(6):649–654.11698165
Rastogi SC. 1992. Cadmium, chromium, lead, and mercury residues in finger-paints and make-up paints. Bull Environ Contam Toxicol 48(2):289–294. 10.1007/bf00194386.1537001
Rastogi SC, Pritzl G. 1996. Migration of some toxic metals from crayons and water colors. Bull Environ Contam Toxicol 56(4):527–533. 10.1007/s001289900076.8645906
Raymond MR, Christensen KY, Thompson BA, . 2016. Associations between fish consumption and contaminant biomarkers with cardiovascular conditions among older male anglers in Wisconsin. J Occup Environ Med 58(7):676–682. 10.1097/jom.0000000000000757.27253229
Razzaghi H, Tinker SC, Crider K. 2014. Blood mercury concentrations in pregnant and nonpregnant women in the United States: National Health and Nutrition Examination Survey 1999-2006. Am J Obstet Gynecol 210(4):357 e351–357 e359. 10.1016/j.ajog.2013.10.884.
Rees JR, Sturup S, Chen C, . 2007. Toenail mercury and dietary fish consumption. J Expo Sci Environ Epidemiol 17(1):25–30. 10.1038/sj.jes.7500516.16912698
Refsvik T. 1983. The mechanism of biliary excretion of methyl mercury: Methylthiols. Acta Pharmacol Toxicol (Copenh) 53(2):153–158.6624483
Refsvik T, Norseth T. 1975. Methyl mercuric compounds in rat bile. Acta Pharmacol Toxicol (Copenh) 36(1):67–78.1173724
Regencia ZJG, Dalmacion GV, Baja ES. 2022. Effect of heavy metals on ventricular repolarization and depolarization in the Metropolitan Manila Development Authority (MMDA) traffic enforcers’ health study. Arch Environ Occup Health 77(2):87–95. 10.1080/19338244.2020.1853017.34027826
Regnell O, Tunlid A. 1991. Laboratory study of chemical speciation of mercury in lake sediment and water under aerobic and anaerobic conditions. Appl Environ Microbiol 57(3):789–795. 10.1128/aem.57.3.789-795.1991.16348444
Ren M, Zhao J, Wang B, . 2022. Associations between hair levels of trace elements and the risk of preterm birth among pregnant women: A prospective nested case-control study in Beijing Birth Cohort (BBC), China. Environ Int 158:106965. 10.1016/j.envint.2021.106965.34735958
Renzetti S, Cagna G, Calza S, . 2021. The effects of the exposure to neurotoxic elements on Italian schoolchildren behavior. Sci Rep 11(1):9898. 10.1038/s41598-021-88969-z.33972598
RePORTER. 2024. Mercury and mercury compounds. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. March 14, 2024.
Reuben A, Frischtak H, Berky A, . 2020. Elevated hair mercury levels are associated with neurodevelopmental deficits in children living near artisanal and small-scale gold mining in Peru. Geohealth 4(5):e2019GH000222. 10.1029/2019gh000222.
Reuhl KR, Chang LW, Townsend JW. 1981a. Pathological effects of in utero methylmercury exposure on the cerebellum of the golden hamster (Mesocricetus auratus): 1. Early effects on the neonatal cerebellar cortex. Environ Res 26(2):281–306. 10.1016/0013-9351(81)90205-x.7318786
Reuhl KR, Chang LW, Townsend JW. 1981b. Pathological effects of in utero methylmercury exposure on the cerebellum of the golden hamster (Mesocricetus auratus): 2. Residual effects on the adult cerebellum. Environ Res 26(2):307–327. 10.1016/0013-9351(81)90206-1.7318787
Revis NW, Osborne TR, Holdsworth G, . 1989. Distribution of mercury species in soil from a mercury-contaminated site. Water Air Soil Pollut 45(1–2):105–114.
Revis NW, Osborne TR, Holdsworth G, . 1990. Mercury in soil: A method for assessing acceptable limits. Arch Environ Contam Toxicol 19(2):221–226.
Rezaei M, Javadmoosavi SY, Mansouri B, . 2019. Thyroid dysfunction: how concentration of toxic and essential elements contribute to risk of hypothyroidism, hyperthyroidism, and thyroid cancer. Environ Sci Pollut Res Int 26(35):35787–35796. 10.1007/s11356-019-06632-7.31701424
Rezaei M, Blaszczyk M, Tinkov AA, . 2021. Relationship between gestational diabetes and serum trace element levels in pregnant women from Eastern Iran: a multivariate approach. Environ Sci Pollut Res Int 28(33):45230–45239. 10.1007/s11356-021-13927-1.33860892
Rhee J, Vance TM, Lim R, . 2020. Association of blood mercury levels with nonmelanoma skin cancer in the U.S.A. using National Health and Nutrition Examination Survey data (2003-2016). Br J Dermatol 183(3):480–487. 10.1111/bjd.18797.32020585
Ribeyre F, Boudou A, Maury-Brachet R. 1991. Multicompartment ecotoxicological models to study mercury bioaccumulation and transfer in freshwater systems. Water Air Soil Pollut 56(1):641–652. 10.1007/bf00342306.
Rice DC. 1989a. Blood mercury concentrations following methyl mercury exposure in adult and infant monkeys. Environ Res 49(1):115–126. 10.1016/s0013-9351(89)80026-x.2721472
Rice DC. 1989b. Brain and tissue levels of mercury after chronic methylmercury exposure in the monkey. J Toxicol Environ Health 27(2):189–198. 10.1080/15287398909531290.2499694
Rice DC. 1989c. Delayed neurotoxicity in monkeys exposed developmentally to methylmercury. Neurotoxicology 10(4):645–650.2562538
Rice DC. 1992. Effects of pre- plus postnatal exposure to methylmercury in the monkey on fixed interval and discrimination reversal performance. Neurotoxicology 13(2):443–452.1436760
Rice DC. 1998a. Age-related increase in auditory impairment in monkeys exposed in utero plus postnatally to methylmercury. Toxicol Sci 44(2):191–196. 10.1006/toxs.1998.2487.9742657
Rice DC. 1998b. Lack of effect of methylmercury exposure from birth to adulthood on information processing speed in the monkey. Neurotoxicol Teratol 20(3):275–283.9638685
Rice DC, Gilbert SG. 1982. Early chronic low-level methylmercury poisoning in monkeys impairs spatial vision. Science 216(4547):759–761. 10.1126/science.7079739.7079739
Rice DC, Gilbert SG. 1990. Effects of developmental exposure to methyl mercury on spatial and temporal visual function in monkeys. Toxicol Appl Pharmacol 102(1):151–163. 10.1016/0041-008x(90)90092-9.2296766
Rice DC, Gilbert SG. 1992. Exposure to methyl mercury from birth to adulthood impairs high-frequency hearing in monkeys. Toxicol Appl Pharmacol 115(1):6–10. 10.1016/0041-008x(92)90361-u.1631895
Rice DC, Hayward S. 1999. Comparison of visual function at adulthood and during aging in monkeys exposed to lead or methylmercury. Neurotoxicology 20(5):767–784.10591513
Rice DC, Krewski D, Collins BT, . 1989. Pharmacokinetics of methylmercury in the blood of monkeys (Macaca fascicularis). Fundam Appl Toxicol 12(1):23–33.2925016
Rice KM, Walker EM, Wu M, . 2014. Environmental mercury and its toxic effects. J Prev Med Public Health 47(2):74–83. 10.3961/jpmph.2014.47.2.74.24744824
Rieber M, Harris DP. 1994. Mercury pollution: The impact of U.S. government stockpile releases. In: Watras CJ, Huckabee JW, eds. Mercury pollution integration and synthesis. Boca Raton, FL: Lewis Publishers, 615–620.
Riisgard HU, Hansen S. 1990. Biomagnification of mercury in a marine grazing food-chain: Algal cells Phaeodactylum tricornutum, mussels Mytilus edulis and flounders Platichthys flesus studied by means of a stepwise-reduction-CVAA method. Mar Ecol Prog Ser 62(3):259–270.
Riley DM, Newby CA, Leal-Almeraz TO, . 2001. Assessing elemental mercury vapor exposure from cultural and religious practices. Environ Health Perspect 109(8):779–784. 10.1289/ehp.01109779.11564612
Riley DM, Newby CA, Leal-Almeraz TO. 2006. Incorporating ethnographic methods in multidisciplinary approaches to risk assessment and communication: cultural and religious uses of mercury in Latino and Caribbean communities. Risk Anal 26(5):1205–1221. 10.1111/j.1539-6924.2006.00809.x.17054526
Risch MR, Gay DA, Fowler KK, . 2012. Spatial patterns and temporal trends in mercury concentrations, precipitation depths, and mercury wet deposition in the North American Great Lakes region, 2002-2008. Environ Pollut 161:261–271. 10.1016/j.envpol.2011.05.030.21745704
Risch MR, DeWild JF, Gay DA, . 2017. Atmospheric mercury deposition to forests in the eastern USA. Environ Pollut 228:8–18. 10.1016/j.envpol.2017.05.004.28501633
Ritchie KA, Gilmour WH, Macdonald EB, . 2002. Health and neuropsychological functioning of dentists exposed to mercury. Occup Environ Med 59(5):287–293. 10.1136/oem.59.5.287.11983843
Robinson JW, Skelly EM. 1983. The direct determination of mercury in sweat. Spectrosc Lett 16(2):133–150. 10.1080/00387018308062329.
Robinson JF, Theunissen PT, van Dartel DA, . 2011. Comparison of MeHg-induced toxicogenomic responses across in vivo and in vitro models used in developmental toxicology. Reprod Toxicol 32(2):180–188. 10.1016/j.reprotox.2011.05.011.21664453
Rodier PM, Kates B, Simons R. 1988. Mercury localization in mouse kidney over time: Autoradiography versus silver staining. Toxicol Appl Pharmacol 92(2):235–245.2448914
Rodriguez LH, Rodriguez-Villamizar LA, Florez-Vargas O, . 2017. No effect of mercury exposure on kidney function during ongoing artisanal gold mining activities in Colombia. Toxicol Ind Health 33(1):67–78. 10.1177/0748233716659031.27449026
Rodríguez-Carrillo A, Mustieles V, D’Cruz SC, . 2022. Exploring the relationship between metal exposure, BDNF, and behavior in adolescent males. Int J Hyg Environ Health 239:113877. 10.1016/j.ijheh.2021.113877.34757248
Rodríguez-Viso P, Domene A, Vélez D, . 2023. Oral exposure to inorganic mercury or methylmercury elicits distinct pro-inflammatory and pro-oxidant intestinal responses in a mouse model system. Food Chem Toxicol 177:113801. 10.1016/j.fct.2023.113801.37137463
Roels H, Lauwerys R, Buchet JP, . 1982. Comparison of renal function and psychomotor performance in workers exposed to elemental mercury. Int Arch Occup Environ Health 50(1):77–93. 10.1007/bf00432495.7085088
Roels H, Abdeladim S, Ceulemans E, . 1987. Relationships between the concentrations of mercury in air and in blood or urine in workers exposed to mercury vapour. Ann Occup Hyg 31(2):135–145. 10.1093/annhyg/31.2.135.3688710
Rogers HS, McCullough J, Kieszak S, . 2007. Exposure assessment of young children living in Chicago communities with historic reports of ritualistic use of mercury. Clin Toxicol 45(3):240–247. 10.1080/15563650601031643.
Roman HA, Walsh TL, Coull BA, . 2011. Evaluation of the cardiovascular effects of methylmercury exposures: current evidence supports development of a dose-response function for regulatory benefits analysis. Environ Health Perspect 119(5):607–614. 10.1289/ehp.1003012.21220222
Roman-Franco AA, Turiello M, Albini B, . 1978. Anti-basement membrane antibodies and antigen-antibody complexes in rabbits injected with mercuric chloride. Clin Immunol Immunopathol 9(4):464–481. 10.1016/0090-1229(78)90143-5.648040
Roos PM, Dencker L. 2012. Mercury in the spinal cord after inhalation of mercury. Basic Clin Pharmacol Toxicol 111(2):126–132. 10.1111/j.1742-7843.2012.00872.x.22364490
Roos D, Seeger R, Puntel R, . 2012. Role of calcium and mitochondria in MeHg-mediated cytotoxicity. J Biomed Biotechnol 2012:1–15. 10.1155/2012/248764.21836813
Rosa-Silva HTD, Panzenhagen AC, Schmidtt V, . 2020a. Hepatic and neurobiological effects of foetal and breastfeeding and adulthood exposure to methylmercury in Wistar rats. Chemosphere 244:125400. 10.1016/j.chemosphere.2019.125400.31809933
Rosa-Silva HTD, Panzenhagen AC, Espitia-Pérez P, . 2020b. Effects of foetal and breastfeeding exposure to methylmercury (MeHg) and retinol palmitate (Vitamin A) in rats: Redox parameters and susceptibility to DNA damage in liver. Mutat Res Genet Toxicol Environ Mutagen 858–860:503239. 10.1016/j.mrgentox.2020.503239.
Rossa-Roccor V, Karim ME. 2021. Are US adults with low-exposure to methylmercury at increased risk for depression? A study based on 2011-2016 National Health and Nutrition Examination Surveys (NHANES). Int Arch Occup Environ Health 94(3):419–431. 10.1007/s00420-020-01592-9.33104857
Rossi AD, Ahlbom E, Ogren SO, . 1997. Prenatal exposure to methylmercury alters locomotor activity of male but not female rats. Exp Brain Res 117(3):428–436. 10.1007/s002210050237.9438710
Rothenberg SE, Keiser S, Ajami NJ, . 2016a. The role of gut microbiota in fetal methylmercury exposure: Insights from a pilot study. Toxicol Lett 242:60–67. 10.1016/j.toxlet.2015.11.022.26626101
Rothenberg SE, Yu X, Liu J, . 2016b. Maternal methylmercury exposure through rice ingestion and offspring neurodevelopment: A prospective cohort study. Int J Hyg Environ Health 219(8):832–842. 10.1016/j.ijheh.2016.07.014.27503636
Rothenberg SE, Wagner CL, Hamidi B, . 2019. Longitudinal changes during pregnancy in gut microbiota and methylmercury biomarkers, and reversal of microbe-exposure correlations. Environ Res 172:700–712. 10.1016/j.envres.2019.01.014.30903970
Rothenberg SE, Korrick SA, Liu J, . 2021. Maternal methylmercury exposure through rice ingestion and child neurodevelopment in the first three years: a prospective cohort study in rural China. Environ Health 20(1):50. 10.1186/s12940-021-00732-z.33910568
Rowens B, Guerrero-Betancourt D, Gottlieb CA, . 1991. Respiratory failure and death following acute inhalation of mercury vapor. Chest 99(1):185–190. 10.1378/chest.99.1.185.1984951
Rowland IR, Davies MJ, Grasso P. 1975a. The methylation of mercury by the gastro-intestinal contents of the rat. Biochem Soc Trans 3(4):502–504.1183706
Rowland IR, Grasso P, Davies MJ. 1975b. The methylation of mercuric chloride by human intestinal bacteria. Experientia 31(9):1064–1065.1100426
Rozalski M, Wierzbicki R. 1983. Effect of mercuric chloride on cultured rat fibroblasts: survival, protein biosynthesis and binding of mercury to chromatin. Biochem Pharmacol 32(13):2124–2126.6223640
Rozgaj R, Kasuba V, Blanusa M. 2005. Mercury chloride genotoxicity in rats following oral exposure, evaluated by comet assay and micronucleus test. Arh Hig Rada Toksikol 56(1):9–15.15969203
RTECS. 1997. Mercury. Registry of Toxic Effects of Chemical Substances, Micromedex, Inc.
Ruiz P, Ray M, Fisher J, . 2011. Development of a human physiologically based pharmacokinetic (PBPK) toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Rule JH, Iwashchenko MS. 1998. Mercury concentrations in soils adjacent to a former chlor-alkali plant. J Environ Qual 27(1):31–37.
Rumbold DG, Lienhardt CT, Parsons ML. 2018. Mercury biomagnification through a coral reef ecosystem. Arch Environ Contam Toxicol 75(1):121–133. 10.1007/s00244-018-0523-0.29675668
Ruus A, Overjordet IB, Braaten HF, . 2015. Methylmercury biomagnification in an Arctic pelagic food web. Environ Toxicol Chem 34(11):2636–2643. 10.1002/etc.3143.26274519
Ryan L. 2008. Combining data from multiple sources, with applications to environmental risk assessment. Stat Med 27(5):698–710. 10.1002/sim.3053.18069727
Ryu J, Ha EH, Kim BN, . 2017. Associations of prenatal and early childhood mercury exposure with autistic behaviors at 5years of age: The Mothers and Children’s Environmental Health (MOCEH) study. Sci Total Environ 605–606:251–257. 10.1016/j.scitotenv.2017.06.227.
Sabir S, Saleem U, Akash MSH, . 2022. Thymoquinone induces Nrf2 mediated adaptive homeostasis: implication for mercuric chloride-induced nephrotoxicity. ACS Omega 7(8):7370–7379. 10.1021/acsomega.2c00028.35252727
Sager PR, Doherty RA, Olmsted JB. 1983. Interaction of methylmercury with microtubules in cultured cells and in vitro. Exp Cell Res 146(1):127–137.6305690
Sagiv SK, Thurston SW, Bellinger DC, . 2012. Prenatal exposure to mercury and fish consumption during pregnancy and attention-deficit/hyperactivity disorder-related behavior in children. Arch Pediatr Adolesc Med 166(12):1123–1131. 10.1001/archpediatrics.2012.1286.23044994
Saint-Amour D, Roy MS, Bastien C, . 2006. Alterations of visual evoked potentials in preschool Inuit children exposed to methylmercury and polychlorinated biphenyls from a marine diet. Neurotoxicology 27(4):567–578. 10.1016/j.neuro.2006.02.008.16620993
Saito H, Sekikawa T, Taguchi J, . 2020. Prenatal and postnatal methyl mercury exposure in Niigata, Japan: adult outcomes. Neurotoxicology 81:364–372. 10.1016/j.neuro.2020.09.031.35587140
Sakamoto M, Kakita A, Wakabayashi K, . 2002. Evaluation of changes in methylmercury accumulation in the developing rat brain and its effects: a study with consecutive and moderate dose exposure throughout gestation and lactation periods. Brain Res 949(1–2):51–59. 10.1016/s0006-8993(02)02964-5.12213299
Sakamoto M, Kakita A, de Oliveira RB, . 2004. Dose-dependent effects of methylmercury administered during neonatal brain spurt in rats. Brain Res Dev Brain Res 152(2):171–176. 10.1016/j.devbrainres.2004.06.016.15351505
Sakamoto M, Kaneoka T, Murata K, . 2007. Correlations between mercury concentrations in umbilical cord tissue and other biomarkers of fetal exposure to methylmercury in the Japanese population. Environ Res 103(1):106–111. 10.1016/j.envres.2006.03.004.16650842
Sakamoto M, Kubota M, Murata K, . 2008. Changes in mercury concentrations of segmental maternal hair during gestation and their correlations with other biomarkers of fetal exposure to methylmercury in the Japanese population. Environ Res 106(2):270–276. 10.1016/j.envres.2007.10.002.18054904
Sakamoto M, Yasutake A, Domingo JL, . 2013. Relationships between trace element concentrations in chorionic tissue of placenta and umbilical cord tissue: potential use as indicators for prenatal exposure. Environ Int 60:106–111. 10.1016/j.envint.2013.08.007.24028800
Sakamoto M, Chan HM, Domingo JL, . 2015. Significance of fingernail and toenail mercury concentrations as biomarkers for prenatal methylmercury exposure in relation to segmental hair mercury concentrations. Environ Res 136:289–294. 10.1016/j.envres.2014.09.034.25460648
Sakamoto M, Murata K, Domingo JL, . 2016. Implications of mercury concentrations in umbilical cord tissue in relation to maternal hair segments as biomarkers for prenatal exposure to methylmercury. Environ Res 149:282–287. 10.1016/j.envres.2016.04.023.27156841
Sakamoto M, Kakita A, Domingo JL, . 2017. Stable and episodic/bolus patterns of methylmercury exposure on mercury accumulation and histopathologic alterations in the nervous system. Environ Res 152:446–453. 10.1016/j.envres.2016.06.034.27450633
Sakamoto M, Chan HM, Domingo JL, . 2018. Placental transfer and levels of mercury, selenium, vitamin E, and docosahexaenoic acid in maternal and umbilical cord blood. Environ Int 111:309–315. 10.1016/j.envint.2017.11.001.29150340
Sakamoto M, Kakita A, Sakai K, . 2020. Methylmercury exposure during the vulnerable window of the cerebrum in postnatal developing rats. Environ Res 188:109776. 10.1016/j.envres.2020.109776.32592939
Salazar-Camacho C, Salas-Moreno M, Paternina-Uribe R, . 2021. Mercury species in fish from a tropical river highly impacted by gold mining at the Colombian Pacific region. Chemosphere 264(Pt 2):128478. 10.1016/j.chemosphere.2020.128478.33065322
Sallsten G, Barregard L, Schutz A. 1994. Clearance half life of mercury in urine after the cessation of long term occupational exposure: influence of a chelating agent (DMPS) on excretion of mercury in urine. Occup Environ Med 51(5):337–342. 10.1136/oem.51.5.337.8199685
Salonen JT, Seppanen K, Nyyssonen K, . 1995. Intake of mercury from fish, lipid peroxidation, and the risk of myocardial infarction and coronary, cardiovascular, and any death in eastern Finnish men. Circulation 91(3):645–655. 10.1161/01.cir.91.3.645.7828289
Salonen JT, Seppanen K, Lakka TA, . 2000. Mercury accumulation and accelerated progression of carotid atherosclerosis: a population-based prospective 4-year follow-up study in men in eastern Finland. Atherosclerosis 148(2):265–273. 10.1016/s0021-9150(99)00272-5.10657561
Samudralwar DL, Garg AN. 1996. Minor and trace elemental determination in the Indian herbal and other medicinal preparations. Biol Trace Elem Res 54(2):113–121. 10.1007/bf02786258.8886311
Sanchez Rodriguez LH, Florez-Vargas O, Rodriguez-Villamizar LA, . 2015. Lack of autoantibody induction by mercury exposure in artisanal gold mining settings in Colombia: Findings and a review of the epidemiology literature. J Immunotoxicol 12(4):368–375. 10.3109/1547691x.2014.986591.25477026
Sandborgh-Englund G, Elinder CG, Johanson G, . 1998. The absorption, blood levels, and excretion of mercury after a single dose of mercury vapor in humans. Toxicol Appl Pharmacol 150(1):146–153. 10.1006/taap.1998.8400.9630463
Sandborgh-Englund G, Ask K, Belfrage E, . 2001. Mercury exposure in utero and during infancy. J Toxicol Environ Health A 63(5):317–320. 10.1080/15287390152103634.11471864
Sandborgh-Englund G, Einarsson C, Sandstrom M, . 2004. Gastrointestinal absorption of metallic mercury. Arch Environ Health 59(9):449–454. 10.1080/00039890409603424.16381485
Sanders AP, Mazzella MJ, Malin AJ, . 2019. Combined exposure to lead, cadmium, mercury, and arsenic and kidney health in adolescents age 12-19 in NHANES 2009-2014. Environ Int 131:104993. 10.1016/j.envint.2019.104993.31326826
Sanga RN, Bartell SM, Ponce RA, . 2001. Effects of uncertainties on exposure estimates to methylmercury: a Monte Carlo analysis of exposure biomarkers versus dietary recall estimation. Risk Anal 21(5):859–868. 10.1111/0272-4332.215157.11798122
Santana L, Bittencourt LO, Nascimento PC, . 2019. Low doses of methylmercury exposure during adulthood in rats display oxidative stress, neurodegeneration in the motor cortex and lead to impairment of motor skills. J Trace Elem Med Biol 51:19–27. 10.1016/j.jtemb.2018.09.004.30466930
Sapin C, Druet E, Druet P. 1977. Induction of anti-glomerular basement membrane antibodies in the Brown-Norway rat by mercuric chloride. Clin Exp Immunol 28(1):173–179.324675
Sartorelli P, Montomoli L, Sisinni AG, . 2003. Percutaneous penetration of inorganic mercury from soil: an in vitro study. Bull Environ Contam Toxicol 71(6):1091–1099.14756275
Sarzo B, Ballester F, Soler-Blasco R, . 2022. Pre and postnatal exposure to mercury and sexual development in 9-year-old children in Spain: The role of brain-derived neurotrophic factor. Environ Res 213:113620. 10.1016/j.envres.2022.113620.35697081
Satoh H, Hursh JB, Clarkson TW, . 1981. Selective determination of elemental mercury in blood and urine exposed to mercury vapor in vitro. J Appl Toxicol 1(3):177–181. 10.1002/jat.2550010309.7185883
Sawyer J. 2015. Hartford man had skeletal remains in apartment for religious reasons: PD. NBC Connecticut. https://www.nbcconnecticut.com/news/local/Skeletal-Remains-of-Five-Bodies-Stolen-From-Massachusetts-Cemetery-Found-in-Hartford-Apartment-Police-360669131.html. May 17, 2021.
Schiffer L, Barnard L, Baranowski ES, . 2019. Human steroid biosynthesis, metabolism and excretion are differentially reflected by serum and urine steroid metabolomes: A comprehensive review. J Steroid Biochem Mol Biol 194:1–25. 10.1016/j.jsbmb.2019.105439.
Schiønning JD, Larsen JO, Eide R. 1998a. A stereological study of dorsal root ganglion cells and nerve root fibers from rats exposed to mercury vapor. Acta Neuropathol (Berl) 96(2):185–190. 10.1007/s004010050880.9705135
Schiønning JD, Larsen JO, Tandrup T, . 1998b. Selective degeneration of dorsal root ganglia and dorsal nerve roots in methyl mercury-intoxicated rats: a stereological study. Acta Neuropathol (Berl) 96(2):191–201.9705136
Schmid K, Sassen A, Staudenmaier R, . 2007. Mercuric dichloride induces DNA damage in human salivary gland tissue cells and lymphocytes. Arch Toxicol 81(11):759–767. 10.1007/s00204-007-0208-3.17479252
Schroeder WH, Fanaki FH. 1988. Field measurements of water-air exchange of mercury in freshwater systems. Environ Technol Lett 9(5):369–374. 10.1080/09593338809384579.
Schumacher L, Abbott LC. 2017. Effects of methyl mercury exposure on pancreatic beta cell development and function. J Appl Toxicol 37(1):4–12. 10.1002/jat.3381.27594070
Schurz F, Sabater-Vilar M, Fink-Gremmels J. 2000. Mutagenicity of mercury chloride and mechanisms of cellular defence: The role of metal-binding proteins. Mutagenesis 15(6):525–530.11077005
Schuster E. 1991. The behavior of mercury in the soil with special emphasis on complexation and adsorption processes - A review of the literature. Water Air Soil Pollut 56(1):667–680. 10.1007/bf00342308.
Schuurs AH. 1999. Reproductive toxicity of occupational mercury. A review of the literature. J Dent 27(4):249–256.10193101
Sears ME, Kerr KJ, Bray RI. 2012. Arsenic, cadmium, lead, and mercury in sweat: A systematic review. J Environ Public Health 2012:1–10. 10.1155/2012/184745.
Seki N, Akiyama M, Yamakawa H, . 2021. Adverse effects of methylmercury on gut bacteria and accelerated accumulation of mercury in organs due to disruption of gut microbiota. J Toxicol Sci 46(2):91–97. 10.2131/jts.46.91.33536393
Sell JL, Davison KL. 1975. Metabolism of mercury, administered as methylmercuric chloride or mercuric chloride, by lactating ruminants. J Agric Food Chem 23(4):803–808.1141531
SERDP. 2014 Bioavailability and methylation potential of mercury sulfides in sediments. Alexandria, VA: Strategic Environmental Research and Development Program. ER1744.
Shaheen SO, Newson RB, Henderson AJ, . 2004. Umbilical cord trace elements and minerals and risk of early childhood wheezing and eczema. Eur Respir J 24(2):292–297. 10.1183/09031936.04.00117803.15332400
Shah-Kulkarni S, Lee S, Jeong KS, . 2020. Prenatal exposure to mixtures of heavy metals and neurodevelopment in infants at 6 months. Environ Res 182:109122. 10.1016/j.envres.2020.109122.32069757
Shamalaye C, Davidson PW, Myers GJ. 2004. The Seychelles Child Development Study: Two decades of collaboration. Seychelles Med Dent J 7(1):92–99.
Shapiro AM, Chan HM. 2008. Characterization of demethylation of methylmercury in cultured astrocytes. Chemosphere 74(1):112–118. 10.1016/j.chemosphere.2008.09.019.18950830
Shen Y, Laue HE, Shrubsole MJ, . 2022. Associations of childhood and perinatal blood metals with children’s gut microbiomes in a Canadian gestation cohort. Environ Health Perspect 130(1):17007. 10.1289/EHP9674.35037767
Shen L, Liang C, Li D, . 2023. The association between exposure to multiple toxic metals and the risk of endometriosis: Evidence from the results of blood and follicular fluid. Sci Total Environ 855:158882. 10.1016/j.scitotenv.2022.158882.36155031
Shenker BJ, Maserejian NN, Zhang A, . 2008. Immune function effects of dental amalgam in children: a randomized clinical trial. J Am Dent Assoc 139(11):1496–1505. 10.14219/jada.archive.2008.0076.18978388
Sherlock JC, Lindsay DG, Evans WH, . 1982. Duplication diet study on mercury intake by fish consumers in the UK. Arch Environ Health 37(5):271–278.7138076
Sherlock J, Hislop J, Newton D, . 1984. Elevation of mercury in human blood from controlled chronic ingestion of methylmercury in fish. Hum Toxicol 3(2):117–131.6724592
Sherman LS, Blum JD, Franzblau A, . 2013. New insight into biomarkers of human mercury exposure using naturally occurring mercury stable isotopes. Environ Sci Technol 47(7):3403–3409. 10.1021/es305250z.23463943
Shi CY, Lane AT, Clarkson TW. 1990. Uptake of mercury by the hair of methylmercury-treated newborn mice. Environ Res 51(2):170–181.2335158
Shi X, Chan CPS, Man GKY, . 2021. Associations between blood metal/ metalloid concentration and human semen quality and sperm function: A cross-sectional study in Hong Kong. J Trace Elem Med Biol 65:126735. 10.1016/j.jtemb.2021.126735.33647736
Shimada A, Yamamoto E, Morita T, . 2004. Ultrastructural demonstration of mercury granules in the placenta of metallothionein-null pregnant mice after exposure to mercury vapor. Toxicol Pathol 32(5):519–526. 10.1080/01926230490496302.15603537
Shin YY, Ryu IK, Park MJ, . 2018. The association of total blood mercury levels and overweight among Korean adolescents: analysis of the Korean National Health and Nutrition Examination Survey (KNHANES) 2010-2013. Korean J Pediatr 61(4):121–128. 10.3345/kjp.2018.61.4.121.29713358
Shinoda Y, Ehara S, Tatsumi S, . 2019. Methylmercury-induced neural degeneration in rat dorsal root ganglion is associated with the accumulation of microglia/macrophages and the proliferation of Schwann cells. J Toxicol Sci 44(3):191–199. 10.2131/jts.44.191.30842371
Shipp AM, Gentry PR, Lawrence G, . 2000. Determination of a site-specific reference dose for methylmercury for fish-eating populations. Toxicol Ind Health 16(9–10):335–438. 10.1177/074823370001600901.11762928
Siblerud RL. 1990. The relationship between mercury from dental amalgam and the cardiovascular system. Sci Total Environ 99(1–2):23–35. 10.1016/0048-9697(90)90207-b.2270468
Siegler RW, Nierenberg DW, Hickey WF. 1999. Fatal poisoning from liquid dimethylmercury: A neuropathologic study. Hum Pathol 30(6):720–723.10374784
Signes-Pastor AJ, Desai G, García-Villarino M, . 2021. Exposure to a mixture of metals and growth indicators in 6-11-year-old children from the 2013-16 NHANES. Expo Health 13(2):173–184. 10.1007/s12403-020-00371-8.34151044
Silbergeld EK, Silva IA, Nyland JF. 2005. Mercury and autoimmunity: Implications for occupational and environmental health. Toxicol Appl Pharmacol 207(2 Suppl):282–292. 10.1016/j.taap.2004.11.035.16023690
Silva JL, Leocádio PCL, Reis JM, . 2021. Oral methylmercury intoxication aggravates cardiovascular risk factors and accelerates atherosclerosis lesion development in ApoE knockout and C57BL/6 mice. Toxicol Res 37(3):311–321. 10.1007/s43188-020-00066-x.34295795
Silva MCD, Oliveira RAA, Vasconcellos ACS, . 2023. Chronic mercury exposure and GSTP1 polymorphism in Munduruku indigenous from Brazilian Amazon. Toxics 11(2):138. 10.3390/toxics11020138.36851015
Simmons-Willis TA, Koh AS, Clarkson TW, . 2002. Transport of a neurotoxicant by molecular mimicry: the methylmercury-L-cysteine complex is a substrate for human L-type large neutral amino acid transporter (LAT) 1 and LAT2. Biochem J 367(Pt 1):239–246. 10.1042/bj20020841.12117417
Sin YM, Teh WF. 1992. Effect of long-term uptake of mercuric sulphide on thyroid hormones and glutathione in mice. Bull Environ Contam Toxicol 49(6):847–854. 10.1007/BF00203157.1450564
Sin YM, Lim YF, Wong MK. 1983. Uptake and distribution in mice from ingesting soluble and insoluble mercury compounds. Bull Environ Contam Toxicol 31(5):605–612.6640159
Sin YM, Teh WF, Wong MK. 1989. Absorption of mercuric chloride and mercuric sulphide and their possible effects on tissue glutathione in mice. Bull Environ Contam Toxicol 42(2):307–314.2920239
Sin YM, Teh WF, Wong MK, . 1990. Effect of mercury on glutathione and thyroid hormones. Bull Environ Contam Toxicol 44(4):616–622. 10.1007/BF01700885.2322688
Sirivarasai J, Chaisungnern K, Panpunuan P, . 2021. Role of MT1A polymorphism and environmental mercury exposure on the Montreal Cognitive Assessment (MoCA). Neuropsychiatr Dis Treat 17:2429–2439. 10.2147/ndt.S320374.34326641
Sirot V, Guerin T, Mauras Y, . 2008. Methylmercury exposure assessment using dietary and biomarker data among frequent seafood consumers in France CALIPSO study. Environ Res 107(1):30–38. 10.1016/j.envres.2007.12.005.18261721
Sitarek K, Gralewicz S. 2009. Early developmental effects of separate or combined perinatal exposure to methylmercury (MeHg) and 2,2′,4,4′,5,5′-hexachlorobiphenyl (PCB 153) in the rat. Int J Occup Med Environ Health 22(2):89–105. 10.2478/v10001-009-0015-6.19617190
Sizmur T, O’Driscoll N, Cai Y. 2018. JES Special issue in mercury biogeochemistry and fate. J Environ Sci (China) 68:1–4. 10.1016/j.jes.2018.05.020.29908728
Skerfving S, Hansson K, Lindsten J. 1970. Chromosome breakage in humans exposed to methyl mercury through fish consumption. Arch Environ Health 21:133–139.5464308
Skerfving S, Hansson K, Mangs C, . 1974. Methylmercury-induced chromosome damage in man. Environ Res 7(1):83–98.
Skogheim TS, Weyde KVF, Engel SM, . 2021. Metal and essential element concentrations during pregnancy and associations with autism spectrum disorder and attention-deficit/hyperactivity disorder in children. Environ Int 152:106468. 10.1016/j.envint.2021.106468.33765546
Skoglund A, Egelrud T. 1991. Hypersensitivity reactions to dental materials in patients with lichenoid oral mucosal lesions and in patients with burning mouth syndrome. Scand J Dent Res 99(4):320–328. 10.1111/j.1600-0722.1991.tb01035.x.1771379
Skowronski GA, Turkall RM, Abdel-Rahman MS. 2000. In vitro penetration of soil-aged mercury through pig skin. J Toxicol Environ Health A 61(3):189–200.11036507
Skröder H, Kippler M, Tofail F, . 2017. Early-life selenium status and cognitive function at 5 and 10 years of age in Bangladeshi children. Environ Health Perspect 125(11):1–13. 10.1289/ehp1691.27384039
Sletvold H, Svendsen K, Aas O, . 2012. Neuropsychological function and past exposure to metallic mercury in female dental workers. Scand J Psychol 53(2):136–143. 10.1111/j.1467-9450.2011.00929.x.22092046
Smith TG, Armstrong FAJ. 1975. Mercury in seals, terrestrial carnivores, and principal food items of the Inuit, from Holman, N.W.T. J Fish Res Board Can 32(6):795–802.
Smith TG, Armstrong FAJ. 1978. Mercury and selenium in ringed and bearded seal tissues from Arctic Canada. J Arctic Inst North Am 31(2):75–84.
Smith PJ, Langolf GD, Goldberg J. 1983. Effects of occupational exposure to elemental mercury on short term memory. Br J Ind Med 40(4):413–419.6626469
Smith JC, Allen PV, Turner MD, . 1994. The kinetics of intravenously administered methyl mercury in man. Toxicol Appl Pharmacol 128(2):251–256. 10.1006/taap.1994.1204.7940540
Smith KM, Barraj LM, Kantor M, . 2009. Relationship between fish intake, n-3 fatty acids, mercury and risk markers of CHD (National Health and Nutrition Examination Survey 1999-2002). Public Health Nutr 12(8):1261–1269. 10.1017/s1368980008003844.18986590
Snapp KR, Boyer DB, Peterson LC, . 1989. The contribution of dental amalgam to mercury in blood. J Dent Res 68(5):780–785. 10.1177/00220345890680050501.2715470
Snoj Tratnik J, Falnoga I, Trdin A, . 2017. Prenatal mercury exposure, neurodevelopment and apolipoprotein E genetic polymorphism. Environ Res 152:375–385. 10.1016/j.envres.2016.08.035.27616663
Sohn SH, Heo HC, Jo S, . 2020. The association between mercury concentrations and lipid profiles in the Korean National Environmental Health Survey (KoNEHS) cycle 3. Ann Occup Environ Med 32:e19. 10.35371/aoem.2020.32.e19.32676197
Soldin OP, O’Mara DM, Aschner M. 2008. Thyroid hormones and methylmercury toxicity. Biol Trace Elem Res 126(1–3):1–12. 10.1007/s12011-008-8199-3.18716716
Solecki R, Hothorn L, Holzweissig M, . 1991. Computerised analysis of pathological findings in longterm trials with phenylmercuric acetate in rats. Arch Toxicol Suppl 14:100–103. 10.1007/978-3-642-74936-0_21.1805715
Somers EC, Ganser MA, Warren JS, . 2015. Mercury exposure and antinuclear antibodies among females of reproductive age in the United States: NHANES. Environ Health Perspect 123(8):792–798. 10.1289/ehp.1408751.25665152
Sommar JN, Svensson MK, Bjor BM, . 2013. End-stage renal disease and low level exposure to lead, cadmium and mercury; a population-based, prospective nested case-referent study in Sweden. Environ Health 12:9. 10.1186/1476-069x-12-9.23343055
Son HY, Lee S, Park SB, . 2010. Toxic effects of mercuric sulfide on immune organs in mice. Immunopharmacol Immunotoxicol 32(2):277–283. 10.3109/08923970903305499.20017590
Song JW, Choi BS. 2013. Mercury induced the accumulation of amyloid beta (abeta) in PC12 cells: The role of production and degradation of abeta. Toxicol Res 29(4):235–240. 10.5487/tr.2013.29.4.235.24578793
Song KB, Lee YE, Jeong SH, . 2002. Mercury distribution and concentration in rats fed powdered dental amalgam. Arch Oral Biol 47(4):307–313.11922873
Sørensen N, Murata K, Budtz-Jorgensen E, . 1999. Prenatal methylmercury exposure as a cardiovascular risk factor at seven years of age. Epidemiology 10(4):370–375.10401870
Sørensen FW, Larsen JO, Eide R, . 2000. Neuron loss in cerebellar cortex of rats exposed to mercury vapor: A stereological study. Acta Neuropathol (Berl) 100(1):95–100. 10.1007/s004010051198.10912926
Spencer JN, Voigt AF. 1968. Thermodynamics of the solution of mercury metal. I. Tracer determination of the solubility in various liquids. J Phys Chem 72(2):464–470. 10.1021/j100848a012.
Spiller HA. 2018. Rethinking mercury: the role of selenium in the pathophysiology of mercury toxicity. Clin Toxicol (Phila) 56(5):313–326. 10.1080/15563650.2017.1400555.29124976
Sprovieri F, Pirrone N, Bencardino M, . 2016. Atmospheric mercury concentrations observed at ground-based monitoring sites globally distributed in the framework of the GMOS network. Atmos Chem Phys 16(18):11915–11935. 10.5194/acp-16-11915-2016.30245704
Stankovic R. 2006. Atrophy of large myelinated motor axons and declining muscle grip strength following mercury vapor inhalation in mice. Inhal Toxicol 18(1):57–69. 10.1080/08958370500282902.16326402
Stein ED, Cohen Y, Winer AM. 1996. Environmental distribution and transformation of mercury compounds. Crit Rev Environ Sci 26(1):1–43. 10.1080/10643389609388485.
Stern AH. 1997. Estimation of the interindividual variability in the one-compartment pharmacokinetic model for methylmercury: implications for the derivation of a reference dose. Regul Toxicol Pharmacol 25(3):277–288. 10.1006/rtph.1997.1105.9237329
Stern AH. 2005. Balancing the risks and benefits of fish consumption. Ann Intern Med 142(11):949.
Stern AH, Smith AE. 2003. An assessment of the cord blood:maternal blood methylmercury ratio: implications for risk assessment. Environ Health Perspect 111(12):1465–1470.12948885
Stern S, Cox C, Cernichiari E, . 2001. Perinatal and lifetime exposure to methylmercury in the mouse: blood and brain concentrations of mercury to 26 months of age. Neurotoxicology 22(4):467–477.11579926
Steuerwald U, Weihe P, Jorgensen PJ, . 2000. Maternal seafood diet, methylmercury exposure, and neonatal neurologic function. J Pediatr 136(5):599–605. 10.1067/mpd.2000.102774.10802490
Stewart PW, Reihman J, Lonky EI, . 2003. Cognitive development in preschool children prenatally exposed to PCBs and MeHg. Neurotoxicol Teratol 25(1):11–22. 10.1016/s0892-0362(02)00320-3.12633733
Stoiber T, Bonacker D, Bohm KJ, . 2004. Disturbed microtubule function and induction of micronuclei by chelate complexes of mercury(II). Mutat Res 563(2):97–106. 10.1016/j.mrgentox.2004.06.009.15364276
Stoltenburg-Didinger G, Markwort S. 1990. Prenatal methylmercury exposure results in dendritic spine dysgenesis in rats. Neurotoxicol Teratol 12(6):573–576. 10.1016/0892-0362(90)90064-j.
Storelli MM, Giacominelli Stuffler R, Storelli A, . 2003. Total mercury and methylmercury content in edible fish from the Mediterranean Sea. J Food Prot 66(2):300–303.12597492
Storm DL. 1994. Chemical monitoring of California’s public drinking water sources: Public exposures and health impacts. In: Wang RG, ed. Water contamination and health. New York, NY: Marcel Dekker, Inc, 67–124.
Strain JJ, Davidson PW, Bonham MP, . 2008. Associations of maternal long-chain polyunsaturated fatty acids, methyl mercury, and infant development in the Seychelles Child Development Nutrition Study. Neurotoxicology 29(5):776–782. 10.1016/j.neuro.2008.06.002.18590765
Strain JJ, Davidson PW, Thurston SW, . 2012. Maternal PUFA status but not prenatal methylmercury exposure is associated with children’s language functions at age five years in the Seychelles. J Nutr 142(11):1943–1949. 10.3945/jn.112.163493.23014496
Strain JJ, Yeates AJ, van Wijngaarden E, . 2015. Prenatal exposure to methyl mercury from fish consumption and polyunsaturated fatty acids: associations with child development at 20 mo of age in an observational study in the Republic of Seychelles. Am J Clin Nutr 101(3):530–537. 10.3945/ajcn.114.100503.25733638
Strain JJ, Love TM, Yeates AJ, . 2021. Associations of prenatal methylmercury exposure and maternal polyunsaturated fatty acid status with neurodevelopmental outcomes at 7 years of age: results from the Seychelles Child Development Study Nutrition Cohort 2. Am J Clin Nutr 113(2):304–313. 10.1093/ajcn/nqaa338.33330939
Stratakis N, Golden-Mason L, Margetaki K, . 2021. In utero exposure to mercury is associated with increased susceptibility to liver injury and inflammation in childhood. Hepatology 74(3):1546–1559. 10.1002/hep.31809.33730435
Streets DG, Horowitz HM, Jacob DJ, . 2017. Total mercury released to the environment by human activities. Environ Sci Technol 51(11):5969–5977. 10.1021/acs.est.7b00451.28448134
Su M, Wakabayashi K, Kakita A, . 1998. Selective involvement of large motor neurons in the spinal cord of rats treated with methylmercury. J Neurol Sci 156(1):12–17. 10.1016/s0022-510x(98)00030-6.9559981
Subhavana KL, Qureshi A, Roy A. 2019. Mercury levels in human hair in South India: baseline, artisanal goldsmiths and coal-fired power plants. J Expo Sci Environ Epidemiol 29(5):697–705. 10.1038/s41370-018-0107-0.30631141
Suda I, Hirayama K. 1992. Degradation of methyl and ethyl mercury into inorganic mercury by hydroxyl radical produced from rat liver microsomes. Arch Toxicol 66(6):398–402.1332650
Suda I, Totoki S, Uchida T, . 1992. Degradation of methyl and ethyl mercury into inorganic mercury by various phagocytic cells. Arch Toxicol 66(1):40–44.1316116
Suda I, Suda M, Hirayama K. 1993. Phagocytic cells as a contributor to in vivo degradation of alkyl mercury. Bull Environ Contam Toxicol 51(3):394–400. 10.1007/bf00201758.8219595
Sugawara N, Lai YR, Sugaware C, . 1998. Decreased hepatobiliary secretion of inorganic mercury, its deposition and toxicity in the Eisai hyperbilirubinemic rat with no hepatic canalicular organic anion transporter. Toxicology 126(1):23–31.9585089
Sukhn C, Awwad J, Ghantous A, . 2018. Associations of semen quality with non-essential heavy metals in blood and seminal fluid: Data from the environment and male infertility (EMI) study in Lebanon. J Assist Reprod Genet 35:1691–1701. 10.1007/s10815-018-1236-z.29931406
Sumino K, Hayakawa K, Shibata T, . 1975. Heavy metals in normal Japanese tissues: Amounts of 15 heavy metals in 30 subjects. Arch Environ Health 30(10):487–494.1180571
Sun YH, Nfor ON, Huang JY, . 2015. Association between dental amalgam fillings and Alzheimer’s disease: a population-based cross-sectional study in Taiwan. Alzheimers Res Ther 7(1):65. 10.1186/s13195-015-0150-1.26560125
Sun B, Fan S, Yao K, . 2018. Changes in intraepidermal nerve fiber and Langerhans cell densities in the plantar skin of rats after mercuric chloride exposure. J Peripher Nerv Syst 23(1):17–22. 10.1111/jns.12246.29168293
Sun Y, Zhou Q, Zheng J. 2019. Nephrotoxic metals of cadmium, lead, mercury and arsenic and the odds of kidney stones in adults: An exposure-response analysis of NHANES 2007-2016. Environ Int 132:105115. 10.1016/j.envint.2019.105115.31473411
Sun Y, Liu B, Rong S, . 2021. Association of seafood consumption and mercury exposure with cardiovascular and all-cause mortality among US adults. JAMA Netw Open 4(11):e2136367. 10.1001/jamanetworkopen.2021.36367.34842923
Sundberg J, Oskarsson A, Albanus L. 1991. Methylmercury exposure during lactation: milk concentration and tissue uptake of mercury in the neonatal rat. Bull Environ Contam Toxicol 46(2):255–262.2018872
Sundberg J, Jonsson S, Karlsson MO, . 1998. Kinetics of methylmercury and inorganic mercury in lactating and nonlactating mice. Toxicol Appl Pharmacol 151(2):319–329. 10.1006/taap.1998.8456.9707508
Sundberg J, Jonsson S, Karlsson MO, . 1999. Lactational exposure and neonatal kinetics of methylmercury and inorganic mercury in mice. Toxicol Appl Pharmacol 154(2):160–169. 10.1006/taap.1998.8566.9925800
Sunderman FW. 1978. Clinical response to therapeutic agents in poisoning from mercury vapor. Ann Clin Lab Sci 8(4):259–269.210702
Surkan PJ, Wypij D, Trachtenberg F, . 2009. Neuropsychological function in school-age children with low mercury exposures. Environ Res 109(6):728–733. 10.1016/j.envres.2009.04.006.19464677
Suter KE. 1975. Studies on the dominant-lethal and fertility effects of the heavy metal compounds methylmercuric hydroxide, mercuric chloride, and cadmium chloride in male and female mice. Mutat Res 30(3):365–374.1238902
Suvarapu LN, Baek SO. 2017. Recent studies on the speciation and determination of mercury in different environmental matrices using various analytical techniques. Int J Anal Chem 2017:1–28. 10.1155/2017/3624015.
Suzuki T, Matsumoto N, Miyama T, . 1967. Placental transfer of mercuric chloride, phenyl mercury acetate and methyl mercury acetate in mice. Ind Health 5:149–155.
Suzuki T, Miyama T, Katsunuma H. 1970. Comparison of mercury contents in maternal blood, umbilical cord blood, and placental tissues. Bull Environ Contam Toxicol 5(6):502–508. 10.1007/bf01539978.23989413
Suzuki T, Watanabe S, Matsuo N. 1989. Comparison of hair with nail as index media for biological monitoring of mercury. Sangyo Igaku 31(4):235–238. 10.1539/joh1959.31.235.2585806
Swain EB, Engstrom DR, Brigham ME, . 1992. Increasing rates of atmospheric mercury deposition in midcontinental North America. Science 257(5071):784–787. 10.1126/science.257.5071.784.17736465
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Elsevier, Inc., 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Syversen T, Kaur P. 2012. The toxicology of mercury and its compounds. J Trace Elem Med Biol 26(4):215–226. 10.1016/j.jtemb.2012.02.004.22658719
Szász A, Barna B, Gajda Z, . 2002. Effects of continuous low-dose exposure to organic and inorganic mercury during development on epileptogenicity in rats. Neurotoxicology 23(2):197–206. 10.1016/s0161-813x(02)00022-0.12224761
Takahashi H, Takahashi H, Nomiyama K. 2000a. Mercury exposure does not elevate systolic blood pressure in normotensive rats. J Trace Elem Exp Med 13:239–247.
Takahashi H, Nomiyama H, Nomiyama K. 2000b. Mercury elevates systolic blood pressure in spontaneously hypertensive rats. J Trace Elem Exp Med 13:227–237.
Takahashi Y, Tsuruta S, Hasegawa J, . 2001. Release of mercury from dental amalgam fillings in pregnant rats and distribution of mercury in maternal and fetal tissues. Toxicology 163(2–3):115–126.11516521
Takatani T, Eguchi A, Yamamoto M, . 2022. Individual and mixed metal maternal blood concentrations in relation to birth size: An analysis of the Japan Environment and Children’s Study (JECS). Environ Int 165:107318. 10.1016/j.envint.2022.107318.35679738
Takeuchi H, Shiota Y, Yaoi K, . 2022a. Mercury levels in hair are associated with reduced neurobehavioral performance and altered brain structures in young adults. Commun Biol 5(1):529. 10.1038/s42003-022-03464-z.35655003
Takeuchi H, Shiota Y, Yaoi K, . 2022b. Supplemental material: Mercury levels in hair are associated with reduced neurobehavioral performance and altered brain structures in young adults. Commun Biol 5(1) 10.1038/s42003-022-03464-z.
Takeuchi M, Yoshida S, Kawakami C, . 2022c. Association of maternal heavy metal exposure during pregnancy with isolated cleft lip and palate in offspring: Japan Environment and Children’s Study (JECS) cohort study. PLoS ONE 17(3):e0265648. 10.1371/journal.pone.0265648.35324965
Tamashiro H, Arakaki M, Akagi H, . 1985. Mortality and survival for Minamata disease. Int J Epidemiol 14(4):582–588. 10.1093/ije/14.4.582.4086144
Tamashiro H, Arakaki M, Akagi H, . 1986. Effects of ethanol on methyl mercury toxicity in rats. J Toxicol Environ Health 18(4):595–605. 10.1080/15287398609530897.3735459
Tan SW, Meiller JC, Mahaffey KR. 2009. The endocrine effects of mercury in humans and wildlife. Crit Rev Toxicol 39(3):228–269. 10.1080/10408440802233259.19280433
Tan YM, Chan M, Chukwudebe A, . 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Tan Y, Fu Y, Huang F, . 2023. Association between blood metal exposures and hyperuricemia in the U.S. general adult: A subgroup analysis from NHANES. Chemosphere 318:137873. 10.1016/j.chemosphere.2023.137873.36681199
Tanaka T, Naganuma A, Imura N. 1990. Role of gamma-glutamyltranspeptidase in renal uptake and toxicity of inorganic mercury in mice. Toxicology 60(3):187–198. 10.1016/0300-483x(90)90142-4.1969183
Tanaka T, Naganuma A, Imura N. 1992. Routes for renal transport of methylmercury in mice. Eur J Pharmacol 228(1):9–14.1397070
Tanaka-Kagawa T, Naganuma A, Imura N. 1993. Tubular secretion and reabsorption of mercury compounds in mouse kidney. J Pharmacol Exp Ther 264(2):776–782.8094752
Tang N, Li YM. 2006. Neurotoxic effects in workers of the clinical thermometer manufacture plant. Int J Occup Med Environ Health 19(3):198–202. 10.2478/v10001-006-0023-8.17252671
Tang M, Xu C, Lin N, . 2016. Lead, mercury, and cadmium in umbilical cord serum and birth outcomes in Chinese fish consumers. Chemosphere 148:270–275. 10.1016/j.chemosphere.2016.01.058.26812370
Tang J, Zhu Q, Xu Y, . 2022a. Total arsenic, dimethylarsinic acid, lead, cadmium, total mercury, methylmercury and hypertension among Asian populations in the United States: NHANES 2011-2018. Ecotoxicol Environ Saf 241:113776. 10.1016/j.ecoenv.2022.113776.35738098
Tang Y, Yi Q, Wang S, . 2022b. Normal concentration range of blood mercury and bone mineral density: a cross-sectional study of National Health and Nutrition Examination Survey (NHANES) 2005-2010. Environ Sci Pollut Res Int 29(5):7743–7757. 10.1007/s11356-021-16162-w.34480303
Tarabar AF, Su M. 2003. Mercury and cadmium toxicity in a Haitian voodoo minister that resulted in acute renal failure. J Toxicol Clin Toxicol 41(5):741–742.
Tatsuta N, Kurokawa N, Nakai K, . 2017. Effects of intrauterine exposures to polychlorinated biphenyls, methylmercury, and lead on birth weight in Japanese male and female newborns. Environ Health Prev Med 22(1):39. 10.1186/s12199-017-0635-6.29165117
Tatsuta N, Iwai-Shimada M, Nakayama SF, . 2022. Association between whole blood metallic elements concentrations and gestational diabetes mellitus in Japanese women: The Japan environment and Children’s study. Environ Res 212(Pt B):113231. 10.1016/j.envres.2022.113231.35405127
Taylor CM, Golding J, Emond AM. 2016. Blood mercury levels and fish consumption in pregnancy: Risks and benefits for birth outcomes in a prospective observational birth cohort. Int J Hyg Environ Health 219(6):513–520. 10.1016/j.ijheh.2016.05.004.27252152
Taylor CM, Emond AM, Lingam R, . 2018a. Prenatal lead, cadmium and mercury exposure and associations with motor skills at age 7 years in a UK observational birth cohort. Environ Int 117:40–47. 10.1016/j.envint.2018.04.032.29723752
Taylor VF, Buckman KL, Seelen EA, . 2018b. Organic carbon content drives methylmercury levels in the water column and in estuarine food webs across latitudes in the Northeast United States. Environ Pollut 246:639–649. 10.1016/j.envpol.2018.12.064.30605819
Teisinger J, Fiserova-Bergerova V. 1965. Pulmonary retention and excretion of mercury vapors in man. Ind Med Surg 34:580–584.14317595
Teixeira FB, Fernandes RM, Farias-Junior PM, . 2014. Evaluation of the effects of chronic intoxication with inorganic mercury on memory and motor control in rats. Int J Environ Res Public Health 11(9):9171–9185. 10.3390/ijerph110909171.25198682
Teixeira FB, de Oliveira ACA, Leão LKR, . 2018. Exposure to inorganic mercury causes oxidative stress, cell death, and functional deficits in the motor cortex. Front Mol Neurosci 11:1–11. 10.3389/fnmol.2018.00125.29403353
Teixeira FB, Leão LKR, Bittencourt LO, . 2019. Neurochemical dysfunction in motor cortex and hippocampus impairs the behavioral performance of rats chronically exposed to inorganic mercury. J Trace Elem Med Biol 52:143–150. 10.1016/j.jtemb.2018.12.008.30732875
Teng CT, Brennan JC. 1959. Acute mercury vapor poisoning. Radiology 73(3):354–361. 10.1148/73.3.354.13837410
Tennant R, Johnston HJ, Wells JB. 1961. Acute bilateral pneumonitis associated with the inhalation of mercury vapor. Report of five cases. Conn Med 25:106–109.13775895
Thanyavuthi A, Boonchai W, Kasemsarn P. 2016. Amalgam contact allergy in oral lichenoid lesions. Dermatitis 27(4):215–221. 10.1097/der.0000000000000204.27323234
Thera JC, Rumbold DG. 2014. Biomagnification of mercury through a subtropical coastal food web off southwest Florida. Environ Toxicol Chem 33(1):65–73. 10.1002/etc.2416.24123350
Theunissen PT, Pennings JL, Robinson JF, . 2011. Time-response evaluation by transcriptomics of methylmercury effects on neural differentiation of murine embryonic stem cells. Toxicol Sci 122(2):437–447. 10.1093/toxsci/kfr134.21613230
Thomas DJ, Smith JC. 1979. Partial characterization of a low-molecular weight methylmercury complex in rat cerebrum. Toxicol Appl Pharmacol 47(3):547–556.442094
Thomas DJ, Smith JC. 1982. Effects of coadministered low-molecular-weight thiol compounds on short-term distribution of methyl mercury in the rat. Toxicol Appl Pharmacol 62(1):104–110.7064146
Thomas DJ, Fisher HL, Sumler MR, . 1986. Sexual differences in the distribution and retention of organic and inorganic mercury in methyl mercury-treated rats. Environ Res 41(1):219–234.3757970
Thurston SW, Bovet P, Myers GJ, . 2007. Does prenatal methylmercury exposure from fish consumption affect blood pressure in childhood? Neurotoxicology 28(5):924–930. 10.1016/j.neuro.2007.06.002.17659343
Thurston SW, Myers G, Mruzek D, . 2022. Associations between time-weighted postnatal methylmercury exposure from fish consumption and neurodevelopmental outcomes through 24 years of age in the Seychelles Child Development Study Main Cohort. Neurotoxicology 91:234–244. 10.1016/j.neuro.2022.05.016.35643326
Thuvander A, Sundberg J, Oskarsson A. 1996. Immunomodulating effects after perinatal exposure to methylmercury in mice. Toxicology 114(2):163–175. 10.1016/s0300-483x(96)03486-5.8947615
Tian W, Egeland GM, Sobol I, . 2011. Mercury hair concentrations and dietary exposure among Inuit preschool children in Nunavut, Canada. Environ Int 37(1):42–48. 10.1016/j.envint.2010.05.017.20673686
Tian T, Yin S, Jin L, . 2021. Single and mixed effects of metallic elements in maternal serum during pregnancy on risk for fetal neural tube defects: A Bayesian kernel regression approach. Environ Pollut 285:117203. 10.1016/j.envpol.2021.117203.33932758
Tibau AV, Grube BD. 2019. Mercury contamination from dental amalgam. J Health Pollut 9(22):190612. 10.5696/2156-9614-9.22.190612.31259088
Timmermann CAG, Choi AL, Petersen MS, . 2017. Secondary sex ratio in relation to exposures to polychlorinated biphenyls, dichlorodiphenyl dichloroethylene and methylmercury. Int J Circumpolar Health 76(1):1–8. 10.1080/22423982.2017.1406234.
Tiwari SM, Gebauer K, Frydrych AM, . 2018. Dental patch testing in patients with undifferentiated oral lichen planus. Australas J Dermatol 59:188–193. 10.1111/ajd.12692.28695565
Tonk EC, de Groot DM, Penninks AH, . 2010. Developmental immunotoxicity of methylmercury: the relative sensitivity of developmental and immune parameters. Toxicol Sci 117(2):325–335. 10.1093/toxsci/kfq223.20660081
Toribara TY, Clarkson TW, Nierenberg DW. 1997. More on working with dimethylmercury. Chem Eng News 75(24):3, 6, 11, 12.
Trachtenberg F, Barregard L, McKinlay S. 2010. The influence of urinary flow rate on mercury excretion in children. J Trace Elem Med Biol 24(1):31–35. 10.1016/j.jtemb.2009.06.003.20122577
Trasande L, Landrigan PJ, Schechter C. 2005. Public health and economic consequences of methyl mercury toxicity to the developing brain. Environ Health Perspect 113(5):590–596.15866768
TRI22. 2024. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. March 15, 2023.
Trotter R. 1985. Greta and azarcon: A survey of episodic lead poisoning from a folk remedy. Hum Organ 44(1):64–72. 10.17730/humo.44.1.u448k01428282555.10270259
Tsai TL, Kuo CC, Pan WH, . 2019. Type 2 diabetes occurrence and mercury exposure - From the National Nutrition and Health Survey in Taiwan. Environ Int 126:260–267. 10.1016/j.envint.2019.02.038.30825744
Tseng CF, Chen KH, Yu HC, . 2020a. Dental amalgam fillings and multiple sclerosis: A nationwide population-based case-control study in Taiwan. Int J Environ Res Public Health 17(8):2637. 10.3390/ijerph17082637.32290568
Tseng CF, Chen KH, Yu HC, . 2020b. Association between dental amalgam filling and essential tremor: A nationwide population-based case control study in Taiwan. Int J Environ Res Public Health 17(3):780. 10.3390/ijerph17030780.32012693
Tsuji JS, Williams PR, Edwards MR, . 2003. Evaluation of mercury in urine as an indicator of exposure to low levels of mercury vapor. Environ Health Perspect 111(4):623–630.12676626
Tsuji M, Shibata E, Morokuma S, . 2018. The association between whole blood concentrations of heavy metals in pregnant women and premature births: The Japan Environment and Children’s Study (JECS). Environ Res 166:562–569. 10.1016/j.envres.2018.06.025.29966876
Tsuji M, Shibata E, Askew DJ, . 2019. Associations between metal concentrations in whole blood and placenta previa and placenta accreta: the Japan Environment and Children’s Study (JECS). Environ Health Prev Med 24(1):40. 10.1186/s12199-019-0795-7.31174461
Tuček M, Bušová M, Čejchanová M, . 2020. Exposure to mercury from dental amalgam: actual contribution for risk assessment. Cent Eur J Public Health 28(1):40–43. 10.21101/cejph.a5965.32228815
Turner RR, Bogle MA. 1993. Ambient air monitoring for mercury around an industrial complex. In: Chow W, Connor KK, eds. Managing hazardous air pollutants state of the art. Boca Raton, FL: Lewis Publishers, 162–172.
Turner RR, Mitchell CPJ, Kopec AD, . 2018. Tidal fluxes of mercury and methylmercury for Mendall Marsh, Penobscot River estuary, Maine. Sci Total Environ 637–638:145–154. 10.1016/j.scitotenv.2018.04.395.
U.S. Atomic Energy Commission. 1961. Studies on the equilibration of mercury vapor with blood. UR Reports. U.S. Atomic Energy Commission. UR-582.
Uchikawa T, Kanno T, Maruyama I, . 2016. Demethylation of methylmercury and the enhanced production of formaldehyde in mouse liver. J Toxicol Sci 41(4):479–487. 10.2131/jts.41.479.27432234
Uchino M, Hirano T, Satoh H, . 2005. The severity of Minamata disease declined in 25 years: temporal profile of the neurological findings analyzed by multiple logistic regression model. Tohoku J Exp Med 205(1):53–63.15635274
UNEP. 2018. Global mercury assessment 2018. Geneva, Switzerland: United Nations Environment Programme. https://www.unep.org/resources/publication/global-mercury-assessment-2018. August 20, 2021.
Urano T, Iwasaki A, Himeno S, . 1990. Absorption of methylmercury compounds from rat intestine. Toxicol Lett 50(2–3):159–164.2309235
Urban P, Gobba F, Nerudova J, . 2003. Color discrimination impairment in workers exposed to mercury vapor. Neurotoxicology 24(4–5):711–716. 10.1016/s0161-813x(03)00036-6.12900084
Ursitti F, Marano M, Locatelli CA, . 2022. Developmental regression, hypertension, and pink extremities in childhood mercury poisoning. Neuropediatrics 53(6):448–450. 10.1055/a-1788-7340.35253146
USGS. 1997. Mercury. United States Geological Survey.
USGS. 2013. Mineral commodity summaries, January 2013. U.S. Geological Survey. 10.3133/mineral2013.
USGS. 2014. Mercury in the nation’s streams - levels, trends, and implications. Reston, VA: U.S. Geological Survey. Circular 1395. 10.3133/cir1395.
USGS. 2016. Mercury concentrations in water and mercury and selenium concentrations in fish from Brownlee Reservoir and selected sites in Boise and Snake Rivers, Idaho and Oregon, 2013-15. U.S. Geological Survey. Open-File Report 2016–1098. 10.3133/ofr20161098.
USGS. 2020. Mineral commodity summaries, January 2020. U.S. Geological Survey. https://pubs.usgs.gov/periodicals/mcs2020/mcs2020.pdf. January 21, 2021.
USGS. 2023a. Mineral commodity summaries 2023. Reston, VA: U.S. Geological Survey. 10.3133/mcs2023.
USGS. 2023b. Great lakes sediment surveillance program: mercury concentrations and mercury stable isotopes in sediments of the Laurentian Great Lakes. U.S. Geological Survey. 10.5066/P9VB8GO6.
Usuki F, Yasutake A, Matsumoto M, . 1998. The effect of methylmercury on skeletal muscle in the rat: A histopathological study. Toxicol Lett 94(3):227–232. 10.1016/s0378-4274(98)00022-8.9609326
Vahter M, Mottet NK, Friberg L, . 1994. Speciation of mercury in the primate blood and brain following long-term exposure to methyl mercury. Toxicol Appl Pharmacol 124(2):221–229. 10.1006/taap.1994.1026.8122267
Vahter ME, Mottet NK, Friberg LT, . 1995. Demethylation of methyl mercury in different brain sites of Macaca fascicularis monkeys during long-term subclinical methyl mercury exposure. Toxicol Appl Pharmacol 134(2):273–284. 10.1006/taap.1995.1193.7570604
Vahter M, Akesson A, Lind B, . 2000. Longitudinal study of methylmercury and inorganic mercury in blood and urine of pregnant and lactating women, as well as in umbilical cord blood. Environ Res 84(2):186–194. 10.1006/enrs.2000.4098.11068932
Valcke M, Ouellet N, Dubé M, . 2019. Biomarkers of cadmium, lead and mercury exposure in relation with early biomarkers of renal dysfunction and diabetes: Results from a pilot study among aging Canadians. Toxicol Lett 312:148–156. 10.1016/j.toxlet.2019.05.014.31100493
Valent F, Mariuz M, Bin M, . 2013. Associations of prenatal mercury exposure from maternal fish consumption and polyunsaturated fatty acids with child neurodevelopment: a prospective cohort study in Italy. J Epidemiol 23(5):360–370. 10.2188/jea.je20120168.23933621
Valera B, Dewailly E, Poirier P. 2008. Cardiac autonomic activity and blood pressure among Nunavik Inuit adults exposed to environmental mercury: a cross-sectional study. Environ Health 7:29. 10.1186/1476-069x-7-29.18538022
Valera B, Dewailly E, Poirier P. 2009. Environmental mercury exposure and blood pressure among Nunavik Inuit adults. Hypertension 54(5):981–986. 10.1161/hypertensionaha.109.135046.19805642
Valera B, Dewailly E, Poirier P, . 2011a. Influence of mercury exposure on blood pressure, resting heart rate and heart rate variability in French Polynesians: a cross-sectional study. Environ Health 10:99. 10.1186/1476-069x-10-99.22078280
Valera B, Dewailly E, Poirier P. 2011b. Impact of mercury exposure on blood pressure and cardiac autonomic activity among Cree adults (James Bay, Quebec, Canada). Environ Res 111(8):1265–1270. 10.1016/j.envres.2011.09.001.21962568
Valera B, Muckle G, Poirier P, . 2012. Cardiac autonomic activity and blood pressure among Inuit children exposed to mercury. Neurotoxicology 33(5):1067–1074.23227484
Valera B, Dewailly E, Poirier P. 2013. Association between methylmercury and cardiovascular risk factors in a native population of Quebec (Canada): a retrospective evaluation. Environ Res 120:102–108. 10.1016/j.envres.2012.08.002.22959488
van Wijngaarden E, Beck C, Shamlaye CF, . 2006. Benchmark concentrations for methyl mercury obtained from the 9-year follow-up of the Seychelles Child Development Study. Neurotoxicology 27(5):702–709. 10.1016/j.neuro.2006.05.016.16806480
van Wijngaarden E, Myers GJ, Thurston SW, . 2009. Interpreting epidemiological evidence in the presence of multiple endpoints: an alternative analytic approach using the 9-year follow-up of the Seychelles child development study. Int Arch Occup Environ Health 82(8):1031–1041. 10.1007/s00420-009-0402-0.19205720
van Wijngaarden E, Davidson PW, Smith TH, . 2013. Autism spectrum disorder phenotypes and prenatal exposure to methylmercury. Epidemiology 24(5):651–659. 10.1097/EDE.0b013e31829d2651.23873071
van Wijngaarden E, Harrington D, Kobrosly R, . 2014. Prenatal exposure to methylmercury and LCPUFA in relation to birth weight. Ann Epidemiol 24(4):273–278. 10.1016/j.annepidem.2014.01.002.24525104
van Wijngaarden E, Thurston SW, Myers GJ, . 2017. Methyl mercury exposure and neurodevelopmental outcomes in the Seychelles Child Development Study Main cohort at age 22 and 24 years. Neurotoxicol Teratol 59:35–42. 10.1016/j.ntt.2016.10.011.27989696
Vandal GM, Mason RP, Fitzgerald WF. 1991. Cycling of volatile mercury in temperate lakes. Water Air Soil Pollut 56(1):791–803. 10.1007/bf00342317.
Vas J, Monestier M. 2008. Immunology of mercury. Ann N Y Acad Sci 1143:240–267. 10.1196/annals.1443.022.19076354
Vasquez C. 2012. Human skull, bones found at site of horse slaughter investigation. Local10. http://www.local10.com/news/Human-skull-bones-found-at-site-of-horse-slaughter-investigation/-/1717324/10536270/-/foq2vmz/-/index.html. May 17, 2021.
Vassallo DV, Simoes MR, Furieri LB, . 2011. Toxic effects of mercury, lead and gadolinium on vascular reactivity. Braz J Med Biol Res 44(9):939–946.21845340
Vazquez M, Velez D, Devesa V. 2014. In vitro characterization of the intestinal absorption of methylmercury using a Caco-2 cell model. Chem Res Toxicol 27(2):254–264. 10.1021/tx4003758.24397474
Vazquez M, Velez D, Devesa V, . 2015. Participation of divalent cation transporter DMT1 in the uptake of inorganic mercury. Toxicology 331:119–124. 10.1016/j.tox.2015.03.005.25772431
Vejrup K, Schjolberg S, Knutsen HK, . 2016. Prenatal methylmercury exposure and language delay at three years of age in the Norwegian Mother and Child Cohort Study. Environ Int 92–93:63–69. 10.1016/j.envint.2016.03.029.
Vejrup K, Brandlistuen RE, Brantsaeter AL, . 2018. Prenatal mercury exposure, maternal seafood consumption and associations with child language at five years. Environ Int 110:71–79. 10.1016/j.envint.2017.10.008.29089166
Vejrup K, Brantsæter AL, Meltzer HM, . 2022. Prenatal mercury exposure, fish intake and child emotional behavioural regulation in the Norwegian Mother, Father and Child Cohort Study. BMJ Nutr Prev Health 5(2):313–320. 10.1136/bmjnph-2021-000412.
Venter C, Olivier A, Taute H, . 2020. Histological analysis of the effects of cadmium, chromium and mercury alone and in combination on the spleen of male Sprague-Dawley rats. J Environ Sci Health A Tox Hazard Subst Environ Eng 55(8):925–934. 10.1080/10934529.2020.1756158.32419600
Ventura DF, Costa MT, Costa MF, . 2004. Multifocal and full-field electroretinogram changes associated with color-vision loss in mercury vapor exposure. Vis Neurosci 21(3):421–429.15518224
Ventura DF, Simoes AL, Tomaz S, . 2005. Colour vision and contrast sensitivity losses of mercury intoxicated industry workers in Brazil. Environ Toxicol Pharmacol 19(3):523–529. 10.1016/j.etap.2004.12.016.21783522
Verberk MM, SallÉ HJA, Kemper CH. 1986. Tremor in workers with low exposure to metallic mercury. Am Ind Hyg Assoc J 47(9):559–562. 10.1080/15298668691390232.3766401
Verger P, Houdart S, Marette S, . 2007. Impact of a risk-benefit advisory on fish consumption and dietary exposure to methylmercury in France. Regul Toxicol Pharmacol 48(3):259–269. 10.1016/j.yrtph.2007.04.005.17566619
Verschaeve L, Kirsch-Volders M, Susanne C, . 1976. Genetic damage induced by occupationally low mercury exposure. Environ Res 12(3):306–316.1001301
Verschaeve L, Tassignon JP, Lefevre M, . 1979. Cytogenetic investigation on leukocytes of workers exposed to metallic mercury. Environ Mutagen 1(3):259–268. 10.1002/em.2860010308.553805
Verschueren K. 1983. Mercury. In: Handbook of environmental data on organic chemicals. 2^nd^ ed. New York, NY: Van Nostrand Reinhold Co, 991–992.
Verschuuren HG, Kroes R, Den Tonkelaar EM, . 1976. Toxicity of methylmercury chloride in rats. III. Long-term toxicity study. Toxicology 6(1):107–123. 10.1016/0300-483x(76)90012-3.941159
Vezér T, Papp A, Kurunczi A, . 2005. Behavioral and neurotoxic effects seen during and after subchronic exposure of rats to organic mercury. Environ Toxicol Pharmacol 19(3):785–796. 10.1016/j.etap.2004.12.045.21783556
Vigeh M, Nishioka E, Ohtani K, . 2018. Prenatal mercury exposure and birth weight. Reprod Toxicol 76:78–83. 10.1016/j.reprotox.2018.01.002.29360564
Vilagi I, Doczi J, Banczerowski-Pelyhe I. 2000. Altered electrophysiological characteristics of developing rat cortical neurones after chronic methylmercury chloride treatment. Int J Dev Neurosci 18(6):493–499. 10.1016/s0736-5748(00)00027-7.10884594
Vimercati L, Santarelli L, Pesola G, . 2001. Monocyte-macrophage system and polymorphonuclear leukocytes in workers exposed to low levels of metallic mercury. Sci Total Environ 270(1–3):157–163. 10.1016/s0048-9697(00)00780-4.11327389
Vimy MJ, Takahashi Y, Lorscheider FL. 1990. Maternal-fetal distribution of mercury (203Hg) released from dental amalgam fillings. Am J Physiol Regul Integr Comp Physiol 258(4):R939–R945. 10.1152/ajpregu.1990.258.4.R939.
Virtanen JK, Voutilainen S, Rissanen TH, . 2005. Mercury, fish oils, and risk of acute coronary events and cardiovascular disease, coronary heart disease, and all-cause mortality in men in eastern Finland. Arterioscler Thromb Vasc Biol 25(1):228–233. 10.1161/01.atv.0000150040.20950.61.15539625
Virtanen JK, Rissanen TH, Voutilainen S, . 2007. Mercury as a risk factor for cardiovascular diseases. J Nutr Biochem 18(2):75–85. 10.1016/j.jnutbio.2006.05.001.16781863
Virtanen JK, Laukkanen JA, Mursu J, . 2012a. Serum long-chain n-3 polyunsaturated fatty acids, mercury, and risk of sudden cardiac death in men: A prospective population-based study. PLoS ONE 7(7):e41046. 10.1371/journal.pone.0041046.22815906
Virtanen JK, Nyantika AN, Kauhanen J, . 2012b. Serum long-chain n-3 polyunsaturated fatty acids, methylmercury and blood pressure in an older population. Hypertens Res 35(10):1000–1004. 10.1038/hr.2012.80.22673531
Vogel DG, Margolis RL, Mottet NK. 1985. The effects of methyl mercury binding to microtubules. Toxicol Appl Pharmacol 80(3):473–486. 10.1016/0041-008x(85)90392-8.4035699
Vollset M, Iszatt N, Enger Ø, . 2019. Concentration of mercury, cadmium, and lead in breast milk from Norwegian mothers: Association with dietary habits, amalgam and other factors. Sci Total Environ 677:466–473. 10.1016/j.scitotenv.2019.04.252.31063889
Vupputuri S, Longnecker MP, Daniels JL, . 2005. Blood mercury level and blood pressure among US women: results from the National Health and Nutrition Examination Survey 1999-2000. Environ Res 97(2):195–200. 10.1016/j.envres.2004.05.001.15533335
Wagemann R, Lockhart WL, Welch H, . 1995. Arctic marine mammals as integrators and indicators of mercury in the arctic. In: Porcella DB, Wheatley B, eds. Mercury as a global pollutant. Proceedings of the Third International Conference Whistler, British Columbia, July 10-14, 1994. Boston, MA: Kluwer Academic Publishers, 683–693.
Wahlberg JE. 1965. Percutaneous toxicity of metal compounds. A comparative investigation in guinea pigs. Arch Environ Health 11(2):201–204. 10.1080/00039896.1965.10664198.5832249
Wahlberg K, Love TM, Pineda D, . 2018. Maternal polymorphisms in glutathione-related genes are associated with maternal mercury concentrations and early child neurodevelopment in a population with a fish-rich diet. Environ Int 115:142–149. 10.1016/j.envint.2018.03.015.29573653
Wakita Y. 1987. Hypertension induced by methyl mercury in rats. Toxicol Appl Pharmacol 89(1):144–147. 10.1016/0041-008x(87)90185-2.3590186
Walker EV, Girgis S, Yuan Y, . 2021. Community-driven research in the Canadian Arctic: dietary exposure to methylmercury and gastric health outcomes. Int J Circumpolar Health 80(1):1889879. 10.1080/22423982.2021.1889879.33646085
Wands JR, Weiss SW, Yardley JH, . 1974. Chronic inorganic mercury poisoning due to laxative abuse: A clinical and ultrastructural study. Am J Med 57(1):92–101. 10.1016/0002-9343(74)90773-6.4834510
Wang JS, Huang PM, Liaw WK, . 1991. Kinetics of the desorption of mercury from selected freshwater sediments as influenced by chloride. Water Air Soil Pollut 56(1):533–542. 10.1007/bf00342297.
Wang W, Clarkson TW, Ballatori N. 2000. gamma-Glutamyl transpeptidase and l-cysteine regulate methylmercury uptake by HepG2 cells, a human hepatoma cell line. Toxicol Appl Pharmacol 168(1):72–78. 10.1006/taap.2000.9018.11000102
Wang Y, Goodrich JM, Werner R, . 2012. An investigation of modifying effects of single nucleotide polymorphisms in metabolism-related genes on the relationship between peripheral nerve function and mercury levels in urine and hair. Sci Total Environ 417–418:32–38. 10.1016/j.scitotenv.2011.12.019.
Wang Q, Yang X, Zhang B, . 2013. Cinnabar is different from mercuric chloride in mercury absorption and influence on the brain serotonin level. Basic Clin Pharmacol Toxicol 112(6):412–417. 10.1111/bcpt.12045.23302034
Wang X, Mukherjee B, Park SK. 2018. Associations of cumulative exposure to heavy metal mixtures with obesity and its comorbidities among U.S. adults in NHANES 2003-2014. Environ Int 121(Pt 1):683–694. 10.1016/j.envint.2018.09.035.30316184
Wang J, Wu W, Li H, . 2019a. Relation of prenatal low-level mercury exposure with early child neurobehavioral development and exploration of the effects of sex and DHA on it. Environ Int 126:14–23. 10.1016/j.envint.2019.02.012.30776746
Wang Y, Zhang P, Chen X, . 2019b. Multiple metal concentrations and gestational diabetes mellitus in Taiyuan, China. Chemosphere 237:124412. 10.1016/j.chemosphere.2019.124412.31376695
Wang G, DiBari J, Bind E, . 2019c. In utero exposure to mercury and childhood overweight or obesity: counteracting effect of maternal folate status. BMC Med 17(1):216. 10.1186/s12916-019-1442-2.31775748
Wang Y, Wang K, Han T, . 2020. Exposure to multiple metals and prevalence for preeclampsia in Taiyuan, China. Environ Int 145:106098. 10.1016/j.envint.2020.106098.32916414
Wang G, Tang WY, Ji H, . 2021a. Prenatal exposure to mercury and precocious puberty: a prospective birth cohort study. Hum Reprod 36(3):712–720. 10.1093/humrep/deaa315.33367618
Wang X, Karvonen-Gutierrez CA, Herman WH, . 2021b. Urinary heavy metals and longitudinal changes in blood pressure in midlife women: the study of women’s health across the nation. Hypertension 78(2):543–551. 10.1161/hypertensionaha.121.17295.34148361
Wang W, Zhang L, Deng C, . 2022a. In utero exposure to methylmercury impairs cognitive function in adult offspring: Insights from proteomic modulation. Ecotoxicol Environ Saf 231:113191. 10.1016/j.ecoenv.2022.113191.35051767
Wang J, Yin J, Hong X, . 2022b. Exposure to heavy metals and allergic outcomes in children: a systematic review and meta-analysis. Biol Trace Elem Res 200(11):4615–4631. 10.1007/s12011-021-03070-w.35006554
Wang C, Pi X, Yin S, . 2022c. Maternal exposure to heavy metals and risk for severe congenital heart defects in offspring. Environ Res 212(Pt C):113432. 10.1016/j.envres.2022.113432.35533713
Wang K, Mao Y, Liu Z, . 2023a. Association of blood heavy metal exposure with atherosclerotic cardiovascular disease (ASCVD) among white adults: evidence from NHANES 1999-2018. Biol Trace Elem Res 201(9):4321–4333. 10.1007/s12011-022-03537-4.36542304
Wang G, Fang L, Chen Y, . 2023b. Association between exposure to mixture of heavy metals and hyperlipidemia risk among U.S. adults: A cross-sectional study. Chemosphere 344:140334. 10.1016/j.chemosphere.2023.140334.37788750
Wang X, Ding N, Harlow SD, . 2023c. Exposure to heavy metals and hormone levels in midlife women: The Study of Women’s Health Across the Nation (SWAN). Environ Pollut 317:120740. 10.1016/j.envpol.2022.120740.36436662
Wang YL, Tsou MM, Lai LC, . 2023d. Oral and inhalation bioaccessibility of mercury in contaminated soils and potential health risk to the kidneys and neurodevelopment of children in Taiwan. Environ Geochem Health 45(8):6267–6286. 10.1007/s10653-023-01633-5.37289259
Warfvinge K. 2000. Mercury distribution in the neonatal and adult cerebellum after mercury vapor exposure of pregnant squirrel monkeys. Environ Res 83(2):93–101. 10.1006/enrs.1999.4013.10856181
Warfvinge K, Bruun A. 1996. Mercury accumulation in the squirrel monkey eye after mercury vapour exposure. Toxicology 107(3):189–200. 10.1016/0300-483x(95)03257-g.8604479
Warfvinge K, Bruun A. 2000. Mercury distribution in the squirrel monkey retina after in utero exposure to mercury vapor. Environ Res 83(2):102–109. 10.1006/enrs.1999.4029.10856182
Warfvinge K, Hua J, Logdberg B. 1994a. Mercury distribution in cortical areas and fiber systems of the neonatal and maternal adult cerebrum after exposure of pregnant squirrel monkeys to mercury vapor. Environ Res 67(2):196–208. 10.1006/enrs.1994.1074.7982394
Warfvinge G, Warfvinge K, Larsson A. 1994b. Histochemical visualization of mercury in the oral mucosa, salivary and lacrimal glands of BN rats with HgCl2-induced autoimmunity. Exp Toxicol Pathol 46(4):329–334. 10.1016/S0940-2993(11)80112-0.7894244
Warfvinge K, Hansson H, Hultman P. 1995. Systemic autoimmunity due to mercury vapor exposure in genetically susceptible mice: dose-response studies. Toxicol Appl Pharmacol 132(2):299–309. 10.1006/taap.1995.1111.7785057
Warren CJ, Dudas MJ. 1992. Acidification adjacent to an elemental sulfur stockpile: II. Trace element redistribution. Can J Soil Sci 72(2):127–134. 10.4141/cjss92-012.
Warwick D, Young M, Palmer J, . 2019. Mercury vapor volatilization from particulate generated from dental amalgam removal with a high-speed dental drill – a significant source of exposure. J Occup Med Toxicol 14(1):22. 10.1186/s12995-019-0240-2.31346345
Washam C. 2011. Beastly beauty products: Exposure to inorganic mercury in skin-lightening creams. Environ Health Perspect 119(2):A80.
Washington State Department of Ecology. 2013. Metals concentrations in sediments of lakes and wetlands in the Upper Columbia River watershed: Lead, zinc, arsenic, cadmium, antimony, and mercury. Washington State Department of Ecology. PB2013109530. Publication No. 13-03-012. https://apps.ecology.wa.gov/publications/SummaryPages/1303012.html. January 19, 2021.
Wasiuta V, Kirk JL, Chambers PA, . 2019. Accumulating mercury and methylmercury burdens in watersheds impacted by oil sands pollution. Environ Sci Technol 53(21):12856–12864. 10.1021/acs.est.9b02373.31621313
Wastensson G, Lamoureux D, Sallsten G, . 2006. Quantitative tremor assessment in workers with current low exposure to mercury vapor. Neurotoxicol Teratol 28(6):681–693. 10.1016/j.ntt.2006.09.001.17056227
Wastensson G, Lamoureux D, Sallsten G, . 2008. Quantitative assessment of neuromotor function in workers with current low exposure to mercury vapor. Neurotoxicology 29(4):596–604. 10.1016/j.neuro.2008.03.005.18452994
Watras CJ, Bloom NS. 1992. Mercury and methylmercury, in individual zooplankton: Implications for bioaccumulation. Limnol Oceanogr 37(6):1313–1318. 10.4319/lo.1992.37.6.1313.
Watson GE, Lynch M, Myers GJ, . 2011. Prenatal exposure to dental amalgam: Evidence from the Seychelles Child Development Study main cohort. J Am Dent Assoc 142(11):1283–1294. 10.14219/jada.archive.2011.0114.22041415
Watson GE, Evans K, Thurston SW, . 2012. Prenatal exposure to dental amalgam in the Seychelles Child Development Nutrition Study: associations with neurodevelopmental outcomes at 9 and 30 months. Neurotoxicology 33(6):1511–1517. 10.1016/j.neuro.2012.10.001.23064204
Weast RC. 1988. Mercury. In: CRC handbook of chemistry and physics. 69^th^ ed. Boca Raton, FL: CRC Press Inc., B-106 to B-108, F-103.
Webster JP, Kane TJ, Obrist D, . 2016. Estimating mercury emissions resulting from wildfire in forests of the Western United States. Sci Total Environ 568:578–586. 10.1016/j.scitotenv.2016.01.166.26897612
Wei H, Qiu L, Divine KK, . 1999. Toxicity and transport of three synthesized mercury-thiol-complexes in isolated rabbit renal proximal tubule suspensions. Drug Chem Toxicol 22(2):323–341. 10.3109/01480549909017838.10234470
Wei MH, Cui Y, Zhou HL, . 2021. Associations of multiple metals with bone mineral density: A population-based study in US adults. Chemosphere 282:131150. 10.1016/j.chemosphere.2021.131150.34470175
Wei Y, Lyu Y, Cao Z, . 2022. Association of low cadmium and mercury exposure with chronic kidney disease among Chinese adults aged ≥80 years: A cross-sectional study. Chin Med J (Engl) 135(24):2976–2983. 10.1097/cm9.0000000000002395.36580647
Weidenhammer W, Bornschein S, Zilker T, . 2010. Predictors of treatment outcomes after removal of amalgam fillings: associations between subjective symptoms, psychometric variables and mercury levels. Community Dent Oral Epidemiol 38(2):180–189. 10.1111/j.1600-0528.2009.00523.x.20074291
Weigert P. 1991. Metal loads of food of vegetable origin including mushrooms. In: Merian E, ed. Metals and their compounds in the environment. Weinheim, Germany: VCH, 449–468.
Weihe P, Grandjean P, Debes F, . 1996. Health implications for Faroe Islanders of heavy metals and PCBs from pilot whales. Sci Total Environ 186(1–2):141–148.8685706
Weinhouse C, Ortiz EJ, Berky AJ, . 2017. Hair mercury level is associated with anemia and micronutrient status in children living near artisanal and small-scale gold mining in the Peruvian Amazon. Am J Trop Med Hyg 97(6):1886–1897. 10.4269/ajtmh.17-0269.29016304
Weinstein M, Bernstein S. 2003. Pink ladies: mercury poisoning in twin girls. Can Med Assoc J 168(2):201.12538551
Weiss G. 1986. Mercury. In: Hazardous chemicals data book. 2^nd^ ed. Rahway, NJ: Noyes Data Corp, 650–662.
Weiss B, Stern S, Cox C, . 2005. Perinatal and lifetime exposure to methylmercury in the mouse: behavioral effects. Neurotoxicology 26(4):675–690. 10.1016/j.neuro.2005.05.003.15970329
Weiss-Penzias P, Sorooshian A, Coale K, . 2018. Aircraft measurements of total mercury and monomethyl mercury in summertime marine stratus cloudwater from Coastal California, USA. Environ Sci Technol 52(5):2527–2537. 10.1021/acs.est.7b05395.29401398
Wells EM, Herbstman JB, Lin YH, . 2016. Cord blood methylmercury and fetal growth outcomes in Baltimore newborns: Potential confounding and effect modification by omega-3 fatty acids, selenium, and sex. Environ Health Perspect 124(3):373–379. 10.1289/ehp.1408596.26115160
Wells EM, Herbstman JB, Lin YH, . 2017. Methyl mercury, but not inorganic mercury, associated with higher blood pressure during pregnancy. Environ Res 154:247–252. 10.1016/j.envres.2017.01.013.28110211
Wells EM, Kopylev L, Nachman R, . 2020. Seafood, wine, rice, vegetables, and other food items associated with mercury biomarkers among seafood and non-seafood consumers: NHANES 2011-2012. J Expo Sci Environ Epidemiol 30(3):504–514. 10.1038/s41370-020-0206-6.32015433
Wen J, Giri M, Xu L, . 2023. Association between exposure to selected heavy metals and blood eosinophil counts in asthmatic adults: Results from NHANES 2011-2018. J Clin Med 12(4):1543. 10.3390/jcm12041543.36836077
Wendroff AP. 1990. Domestic mercury pollution. Nature 347(6294):623–623. 10.1038/347623a0.2215693
Wendroff AP. 1991. Bringing attention to mercury threat. SfAA News 2(1):3–5. https://www.appliedanthro.org/application/files/6815/8870/3319/Feb_1991.pdf. January 15, 2021.
Wennberg M, Bergdahl IA, Hallmans G, . 2011. Fish consumption and myocardial infarction: a second prospective biomarker study from northern Sweden. Am J Clin Nutr 93(1):27–36. 10.3945/ajcn.2010.29408.21048056
Wennberg M, Stromberg U, Bergdahl IA, . 2012. Myocardial infarction in relation to mercury and fatty acids from fish: a risk-benefit analysis based on pooled Finnish and Swedish data in men. Am J Clin Nutr 96(4):706–713. 10.3945/ajcn.111.033795.22894940
Wesolowska M, Yeates AJ, McSorley EM, . 2023. Potential role of selenium in modifying the effect of maternal methylmercury exposure on child neurodevelopment - A review. Neurotoxicology 99:59–69. 10.1016/j.neuro.2023.08.003.37659579
Weyde KVF, Olsen AK, Duale N, . 2021. Gestational blood levels of toxic metal and essential element mixtures and associations with global DNA methylation in pregnant women and their infants. Sci Total Environ 787:147621. 10.1016/j.scitotenv.2021.147621.34000534
WHO. 1990. Methyl mercury. Environmental health criteria. Geneva, Switzerland: World Health Organization. EHC 101. http://www.inchem.org/documents/ehc/ehc/ehc101.htm. January 15, 2021.
WHO. 1991. Inorganic mercury. Environmental health criteria. Geneva, Switzerland: World Health Organization. EHC 118. http://www.inchem.org/documents/ehc/ehc/ehc118.htm January 15, 2021.
WHO. 2000. Air quality guidelines for Europe. Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/handle/10665/107335. April 18, 2023.
WHO. 2004. Methylmercury (addendum). World Health Organization. WHO Food Additives Series 52. http://www.inchem.org/documents/jecfa/jecmono/v52je23.htm. January 19, 2021.
WHO. 2007. Methyl mercury. Safety evaluation of certain food additives and contaminants: prepared by the sixty-seventh meeting of the Joint FAO/WHO Expert Committee on Food Additives (JECFA). Geneva, Switzerland: World Health Organization. WHO food additives series 58. https://apps.who.int/food-additives-contaminants-jecfa-database/Document/Index/9006. April 18, 2023.
WHO. 2010. Children’s exposure to mercury compounds. Geneva, Switzerland: World Health Organization. https://www.who.int/publications/i/item/9789241500456. January 15, 2021.
WHO. 2011. Mercury (addendum). Safety evaluation of certain contaminants in food: prepared by the seventy-second meeting of the Joint FAO/WHO Expert Committee on Food Additives (JECFA). Geneva, Switzerland: World Health Organization. WHO Food Additives Series 63. https://apps.who.int/food-additives-contaminants-jecfa-database/Document/Index/8996. April 18, 2023.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Wiener JG, Fitzergerald WF, Watras CJ, . 1990. Partitioning and bioavailability of mercury in an experimentally acidified Wisconsin Lake. Environ Toxicol Chem 9(7):909–918.
Wiggers GA, Pecanha FM, Briones AM, . 2008. Low mercury concentrations cause oxidative stress and endothelial dysfunction in conductance and resistance arteries. Am J Physiol Heart Circ Physiol 295(3):H1033–H1043. 10.1152/ajpheart.00430.2008.18599595
Wild LG, Ortega HG, Lopez M, . 1997. Immune system alteration in the rat after indirect exposure to methyl mercury chloride or methyl mercury sulfide. Environ Res 74(1):34–42. 10.1006/enrs.1997.3748.9339212
Wildemann TM, Mirhosseini N, Siciliano SD, . 2015a. Cardiovascular responses to lead are biphasic, while methylmercury, but not inorganic mercury, monotonically increases blood pressure in rats. Toxicology 328:1–11. 10.1016/j.tox.2014.11.009.25478804
Wildemann TM, Weber LP, Siciliano SD. 2015b. Combined exposure to lead, inorganic mercury and methylmercury shows deviation from additivity for cardiovascular toxicity in rats. J Appl Toxicol 35(8):918–926. 10.1002/jat.3092.25523840
Wildemann TM, Siciliano SD, Weber LP. 2016. The mechanisms associated with the development of hypertension after exposure to lead, mercury species or their mixtures differs with the metal and the mixture ratio. Toxicology 339:1–8. 10.1016/j.tox.2015.11.004.26612503
Willes RF, Truelove JF, Nera EA. 1978. Neurotoxic response of infant monkeys to methylmercury. Toxicology 9(1–2):125–135. 10.1016/0300-483x(78)90037-9.418532
Willett KL, Turner RR, Beauchamp JJ. 1992. Effect of chemical form of mercury on the performance of dosed soils in standard leaching protocols: EP and TCLP. Hazard Waste Hazard Mater 9(3):275–288.
Williams MV, Winters T, Waddell KS. 1987. In-vivo effects of mercury (II) on deoxyuridine triphosphate nucleotidohydrolase, DNA polymerase (α, β), and uracil-DNA glycosylase activities in cultured human cells: Relationship to DNA damage, DNA repair, and cytotoxicity. Mol Pharmacol 31(2):200–207.3027530
Williston SH. 1968. Mercury in the atmosphere. J Geophys Res 73:7051–7055.
Windham-Myers L, Marvin-DiPasquale M, Kakouros E, . 2014. Mercury cycling in agricultural and managed wetlands of California, USA: seasonal influences of vegetation on mercury methylation, storage, and transport. Sci Total Environ 484:308–318. 10.1016/j.scitotenv.2013.05.027.23809880
Wirth JJ, Mijal RS. 2010. Adverse effects of low level heavy metal exposure on male reproductive function. Syst Biol Reprod Med 56(2):147–167. 10.3109/19396360903582216.20377313
Wong PK. 1988. Mutagenicity of heavy metals. Bull Environ Contam Toxicol 40(4):597–603. 10.1007/bf01688386.3285919
Wood JM. 1974. Biological cycles for toxic elements in the environment. Science 183(4129):1049–1052. 10.1126/science.183.4129.1049.4812035
Woods JS, Echeverria D, Heyer NJ, . 2005. The association between genetic polymorphisms of coproporphyrinogen oxidase and an atypical porphyrinogenic response to mercury exposure in humans. Toxicol Appl Pharmacol 206(2):113–120. 10.1016/j.taap.2004.12.016.15967199
Woods JS, Martin MD, Leroux BG, . 2007. The contribution of dental amalgam to urinary mercury excretion in children. Environ Health Perspect 115(10):1527–1531. 10.1289/ehp.10249.17938746
Woods JS, Martin MD, Leroux BG, . 2008. Biomarkers of kidney integrity in children and adolescents with dental amalgam mercury exposure: findings from the Casa Pia children’s amalgam trial. Environ Res 108(3):393–399. 10.1016/j.envres.2008.07.003.18721920
Woods JS, Martin MD, Leroux BG, . 2009. Urinary porphyrin excretion in children with mercury amalgam treatment: findings from the Casa Pia Children’s Dental Amalgam Trial. J Toxicol Environ Health A 72(14):891–896. 10.1080/15287390902959557.19557617
Woods JS, Heyer NJ, Echeverria D, . 2012. Modification of neurobehavioral effects of mercury by a genetic polymorphism of coproporphyrinogen oxidase in children. Neurotoxicol Teratol 34(5):513–521. 10.1016/j.ntt.2012.06.004.22765978
Woods JS, Heyer NJ, Russo JE, . 2013. Modification of neurobehavioral effects of mercury by genetic polymorphisms of metallothionein in children. Neurotoxicol Teratol 39:36–44. 10.1016/j.ntt.2013.06.004.23827881
Woods JS, Heyer NJ, Russo JE, . 2014. Genetic polymorphisms affecting susceptibility to mercury neurotoxicity in children: summary findings from the Casa Pia Children’s Amalgam clinical trial. Neurotoxicology 44:288–302. 10.1016/j.neuro.2014.07.010.25109824
WQP. 2024. Mercury. Water quality portal. Advisory Committee on Water Information (ACWI); Agricultural Research Service (ARS); Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. February 26, 2024.
Wright DL, Afeiche MC, Ehrlich S, . 2015. Hair mercury concentrations and in vitro fertilization (IVF) outcomes among women from a fertility clinic. Reprod Toxicol 51:125–132. 10.1016/j.reprotox.2015.01.003.25601638
Wu G. 1995. Screening of potential transport systems for methyl mercury uptake in rat erythrocytes at 5 degrees by use of inhibitors and substrates. Pharmacol Toxicol 77(3):169–176.8884879
Wu G. 1996. Methylmercury-cysteine uptake by rat erythrocytes: evidence for several transport systems. J Appl Toxicol 16(1):77–83. 10.1002/(sici)1099-1263(199601)16:1<77::aid-jat319>3.0.co;2-c.8821680
Wu G. 1997. Effect of probenecid on the transport of methyl mercury in erythrocytes by the organic anion transport system. Arch Toxicol 71(4):218–222.9101037
Wu J, Ying T, Shen Z, . 2014. Effect of low-level prenatal mercury exposure on neonate neurobehavioral development in China. Pediatr Neurol 51(1):93–99. 10.1016/j.pediatrneurol.2014.03.018.24938141
Wu X, Cobbina SJ, Mao G, . 2016. A review of toxicity and mechanisms of individual and mixtures of heavy metals in the environment. Environ Sci Pollut Res Int 23(9):8244–8259. 10.1007/s11356-016-6333-x.26965280
Wu P, Kainz MJ, Bravo AG, . 2019. The importance of bioconcentration into the pelagic food web base for methylmercury biomagnification: A meta-analysis. Sci Total Environ 646:357–367. 10.1016/j.scitotenv.2018.07.328.30055496
Wu B, Qu Y, Lu Y, . 2022. Mercury may reduce the protective effect of sea fish consumption on serum triglycerides levels in Chinese adults: Evidence from China National Human Biomonitoring. Environ Pollut 311:119904. 10.1016/j.envpol.2022.119904.35961572
Wu X, Li P, Tao J, . 2023. Subchronic low-dose methylmercury exposure accelerated cerebral telomere shortening in relevant with declined urinary aMT6s level in rats. Toxics 11(2):191. 10.3390/toxics11020191.36851065
Wulf HC, Kromann N, Kousgaard N, . 1986. Sister chromatid exchange (SCE) in Greenlandic Eskimos. Dose-response relationship between SCE and seal diet, smoking, and blood cadmium and mercury concentrations. Sci Total Environ 48(1–2):81–94. 10.1016/0048-9697(86)90155-5.3945798
Wyatt L, Permar SR, Ortiz E, . 2019. Mercury exposure and poor nutritional status reduce response to six expanded program on immunization vaccines in children: an observational cohort study of communities affected by gold mining in the Peruvian Amazon. Int J Environ Res Public Health 16(4):638. 10.3390/ijerph16040638.30795575
Xiong J, Lv Y, Wei Y, . 2022. Association of blood mercury exposure with depressive symptoms in the Chinese oldest old. Ecotoxicol Environ Saf 243:113976. 10.1016/j.ecoenv.2022.113976.35994910
Xu Y, Khoury JC, Sucharew H, . 2016. Low-level gestational exposure to mercury and maternal fish consumption: Associations with neurobehavior in early infancy. Neurotoxicol Teratol 54:61–67. 10.1016/j.ntt.2016.02.002.26876455
Xu J, Engel LS, Rhoden J, . 2021. The association between blood metals and hypertension in the GuLF study. Environ Res 202:111734. 10.1016/j.envres.2021.111734.34303682
Xu R, Meng X, Pang Y, . 2022a. Associations of maternal exposure to 41 metals/metalloids during early pregnancy with the risk of spontaneous preterm birth: Does oxidative stress or DNA methylation play a crucial role? Environ Int 158:106966. 10.1016/j.envint.2021.106966.34735952
Xu S, Hansen S, Sripada K, . 2022b. Maternal blood levels of toxic and essential elements and birth outcomes in Argentina: The EMASAR study. Int J Environ Res Public Health 19(6):3643. 10.3390/ijerph19063643.35329330
Xu J, Zhu X, Hui R, . 2022c. Associations of metal exposure with hyperuricemia and gout in general adults. Front Endocrinol (Lausanne) 13:1052784. 10.3389/fendo.2022.1052784.36531480
Xu W, Park SK, Gruninger SE, . 2023a. Associations between mercury exposure with blood pressure and lipid levels: A cross-sectional study of dental professionals. Environ Res 220:115229. 10.1016/j.envres.2023.115229.36610536
Xu K, Gao B, Liu T, . 2023b. Association of blood mercury levels with bone mineral density in adolescents aged 12-19. Environ Sci Pollut Res Int 30(16):46933–46939. 10.1007/s11356-023-25701-6.36735129
Xue F, Holzman C, Rahbar MH, . 2007. Maternal fish consumption, mercury levels, and risk of preterm delivery. Environ Health Perspect 115(1):42–47. 10.1289/ehp.9329.
Yaginuma-Sakurai K, Murata K, Iwai-Shimada M, . 2012. Hair-to-blood ratio and biological half-life of mercury: experimental study of methylmercury exposure through fish consumption in humans. J Toxicol Sci 37(1):123–130.22293416
Yahyazedeh A, Altunkaynak BZ, Akgul N, . 2017. A histopathological and stereological study of liver damage in female rats caused by mercury vapor. Biotech Histochem 92(5):338–346. 10.1080/10520295.2017.1312527.28598684
Yalçin SS, Erdal İ, Oğuz B, . 2022. Associations between toxic elements and blood pressure parameters in adolescents. J Trace Elem Med Biol 71:126949. 10.1016/j.jtemb.2022.126949.35193093
Yamaguchi S, Matsumoto H, Kaku S, . 1975. Factors affecting the amount of mercury in human scalp hair. Am J Public Health 65(5):484–488.1130571
Yamamoto R, Suzuki T. 1978. Effects of artificial hair-waving on hair mercury values. Int Arch Occup Environ Health 42(1):1–9. 10.1007/bf00385706.711345
Yang J, Jiang Z, Wang Y, . 1997. Maternal-fetal transfer of metallic mercury via the placenta and milk. Ann Clin Lab Sci 27:135–141.9098513
Yang YJ, Yang EJ, Park K, . 2021. Association between blood mercury levels and non-alcoholic fatty liver disease in non-obese populations: The Korean National Environmental Health Survey (KoNEHS) 2012-2014. Int J Environ Res Public Health 18(12):6412. 10.3390/ijerph18126412.34199270
Yang D, Zhu H, Chen H, . 2023. Association between serum trace heavy metals and liver function among adolescents. J Occup Environ Med 65(3):e155–e160. 10.1097/jom.0000000000002778.36868864
Yannai S, Sachs KM. 1993. Absorption and accumulation of cadmium, lead and mercury from foods by rats. Food Chem Toxicol 31(5):351–335.8505020
Yannai S, Berdicevsky I, Duek L. 1991. Transformations of inorganic mercury by Candida albicans and Saccharomyces cerevisiae. Appl Environ Microbiol 57(1):245–247.2036011
Yao B, Lu X, Xu L, . 2020. Relationship between low-level lead, cadmium and mercury exposures and blood pressure in children and adolescents aged 8-17 years: An exposure-response analysis of NHANES 2007-2016. Sci Total Environ 726:138446. 10.1016/j.scitotenv.2020.138446.32320874
Yasuda Y, Datu AR, Hirata S, . 1985. Characteristics of growth and palatal shelf development in ICR mice after exposure to methylmercury. Teratology 32(2):273–286. 10.1002/tera.1420320216.4049286
Yasutake A, Hirayama K. 2001. Evaluation of methylmercury biotransformation using rat liver slices. Arch Toxicol 75(7):400–406.11693180
Yasutake A, Hachiya N. 2006. Accumulation of inorganic mercury in hair of rats exposed to methylmercury or mercuric chloride. Tohoku J Exp Med 210(4):301–306.17146195
Yasutake A, Nakamura M. 2011. Induction by mercury compounds of metallothioneins in mouse tissues: inorganic mercury accumulation is not a dominant factor for metallothionein induction in the liver. J Toxicol Sci 36(3):365–372.21628964
Yasutake A, Hirayama K, Inoue M. 1989. Mechanism of urinary excretion of methylmercury in mice. Arch Toxicol 63(6):479–483.2575893
Yasutake A, Hirayama Y, Inouye M. 1991. Sex difference of nephrotoxicity by methylmercury in mice. In: Bach PH, Ulrich KJ, eds. Nephrotoxicity: Mechanisms, early diagnosis, and therapeutic management; Fourth International symposium on nephrotoxicity, Guilford, England, UK, 1989. New York, NY: Marcel Dekker, Inc., 389–396.
Yasutake A, Nakano A, Miyamoto K, . 1997. Chronic effects of methylmercury in rats. I. Biochemical aspects. Tohoku J Exp Med 182(3):185–196.9362101
Yasutake A, Matsumoto M, Yamaguchi M, . 2003. Current hair mercury levels in Japanese: survey in five districts. Tohoku J Exp Med 199(3):161–169.12703660
Yau VM, Green PG, Alaimo CP, . 2014. Prenatal and neonatal peripheral blood mercury levels and autism spectrum disorders. Environ Res 133:294–303. 10.1016/j.envres.2014.04.034.24981828
Yawei S, Jianhai L, Junxiu Z, . 2021. Epidemiology, clinical presentation, treatment, and follow-up of chronic mercury poisoning in China: a retrospective analysis. BMC Pharmacol Toxicol 22(1):25. 10.1186/s40360-021-00493-y.33941274
Ye X, Qian H, Xu P, . 2009. Nephrotoxicity, neurotoxicity, and mercury exposure among children with and without dental amalgam fillings. Int J Hyg Environ Health 212(4):378–386. 10.1016/j.ijheh.2008.09.004.18996050
Ye Z, Mao H, Lin CJ, . 2016. Investigation of processes controlling summertime gaseous elemental mercury oxidation at midlatitudinal marine, coastal, and inland sites. Atmos Chem Phys 16(13):8461–8478. 10.5194/acp-16-8461-2016.
Yeates KO, Mortensen ME. 1994. Acute and chronic neuropsychological consequences of mercury vapor poisoning in two early adolescents. J Clin Exp Neuropsychol 16(2):209–222. 10.1080/01688639408402632.8021308
Yeates AJ, Zavez A, Thurston SW, . 2020. Maternal long-chain polyunsaturated fatty acid status, methylmercury exposure, and birth outcomes in a high-fish-eating mother-child cohort. J Nutr 150(7):1749–1756. 10.1093/jn/nxaa131.32433731
Yen CC, Chen HH, Hsu YT, . 2022. Effects of heavy metals in acute ischemic stroke patients: A cross-sectional study. Medicine (Baltimore) 101(9):e28973. 10.1097/md.0000000000028973.35244065
Yess NJ. 1993. U.S. Food and Drug Administration survey of methyl mercury in canned tuna. J AOAC Int 76(1):36–38.8448441
Yildirim E, Derici MK, Demir E, . 2019. Is the Concentration of Cadmium, Lead, Mercury, and Selenium Related to Preterm Birth? Biol Trace Elem Res 191(2):306–312. 10.1007/s12011-018-1625-2.30600504
Yilmaz OH, Karakulak UN, Tutkun E, . 2016. Assessment of the cardiac autonomic nervous system in mercury-exposed individuals via post-exercise heart rate recovery. Med Princ Pract 25(4):343–349. 10.1159/000445322.26964065
Yin R, Feng X, Meng B. 2013. Stable mercury isotope variation in rice plants (Oryza sativa L.) from the Wanshan mercury mining district, SW China. Environ Sci Technol 47(5):2238–2245. 10.1021/es304302a.23363238
Yin L, Yu K, Lin S, . 2016. Associations of blood mercury, inorganic mercury, methyl mercury and bisphenol A with dental surface restorations in the U.S. population, NHANES 2003-2004 and 2010-2012. Ecotoxicol Environ Saf 134P1:213–225. 10.1016/j.ecoenv.2016.09.001.27639196
Yin L, Lin S, Summers AO, . 2021. Children with amalgam dental restorations have significantly elevated blood and urine mercury levels. Toxicol Sci 184(1):104–126. 10.1093/toxsci/kfab108.34453845
Yin L, Lin S, Summers AO, . 2022. Corrigendum to: Children with amalgam dental restorations have significantly elevated blood and urine mercury levels. Toxicol Sci 186(1):174. 10.1093/toxsci/kfab156.35107165
Yip RK, Chang LW. 1981. Vulnerability of dorsal root neurons and fibers toward methylmercury toxicity: a morphological evaluation. Environ Res 26(1):152–167. 10.1016/0013-9351(81)90194-8.7297528
Ynalvez R, Gutierrez J, Gonzalez-Cantu H. 2016. Mini-review: toxicity of mercury as a consequence of enzyme alteration. Biometals 29(5):781–788. 10.1007/s10534-016-9967-8.27591997
Yokoo EM, Valente JG, Grattan L, . 2003. Low level methylmercury exposure affects neuropsychological function in adults. Environ Health 2(1):8. 10.1186/1476-069x-2-8.12844364
Yoo JI, Ha YC, Lee YK, . 2016. High levels of heavy metals increase the prevalence of sarcopenia in the elderly population. J Bone Metab 23(2):101–109. 10.11005/jbm.2016.23.2.101.27294082
Yorifuji T, Tsuda T, Takao S, . 2008. Long-term exposure to methylmercury and neurologic signs in Minamata and neighboring communities. Epidemiology 19(1):3–9. 10.1097/EDE.0b013e31815c09d2.18091411
Yorifuji T, Tsuda T, Takao S, . 2009. Total mercury content in hair and neurologic signs: historic data from Minamata. Epidemiology 20(2):188–193. 10.1097/EDE.0b013e318190e73f.19057389
Yorifuji T, Tsuda T, Kashima S, . 2010. Long-term exposure to methylmercury and its effects on hypertension in Minamata. Environ Res 110(1):40–46. 10.1016/j.envres.2009.10.011.19922910
Yorifuji T, Tsuda T, Inoue S, . 2011. Long-term exposure to methylmercury and psychiatric symptoms in residents of Minamata, Japan. Environ Int 37(5):907–913. 10.1016/j.envint.2011.03.008.21470684
Yorifuji T, Murata K, Bjerve KS, . 2013. Visual evoked potentials in children prenatally exposed to methylmercury. Neurotoxicology 37:15–18. 10.1016/j.neuro.2013.03.009.23548974
Yorifuji T, Kato T, Kado Y, . 2015. Intrauterine exposure to methylmercury and neurocognitive functions: Minamata disease. Arch Environ Occup Health 70(5):297–302. 10.1080/19338244.2014.904268.24971622
Yorifuji T, Kado Y, Diez MH, . 2016. Neurological and neurocognitive functions from intrauterine methylmercury exposure. Arch Environ Occup Health 71(3):170–177. 10.1080/19338244.2015.1080153.26267674
Yorifuji T, Takaoka S, Grandjean P. 2018. Accelerated functional losses in ageing congenital Minamata disease patients. Neurotoxicol Teratol 69:49–53. 10.1016/j.ntt.2018.08.001.30102975
Yorifuji T, Kadowaki T, Yasuda M, . 2023. Neurological and neurocognitive impairments in adults with a history of prenatal methylmercury poisoning: Minamata disease. Int J Environ Res Public Health 20(12):6173. 10.3390/ijerph20126173.37372760
Yoshida M, Satoh M, Shimada A, . 2002. Maternal-to-fetus transfer of mercury in metallothionein-null pregnant mice after exposure to mercury vapor. Toxicology 175(1–3):215–222. 10.1016/s0300-483x(02)00084-7.12049849
Yoshida M, Suzuki M, Satoh M, . 2011. Neurobehavioral effects of combined prenatal exposure to low-level mercury vapor and methylmercury. J Toxicol Sci 36(1):73–80. 10.2131/jts.36.73.21297343
Yoshida M, Watanabe C, Honda A, . 2013. Emergence of delayed behavioral effects in offspring mice exposed to low levels of mercury vapor during the lactation period. J Toxicol Sci 38(1):1–6. 10.2131/jts.38.1.23358134
Yoshida M, Lee JY, Satoh M, . 2018. Neurobehavioral effects of postnatal exposure to low-level mercury vapor and/or methylmercury in mice. J Toxicol Sci 43(1):11–17. 10.2131/jts.43.11.29415947
Yoshimasu K, Kiyohara C, Takemura S, . 2014. A meta-analysis of the evidence on the impact of prenatal and early infancy exposures to mercury on autism and attention deficit/hyperactivity disorder in the childhood. Neurotoxicology 44:121–131. 10.1016/j.neuro.2014.06.007.24952233
Yoshizawa K, Rimm EB, Morris JS, . 2002. Mercury and the risk of coronary heart disease in men. N Engl J Med 347(22):1755–1760. 10.1056/NEJMoa021437.12456851
You CH, Kim BG, Kim YM, . 2014. Relationship between dietary mercury intake and blood mercury level in Korea. J Korean Med Sci 29(2):176–182. 10.3346/jkms.2014.29.2.176.24550642
You SH, Wang SL, Pan WH, . 2018. Risk assessment of methylmercury based on internal exposure and fish and seafood consumption estimates in Taiwanese children. Int J Hyg Environ Health 221(4):697–703. 10.1016/j.ijheh.2018.03.002.29567374
Young JF, Wosilait WD, Luecke RH. 2001. Analysis of methylmercury disposition in humans utilizing a PBPK model and animal pharmacokinetic data. J Toxicol Environ Health A 63(1):19–52. 10.1080/152873901750128344.11346132
Young EC, Davidson PW, Wilding G, . 2020. Association between prenatal dietary methyl mercury exposure and developmental outcomes on acquisition of articulatory-phonologic skills in children in the Republic of Seychelles. Neurotoxicology 81:353–357. 10.1016/j.neuro.2020.09.028.33741116
Yu Y, Gao M, Wang X, . 2019. Recommended acceptable levels of maternal serum typical toxic metals from the perspective of spontaneous preterm birth in Shanxi Province, China. Sci Total Environ 686:599–605. 10.1016/j.scitotenv.2019.05.413.31185407
Zalups RK. 1995. Organic anion transport and action of gamma-glutamyl transpeptidase in kidney linked mechanistically to renal tubular uptake of inorganic mercury. Toxicol Appl Pharmacol 132(2):289–298. 10.1006/taap.1995.1110.7785056
Zalups RK. 1998. Intestinal handling of mercury in the rat: Implications of intestinal secretion of inorganic mercury following biliary ligation or cannulation. J Toxicol Environ Health A 53(8):615–636. 10.1080/009841098159079.9572160
Zalups RK. 2000. Molecular interactions with mercury in the kidney. Pharmacol Rev 52(1):113–143.10699157
Zalups RK, Barfuss D. 1990. Accumulation of inorganic mercury along the renal proximal tubule of the rabbit. Toxicol Appl Pharmacol 106(2):245–253. 10.1016/0041-008x(90)90244-o.2256114
Zalups RK, Cherian MG. 1992. Renal metallothionein metabolism after a reduction of renal mass. II. Effect of zinc pretreatment on the renal toxicity and intrarenal accumulation of inorganic mercury. Toxicology 71(1–2):103–117.1729759
Zalups RK, Minor KH. 1995. Luminal and basolateral mechanisms involved in the renal tubular uptake of inorganic mercury. J Toxicol Environ Health 46(1):73–100. 10.1080/15287399509532019.7666495
Zalups RK, Lash LH. 1997. Binding of mercury in renal brush-border and basolateral membrane-vesicles. Biochem Pharmacol 53(12):1889–1900. 10.1016/s0006-2952(97)00138-x.9256164
Zalups RK, Ahmad S. 2004. Homocysteine and the renal epithelial transport and toxicity of inorganic mercury: role of basolateral transporter organic anion transporter 1. J Am Soc Nephrol 15(8):2023–2031. 10.1097/01.asn.0000135115.63412.a9.15284288
Zalups RK, Diamond GL. 2005. Nephrotoxicology of metals. In: Tarloff JB, Lash LH, eds. Toxicology of the kidney. 3^rd^ ed. Boca Raton, FL: CRC Press, 767–814.
Zalups RK, Ahmad S. 2005a. Handling of cysteine S-conjugates of methylmercury in MDCK cells expressing human OAT1. Kidney Int 68(4):1684–1699. 10.1111/j.1523-1755.2005.00585.x.16164645
Zalups RK, Ahmad S. 2005b. Handling of the homocysteine S-conjugate of methylmercury by renal epithelial cells: role of organic anion transporter 1 and amino acid transporters. J Pharmacol Exp Ther 315(2):896–904. 10.1124/jpet.105.090530.16081680
Zalups RK, Ahmad S. 2005c. Transport of N-acetylcysteine s-conjugates of methylmercury in Madin-Darby canine kidney cells stably transfected with human isoform of organic anion transporter 1. J Pharmacol Exp Ther 314(3):1158–1168. 10.1124/jpet.105.086645.15908511
Zalups RK, Bridges CC. 2012. Relationships between the renal handling of DMPS and DMSA and the renal handling of mercury. Chem Res Toxicol 25(9):1825–1838. 10.1021/tx3001847.22667351
Zalups RK, Barfuss DW, Kostyniak PJ. 1992. Altered intrarenal accumulation of mercury in uninephrectomized rats treated with methylmercury chloride. Toxicol Appl Pharmacol 115(2):174–182.1641852
Zalups RK, Knutson KL, Schnellmann RG. 1993. In vitro analysis of the accumulation and toxicity of inorganic mercury in segments of the proximal tubule isolated from the rabbit kidney. Toxicol Appl Pharmacol 119(2):221–227.8480331
Zalups RK, Barfuss DW, Lash LH. 1999. Disposition of inorganic mercury following biliary obstruction and chemically induced glutathione depletion: dispositional changes one hour after the intravenous administration of mercuric chloride. Toxicol Appl Pharmacol 154(2):135–144. 10.1006/taap.1998.8562.9925797
Zalups RK, Aslamkhan AG, Ahmad S. 2004. Human organic anion transporter 1 mediates cellular uptake of cysteine-S conjugates of inorganic mercury. Kidney Int 66(1):251–261. 10.1111/j.1523-1755.2004.00726.x.15200431
Zanoli P, Truzzi C, Veneri C, . 1994. Methyl mercury during late gestation affects temporarily the development of cortical muscarinic receptors in rat offspring. Pharmacol Toxicol 75(5):261–264. 10.1111/j.1600-0773.1994.tb00358.x.7870696
Zareba G, Cernichiari E, Goldsmith LA, . 2008. Validity of methyl mercury hair analysis: mercury monitoring in human scalp/nude mouse model. J Appl Toxicol 28(4):535–542. 10.1002/jat.1307.18004718
Zareba W, Thurston SW, Zareba G, . 2019. Prenatal and recent methylmercury exposure and heart rate variability in young adults: the Seychelles Child Development Study. Neurotoxicol Teratol 74:106810. 10.1016/j.ntt.2019.106810.31128243
Zasukhina GD, Vasilyeva IM, Sdirkova NI, . 1983. Mutagenic effect of thallium and mercury salts on rodent cells with different repair activities. Mutat Res 124(2):163–173.6646156
Zayas LH, Ozuah PO. 1996. Mercury use in espiritismo: a survey of botanicas. Am J Public Health 86(1):111–112. 10.2105/ajph.86.1.111.8561228
Zefferino R, Piccoli C, Ricciardi N, . 2017. Possible mechanisms of mercury toxicity and cancer promotion: Involvement of gap junction intercellular communications and inflammatory cytokines. Oxid Med Cell Longev 2017:1–6. 10.1155/2017/7028583.
Zeng Q, Zhou B, Feng W, . 2013. Associations of urinary metal concentrations and circulating testosterone in Chinese men. Reprod Toxicol 41:109–114. 10.1016/j.reprotox.2013.06.062.23791927
Zeng Q, Feng W, Zhou B, . 2015. Urinary metal concentrations in relation to semen quality: A cross-sectional study in China. Environ Sci Technol 49(8):5052–5059. 10.1021/es5053478.25827020
Zhai Q, Cen S, Jiang J, . 2019. Disturbance of trace element and gut microbiota profiles as indicators of autism spectrum disorder: A pilot study of Chinese children. Environ Res 171:501–509. 10.1016/j.envres.2019.01.060.30743242
Zhang Y, Bolivar VJ, Lawrence DA. 2013. Maternal exposure to mercury chloride during pregnancy and lactation affects the immunity and social behavior of offspring. Toxicol Sci 133(1):101–111. 10.1093/toxsci/kft023.23392568
Zhang H, Feng X, Larssen T, . 2010. In inland China, rice, rather than fish, is the major pathway for methylmercury exposure. Environ Health Perspect 118(9):1183–1188. 10.1289/ehp.1001915.20378486
Zhang Y, Gao D, Bolivar VJ, . 2011. Induction of autoimmunity to brain antigens by developmental mercury exposure. Toxicol Sci 119(2):270–280. 10.1093/toxsci/kfq334.21071724
Zhang BB, Li WK, Hou WY, . 2017. Zuotai and HgS differ from HgCl2 and methyl mercury in Hg accumulation and toxicity in weanling and aged rats. Toxicol Appl Pharmacol 331:76–84. 10.1016/j.taap.2017.05.021.28536007
Zhang C, Wu HB, Cheng MX, . 2019. Association of exposure to multiple metals with papillary thyroid cancer risk in China. Environ Sci Pollut Res Int 26(20):20560–20572. 10.1007/s11356-019-04733-x.31104243
Zhang Y, Huo X, Lu X, . 2020a. Exposure to multiple heavy metals associate with aberrant immune homeostasis and inflammatory activation in preschool children. Chemosphere 257:127257. 10.1016/j.chemosphere.2020.127257.32534297
Zhang C, Gan C, Ding L, . 2020b. Maternal inorganic mercury exposure and renal effects in the Wanshan mercury mining area, southwest China. Ecotoxicol Environ Saf 189:109987. 10.1016/j.ecoenv.2019.109987.31784104
Zhang J, Wang J, Hu J, . 2021a. Associations of total blood mercury and blood methylmercury concentrations with diabetes in adults: An exposure-response analysis of 2005-2018 NHANES. J Trace Elem Med Biol 68:126845. 10.1016/j.jtemb.2021.126845.34418744
Zhang M, Liu T, Wang G, . 2021b. In utero exposure to heavy metals and trace elements and childhood blood pressure in a U.S. urban, low-income, minority birth cohort. Environ Health Perspect 129(6):67005. 10.1289/EHP8325.34160246
Zhang Y, Chen T, Zhang Y, . 2021c. Contribution of trace element exposure to gestational diabetes mellitus through disturbing the gut microbiome. Environ Int 153:106520. 10.1016/j.envint.2021.106520.33774496
Zhang Q, Hu M, Wu H, . 2021d. Plasma polybrominated diphenyl ethers, urinary heavy metals and the risk of thyroid cancer: A case-control study in China. Environ Pollut 269:116162. 10.1016/j.envpol.2020.116162.33303234
Zhang W, Li F, Gao L, . 2022. Understanding the excretion rates of methylmercury and inorganic mercury from human body via hair and fingernails. J Environ Sci (China) 119:59–67. 10.1016/j.jes.2022.01.041.35934466
Zhang W, Cui Y, Liu J. 2023a. The association between blood heavy metals level and sex hormones among postmenopausal women in the US. Front Endocrinol (Lausanne) 14:1175011. 10.3389/fendo.2023.1175011.37534216
Zhang X, Wei H, Guan Q, . 2023b. Maternal exposure to trace elements, toxic metals, and longitudinal changes in infancy anthropometry and growth trajectories: a prospective cohort study. Environ Sci Technol 57(32):11779–11791. 10.1021/acs.est.3c02535.37525382
Zhao Y, Zhou C, Wu C, . 2020. Subchronic oral mercury caused intestinal injury and changed gut microbiota in mice. Sci Total Environ 721:137639. 10.1016/j.scitotenv.2020.137639.32172103
Zhao Y, Zhou C, Guo X, . 2021. Exposed to mercury-induced oxidative stress, changes of intestinal microflora, and association between them in mice. Biol Trace Elem Res 199(5):1900–1907. 10.1007/s12011-020-02300-x.32734533
Zhao S, Yang X, Xu Q, . 2023. Association of maternal metals exposure, metabolites and birth outcomes in newborns: A prospective cohort study. Environ Int 179:108183. 10.1016/j.envint.2023.108183.37690219
Zheng Y, Lin PD, Williams PL, . 2021. Early pregnancy essential and non-essential metal mixtures and gestational glucose concentrations in the 2^nd^ trimester: Results from project viva. Environ Int 155:106690. 10.1016/j.envint.2021.106690.34120006
Zheng L, Yu Y, Tian X, . 2023. The association between multi-heavy metals exposure and lung function in a typical rural population of Northwest China. Environ Sci Pollut Res Int 30(24):65646–65658. 10.1007/s11356-023-26881-x.37085680
Zhou CC, Fu H, Zhang GY, . 2021. Effects of low-level mercury exposure on brain-derived neurotrophic factor in preschool children. Ecotoxicol Environ Saf 208:111642. 10.1016/j.ecoenv.2020.111642.33396162
Zhou X, Feng Y, Gong Z. 2022. Associations between lead, cadmium, mercury, and arsenic exposure and alanine aminotransferase elevation in the general adult population: an exposure-response analysis. Environ Sci Pollut Res Int 29(35):53633–53641. 10.1007/s11356-022-19698-7.35292896
Zhu X, Kusaka Y, Sato K, . 2000. The endocrine disruptive effects of mercury. Environ Health Prev Med 4(4):174–183. 10.1007/bf02931255.21432482
Zhu XJ, Wang JJ, Mao JH, . 2019. Relationships of cadmium, lead, and mercury levels with albuminuria in US adults: Results from the National Health and Nutrition Examination Survey database, 2009-2012. Am J Epidemiol 188(7):1281–1287. 10.1093/aje/kwz070.30874715
Zhu F, Chen C, Zhang Y, . 2020. Elevated blood mercury level has a non-linear association with infertility in U.S. women: Data from the NHANES 2013-2016. Reprod Toxicol 91:53–58. 10.1016/j.reprotox.2019.11.005.31756438
Zorn NE, Smith JT. 1989. In vivo methylation of inorganic mercury in guinea pigs. Biochem Arch 5:141–146.
Zuk AM, Liberda EN, Tsuji LJS. 2021. Environmental contaminant body burdens and the relationship with blood pressure measures among indigenous adults. Environ Epidemiol 5(2):e137. 10.1097/ee9.0000000000000137.33870012
Zwicker JD, Dutton DJ, Emery JC. 2014. Longitudinal analysis of the association between removal of dental amalgam, urine mercury and 14 self-reported health symptoms. Environ Health 13:95. 10.1186/1476-069x-13-95.25404430