# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Rae T. Benedict, Ph.D. (Lead)
  Breanna Alman, M.P.H
  Fahim Atif, Ph.D.
  Franco Scinicariello, M.D., M.P.H.
  ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA
- Julie M. Klotzbach, Ph.D.
  Mario Citra, Ph.D.
  Gary L. Diamond, Ph.D.
  Deborah Herber, Ph.D.
  Lisa Ingerman, Ph.D., D.A.B.T.
  Connor McGuire, Ph.D.
  Sara Nieman, M.S.
  Sabah Tariq, M.S,
  Kimberly Zaccaria, Ph.D., D.A.B.T.
  SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

- Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA), Center for Public Health and environmental Assessment; EPA, Office of Water; National Toxicology Program (NTP).

Additional reviews for science and/or policy:

- ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Research and Development; EPA, Office of Water.

## PEER REVIEWERS

1. Harvey Clewell, Ph.D.; Principal Consultant; Ramboll US Consulting, Inc.; Monroe, Louisiana
2. William Pan, Ph.D.; The Elizabeth Brooks Reid and Whitelaw; Reid Associate Professor of Population Studies; Durham, North Carolina
3. Kristine Vejrup, Ph.D.; Associate Professor; Norwegian Institute of Public Health; Division of Occupational and Environmental Medicine; Lund University; Lund, Sweden

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.