# VERSION HISTORY

Date | Description
October 2024 | Final toxicological profile released
April 2022 | Draft for public comment toxicological profile released
March 2013 | Addendum to the toxicological profile released
March 1999 | Final toxicological profile released
May 1994 | Final toxicological profile released
December 1989 | Final toxicological profile released