# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding mercury in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for mercury.

Table 7-1 Regulations and Guidelines Applicable to Mercury (Hg)

Agency | Description | Information | Reference
Air
EPA | RfC | | IRIS 1995a
EPA | Mercury, elemental | 3×10^−4^ mg/m^3^ (0.00004 ppm) | IRIS 1995a
WHO | Air quality guidelines | | WHO 2000
WHO | Mercury vapor | 1 µg/m^3^ annual average (0.0001 ppm) | WHO 2000
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | Mercury, inorganic | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | 0.002 mg/L | EPA 2018a
EPA | 10-Day health advisory (10-kg child) | 0.002 mg/L | EPA 2018a
EPA | DWEL | 0.01 mg/L | EPA 2018a
EPA | Lifetime health advisory | 0.002 mg/L | EPA 2018a
EPA | National primary drinking water regulations | No data | EPA 2009
EPA | Mercury, inorganic | | EPA 2009
EPA | MCL | 0.002 mg/L | EPA 2009
EPA | RfD | | EPA 2009
EPA | Mercuric chloride | 3×10^−4^ mg/kg/day | IRIS 1995b
EPA | Methylmercury | 1×10^−4^ mg/kg/day | IRIS 2001
EPA | Phenylmercuric acetate | 8×10^−5^ mg/kg/day | IRIS 1987
WHO | Drinking water quality guidelines | | WHO 2022
WHO | Mercury, inorganic | | WHO 2022
WHO | Guideline value | 0.006 mg/L | WHO 2022
WHO | TDI | 2 µg/kg body weight | WHO 2022
WHO | Provisional tolerable weekly intake
WHO | Mercury, inorganic | 4 µg/kg body weight | WHO 2011
WHO | Methylmercury | 1.6 µg/kg body weight | WHO 2007
FDA | Substances added to food^a^ | No data | FDA 2023
FDA | Action level in human food and animal feed
FDA | Mercury | | FDA 2018a
FDA | Wheat (pink kernels only) | 1 ppm on pink kernels and an average of 10 or more pink kernels/500 g | FDA 2018a
FDA | Methylmercury (as Hg) | | FDA 2018b
FDA | Fish, shellfish, crustaceans, other aquatic animals (fresh, frozen, or processed) | 1 ppm in edible portion | FDA 2018b
FDA | Allowable level in bottled water
FDA | Mercury | 0.002 mg/L | FDA 2017b
Cancer
HHS | Carcinogenicity classification | Not evaluated | NTP 2021
EPA | Carcinogenicity classification
EPA | Mercury, elemental | D^b^ | IRIS 1995a
EPA | Mercuric chloride | C^c^ | IRIS 1995b
EPA | Methylmercury | C^c^ | IRIS 2001
IARC | Carcinogenicity classification | | IARC 1993
IARC | Mercury and inorganic mercury compounds | Group 3^d^ | IARC 1993
IARC | Methylmercury compounds | Group 2B^e^ | IARC 1993
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | | OSHA 2005, 2021a, 2021b, 2021c
OSHA | Mercury, except (organo) alkyl compounds (as Hg) | 1 mg/10 m³ (0.1 mg/m³)^f^ | OSHA 2005, 2021a, 2021b, 2021c
OSHA | Mercury (organo) alkyl compounds | 0.01 mg/m³ ^f^ | OSHA 2005, 2021a, 2021b, 2021c
OSHA | PEL (ceiling) for general industry | | OSHA 2005, 2021a, 2021b, 2021c
OSHA | Mercury (organo) alkyl compounds | 0.04 mg/m³ ^f^ | OSHA 2005, 2021a, 2021b, 2021c
NIOSH | REL (up to 10-hour TWA)
NIOSH | Mercury vapor | 0.05 mg/m³ ^f^ | NIOSH 2019a
NIOSH | Mercury (organo) alkyl compounds (as Hg) | 0.01 mg/m^3f^ | NIOSH 2019b
NIOSH | REL (ceiling)
NIOSH | Mercury compounds except (organo) alkyls (as Hg) | 0.1 mg/m³ ^f^ | NIOSH 2019a
NIOSH | STEL^g^
NIOSH | Mercury (organo) alkyl compounds (as Hg) | 0.03 mg/m^3f^ | NIOSH 2019b
NIOSH | IDLH
NIOSH | Mercury compounds except (organo) alkyls (as Hg) | 10 mg/m^3^ | NIOSH 1994a
NIOSH | Mercury (organo) alkyl compounds (as Hg) | 2 mg/m^3^ | NIOSH 1994b
Emergency Criteria
EPA | AEGLs-air | | EPA 2018b
EPA | Mercury vapor | | EPA 2018b
EPA | AEGL 1^h^ | Not recommended | EPA 2018b
EPA | AEGL 2^h^ | | EPA 2018b
EPA | 10-minute | 3.1 mg/m^3^ | EPA 2018b
EPA | 30-minute | 2.1 mg/m^3^ | EPA 2018b
EPA | 60-minute | 1.7 mg/m^3^ | EPA 2018b
EPA | 4-hour | 0.67 mg/m^3^ | EPA 2018b
EPA | 8-hour | 0.33 mg/m^3^ | EPA 2018b
EPA | AEGL 3^h^ | | EPA 2018b
EPA | 10-minute | 16 mg/m^3^ | EPA 2018b
EPA | 30-minute | 11 mg/m^3^ | EPA 2018b
EPA | 60-minute | 8.9 mg/m^3^ | EPA 2018b
EPA | 4-hour | 2.2 mg/m^3^ | EPA 2018b
EPA | 8-hour | 2.2 mg/m^3^ | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | Mercury vapor | | DOE 2018a
DOE | PAC-1^i^ | 0.15 mg/m^3^ | DOE 2018a
DOE | PAC-2^i^ | 1.7 mg/m^3^ | DOE 2018a
DOE | PAC-3^i^ | 8.9 mg/m^3^ | DOE 2018a
DOE | Mercury(II) chloride | | DOE 2018a
DOE | PAC-1^i^ | 0.1 mg/m^3^ | DOE 2018a
DOE | PAC-2^i^ | 0.14 mg/m^3^ | DOE 2018a
DOE | PAC-3^i^ | 38 mg/m^3^ | DOE 2018a
DOE | Mercury(I) chloride | | DOE 2018a
DOE | PAC-1^i^ | 0.088 mg/m^3^ | DOE 2018a
DOE | PAC-2^i^ | 0.12 mg/m^3^ | DOE 2018a
DOE | PAC-3^i^ | 33 mg/m^3^ | DOE 2018a
DOE | Mercuric acetate | | DOE 2018a
DOE | PAC-1^i^ | 0.048 mg/m^3^ | DOE 2018a
DOE | PAC-2^i^ | 0.64 mg/m^3^ | DOE 2018a
DOE | PAC-3^i^ | 3.2 mg/m^3^ | DOE 2018a
DOE | Dimethylmercury | | DOE 2018a
DOE | PAC-1^i^ | 0.034 mg/m^3^ | DOE 2018a
DOE | PAC-2^i^ | 0.046 mg/m^3^ | DOE 2018a
DOE | PAC-3^i^ | 2.3 mg/m^3^ | DOE 2018a
DOE | Phenylmercury acetate | | DOE 2018a
DOE | PAC-1^i^ | 2 mg/m^3^ | DOE 2018a
DOE | PAC-2^i^ | 22 mg/m^3^ | DOE 2018a
DOE | PAC-3^i^ | 47 mg/m^3^ | DOE 2018a
DOE | Methylmercury | | DOE 2018a
DOE | PAC-1^i^ | 0.032 mg/m^3^ | DOE 2018a
DOE | PAC-2^i^ | 0.043 mg/m^3^ | DOE 2018a
DOE | PAC-3^i^ | 2.1 mg/m^3^ | DOE 2018a

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS”.

b D: not classifiable as to human carcinogenicity.

c C: possible human carcinogen.

d Group 3: not classifiable as to its carcinogenicity to humans.

e Group 2B: possibly carcinogenic to humans.

f Skin notation.

g Short-term exposure limit, a 15-minute TWA exposure that should not be exceeded at any time during a workday.

h Definitions of AEGL terminology are available from EPA (2018c).

i Definitions of PAC terminology are available from DOE (2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = U.S. Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure limit; TDI = tolerable daily intake; TWA = time-weighted average; WHO = World Health Organization