# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR MERCURY

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to mercury.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for mercury. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of mercury have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of mercury are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

- Health Effects; - Species; - Human; - Laboratory mammals; - Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data); - Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer; - Toxicokinetics; - Absorption; - Distribution; - Metabolism; - Excretion; - PBPK models; - Biomarkers; - Biomarkers of exposure; - Biomarkers of effect; - Interactions with other chemicals; - Potential for human exposure; - Releases to the environment; - Air; - Water; - Soil; - Environmental fate; - Transport and partitioning; - Transformation and degradation; - Environmental monitoring; - Air; - Water; - Sediment and soil; - Other media; - Biomonitoring; - General populations; - Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the Draft Toxicological Profile for Mercury released for public comment in 2022; thus, the literature search was restricted to studies published between December 2018 and October 2023. The following main databases were searched in October 2023:

- PubMed
- National Technical Reports Library
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for mercury. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to mercury were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
10/2023 | (((“mercury/toxicity”[mh] OR “mercury/adverse effects”[mh] OR “mercury/poisoning”[mh] OR “mercury/pharmacokinetics”[mh] OR (“mercury”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercury”[mh] AND toxicokinetics[mh:noexp]) OR (“mercury/blood”[mh] OR “mercury/cerebrospinal fluid”[mh] OR “mercury/urine”[mh] OR “mercury/antagonists and inhibitors”[mh]) OR (“mercury/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercury”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercury/pharmacology”[majr])) OR (“phenylmercuric acetate/toxicity”[mh] OR “phenylmercuric acetate/adverse effects”[mh] OR “phenylmercuric acetate/poisoning”[mh] OR “phenylmercuric acetate/pharmacokinetics”[mh] OR (“phenylmercuric acetate”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“phenylmercuric acetate”[mh] AND toxicokinetics[mh:noexp]) OR (“phenylmercuric acetate/blood”[mh] OR “phenylmercuric acetate/cerebrospinal fluid”[mh] OR “phenylmercuric acetate/urine”[mh] OR “phenylmercuric acetate/antagonists and inhibitors”[mh]) OR (“phenylmercuric acetate/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“phenylmercuric acetate”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “phenylmercuric acetate/pharmacology”[majr])) OR (“mercuric chloride/toxicity”[mh] OR “mercuric chloride/adverse effects”[mh] OR “mercuric chloride/poisoning”[mh] OR “mercuric chloride/pharmacokinetics”[mh] OR (“mercuric chloride”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercuric chloride”[mh] AND toxicokinetics[mh:noexp]) OR (“mercuric chloride/blood”[mh] OR “mercuric chloride/cerebrospinal fluid”[mh] OR “mercuric chloride/urine”[mh] OR “mercuric chloride/antagonists and inhibitors”[mh]) OR (“mercuric chloride/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercuric chloride”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercuric chloride/pharmacology”[majr])) OR “Mercury poisoning”[mh] OR 13966-62-6[rn] OR 72172-67-9[rn] OR ((“mercury”[mh] OR “phenylmercuric acetate”[mh] OR “mercuric chloride”[mh]) AND ((indexingmethod_automated OR indexingmethod_curated) AND (“RNA”[mh] OR “DNA”[mh] OR “DNA Replication”[mh] OR “Salmonella typhimurium”[mh] OR antagonist*[tw] OR inhibitor*[tw] OR “blood”[tw] OR “serum”[tw] OR “plasma”[tw] OR pharmacokinetic*[tw] OR toxicokinetic*[tw] OR “pbpk”[tw] OR “poisoned”[tw] OR “poisoning”[tw] OR “urine”[tw] OR “urinary”[tw] OR “toxicity”[sh] OR “occupational diseases”[mh] OR “hazardous substances”[mh] OR “epidemiology”[sh] OR “epidemiologic studies”[mh])))) AND (2022/09/26:3000[mhda])) OR ((“cinnabar”[tw] OR “mercuric sulfide”[tw] OR “mercuric sulphide”[tw] OR “mercury (ii) sulfide”[tw] OR “mercury monosulfide”[tw] OR “mercury sulfide”[tw] OR “mercury sulphide”[tw] OR “mercury(2+) sulfide”[tw] OR “mercury(ii) sulfide”[tw] OR “monomercury sulfide”[tw]) AND (2022/09/26:3000[edat] OR 2022/09/26:3000[crdat])); ((“mercury compounds/toxicity”[mh] OR “mercury compounds/adverse effects”[mh] OR “mercury compounds/poisoning”[mh] OR “mercury compounds/pharmacokinetics”[mh] OR (“mercury compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercury compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“mercury compounds/blood”[mh] OR “mercury compounds/cerebrospinal fluid”[mh] OR “mercury compounds/urine”[mh] OR “mercury compounds/antagonists and inhibitors”[mh]) OR (“mercury compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercury compounds”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercury compounds/pharmacology”[majr])) OR (“methylmercury compounds/toxicity”[mh] OR “methylmercury compounds/adverse effects”[mh] OR “methylmercury compounds/poisoning”[mh] OR “methylmercury compounds/pharmacokinetics”[mh] OR (“methylmercury compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“methylmercury compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“methylmercury compounds/blood”[mh] OR “methylmercury compounds/cerebrospinal fluid”[mh] OR “methylmercury compounds/urine”[mh] OR “methylmercury compounds/antagonists and inhibitors”[mh]) OR (“methylmercury compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“methylmercury compounds”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “methylmercury compounds/pharmacology”[majr])) OR (“mercury isotopes/toxicity”[mh] OR “mercury isotopes/adverse effects”[mh] OR “mercury isotopes/poisoning”[mh] OR “mercury isotopes/pharmacokinetics”[mh] OR (“mercury isotopes”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercury isotopes”[mh] AND toxicokinetics[mh:noexp]) OR (“mercury isotopes/blood”[mh] OR “mercury isotopes/cerebrospinal fluid”[mh] OR “mercury isotopes/urine”[mh] OR “mercury isotopes/antagonists and inhibitors”[mh]) OR (“mercury isotopes/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercury isotopes”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercury isotopes/pharmacology”[majr])) OR (“organomercury compounds/toxicity”[mh] OR “organomercury compounds/adverse effects”[mh] OR “organomercury compounds/poisoning”[mh] OR “organomercury compounds/pharmacokinetics”[mh] OR (“organomercury compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“organomercury compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“organomercury compounds/blood”[mh] OR “organomercury compounds/cerebrospinal fluid”[mh] OR “organomercury compounds/urine”[mh] OR “organomercury compounds/antagonists and inhibitors”[mh]) OR (“organomercury compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“organomercury compounds”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “organomercury compounds/pharmacology”[majr])) OR ((“mercury compounds”[mh] OR “methylmercury compounds”[mh] OR “mercury isotopes”[mh] OR “organomercury compounds”[mh]) AND ((indexingmethod_automated OR indexingmethod_curated) AND (“RNA”[mh] OR “DNA”[mh] OR “DNA Replication”[mh] OR “Salmonella typhimurium”[mh] OR antagonist*[tw] OR inhibitor*[tw] OR “blood”[tw] OR “serum”[tw] OR “plasma”[tw] OR pharmacokinetic*[tw] OR toxicokinetic*[tw] OR “pbpk”[tw] OR “poisoned”[tw] OR “poisoning”[tw] OR “urine”[tw] OR “urinary”[tw] OR “toxicity”[sh] OR “occupational diseases”[mh] OR “hazardous substances”[mh] OR “epidemiology”[sh] OR “epidemiologic studies”[mh])))) AND (2022/09/26:3000[mhda]); ((((“(acetato)phenylmercury”[tw] OR “(acetato-kappao)phenylmercury”[tw] OR “(acetato-o)phenylmercury”[tw] OR “(acetoxymercuri)benzene”[tw] OR “(acetoxymercurio)benzene”[tw] OR “acetic acid, mercuridi-”[tw] OR “acetic acid, mercury(2+) salt”[tw] OR “acetic acid, phenylmercury deriv.”[tw] OR “acetic acid, phenylmercury(ii) salt”[tw] OR “acetoxyphenylmercury”[tw] OR “benzene, (acetoxymercuri)-”[tw] OR “benzene, (acetoxymercurio)-”[tw] OR “bis(acetyloxy)mercury”[tw] OR “calochlor”[tw] OR “calomel”[tw] OR “chloromethylmercury”[tw] OR “cinnabar”[tw] OR “cinnabarite”[tw] OR “diacetoxymercury”[tw] OR “dichloromercury”[tw] OR “dimercury dichloride”[tw] OR “dimethylmercury”[tw] OR “fungche”[tw] OR “hydrargyrum”[tw] OR “mercuriacetate”[tw] OR “mercuric acetate”[tw] OR “mercuric bichloride”[tw] OR “mercuric chloride”[tw] OR “mercuric diacetate”[tw] OR “mercuric nitrate”[tw] OR “mercuric sulfide”[tw] OR “mercuric sulphide”[tw] OR “mercuridiacetic acid, ”[tw] OR “mercuriphenyl acetate”[tw] OR “mercurius 6a”[tw] OR “mercurous chloride”[tw] OR “mercury”[tw] OR “mercury(1+), methyl-”[tw] OR “mercury(2+) acetate”[tw] OR “mercury(2+) chloride”[tw] OR “mercury(2+) nitrate”[tw] OR “mercury(2+) sulfide”[tw] OR “mercury(i) chloride”[tw] OR “mercury(ii) acetate”[tw] OR “mercury(ii) acetate, phenyl-”[tw] OR “mercury(ii) chloride”[tw] OR “mercury(ii) nitrate”[tw] OR “mercury(ii) sulfide”[tw] OR “mercury, (acetato)phenyl-”[tw] OR “mercury, (acetato-kappao)phenyl-”[tw] OR “mercury, (acetato-o)phenyl-”[tw] OR “mercury, acetoxyphenyl-”[tw] OR “mercury, chloromethyl-”[tw] OR “mercury, dimethyl-”[tw] OR “mercuryl acetate”[tw] OR “mercurymethylchloride”[tw] OR “methyl mercuric chloride”[tw] OR “methyl mercuric(ii) chloride”[tw] OR “methyl meruric chloride”[tw] OR “methylmercuric chloride”[tw] OR “methylmercury”[tw] OR “methylmercury chloride”[tw] OR “methylmercury monochloride”[tw] OR “methylmercury(1+)”[tw] OR “methylmercury(ii) cation”[tw] OR “millon’s reagent”[tw] OR “monomercury sulfide”[tw] OR “monomethylmercury cation”[tw] OR “nitric acid, mercury(2+) salt”[tw] OR “nitric acid, mercury(ii) salt”[tw] OR “phenomercuric acetate”[tw] OR “phenyl mercuric acetate”[tw] OR “phenylmercuriacetate”[tw] OR “phenylmercuric acetate”[tw] OR “phenylmercury acetate”[tw] OR “phenylmercury(ii) acetate”[tw] OR “Anticon”[tw] OR “Celmer”[tw] OR “Femma”[tw] OR “Hexasan”[tw] OR “Hostaquick”[tw] OR “Kwiksan”[tw] OR “Lorophyn”[tw] OR “Parasan”[tw] OR “Phix”[tw] OR “Samtol”[tw] OR “Sanitol”[tw] OR “Sc-110”[tw] OR “Verdasan”[tw] OR “Volpar”[tw] OR “Caspan”[tw] OR “Liquid silver”[tw] OR “Quick silver”[tw] OR “Quicksilver”[tw] OR “Sulem”[tw] OR “Agrosan D”[tw] OR “Agrosan GN 5”[tw] OR “Algimycin 200”[tw] OR “Antimucin WBR”[tw] OR “Antimucin WDR”[tw] OR “Bufen”[tw] OR “Bufen 30”[tw] OR “Cekusil”[tw] OR “Ceresol”[tw] OR “Contra Creme”[tw] OR “Dyanacide”[tw] OR “Fungicide R”[tw] OR “Fungitox OR”[tw] OR “Gallotox”[tw] OR “Hl-331”[tw] OR “Hong nien”[tw] OR “Hostaquik”[tw] OR “Intercide 60”[tw] OR “Intercide PMA 18”[tw] OR “Liquiphene”[tw] OR “Meracen”[tw] OR “Mercron”[tw] OR “Mercuron”[tw] OR “Mergal A 25”[tw] OR “Mersolite”[tw] OR “Metasol 30”[tw] OR “Neantina”[tw] OR “Norforms”[tw] OR “Nuodex PMA 18”[tw] OR “Nylmerate”[tw] OR “PMA (fungicide)”[tw] OR “Pamisan”[tw] OR “Panomatic”[tw] OR “Parasan (bactericide)”[tw] OR “Phenmad”[tw] OR “Programin”[tw] OR “Purasan-SC-10”[tw] OR “Puraturf 10”[tw] OR “Quicksan”[tw] OR “Quicksan 20”[tw] OR “Riogen”[tw] OR “Ruberon”[tw] OR “Sanitized SPG”[tw] OR “Sanmicron”[tw] OR “Scutl”[tw] OR “Seed Dressing R”[tw] OR “Seedtox”[tw] OR “Setrete”[tw] OR “Shimmerex”[tw] OR “Spor-Kil”[tw] OR “Spruce Seal”[tw] OR “Tag (VAN)”[tw] OR “Tag 331”[tw] OR “Tag HL 331”[tw] OR “Tag fungicide”[tw] OR “Trigosan”[tw] OR “Troysan 30”[tw] OR “Troysan PMA 30”[tw] OR “Zaprawa Nasienna R”[tw] OR “Ziarnik”[tw] OR “Hydraargyrum bichloratum”[tw] OR “Calo-Clor”[tw] OR “Calocure”[tw] OR “Calogreen”[tw] OR “Calotab”[tw] OR “Abavit B”[tw] OR “Citrine ointment”[tw] OR “Ethiops mineral”[tw] OR “Mercurius vivus”[tw] OR “beta-Mercuric sulfide”[tw] OR “Phenylquecksilberacetate”[tw] OR “Quecksilber(II)-sulfid, rotes”[tw] OR “Rotes Quecksilbersulfid”[tw] OR “Paragite”[tw] OR “TL 898”[tw]) NOT medline[sb])) AND (2022/09/26:3000[edat] OR 2022/09/26:3000[crdat])) AND (toxicity[ti] OR death OR lethal OR fatal OR fatality OR necrosis OR LC50* OR LD50* OR “body weight” OR “weight loss” OR “weight gain” OR weight-change* OR overweight OR obesity OR inhal* OR respiratory OR pulmonary OR airway OR trachea OR tracheobronchial OR lung OR lungs OR nose OR nasal OR nasopharyngeal OR larynx OR laryngeal OR pharynx OR bronchial OR bronchi OR bronchioles OR bronchitis OR hemothorax OR alveolar OR alveoli OR irritation OR irritant OR sensitization OR sensitizer OR cilia OR mucocilliary OR cvd OR cardio OR vascular OR cardiovascular OR circulatory OR cardiac OR heart OR myocardial OR “chest pain” OR artery OR arteries OR veins OR venules OR cardiotox* OR intestinal OR gastrointestinal OR gastric OR digestive OR intestinal OR “gi tract” OR “gi disorder” OR abdominal OR esophagus OR stomach OR intestine OR pancreas OR pancreatic OR diarrhea OR nausea OR vomit OR ulcer OR constipation OR emesis OR “gut microbes” OR “gut flora” OR “gut microflora” OR anorexia OR hematological OR hematology OR hemato OR haemato OR blood OR anemia OR cyanosis OR erythrocytopenia OR leukopenia OR thrombocytopenia OR hemoglobin OR erythrocyte OR hematocrit OR “bone marrow” OR reticulocyte OR methemoglobin OR red-blood-cell OR musculoskeletal OR skeletal OR muscle OR muscular OR arthritis OR “altered bone” OR “joint pain” OR “joint-ache” OR “limb pain” OR “limb ache” OR hepatic OR liver OR hepatocytes OR gallbladder OR cirrhosis OR jaundice OR hepatocellular OR hepatomegaly OR hepatotox* OR renal OR kidney OR urinary OR bladder OR urine OR “blood urea nitrogen” OR bun OR nephropathy OR nephrotox* OR dermal OR skin OR acanthosis OR dermatitis OR psoriasis OR edema OR ulceration OR acne OR ocular OR “eye function” OR “eye effect” OR “eye irritation” OR “eye drainage” OR “eye tearing” OR blindness OR myopia OR cataracts OR endocrine OR hormone OR “sella turcica” OR thyroid OR adrenal OR pituitary OR immunological OR immunologic OR immune OR lymphoreticular OR lymph-node OR spleen OR thymus OR macrophage OR leukocyte* OR white-blood-cell OR immunotox* OR neurological OR neurologic OR neurotoxic OR neurotoxicity OR neurodegenerat* OR “nervous system” OR brain OR neurotoxicant OR neurochemistry OR neurophysiology OR neuropathology OR “motor activity” OR motor change* OR behavior-change* OR behavioral-change* OR sensory-change* OR cognitive OR vertigo OR drowsiness OR headache OR ataxia OR reproductive OR “reproduction system” OR “reproduction function” OR “reproduction effect” OR “reproduction toxicity” OR fertility OR “maternal toxicity” OR developmental OR “in utero” OR terata* OR terato* OR embryo* OR fetus* OR foetus* OR fetal* OR foetal* OR prenatal* OR “pre-natal” OR perinatal* OR “post-natal” OR postnatal* OR neonat* OR newborn* OR zygote* OR child OR children OR infant* OR offspring OR elderly OR “altered food consumption” OR “altered water consumption” OR “metabolic effect” OR “metabolic toxicity” OR fever OR cancer OR cancerous OR neoplas* OR tumor OR tumors OR tumour* OR malignan* OR carcinoma OR carcinogen OR carcinogen* OR angiosarcoma OR blastoma OR fibrosarcoma OR glioma OR leukemia OR leukaemia OR lymphoma OR melanoma OR meningioma OR mesothelioma OR myeloma OR neuroblastoma OR osteosarcoma OR sarcoma OR mutation OR mutations OR genotoxicity OR genotoxic OR mutagenicity OR mutagenic OR “mechanism of action”[tiab:~0] OR “mechanism of absorption”[tiab:~0] OR “mechanism of distribution”[tiab:~0] OR “mechanism of excretion”[tiab:~0] OR “mechanism of metabolism”[tiab:~0] OR “mechanism of toxic effect”[tiab:~0] OR “mechanism of toxicity” OR “adverse effect” OR “adverse effects” OR “health effects” OR noncancer OR poisoning OR morbidity OR inflammation OR antagonist OR inhibitor OR metabolism OR “environmental exposure” OR toxicokinetics OR pharmacokinetics OR “gene expression” OR “population health” OR epidemiology OR epidemiological OR case-control* OR case-referent OR case-report OR case-series OR cohort* OR correlation-stud* OR cross-sectional-stud* OR ecological-studies OR ecological-study OR follow-up-stud* OR longitudinal-stud* OR metaanalyses OR metaanalysis OR meta-analysis OR prospective-stud* OR record-link* OR retrospective-stud* OR seroepidemiologic-stud* OR occupation* OR worker* OR workmen* OR workplace* OR “human health” OR “oral intake” OR “oral feed” OR “oral ingestion” OR “oral exposure” OR “oral administration” OR ingest* OR gavage* OR “drinking-water” OR NHANES OR “National Health and Nutrition Examination Survey” OR (human AND (risk OR toxic* OR safety)) OR mammal* OR ape OR apes OR baboon* OR balb OR beagle* OR boar OR boars OR bonobo* OR bovine OR C57 OR C57bl OR callithrix OR canine OR canis OR capra OR capuchin* OR cats OR cattle OR cavia OR chicken OR chickens OR chimpanzee* OR chinchilla* OR cow OR cows OR cricetinae OR dog OR dogs OR equus OR feline OR felis OR ferret OR ferrets OR flying-fox OR Fruit-bat OR gerbil* OR gibbon* OR goat OR goats OR guinea-pig* OR guppy OR hamster OR hamsters OR horse OR horses OR jird OR jirds OR lagomorph* OR leontopithecus OR longevans OR macaque* OR marmoset* OR medaka OR merione OR meriones OR mice OR monkey OR monkeys OR mouse OR muridae OR murinae OR murine OR mustela-putorius OR nomascus OR non-human-primate* OR orangutan* OR pan-paniscus OR pan-troglodytes OR pig OR piglet* OR pigs OR polecat* OR pongopygmaeus OR quail OR rabbit OR rabbits OR rat OR rats OR rhesus OR rodent OR rodentia OR rodents OR saguinus OR sheep OR sheeps OR siamang* OR sow OR sows OR Sprague-Dawley OR swine OR swines OR symphalangus OR tamarin* OR vervet* OR wistar OR wood-mouse OR zebra-fish OR zebrafish); (“Cyclosan”[tw] OR “Mercurous iodide”[tw] OR “Mercury telluride”[tw] OR “Mercury hydride”[tw] OR “Mercurane”[tw] OR “Mercury bromide”[tw] OR “Mercury iodide”[tw] OR “Mercury oxide”[tw] OR “Mercuric selenide”[tw] OR “Mercury cyanide”[tw] OR (“Mercury chloride”[tw] NOT “mercuric chloride”[mh])) OR ((“Cyclosan”[tw] OR “Mercury chloride”[tw] OR “Mercury bromide”[tw] OR “Mercuric bromide”[tw] OR “Mercuric dibromide”[tw] OR “Mercury dibromide”[tw] OR “Mercury(II) bromide”[tw] OR “Mercury fulminate”[tw] OR “Mercurous iodide”[tw] OR “Mercuric iodide”[tw] OR “Mercury iodide”[tw] OR “Mercury(II) iodide”[tw] OR “Mercuric oxide”[tw] OR “Mercury oxide”[tw] OR “Red Precipitate”[tw] OR “Yellow precipitate”[tw] OR “Mercuric selenide”[tw] OR “Mercury selenide”[tw] OR “Mercury-selenium complex”[tw] OR “Mercurous sulfate”[tw] OR “Mercury(I) sulfate”[tw] OR “Mercuric sulfate”[tw] OR “Mercuric sulphate”[tw] OR “Mercury sulfate”[tw] OR “Mercury sulphate”[tw] OR “Mercury telluride”[tw] OR “Mercuric cyanide”[tw] OR “Mercurius cyanatus”[tw] OR “Mercury cyanide”[tw] OR “Mercury hydride”[tw] OR “Mercurane”[tw] OR “Mercuric cation”[tw] OR “Mercuric cations”[tw] OR “Mercuric ion”[tw] OR “Mercuric ions”[tw]) NOT medline[sb]) AND (2022/09/26:3000[edat] OR 2022/09/26:3000[crdat])
9/2022 | ((“mercury/toxicity”[mh] OR “mercury/adverse effects”[mh] OR “mercury/poisoning”[mh] OR “mercury/pharmacokinetics”[mh] OR (“mercury”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercury”[mh] AND toxicokinetics[mh:noexp]) OR (“mercury/blood”[mh] OR “mercury/cerebrospinal fluid”[mh] OR “mercury/urine”[mh] OR “mercury/antagonists and inhibitors”[mh]) OR (“mercury/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercury”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercury/pharmacology”[majr])) OR (“phenylmercuric acetate/toxicity”[mh] OR “phenylmercuric acetate/adverse effects”[mh] OR “phenylmercuric acetate/poisoning”[mh] OR “phenylmercuric acetate/pharmacokinetics”[mh] OR (“phenylmercuric acetate”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“phenylmercuric acetate”[mh] AND toxicokinetics[mh:noexp]) OR (“phenylmercuric acetate/blood”[mh] OR “phenylmercuric acetate/cerebrospinal fluid”[mh] OR “phenylmercuric acetate/urine”[mh] OR “phenylmercuric acetate/antagonists and inhibitors”[mh]) OR (“phenylmercuric acetate/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“phenylmercuric acetate”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “phenylmercuric acetate/pharmacology”[majr])) OR (“mercuric chloride/toxicity”[mh] OR “mercuric chloride/adverse effects”[mh] OR “mercuric chloride/poisoning”[mh] OR “mercuric chloride/pharmacokinetics”[mh] OR (“mercuric chloride”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercuric chloride”[mh] AND toxicokinetics[mh:noexp]) OR (“mercuric chloride/blood”[mh] OR “mercuric chloride/cerebrospinal fluid”[mh] OR “mercuric chloride/urine”[mh] OR “mercuric chloride/antagonists and inhibitors”[mh]) OR (“mercuric chloride/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercuric chloride”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercuric chloride/pharmacology”[majr])) OR (“cinnabar”[tw] OR “mercuric sulfide”[tw] OR “mercuric sulphide”[tw] OR “mercury (ii) sulfide”[tw] OR “mercury monosulfide”[tw] OR “mercury sulfide”[tw] OR “mercury sulphide”[tw] OR “mercury(2+) sulfide”[tw] OR “mercury(ii) sulfide”[tw] OR “monomercury sulfide”[tw] OR “Mercury poisoning”[mh])) AND (2018/12/01:3000[edat] OR 2018/12/01:3000[crdat] OR 2018/12/01:3000[mhda] OR 2018/12/01:3000[dp]); ((“mercury compounds/toxicity”[mh] OR “mercury compounds/adverse effects”[mh] OR “mercury compounds/poisoning”[mh] OR “mercury compounds/pharmacokinetics”[mh] OR (“mercury compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercury compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“mercury compounds/blood”[mh] OR “mercury compounds/cerebrospinal fluid”[mh] OR “mercury compounds/urine”[mh] OR “mercury compounds/antagonists and inhibitors”[mh]) OR (“mercury compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercury compounds”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercury compounds/pharmacology”[majr])) OR (“methylmercury compounds/toxicity”[mh] OR “methylmercury compounds/adverse effects”[mh] OR “methylmercury compounds/poisoning”[mh] OR “methylmercury compounds/pharmacokinetics”[mh] OR (“methylmercury compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“methylmercury compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“methylmercury compounds/blood”[mh] OR “methylmercury compounds/cerebrospinal fluid”[mh] OR “methylmercury compounds/urine”[mh] OR “methylmercury compounds/antagonists and inhibitors”[mh]) OR (“methylmercury compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“methylmercury compounds”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “methylmercury compounds/pharmacology”[majr])) OR (“mercury isotopes/toxicity”[mh] OR “mercury isotopes/adverse effects”[mh] OR “mercury isotopes/poisoning”[mh] OR “mercury isotopes/pharmacokinetics”[mh] OR (“mercury isotopes”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercury isotopes”[mh] AND toxicokinetics[mh:noexp]) OR (“mercury isotopes/blood”[mh] OR “mercury isotopes/cerebrospinal fluid”[mh] OR “mercury isotopes/urine”[mh] OR “mercury isotopes/antagonists and inhibitors”[mh]) OR (“mercury isotopes/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercury isotopes”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercury isotopes/pharmacology”[majr])) OR (“organomercury compounds/toxicity”[mh] OR “organomercury compounds/adverse effects”[mh] OR “organomercury compounds/poisoning”[mh] OR “organomercury compounds/pharmacokinetics”[mh] OR (“organomercury compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“organomercury compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“organomercury compounds/blood”[mh] OR “organomercury compounds/cerebrospinal fluid”[mh] OR “organomercury compounds/urine”[mh] OR “organomercury compounds/antagonists and inhibitors”[mh]) OR (“organomercury compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“organomercury compounds”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “organomercury compounds/pharmacology”[majr]))) AND (2018/12/01:3000[edat] OR 2018/12/01:3000[crdat] OR 2018/12/01:3000[mhda] OR 2018/12/01:3000[dp]); (((“(acetato)phenylmercury”[tw] OR “(acetato-kappao)phenylmercury”[tw] OR “(acetato-o)phenylmercury”[tw] OR “(acetoxymercuri)benzene”[tw] OR “(acetoxymercurio)benzene”[tw] OR “acetic acid, mercuridi-”[tw] OR “acetic acid, mercury(2+) salt”[tw] OR “acetic acid, phenylmercury deriv.”[tw] OR “acetic acid, phenylmercury(ii) salt”[tw] OR “acetoxyphenylmercury”[tw] OR “benzene, (acetoxymercuri)-”[tw] OR “benzene, (acetoxymercurio)-”[tw] OR “bis(acetyloxy)mercury”[tw] OR “calochlor”[tw] OR “calomel”[tw] OR “chloromethylmercury”[tw] OR “cinnabar”[tw] OR “cinnabarite”[tw] OR “diacetoxymercury”[tw] OR “dichloromercury”[tw] OR “dimercury dichloride”[tw] OR “dimethylmercury”[tw] OR “fungche”[tw] OR “hydrargyrum”[tw] OR “mercuriacetate”[tw] OR “mercuric acetate”[tw] OR “mercuric bichloride”[tw] OR “mercuric chloride”[tw] OR “mercuric diacetate”[tw] OR “mercuric nitrate”[tw] OR “mercuric sulfide”[tw] OR “mercuric sulphide”[tw] OR “mercuridiacetic acid, ”[tw] OR “mercuriphenyl acetate”[tw] OR “mercurius 6a”[tw] OR “mercurous chloride”[tw] OR “mercury”[tw] OR “mercury(1+), methyl-”[tw] OR “mercury(2+) acetate”[tw] OR “mercury(2+) chloride”[tw] OR “mercury(2+) nitrate”[tw] OR “mercury(2+) sulfide”[tw] OR “mercury(i) chloride”[tw] OR “mercury(ii) acetate”[tw] OR “mercury(ii) acetate, phenyl-”[tw] OR “mercury(ii) chloride”[tw] OR “mercury(ii) nitrate”[tw] OR “mercury(ii) sulfide”[tw] OR “mercury, (acetato)phenyl-”[tw] OR “mercury, (acetato-kappao)phenyl-”[tw] OR “mercury, (acetato-o)phenyl-”[tw] OR “mercury, acetoxyphenyl-”[tw] OR “mercury, chloromethyl-”[tw] OR “mercury, dimethyl-”[tw] OR “mercuryl acetate”[tw] OR “mercurymethylchloride”[tw] OR “methyl mercuric chloride”[tw] OR “methyl mercuric(ii) chloride”[tw] OR “methyl meruric chloride”[tw] OR “methylmercuric chloride”[tw] OR “methylmercury”[tw] OR “methylmercury chloride”[tw] OR “methylmercury monochloride”[tw] OR “methylmercury(1+)”[tw] OR “methylmercury(ii) cation”[tw] OR “millon’s reagent”[tw] OR “monomercury sulfide”[tw] OR “monomethylmercury cation”[tw] OR “nitric acid, mercury(2+) salt”[tw] OR “nitric acid, mercury(ii) salt”[tw] OR “phenomercuric acetate”[tw] OR “phenyl mercuric acetate”[tw] OR “phenylmercuriacetate”[tw] OR “phenylmercuric acetate”[tw] OR “phenylmercury acetate”[tw] OR “phenylmercury(ii) acetate”[tw] OR “Anticon”[tw] OR “Celmer”[tw] OR “Femma”[tw] OR “Hexasan”[tw] OR “Hostaquick”[tw] OR “Kwiksan”[tw] OR “Lorophyn”[tw] OR “Parasan”[tw] OR “Phix”[tw] OR “Samtol”[tw] OR “Sanitol”[tw] OR “Sc-110”[tw] OR “Verdasan”[tw] OR “Volpar”[tw] OR “Caspan”[tw] OR “Liquid silver”[tw] OR “Quick silver”[tw] OR “Quicksilver”[tw] OR “Sulem”[tw] OR “Agrosan D”[tw] OR “Agrosan GN 5”[tw] OR “Algimycin 200”[tw] OR “Antimucin WBR”[tw] OR “Antimucin WDR”[tw] OR “Bufen”[tw] OR “Bufen 30”[tw] OR “Cekusil”[tw] OR “Ceresol”[tw] OR “Contra Creme”[tw] OR “Dyanacide”[tw] OR “Fungicide R”[tw] OR “Fungitox OR”[tw] OR “Gallotox”[tw] OR “Hl-331”[tw] OR “Hong nien”[tw] OR “Hostaquik”[tw] OR “Intercide 60”[tw] OR “Intercide PMA 18”[tw] OR “Liquiphene”[tw] OR “Meracen”[tw] OR “Mercron”[tw] OR “Mercuron”[tw] OR “Mergal A 25”[tw] OR “Mersolite”[tw] OR “Metasol 30”[tw] OR “Neantina”[tw] OR “Norforms”[tw] OR “Nuodex PMA 18”[tw] OR “Nylmerate”[tw] OR “PMA (fungicide)”[tw] OR “Pamisan”[tw] OR “Panomatic”[tw] OR “Parasan (bactericide)”[tw] OR “Phenmad”[tw] OR “Programin”[tw] OR “Purasan-SC-10”[tw] OR “Puraturf 10”[tw] OR “Quicksan”[tw] OR “Quicksan 20”[tw] OR “Riogen”[tw] OR “Ruberon”[tw] OR “Sanitized SPG”[tw] OR “Sanmicron”[tw] OR “Scutl”[tw] OR “Seed Dressing R”[tw] OR “Seedtox”[tw] OR “Setrete”[tw] OR “Shimmerex”[tw] OR “Spor-Kil”[tw] OR “Spruce Seal”[tw] OR “Tag (VAN)”[tw] OR “Tag 331”[tw] OR “Tag HL 331”[tw] OR “Tag fungicide”[tw] OR “Trigosan”[tw] OR “Troysan 30”[tw] OR “Troysan PMA 30”[tw] OR “Zaprawa Nasienna R”[tw] OR “Ziarnik”[tw] OR “Hydraargyrum bichloratum”[tw] OR “Calo-Clor”[tw] OR “Calocure”[tw] OR “Calogreen”[tw] OR “Calotab”[tw] OR “Abavit B”[tw] OR “Citrine ointment”[tw] OR “Ethiops mineral”[tw] OR “Mercurius vivus”[tw] OR “beta-Mercuric sulfide”[tw] OR “Phenylquecksilberacetate”[tw] OR “Quecksilber(II)-sulfid, rotes”[tw] OR “Rotes Quecksilbersulfid”[tw] OR “Paragite”[tw] OR “TL 898”[tw]) NOT medline[sb])) AND (2018/12/01:3000[edat] OR 2018/12/01:3000[crdat] OR 2018/12/01:3000[dp]); (((7546-30-7[rn] OR 10031-18-2[rn] OR 7789-47-1[rn] OR 15385-58-7[rn] OR 628-86-4[rn] OR 7783-30-4[rn] OR 15385-57-6[rn] OR 7774-29-0[rn] OR 10415-75-5[rn] OR 14836-60-3[rn] OR 15829-53-5[rn] OR 21908-53-2[rn] OR 20601-83-6[rn] OR 11138-42-4[rn] OR 7783-36-0[rn] OR 7783-35-9[rn] OR 12068-90-5[rn] OR 592-04-1[rn] OR 631-60-7[rn] OR 14302-87-5[rn] OR 22542-11-6[rn]) AND ((“mercury/toxicity”[mh] OR “mercury/adverse effects”[mh] OR “mercury/poisoning”[mh] OR “mercury/pharmacokinetics”[mh] OR (“mercury”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercury”[mh] AND toxicokinetics[mh:noexp]) OR (“mercury/blood”[mh] OR “mercury/cerebrospinal fluid”[mh] OR “mercury/urine”[mh] OR “mercury/antagonists and inhibitors”[mh]) OR (“mercury/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercury”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercury/pharmacology”[majr])) OR (“phenylmercuric acetate/toxicity”[mh] OR “phenylmercuric acetate/adverse effects”[mh] OR “phenylmercuric acetate/poisoning”[mh] OR “phenylmercuric acetate/pharmacokinetics”[mh] OR (“phenylmercuric acetate”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“phenylmercuric acetate”[mh] AND toxicokinetics[mh:noexp]) OR (“phenylmercuric acetate/blood”[mh] OR “phenylmercuric acetate/cerebrospinal fluid”[mh] OR “phenylmercuric acetate/urine”[mh] OR “phenylmercuric acetate/antagonists and inhibitors”[mh]) OR (“phenylmercuric acetate/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“phenylmercuric acetate”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “phenylmercuric acetate/pharmacology”[majr])) OR (“mercuric chloride/toxicity”[mh] OR “mercuric chloride/adverse effects”[mh] OR “mercuric chloride/poisoning”[mh] OR “mercuric chloride/pharmacokinetics”[mh] OR (“mercuric chloride”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercuric chloride”[mh] AND toxicokinetics[mh:noexp]) OR (“mercuric chloride/blood”[mh] OR “mercuric chloride/cerebrospinal fluid”[mh] OR “mercuric chloride/urine”[mh] OR “mercuric chloride/antagonists and inhibitors”[mh]) OR (“mercuric chloride/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercuric chloride”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercuric chloride/pharmacology”[majr])) OR (“cinnabar”[tw] OR “mercuric sulfide”[tw] OR “mercuric sulphide”[tw] OR “mercury (ii) sulfide”[tw] OR “mercury monosulfide”[tw] OR “mercury sulfide”[tw] OR “mercury sulphide”[tw] OR “mercury(2+) sulfide”[tw] OR “mercury(ii) sulfide”[tw] OR “monomercury sulfide”[tw] OR “Mercury poisoning”[mh]))) OR ((7546-30-7[rn] OR 10031-18-2[rn] OR 7789-47-1[rn] OR 15385-58-7[rn] OR 628-86-4[rn] OR 7783-30-4[rn] OR 15385-57-6[rn] OR 7774-29-0[rn] OR 10415-75-5[rn] OR 14836-60-3[rn] OR 15829-53-5[rn] OR 21908-53-2[rn] OR 20601-83-6[rn] OR 11138-42-4[rn] OR 7783-36-0[rn] OR 7783-35-9[rn] OR 12068-90-5[rn] OR 592-04-1[rn] OR 631-60-7[rn] OR 14302-87-5[rn] OR 22542-11-6[rn]) AND ((“mercury compounds/toxicity”[mh] OR “mercury compounds/adverse effects”[mh] OR “mercury compounds/poisoning”[mh] OR “mercury compounds/pharmacokinetics”[mh] OR (“mercury compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercury compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“mercury compounds/blood”[mh] OR “mercury compounds/cerebrospinal fluid”[mh] OR “mercury compounds/urine”[mh] OR “mercury compounds/antagonists and inhibitors”[mh]) OR (“mercury compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercury compounds”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercury compounds/pharmacology”[majr])) OR (“methylmercury compounds/toxicity”[mh] OR “methylmercury compounds/adverse effects”[mh] OR “methylmercury compounds/poisoning”[mh] OR “methylmercury compounds/pharmacokinetics”[mh] OR (“methylmercury compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“methylmercury compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“methylmercury compounds/blood”[mh] OR “methylmercury compounds/cerebrospinal fluid”[mh] OR “methylmercury compounds/urine”[mh] OR “methylmercury compounds/antagonists and inhibitors”[mh]) OR (“methylmercury compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“methylmercury compounds”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “methylmercury compounds/pharmacology”[majr])) OR (“mercury isotopes/toxicity”[mh] OR “mercury isotopes/adverse effects”[mh] OR “mercury isotopes/poisoning”[mh] OR “mercury isotopes/pharmacokinetics”[mh] OR (“mercury isotopes”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“mercury isotopes”[mh] AND toxicokinetics[mh:noexp]) OR (“mercury isotopes/blood”[mh] OR “mercury isotopes/cerebrospinal fluid”[mh] OR “mercury isotopes/urine”[mh] OR “mercury isotopes/antagonists and inhibitors”[mh]) OR (“mercury isotopes/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“mercury isotopes”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “mercury isotopes/pharmacology”[majr])) OR (“organomercury compounds/toxicity”[mh] OR “organomercury compounds/adverse effects”[mh] OR “organomercury compounds/poisoning”[mh] OR “organomercury compounds/pharmacokinetics”[mh] OR (“organomercury compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“organomercury compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“organomercury compounds/blood”[mh] OR “organomercury compounds/cerebrospinal fluid”[mh] OR “organomercury compounds/urine”[mh] OR “organomercury compounds/antagonists and inhibitors”[mh]) OR (“organomercury compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“organomercury compounds”[majr] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR “organomercury compounds/pharmacology”[majr]))))) AND (2018/12/01:3000[edat] OR 2018/12/01:3000[crdat] OR 2018/12/01:3000[mhda] OR 2018/12/01:3000[dp]); (“Cyclosan”[tw] OR “Mercurous iodide”[tw] OR “Mercury telluride”[tw] OR “Mercury hydride”[tw] OR “Mercurane”[tw] OR “Mercury bromide”[tw] OR “Mercury iodide”[tw] OR “Mercury oxide”[tw] OR “Mercuric selenide”[tw] OR “Mercury cyanide”[tw] OR (“Mercury chloride”[tw] NOT “mercuric chloride”[mh])) OR ((“Cyclosan”[tw] OR “Mercury chloride”[tw] OR “Mercury bromide”[tw] OR “Mercuric bromide”[tw] OR “Mercuric dibromide”[tw] OR “Mercury dibromide”[tw] OR “Mercury(II) bromide”[tw] OR “Mercury fulminate”[tw] OR “Mercurous iodide”[tw] OR “Mercuric iodide”[tw] OR “Mercury iodide”[tw] OR “Mercury(II) iodide”[tw] OR “Mercuric oxide”[tw] OR “Mercury oxide”[tw] OR “Red Precipitate”[tw] OR “Yellow precipitate”[tw] OR “Mercuric selenide”[tw] OR “Mercury selenide”[tw] OR “Mercury-selenium complex”[tw] OR “Mercurous sulfate”[tw] OR “Mercury(I) sulfate”[tw] OR “Mercuric sulfate”[tw] OR “Mercuric sulphate”[tw] OR “Mercury sulfate”[tw] OR “Mercury sulphate”[tw] OR “Mercury telluride”[tw] OR “Mercuric cyanide”[tw] OR “Mercurius cyanatus”[tw] OR “Mercury cyanide”[tw] OR “Mercury hydride”[tw] OR “Mercurane”[tw] OR “Mercuric cation”[tw] OR “Mercuric cations”[tw] OR “Mercuric ion”[tw] OR “Mercuric ions”[tw]) NOT medline[sb]) AND (2018/12/01:3000[edat] OR 2018/12/01:3000[crdat] OR 2018/12/01:3000[mhda] OR 2018/12/01:3000[dp]); 13966-62-6[rn] OR 72172-67-9[rn]
NTRL
10/2023 | 2018-present, Titles or Keywords; “mercuric” OR “mercurous” OR “mercury” OR “methylmercury” OR “methylmercuric” OR “phenylmercury” OR “phenylmercuric” OR “ethylmercury” OR “ethylmercuric” OR “calomel” OR “cinnabar” OR “Hg”; “(acetato)phenylmercury” OR “(acetato-kappao)phenylmercury” OR “(acetato-o)phenylmercury” OR “(acetoxymercuri)benzene” OR “(acetoxymercurio)benzene” OR “acetic acid, mercuridi-” OR “acetic acid, mercury(2+) salt” OR “acetic acid, phenylmercury deriv.” OR “acetic acid, phenylmercury(ii) salt” OR “acetoxyphenylmercury” OR “benzene, (acetoxymercuri)-” OR “benzene, (acetoxymercurio)-” OR “bis(acetyloxy)mercury” OR “calochlor” OR “calomel” OR “chloromethylmercury” OR “cinnabar” OR “cinnabarite” OR “diacetoxymercury” OR “dichloromercury” OR “dimercury dichloride” OR “dimethylmercury” OR “fungche” OR “hydrargyrum” OR “mercuriacetate” OR “mercuric acetate” OR “mercuric bichloride” OR “mercuric chloride” OR “mercuric diacetate” OR “mercuric nitrate” OR “mercuric sulfide” OR “mercuric sulphide” OR “mercuridiacetic acid, ” OR “mercuriphenyl acetate” OR “mercurius 6a” OR “mercurous chloride” OR “mercury(1+), methyl-” OR “mercury(2+) acetate” OR “mercury(2+) chloride” OR “mercury(2+) nitrate” OR “mercury(2+) sulfide” OR “mercury(i) chloride” OR “mercury(ii) acetate” OR “mercury(ii) acetate, phenyl-” OR “mercury(ii) chloride” OR “mercury(ii) nitrate” OR “mercury(ii) sulfide” OR “mercury, (acetato)phenyl-”; “mercury, (acetato-kappao)phenyl-” OR “mercury, (acetato-o)phenyl-” OR “mercury, acetoxyphenyl-” OR “mercury, chloromethyl-” OR “mercury, dimethyl-” OR “mercuryl acetate” OR “mercurymethylchloride” OR “methyl mercuric chloride” OR “methyl mercuric(ii) chloride” OR “methyl meruric chloride” OR “methylmercuric chloride” OR “methylmercury” OR “methylmercury chloride” OR “methylmercury monochloride” OR “methylmercury(1+)” OR “methylmercury(ii) cation” OR “millon’s reagent” OR “monomercury sulfide” OR “monomethylmercury cation” OR “nitric acid, mercury(2+) salt” OR “nitric acid, mercury(ii) salt” OR “phenomercuric acetate” OR “phenyl mercuric acetate” OR “phenylmercuriacetate” OR “phenylmercuric acetate” OR “phenylmercury acetate” OR “phenylmercury(ii) acetate” OR “Anticon” OR “Celmer” OR “Femma” OR “Hexasan” OR “Hostaquick” OR “Kwiksan” OR “Lorophyn” OR “Parasan” OR “Phix” OR “Samtol” OR “Sanitol” OR “Sc-110” OR “Verdasan” OR “Volpar” OR “Caspan” OR “Liquid silver” OR “Quick silver” OR “Quicksilver” OR “Sulem” OR “Agrosan D” OR “Agrosan GN 5” OR “Algimycin 200” OR “Antimucin WBR” OR “Antimucin WDR” OR “Bufen”; “Bufen 30” OR “Cekusil” OR “Ceresol” OR “Contra Creme” OR “Dyanacide” OR “Fungicide R” OR “Fungitox OR” OR “Gallotox” OR “Hl-331” OR “Hong nien” OR “Hostaquik” OR “Intercide 60” OR “Intercide PMA 18” OR “Liquiphene” OR “Meracen” OR “Mercron” OR “Mercuron” OR “Mergal A 25” OR “Mersolite” OR “Metasol 30” OR “Neantina” OR “Norforms” OR “Nuodex PMA 18” OR “Nylmerate” OR “PMA (fungicide)” OR “Pamisan” OR “Panomatic” OR “Parasan (bactericide)” OR “Phenmad” OR “Programin” OR “Purasan-SC-10” OR “Puraturf 10” OR “Quicksan” OR “Quicksan 20” OR “Riogen” OR “Ruberon” OR “Sanitized SPG” OR “Sanmicron” OR “Scutl” OR “Seed Dressing R” OR “Seedtox” OR “Setrete” OR “Shimmerex” OR “Spor-Kil” OR “Spruce Seal” OR “Tag (VAN)” OR “Tag 331” OR “Tag HL 331” OR “Tag fungicide” OR “Trigosan” OR “Troysan 30” OR “Troysan PMA 30” OR “Zaprawa Nasienna R” OR “Ziarnik” OR “Hydraargyrum bichloratum” OR “Calo-Clor” OR “Calocure” OR “Calogreen” OR “Calotab” OR “Abavit B” OR “Citrine ointment” OR “Ethiops mineral” OR “Mercurius vivus” OR “beta-Mercuric sulfide” OR “Phenylquecksilberacetate” OR “Quecksilber(II)-sulfid, rotes” OR “Rotes Quecksilbersulfid” OR “Paragite” OR “TL 898”
Toxcenter
10/2023 | FILE ‘TOXCENTER’ ENTERED AT 15:45:28 ON 09 OCT 2023; CHARGED TO COST=EH038.10.02.LB.05; L1 149470 SEA 7439-97-6; L2 31298 SEA 7487-94-7 OR 1344-48-5 OR 10112-91-1 OR 1600-27-7 OR 115-09-3 OR 593-74-8 OR 62-38-4 OR 22967-92-6 OR 10045-94-0 OR 19122-79-3 OR 7546-30-7 OR 10031-18-2 OR 7789-47-1 OR 15385-58-7 OR 628-86-4; L3 9164 SEA 7783-30-4 OR 15385-57-6 OR 7774-29-0 OR 10415-75-5 OR 14836-60-3 OR 15829-53-5 OR 21908-53-2 OR 20601-83-6 OR 11138-42-4 OR 7783-36-0 OR 7783-35-9 OR 12068-90-5 OR 592-04-1 OR 631-60-7 OR 14302-87-5 OR 22542-11-6; L4 175436 SEA L1 OR L2 OR L3; L5 6694 SEA L4 AND ED>=20220926; L6 6201 SEA L5 NOT PATENT/DT; L7 6201 SEA L6 AND PY>1997; L8 6 SEA 13966-62-6 OR 72172-67-9; L9 0 SEA L8 AND ED>=20220926; ACT TOXQUERY/Q; -------; L10 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L11 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,; IT); L12 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L13 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L14 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L15 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L16 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR; DIETARY OR DRINKING(W)WATER?); L17 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L18 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L19 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR; OVUM?); L20 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L21 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L22 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L23 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR; SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L24 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L25 QUE (ENDOCRIN? AND DISRUPT?); L26 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L27 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L28 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L29 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR; NEOPLAS?); L30 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L31 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L32 QUE (NEPHROTOX? OR HEPATOTOX?); L33 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L34 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L35 QUE L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32 OR L33 OR L34; L36 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE; OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE; OR PORCINE OR MONKEY? OR MACAQUE?); L37 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L38 QUE L35 OR L36 OR L37; L39 QUE (NONHUMAN MAMMALS)/ORGN; L40 QUE L38 OR L39; L41 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR; PRIMATES OR PRIMATE?); L42 QUE L40 OR L41; -------; L43 3744 SEA L7 AND L42; L44 760 SEA L43 AND MEDLINE/FS; L45 1704 SEA L43 NOT CAPLUS/FS; L46 944 SEA L45 NOT L44; L47 1456 DUP REM L44 L46 (248 DUPLICATES REMOVED) D SCAN L47
9/2022 | FILE ‘TOXCENTER’ ENTERED AT 15:30:27 ON 26 SEP 2022; CHARGED TO COST=EH038.10.02.LB.05; L1 143154 SEA FILE=TOXCENTER 7439-97-6; L2 30530 SEA FILE=TOXCENTER 7487-94-7 OR 1344-48-5 OR 10112-91-1 OR 1600-27-7 OR 115-09-3 OR 593-74-8 OR 62-38-4 OR 22967-92-6 OR 10045-94-0 OR 19122-79-3 OR 7546-30-7 OR 10031-18-2 OR 7789-47-1 OR 15385-58-7 OR 628-86-4; L3 8428 SEA FILE=TOXCENTER 7783-30-4 OR 15385-57-6 OR 7774-29-0 OR 10415-75-5 OR 14836-60-3 OR 15829-53-5 OR 21908-53-2 OR 20601-83-6 OR 11138-42-4 OR 7783-36-0 OR 7783-35-9 OR 12068-90-5 OR 592-04-1 OR 631-60-7 OR 14302-87-5 OR 22542-11-6; L4 168057 SEA FILE=TOXCENTER L1 OR L2 OR L3; L5 151731 SEA FILE=TOXCENTER L4 NOT PATENT/DT; L6 151635 SEA FILE=TOXCENTER L5 NOT TSCATS/FS; L7 22428 SEA FILE=TOXCENTER L6 AND ED>=20181201; L8 22411 SEA FILE=TOXCENTER L7 AND PY>1997; L9 6 SEA FILE=TOXCENTER 13966-62-6 OR 72172-67-9; L10 4 SEA FILE=TOXCENTER L9 AND PY>1997 D SCAN L10; L11 3 SEA FILE=TOXCENTER L10 NOT 7439-97-6; ACT TOXQUERY/Q; -------; L12 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L13 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,; IT); L14 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L15 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L16 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L17 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L18 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR; DIETARY OR DRINKING(W)WATER?); L19 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L20 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L21 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR; OVUM?); L22 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L23 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L24 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR; SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L25 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR; SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L26 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L27 QUE (ENDOCRIN? AND DISRUPT?); L28 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L29 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L30 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L31 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR; NEOPLAS?); L32 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L33 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L34 QUE (NEPHROTOX? OR HEPATOTOX?); L35 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L36 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L37 QUE L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32 OR L33 OR L34 OR L35 OR L36; L38 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE; OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE; OR PORCINE OR MONKEY? OR MACAQUE?); L39 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L40 QUE L37 OR L38 OR L39; L41 QUE (NONHUMAN MAMMALS)/ORGN; L42 QUE L40 OR L41; L43 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR; PRIMATES OR PRIMATE?); L44 QUE L42 OR L43; -------; L53 13117 SEA FILE=TOXCENTER L8 AND L44; L54 6220 SEA FILE=TOXCENTER L53 NOT CAPLUS/FS; L55 2389 SEA FILE=TOXCENTER L54 AND MEDLINE/FS; L56 3831 SEA FILE=TOXCENTER L54 NOT L55; L57 5347 DUP REM L55 L56 (873 DUPLICATES REMOVED); L*** DEL 2389 S L54 AND MEDLINE/FS; L*** DEL 2389 S L54 AND MEDLINE/FS; L58 2389 SEA FILE=TOXCENTER L57; L*** DEL 3831 S L54 NOT L55; L*** DEL 3831 S L54 NOT L55; L59 2958 SEA FILE=TOXCENTER L57; L60 2958 SEA FILE=TOXCENTER (L58 OR L59) NOT MEDLINE/FS; L61 21 SEA FILE=TOXCENTER L52 NOT L60; L62 577 SEA FILE=TOXCENTER L60 NOT L52 D SCAN L60

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
10/2023 | No date limit; Compounds searched: 7439-97-6; 7487-94-7; 1344-48-5; 10112-91-1; 1600-27-7; 115-09-3; 593-74-8; 62-38-4; 22967-92-6; 10045-94-0; 19122-79-3; 7546-30-7; 10031-18-2; 7789-47-1; 15385-58-7; 628-86-4; 7783-30-4; 15385-57-6; 7774-29-0; 10415-75-5; 14836-60-3; 15829-53-5; 21908-53-2; 20601-83-6; 11138-42-4; 7783-36-0; 7783-35-9; 12068-90-5; 592-04-1; 631-60-7; 14302-87-5; 22542-11-6; 13966-62-6; 72172-67-9
NTP
10/2023 | Terms searched; exact word or phrase; 2018-present:; mercuric; mercurous; mercury; methylmercury; methylmercuric; phenylmercury; phenylmercuric; ethylmercury; ethylmercuric; calomel; cinnabar; 7439-97-6; 7487-94-7; 1344-48-5; 10112-91-1; 1600-27-7; 115-09-3; 593-74-8; 62-38-4; 22967-92-6; 10045-94-0; 19122-79-3; 7546-30-7; 10031-18-2; 7789-47-1; 15385-58-7; 628-86-4; 7783-30-4; 15385-57-6; 7774-29-0; 10415-75-5; 14836-60-3; 15829-53-5; 21908-53-2; 20601-83-6; 11138-42-4; 7783-36-0; 7783-35-9; 12068-90-5; 592-04-1; 631-60-7; 14302-87-5; 22542-11-6; 13966-62-6; 72172-67-9
Regulations.gov
10/2023 | Terms searched: “mercuric”; “mercurous”; “mercury”; “methylmercury”; “methylmercuric”; “phenylmercury”; “phenylmercuric”; “ethylmercury”; “ethylmercuric”; “calomel”; “cinnabar”; “7439-97-6”; “7487-94-7”; “1344-48-5”; “10112-91-1”; “1600-27-7”; “115-09-3”; “593-74-8”; “62-38-4”; “22967-92-6”; “10045-94-0”; “19122-79-3”; “7546-30-7”; “10031-18-2”; “7789-47-1”; “15385-58-7”; “628-86-4”; “7783-30-4”; “15385-57-6”; “7774-29-0”; “10415-75-5”; “14836-60-3”; “15829-53-5”; “21908-53-2”; “20601-83-6”; “11138-42-4”; “7783-36-0”; “7783-35-9”; “12068-90-5”; “592-04-1”; “631-60-7”; “14302-87-5”; “22542-11-6”; “13966-62-6”; “72172-67-9”
NIH RePORTER
3/2024 | Search Criteria; Fiscal Year: Active Projects; Text Search: “mercuric” OR “mercurous” OR “mercury” OR “methylmercury” OR “methylmercuric” OR “phenylmercury” OR “phenylmercuric” OR “ethylmercury” OR “ethylmercuric” OR “calomel” OR “cinnabar” (advanced); Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2023 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 9,880
- Number of records identified from other strategies: 113
- Total number of records to undergo literature screening: 9,993

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on mercury:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 9,993
- Number of studies considered relevant and moved to the next step: 929

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 929
- Number of studies cited in the pre-public draft of the toxicological profile: 1,614
- Total number of studies cited in the profile: 1,895

Prioritization of Human Data. Due to the extent of the literature database, it is not practical or realistic to cite all, or even most, of the studies on health effects of mercury. This profile is not to provide a comprehensive review of all literature; instead, the purpose and scope of this profile is to summarize the major lines of evidence regarding health effects associated with environmental and occupational exposure to mercury compounds. Therefore, human data were prioritized for inclusion as follows:

- Epidemiological studies of environmental and occupational exposures were only considered for inclusion if they were well-conducted and reported and included the following: measurements of mercury intakes or biomarker data, measures of variance for outcome metrics, and reported methods for addressing confounding.
  ○ Exception: Studies of mercury poisoning outbreaks that lacked biomonitoring data but provided critical hazard identification information (e.g., Minamata disease)
- Human studies reporting health effects associated with consumer or medicinal products containing mercury (e.g., vaccines) were excluded, as these studies are not focused on sources of environmental or occupational exposure.
- Case reports were not included in the profile due to the extensive number of available epidemiological studies.
  ○ Exception 1: Case reports that included discussion of acute-duration accidental or intentional exposure to near-fatal or fatal levels of mercury
  ○ Exception 2: Case reports that described portal-of-entry effects following acute-duration exposures

Quality criteria were considered in selecting studies to include in the mercury profile and, in particular, for consideration as support for MRLs. In general, epidemiological studies that attempted dose-response assessments (e.g., regression models) were included in the profile if the following criteria were met: (1) reported estimates of variance in the dose-response metrics (e.g., SE, CL); (2) included adjustments for confounding; and (3) reported biomarker data. For studies used to derive MRLs, reporting of quality assurance of analytical methods was also required.

Prioritization of Animal Data

- All well-conducted and reported studies were considered for inclusion with a focus on routes of exposure most relevant to environmental exposure of humans (inhalation, oral, dermal).
- Parenteral studies were included only when needed to support understanding of mechanisms, but not for exposure-response relationships (since dose-response relationships observed following parenteral dosing may not accurately reflect exposure-response relationships).
- Animal studies focused on toxicity of traditional medicine or cultural uses of mercury-containing compounds (e.g., cinnabar) were excluded as not relevant to environmental exposures.

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 October 2023 Literature Search Results and Screen for Mercury