# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substances than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## Elemental mercury Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Elemental mercury
CAS Number: | 7439-97-6
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for elemental mercury.

Rationale for Not Deriving an MRL: No epidemiological studies investigating effects of acute-duration exposure to inhaled elemental mercury were identified. Acute-duration inhalation studies in humans are limited to accidental or intentional exposure to fatal or near-fatal levels of elemental mercury vapor.

Studies in rats and mice have identified several targets of toxicity including neurological alterations, neurodevelopmental effects, and renal effects. Acute-duration studies have also reported developmental outcome effects and reproductive effects in rats; however, given the limited number of studies reporting these effects, the data are insufficient to draw conclusions as to whether reproductive and developmental outcome effects are sensitive targets for elemental mercury. It is noted that the reported developmental and reproductive effects occur at higher elemental mercury concentrations than the neurological effects. Summaries of the lowest LOAELs for neurological, neurodevelopmental, renal, developmental, and reproductive endpoints are presented in Table A-1.

Table A-1 Selected NOAEL and LOAEL Values in Animals Acutely Exposed to Inhaled Elemental Mercury

Species | Duration | NOAEL/LOAEL (mg Hg/m^3^) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Neurodevelopmental
Rat | 7 days; PNDs 11–17; 1 hour/day; (WB) | ND | 0.05 | Increased spontaneous locomotion and total activity and decreased rearing counts at 4 months of age; impaired spatial learning at 6 months of age | Fredriksson et al. 1992
Rat | 7 days; PNDs 11–17; 4 hours/day; (WB) | ND | 0.05 | Increased spontaneous locomotion and total activity and decreased rearing counts at 2 months of age; decreased spontaneous locomotion, total activity, and rearing counts at 4 months of age; and impaired spatial learning at 6 months of age | Fredriksson et al. 1992
Rat | 6 days; GDs 14–19; 1.5 hours/day; (WB) | ND | 1.8 | Increased spontaneous locomotion, rearing, and total activity at 4 months of age; impaired spatial learning | Fredriksson et al. 1996
Rat | 8 days; GDs 11–14 + GDs 17–20; 1 or 3 hours/day; (WB) | ND | 1.8 | Decreased spontaneous locomotion, rearing, and total activity at 3 months; reduced novel environment habituation at 7 months | Danielsson et al. 1993
Neurological
Mouse | 4 hours; (WB) | ND | 0.5 | Reduced grip strength 4–7 months post-exposure, decreased motor axon diameter 7 months post-exposure | Stankovic 2006
Rat | GDs 6–15; 2 hours/day; (N) | 4 | 8 | Mild tremor, lethargy, unsteady gait | Morgan et al. 2002
Reproductive
Rat | 11 days; 2 hours/day; (N) | 1 | 2 | Prolonged estrous cycle | Davis et al. 2001
Rat | 1–8 days; 2 hours/day; (N) | ND | 2 | Prolonged estrous cycle after 6–8 days exposure; immature corpora lutea during estrus and metestrus | Davis et al. 2001
Renal
Rat | GDs 6–15; 2 hours/day; (N) | 2 | 4 | Elevated maternal relative kidney weight (32% on GD 15); increased urinary protein (80%) and ALP (943%) | Morgan et al. 2002
Developmental
Rat | GDs 6–15; 2 hours/day; (N) | 4 | 8 | Increased resorptions, decreased litter size, decreased pup weight | Morgan et al. 2002

ALP = alkaline phosphatase; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; (N) = nose-only exposure; ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day; (WB) = whole-body exposure

The lowest LOAEL is 0.05 mg Hg/m^3^ for neurodevelopmental effects in rats exposed on PNDs 11–17 for 1 or 4 hours/day (Fredriksson et al. 1992). When the animals exposed for 4 hours/day were examined at 2 months of age, increased spontaneous locomotion and total activity and decreased rearing were observed. At 4 months of age, spontaneous locomotion and total activity were decreased in the group exposed for 4 hours/day and increased in the group exposed for 1 hour/day. At 6 months of age, impaired spatial learning was observed in the groups exposed for 1 and 4 hours/day. Similar effects were also observed in offspring of rats exposed to 1.8 mg Hg/m^3^ for 1.5 hours/day on GDs 14–19 and tested at 4 months of age (Fredriksson et al. 1996). Neurological effects consisting of reduced grip strength and decreased motor axon diameter were reported in adult mice 4–7 months after a single 4-hour exposure (Stankovic 2006). At higher concentrations, non-neurological effects such as prolonged estrus cycle (Davis et al. 2001), increased resorptions and decreased pup weight (Morgan et al. 2002), and evidence of renal damage (Morgan et al. 2002) were observed.

Although there is strong evidence from epidemiological studies involving chronic exposure and acute- and intermediate-duration animal studies supporting the identification of neurotoxicity/ neurodevelopmental toxicity as the critical effect, the acute-duration inhalation database was not considered adequate for derivation of an MRL. The Fredriksson et al. (1992) study, which identified the lowest LOAEL was not considered a suitable principal study for several reasons: (1) the daily exposure was short (1 or 4 hours/day) and there is uncertainty that the observed effects may not be predictive of continuous exposure; (2) the control group treatment was not identical to the exposed groups (i.e., the controls were placed in exposure chamber for 2 hours/day compared to 1 or 4 hours/day for the exposed groups); and (3) animals received whole-body exposure and no measures were taken to prevent mercury ingestion during preening or inhalation exposure from volatilization of mercury deposited on fur/skin.

Agency Contacts (Chemical Manager): Rae Benedict

## Elemental mercury Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Elemental mercury
CAS Number: | 7439-97-6
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for elemental mercury.

Rationale for Not Deriving an MRL: No intermediate-duration epidemiological studies were identified for elemental mercury. A number of animal studies have evaluated the toxicity of elemental mercury following intermediate-duration inhalation exposure. The results of these studies suggest that neurological and/or neurodevelopmental effects are the most sensitive outcomes. At higher concentrations, renal and male reproductive effects have also been reported. Neurological and/or neurodevelopmental effects observed in monkeys, rats, mice, and rabbits include decreased motor activity, impairments in learning and memory, and tremors (Fukuda 1971; Kishi et al. 1978; Newland et al. 1996; Yoshida et al. 2018). Renal effects include slight degenerative changes in the renal tubular epithelium (Kishi et al. 1978). The male reproductive effects included seminiferous tubule atrophy, and decreased spermatocyte and spermatids (Altunkaynak et al. 2015); it is noted that this is the only reproductive toxicity study on elemental mercury that examined male reproductive effects and the database is considered insufficient to draw conclusions.

Selected NOAEL and LOAEL values are presented in Table A-2. The lowest LOAEL is 0.188 mg Hg/m^3^ for decreased motor activity on PND 77 in the offspring of mice continuously exposed to elemental mercury on PNDs 2–28 (Yoshida et al. 2018); the study only tested one concentration (in addition to a control group). The study did not find alterations in passive avoidance tests or working memory tests. Earlier studies by this group found no alterations in motor activity, learning, or memory in the offspring of mice exposed to 0.03 mg Hg/m^3^ during GDs 0–18 (Yoshida et al. 2011) or in mice exposed to 0.057 mg Hg/m^3^ on PNDs 1–20 (Yoshida et al. 2013).

Table A-2 Selected NOAEL and LOAEL Values in Animals Exposed to Inhaled Elemental Mercury for Intermediate Durations

Species | Duration | NOAEL/LOAEL (mg Hg/m^3^) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Neurodevelopmental
Mouse | PNDs 2–28; 24 hours/day; (WB) | ND | 0.188 | Decreased motor activity at PND 77 | Yoshida et al. 2018
Monkey | 15–17 weeks gestational exposure; 5 days/week; 4 or 7 hours/day; (WB) | ND | 0.5 | Impaired operant training in offspring tested at 0.8–4 years of age | Newland et al. 1996
Mouse | GDs 0–18; 6 hours/day; (WB) | 0.03 | ND | No effect on motor activity, learning, or memory assessed on PND56 | Yoshida et al. 2011
Mouse | PNDs 1–20; 24 hours/day; (WB) | 0.057 | ND | No effect on motor activity, learning, or memory assessed at 3 or 15 months of age | Yoshida et al. 2013
Neurological
Rat | 8 weeks; 4–5 days/week; 5 hours/day; (WB) | ND | 0.5 | Irritability, aggressiveness; loss of Purkinje and granular cells in cerebellum | Sørensen et al. 2000
Reproductive
Rat | 6 weeks; 7 days/week; 9 hours/day; (WB) | ND | 1 | Seminiferous tubule atrophy; damage to spermatogenic cells; decreased testicular and seminiferous tubule volume, decreased seminiferous tubule diameter; decreased Sertoli cells, spermatogonia, spermatocytes, and spermatids | Altunkaynak et al. 2015
Renal
Rat | 12–42 weeks; 5 days/week; 3 hour/day; (WB) | ND | 3 | Slight degenerative changes (i.e., dense deposits in tubule cells and lysosomal inclusions) in the renal tubular epithelium | Kishi et al. 1978

GD = gestation day; LOAEL = lowest-observed-adverse-effect level ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day; (WB) = whole-body exposure

The intermediate-duration inhalation database for elemental mercury was not considered adequate for MRL derivation. Although several studies have identified NOAELs and LOAELs for neurodevelopmental effects (the presumed critical effect), most of the studies only tested a single concentration and the database was considered insufficient for establishing concentration-response relationships. It should also be noted that the highest NOAEL (0.057 mg Hg/m^3^) for the intermediate-duration database is similar to the lowest LOAEL (0.05 mg Hg/m^3^) identified for neurodevelopmental effects in the acute-duration inhalation database; this may be due to, but not limited to, species differences (mice versus rats) and/or differences in the study design (e.g., age at dosing and assessment, exposure duration, total exposure concentration, etc.).

Agency Contacts (Chemical Managers): Rae Benedict

## Elemental mercury Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Elemental mercury
CAS Number: | 7439-97-6
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic
MRL | 0.3 μg Hg/m^3^ (3×10^−4^ mg Hg/m^3^)
Critical Effect: | Tremors
Reference: | Bast-Pettersen et al. 2005; Boogaard et al. 1996; Chapman et al. 1990; Ellingsen et al. 2001; Fawer et al. 1983; Langworth et al. 1992a; Wastensson et al. 2006, 2008
Point of Departure: | 2.84 μg Hg/m^3^ (95% lower confidence limit of weighted median of seven principal studies)
Uncertainty Factor: | 10
LSE Graph Key: | 29
Species: | Human

MRL Summary: A chronic-duration inhalation MRL of 0.3 μg Hg/m^3^ was derived for elemental mercury based on tremors reported in several occupational exposure studies. The MRL is based on 2.84 μg Hg/m^3^, which is the 95% lower confidence limit of the weighted median of 4.92 μg Hg/m^3^ calculated using estimated air concentrations from seven studies, reported in eight publications (Bast-Pettersen et al. 2005; Boogaard et al. 1996; Chapman et al. 1990; Ellingsen et al. 2001; Fawer et al. 1983; Langworth et al. 1992a; Wastensson et al. 2006, 2008) and a total uncertainty factor of 10 for human variability.

Selection of the Critical Effect: The available information on the toxicity of elemental mercury vapor comes from numerous epidemiological studies of workers in the chloralkali, fluorescent lamp, lithium-6 purification, natural gas production, gold mining and processing, and thermometer industries and of dental workers. Most epidemiological studies used urinary mercury levels (expressed as μg Hg/L or μg Hg/g creatinine) as a biomarker of exposure, and some studies also provided work area or breathing zone mercury levels. Reported UHg levels were converted to equivalent exposure concentrations by applying a steady-state mass balance model (see the Calculation of Estimated Air Concentration section below for additional information). No reliable chronic-duration animal studies were identified.

The epidemiological studies provide consistent evidence of neurological effects, specifically alterations in color vision, tremor, nerve conduction velocity, and cognitive function. There is also suggestive evidence of renal effects, particularly glomerular function decrements and tubular injury from epidemiological studies. Neurotoxicity was selected as the critical effect based on the stronger weight of evidence supporting an association with elemental mercury exposure.

Over 35 epidemiological studies have evaluated neurological outcomes among workers exposed to mercury vapor; the most commonly assessed endpoints were decrements or loss in color vision, tremors, and alterations in motor speed and fine motor coordination, and cognitive function (memory, and integrative function), typically compared to a reference group. A list of the studies examining these neurological effects is presented in Table A-3. For each study, observed biomarkers of exposure (e.g., UHg) were converted to estimates of exposure air concentrations and categorized as either an adverse-effect level (AEL) if an adverse effect was observed or a no-adverse-effect level (NAEL) if no adverse effect was observed (Appendix E has for definitions of AEL and NAEL). The aggregate median AEL estimated air concentrations for the types of effects observed are similar, ranging from 8.8 to 13.9 μg Hg/m^3^ (for more details on how air concentrations were estimated, see the Calculation of Estimated Air Concentration section below).

Table A-3 Summary of Adverse Effect Levels for Neurological Effects Reported in Epidemiological Studies of Elemental Mercury

| Median (range) estimated air concentrations; (μg Hg/m^3^) | Number of exposed workers examined in each study | References
Color vision
NAEL | ND; (2.58) | 21 | Cavalleri and Gobba 1998
AEL | 8.76; (0.914–8.74) | 15–40 | Barboni et al. 2008, 2009; Canto-Pereira et al. 2005; Cavalleri and Gobba 1998; Urban et al. 2003; Ventura et al. 2005
Tremor
NAEL | 4.75; (0.914–8.74) | 43–200 | Bast-Pettersen et al. 2005; Boogaard et al. 1996; Ellingsen et al. 2001; Harari et al. 2012; Langworth et al. 1992a; Wastensson et al. 2006, 2008
AEL | 11.72; (0.422–63.1) | 15–13,905 | Albers et al. 1988; Anglen et al. 2015; Bittner et al. 1998; Chapman et al. 1990; Echeverria et al. 2005; Fawer et al. 1983; Frumkin et al. 2001; Harari et al. 2012; Iwata et al. 2007; Langolf et al. 1978; Letz et al. 2000; Miller et al. 1975; Roels et al. 1982; Tang and Li 2006; Verberk et al. 1986
Cognitive function
NAEL | 1.44; (0.072–4.57) | 49–550 | Bast-Pettersen et al. 2005; Factor-Litvak et al. 2003; Ritchie et al. 2002; Sletvold et al. 2012
AEL | 13.9; (0.405–30.5) | 26–426 | Bluhm et al. 1992; Echeverria et al. 1998, 2005; Mathiesen et al. 1999; Ngim et al. 1992; Piikivi and Hanninen 1989; Piikivi et al. 1984; Sletvold et al. 2012; Smith et al. 1983

AEL = adverse-effect level; NAEL = no-adverse-effect level

The tremor endpoint was selected as the critical effect because more studies (20 studies) with larger populations have evaluated tremor compared to color vision (5 studies). Alterations in cognitive function was not selected as the critical effect because the studies evaluated various domains of cognitive function and the number of studies evaluating similar domains is small, as compared to the number of studies evaluating tremors. The NAELs and AELs for the epidemiological studies evaluating tremors are presented in Table A-4.

Table A-4 NAEL and AEL Values for Epidemiological Studies Evaluating Tremor

Study | Population | Number of subjects | Estimated air concentration (μg Hg/m^3^)
Study | Population | Number of subjects | NAEL | AEL
Albers et al. 1988 | Lithium 6 workers | 247 | | 42.6
Anglen et al. 2015 | Dental workers | 13,906 | | 1.00
Bast-Pettersen et al. 2005 | Chloralkali workers | 49 | 4.57
Bittner et al. 1998 | Dental workers | 230 | | 11.7
Boogaard et al. 1996 | Gas production | 40 | 8.74
Chapman et al. 1990 | Chloralkali workers | 18 | | 4.92
Echeverria et al. 2005 | Dental workers | 427 | | 0.422
Ellingsen et al. 2001 | Chloralkali workers | 47 | 4.43
Fawer et al. 1983 | Lamp and chloralkali workers | 26 | | 5.57
Frumkin et al. 2001 | Chloralkali workers | 139 | | 18.7
Harari et al. 2012 | Gold miners | 200 | 0.914
Harari et al. 2012 | Gold merchants | 37 | | 10.2
Iwata et al. 2007 | Cinnabar miners and smelters | 27 | | 63.1
Langolf et al. 1978 | Chloralkali workers | 79 | | 51.1
Langworth et al. 1992a | Chloralkali workers | 85 | 7.03
Letz et al. 2000 | Lithium 6 workers | 104 | | 38.4
Miller et al. 1975 | Chloralkali workers | 77 | | 27.5
Roels et al. 1982 | Chloralkali workers | 43 | | 13.8
Tang and Li 2006 | Thermometer workers | 143 | | 10.7
Verberk et al. 1986 | Lamp workers | 20 | | 9.88
Wastensson et al. 2006, 2008 | Chloralkali workers | 43 | 4.90

AEL = adverse-effect level; NAEL = no-adverse-effect level

Selection of the Principal Study: Rather than selecting an individual study as the principal study, a group of seven studies, reported in eight publications, that provide information on the NAEL/AEL boundary were selected as the principal studies (see the Selection of the Point of Departure section for information on criteria for selecting these studies). Citations for the principal studies are listed below; summaries of these studies are included in Table A-5.

- Bast-Pettersen R, Ellingsen DG, Efskind J, . 2005. A neurobehavioral study of chloralkali workers after the cessation of exposure to mercury vapor. Neurotoxicology 26(3):427–437.15935213
- Boogaard PJ, Houtsma A-T AJ, Journée HL, . 1996. Effects of exposure to elemental mercury on the nervous system and the kidneys of workers producing natural gas. Arch Environ Health 51(2):108–115.8638960
- Chapman LJ, Sauter SL, Henning RA, . 1990. Differences in frequency of finger tremor in otherwise asymptomatic mercury workers. Br J Ind Med 47(12):838–843.2271392
- Ellingsen DG, Bast-Pettersen R, Efskind J, . 2001. Neuropsychological effects of low mercury vapor exposure in chloralkali workers. Neurotoxicology 22(2):249–258.11405256
- Fawer RF, DeRibaupierre Y, Guillemin M, . 1983. Measurement of hand tremor induced by industrial exposure to metallic mercury. Br J Ind Med 40:204–208.6830719
- Langworth S, Almkvist O, Soderman E, . 1992a. Effects of occupational exposure to mercury vapour on the central nervous system. Br J Ind Med 49(8):545–555.1515346
- Wastensson G, Lamoureux D, Sällsten G, . 2006. Quantitative tremor assessment in workers with current low exposure to mercury vapor. Neurotoxicol Teratol 28(6):681–693.17056227
- Wastensson, G, Lamoureux, D, Sallsten G, . 2008. Quantitative assessment of neuromotor function in workers with current low exposure to mercury vapor. Neurotoxicol 29(4):596–604.

Table A-5 Summary of the Principal Studies Examining Tremor in Workers Exposed to Elemental Mercury

Reference: Bast-Pettersen et al. 2005
Study type and population: Retrospective cohort of 49 former chloralkali workers and 49 referents from Norway. Average duration of exposure of workers was 13.1 years. Average time elapsed since exposure ceased was 4.8 years.
Biomarkers:
UHg working (average µg Hg/g Cr/year, range); - Referent: NA; - Exposed: 16.5 (7.1–45) | UHg at testing (mean µg Hg/g Cr, range); - Referent: 2.0 (0.6–5.7); - Exposed: 2.9 (0.4–9.2)
Estimated air concentration^a^: 4.57 µg Hg/m^3^ (based on exposed working average)
Analysis: Subjects were excluded for history of alcohol abuse, major head injuries; or metabolic, major psychiatric or neurological disease that caused severe disability. Data were analyzed using ANOVA for comparison of means between exposure groups and referents.
Results:
Mean (range) of tremor intensity (m/s^2^); - Dominant hand, NS; ○ Exposed: 0.12 (0.07–0.33); ○ Referent: 0.13 (0.07–0.40); ○ Mean ratio: 0.96 (95% CI 0.85, 1.10); - Non-dominant hand, NS; ○ Exposed: 0.12 (0.07–0.31); ○ Referent: 0.12 (0.06–0.51); ○ Mean ratio: 1.01 (95% CI 0.87, 1.17); Mean (range) of frequency dispersion (Hz); - Dominant hand, NS; ○ Exposed: 2.9 (1.2–4.4); ○ Referent: 2.8 (0.9–4.3); ○ Mean difference: 0.1 (95% CI −0.2, 0.4); - Non-dominant hand, NS; ○ Exposed: 3.3 (1.0–4.9); ○ Referent: 3.3 (1.1–6.4); ○ Mean difference: 0 (95% CI −0.3, 0.3) | Mean (range) of center frequency (Hz); - Dominant hand, NS; ○ Exposed: 7.4 (6.0–9.6); ○ Referent: 7.5 (5.8–10.6); ○ Mean difference: −0.1 (95% CI −0.5, 0.3); - Non-dominant hand, NS; ○ Exposed: 7.6 (5.9–10.8); ○ Referent: 7.4 (2.4–9.9); ○ Mean difference: 0.2 (95% CI −0.3, 0.6); Mean (range) of harmonic index; - Dominant hand, NS; ○ Exposed: 0.92 (0.80–0.97); ○ Referent: 0.91 (0.82–0.98); ○ Mean difference: 0.01 (95% CI −0.01, 0.02); - Non-dominant hand, NS; ○ Exposed: 0.89 (0.82–0.98); ○ Referent: 0.89 (0.78–0.97); ○ Mean difference: 0 (95% CI −0.02, 0.02)
Interpretation: Tremor was not significantly different between exposed and referent groups; therefore, the working mean UHg in the exposed group (16.5 µg/g Cr) was considered to be a NAEL for tremor. The equivalent air mercury concentration (4.57 µg Hg/m^3^) was weighted by the number of subjects in the exposed group (49).
Reference: Boogaard et al. 1996
Study type and population: Retrospective cohort of 40 natural gas workers (18 with “high” exposure; 22 with “low” exposure) and 19 referents from the Netherlands. Median (range) exposure time for high- and low-exposure workers was 9 years (1–15 years) and 10 years (3–20 years), respectively. Time elapsed since exposure ceased was not reported.
Biomarkers:
UHg working (median µg Hg/L, range); - Referent: 3 (1–8); - High exposure: 41 (7–72); - Low exposure: 12 (7–53) | UHg at testing (median µg Hg/L, range); - Referent: 2 (0.5–6.8); - High exposure: 17 (3.5–71.9); - Low exposure: 5 (0.6–8.8)
Estimated air concentration^a^: 8.74 µg Hg/m^3^ (based on high working median)
Analysis: Subjects were excluded for history of nonoccupational neuropathies or disorders with potential renal sequelae. Data were analyzed using MANOVA for comparison of means between exposure groups and referents. Multivariate regression analysis was performed for the entire population (referents plus exposed).
Results:
Mean (median; range) of resting tremor; - Right hand, NS; ○ High exposed: 6.49 (6.5; 1.4–10.3); ○ Low exposed: 6.45 (5.95; 2.3–10.2); ○ Referent: 6.34 (6.0; 3.9–9.2); - Left hand, NS; ○ High exposed: 5.94 (4.9; 2.9–10.4); ○ Low exposed: 6.60 (6.8; 2.9–10.5); ○ Referent: 6.64 (6.8; 3.6–10.1); Mean (median; range) of action tremor; - Right hand, NS; ○ High exposed: 6.61 (7.05; 2.2–10.3) (lower end of range reported as 97.05); ○ Low exposed: 7.39 (7.4; 2.0–12.3); ○ Referent: 6.67 (7.5; 2.4–9.0); - Left hand, NS; ○ High exposed: 6.76 (6.8; 2.3–12.0; ○ Low exposed: 7.75 (7.55; 1.6–11.4); ○ Referent: 7.00 (7.7; 2.5–9.5) | Mean (median; range) of intention tremor; - Right hand, NS; ○ High exposed: 5.09 (4.85; 3.9–8.0); ○ Low exposed: 5.38 (5.2; 3.7–10.8); ○ Referent: 5.22 (5.2; 3.9–6.7); - Left hand, NS; ○ High exposed: 5.15 (4.9; 4.2–8.0); ○ Low exposed: 5.50 (5.3; 4.2–10.6); ○ Referent: 5.39 (5.6; 3.9–6.2); No significant correlation between tremor measures and present or historical UHg levels (data not shown).
Interpretation: No significant association between UHg and tremor; therefore, the working median UHg in the high exposure group (41 µg/L) is a NAEL for tremor. The equivalent air mercury concentration (8.74 µg Hg/m^3^) was weighted by the number of subjects in the high exposure group (40).
Reference: Chapman et al. 1990
Study type and population: Cross-sectional cohort of 18 mercury battery workers and 18 referents from the United States. Average exposure time (range) for workers was 5.3 (0.3–32) years.
Biomarkers:; UHg at testing (mean µg Hg/L, SD); - Exposed: 23.1 (28.3); - Referent: Not measured
Estimated air concentration^a^: 4.92 µg Hg/m^3^
Analysis: Subjects were excluded for previous or current injuries or illnesses with neuropathic potential and neurotoxic drug or chemical exposures. Data were analyzed using non-parametric Mann-Whitney test to compare means between exposed and referent subjects, adjusted for the four comparison metrics.
Results:
Mean (SD) of hand tremor amplitude, NS; - Exposed: 35.6 (2.5); - Referent: 23.0 (6.5); Mean (SD) of hand tremor power, p<0.01; - Exposed: 315.0 (37.0); - Referent: 68.0 (5.0) | Mean (SD) of hand tremor half power frequency, NS; - Exposed: 7.8 (0.9) Hz; - Referent: 7.5 (0.6) Hz; Mean (SD) of tremor highest band power (5–15 Hz), p<0.001; - Exposed: 2.6 (2.3); - Referent: 1.5 (0.6)
Interpretation: Tremor was significantly higher in the exposed group; therefore, the mean UHg in the exposed group (23.1 µg/L) is an AEL for tremor. The equivalent air mercury concentration (4.92 µg Hg/m^3^) was weighted by the number of subjects in the exposed group (18).
Reference: Ellingsen et al. 2001
Study type and population: Retrospective cohort of 47 former chloralkali workers exposed for at least one year, and 47 referents; from Norway. Average exposure duration of 13.3 years.
Biomarkers:
UHg working (average µg Hg/g Cr/year, range); - Referent: NA; - Exposed: 16.0 (7.1–35) | UHg at testing (mean µg Hg/g Cr, range); - Referent: 2.3 (0.4–8.9); - Exposed: 10.5 (2.0–30)
Estimated air concentration^a^: 4.43 µg Hg/m^3^ (exposed)
Analysis: Subjects were excluded for alcohol abuse, major heads injuries; or metabolic, psychiatric, neurologic or other diseases causing severe disability. Data on intentional hand steadiness were analyzed by ANOVA of means between exposed and referents.
Results:
Mean (SD) of static steadiness (number of hits); - Dominant hand, NS; ○ Exposed: 126.5 (113.3); ○ Referent: 123.4 (117.0); - Non-dominant hand, NS; ○ Exposed: 112.5 (71.6); ○ Referent: 120.0 (90.7) | Mean (SD) of static steadiness (duration of hits, s); - Dominant hand, NS; ○ Exposed: 7.2 (5.5); ○ Referent: 6.8 (4.4); - Non-dominant hand, NS; ○ Exposed: 7.6 (5.0); ○ Referent: 7.9 (5.1)
Interpretation: Tremor was not significantly different between exposed and referent groups; therefore, the working mean UHg in the exposed group (16.0 µg/g Cr) is a NAEL for tremor. The equivalent air mercury concentration (4.43 µg Hg/m^3^) was weighted by the number of subjects in the exposed group (47).
Reference: Fawer et al. 1983
Study type and population: Cross-sectional cohort of florescent lamp workers (n=7), chloralkali workers (n=12), acetaldehyde production workers (n=7), and 25 referents from Belgium. Average exposure time (±SE) for workers was 15.3±2.6 years
Biomarkers:; UHg at testing (mean μg Hg/g Cr, SE)^b^; - Referent: 6.0 (1.2); - Exposed: 20.1 (2.1)
Estimated air concentration: 5.57 µg Hg/m^3^
Analysis: Criteria for excluding participation in the study were not reported. Data were analyzed by t-test of means between exposed and referents or paired t-test for changes between rest and load.
Results:
Mean (SE) for highest peak frequency of hand tremor; - At rest, p<0.001; ○ Referent: 6.40 (0.19) Hz; ○ Exposed: 7.60 (0.22) Hz; - Changes between rest and load, p<0.001; ○ Referent: 2.69 (0.19) Hz; ○ Exposed: 3.62 (0.29) Hz | Mean (SE) for second moment; - At rest, p>0.002; ○ Referent: 10.9 (1.1) Hz; ○ Exposed: 13.3 (0.9) Hz; - Changes between rest and load, p<0.002; ○ Referent: 0.9 (1.1) Hz; ○ Exposed: 4.1 (1.2) Hz
Interpretation: Tremor was significantly higher in the exposed group; therefore, the mean UHg in the exposed group (20.1 µg/g Cr) is an AEL for tremor. The equivalent air mercury concentration (5.57 µg Hg/m^3^) was weighted by the number of subjects in the exposed group (26).
Reference: Langworth et al. 1992a
Study type and population: Cross-sectional cohort of 89 chloralkali workers and 75 referents from Sweden. Average exposure time (±SD) for workers was 13.5±8.7 years.
Biomarkers:; UHg at testing and while working^b^ (median µg Hg/g Cr, range); - Referent: 1.9 (0–7.6); - Exposed: 25.4 (0.5–83.3)
Estimated air concentration^a^: 7.03 µg Hg/m^3^
Analysis: Subjects were excluded for alcohol abuse, exposure to other heavy metals or organic solvents; or chronic neurological or kidney disease. Data analyzed using the Student’s t test.
Results:
Incidence of slight finger tremor, NS; - Referent: 13/75 (17%); - Exposed: 17/89 (19%) | Forearm tremor (exposed vs referents), NS; - Tremor frequency spectrum; - Tremor acceleration amplitude
Interpretation: Tremor was not significantly different in the exposed and referent group; therefore, the median UHg in the exposed group (24.4 µg/g Cr) is a NAEL for tremor. The equivalent air concentration (7.03 µg Hg/m^3^) was weighted by the number of subjects in the exposed group who were evaluated for tremor (85 of 89).
Reference: Wastensson et al. 2006, 2008
Study type and population: Retrospective cohort of 43 chloralkali workers and 22 referents from Sweden. The average exposure time for workers was 15 years.
Biomarkers:; UHg cumulative work index (mean µg year/g Cr, range); - 266 (8–1,440); UHg average (calculated as 266/15 mean years worked); 17.7 µg/g Cr; UHg at testing (median µg Hg/g Cr, range); - Exposed: 5.9 (1.3–25); - Referent: 0.7 (0.2–4.1)
Estimated air concentration: 4.90 µg Hg/m^3^ (based on cumulative work mean/mean years worked)
Analysis: Subjects were excluded based on medications, diseases (e.g., diabetes), essential tremor, skull or whiplash injury, or other circumstances that could affect tremor or coordination (e.g., pain in upper limb, lack of sleep, nervousness, colds). Data were analyzed using Student’s t-test (n >20), Wilcoxon’s rank sum test, chi-squared test, or Fisher’s exact test to compare means between exposed and referents. Associations between the tremor measures and UHg were evaluated using Spearman’s correlation coefficients (exposed and referent subjects combined). Multivariate linear regression was conducted, adjusting for age, shift work, and smoking.
Results:
Incidence (%) of clinically diagnosed tremor, NS; - Any tremor; ○ Referent: 3/22 (14); ○ Exposed: 7/43 (16); - Rest tremor; ○ Referent: 0/22 (0); ○ Exposed: 1/43 (2); - Postural tremor; ○ Referent: 3/22 (14); ○ Exposed: 5/43 (12); - Intention tremor; ○ Referent: 2/22 (9); ○ Exposed: 5/43 (12); [underlined: Spearman’s correlation coefficients for]:; Postural hand tremor in laser-based system; - Amplitude (RMS), NS; ○ Dominant hand: −0.01; ○ Non-dominant hand: −0.11; - Proportional power (4–6 Hz), p<0.05; ○ Dominant hand: −0.07; ○ Non-dominant hand: 0.26; ▪ Adjusted linear regression NS after exclusion of one outlier | [underlined: Spearman’s correlation coefficients for]:; Postural hand tremor in CATSYS system; - Tremor intensity (RMS), NS; ○ Dominant hand: 0.00; ○ Non-dominant hand: 0.03; - Tremor index, NS; ○ Dominant hand: −0.06; ○ Non-dominant hand: 0.04; Static hand tremor in laser-based system (1^st^ recording, 2^nd^ recording); - Amplitude (RMS), NS; ○ Dominant hand: −0.05, −0.07; ○ Non-dominant hand: −0.10, −0.17; Kinetic hand tremor in laser-based system; - Mean tracking error, NS; ○ Dominant hand: 0.00; ○ Non-dominant hand: 0.01; Hand tremor detected during rapid pointing movements; - Tremor, NS; ○ Dominant hand: −0.03; ○ Non-dominant hand: −0.09
Interpretation: The outcome was designated as a NAEL because the weight of evidence did not support a significant difference in tremor between exposed and referents. Tremor based on all laser measurements was not significant. The only metric that was significant based on the CATSYS measurement was tremor index, which was different when means were assessed by the t-test, but was not significant when medians were assessed by the Wilcoxon rank sum test. Therefore, the UHg average in the workers (17.7 µg/g Cr) is a NAEL for tremor. The equivalent air concentration (4.90 µg Hg/m^3^) was weighted by the number of subjects in the exposed group (43).

a See the Calculation of Estimated Air Concentration section below for how air concentrations were calculated.

b Reported as µmol Hg/mol creatinine and converted to µg Hg/g creatinine as follows: (µmol Hg/mol Cr × µg Hg/µmol Hg)/g Cr/mol Cr.

AEL = adverse-effect level; ANOVA = analysis of variance; CI = confidence interval; Cr = creatinine; MANOVA = multivariate analysis of variance; NAEL = no-adverse-effect level; NS = not significant; RMS = root mean square; SD = standard deviation; SE = standard error; UHg = urine mercury

Selection of the Point of Departure: The MRL was based on a 95% lower confidence limit of the weighted median estimated air concentration of 2.84 μg Hg/m^3^, based on the seven principal studies.

Typically, the point of departure (POD) would be highest NAEL or lowest AEL. The problem with this approach being applied to the occupational worker tremor studies is that there is substantial overlap in reported NAELs and AELs. The overlap between the lower end of the AEL range and the NAEL range does not support selection of any single NAEL or AEL as a POD. As an alternative approach, the following was assumed:

1. A NAEL/AEL boundary exists and is located somewhere within the range of overlapping NAELs and AELs.
2. Each NAEL and AEL in this range represents an independent estimate of the NAEL/AEL boundary.
3. The best estimate of the NAEL/AEL boundary is the weighted median of the set of overlapping NAELs and AELs (weighted for study size which assumes greater confidence in estimates from larger studies).
4. The lower 95% confidence limit on the median was selected as the POD, to account for uncertainty in the estimated weighted median.

This approach avoids having to make a highly uncertain selection of a single study as the basis for the POD and, instead, utilizes information from multiple studies to identify an exposure that is most likely to be the NAEL/AEL boundary.

Overlapping NAELs and AELs include all AELs that are less than or equal to the highest NAEL for the outcome, plus all NAELs that are greater than or equal to the lowest AEL. For tremor, the highest NAEL is 8.74 μg Hg/m^3^ (Boogaard et al. 1996) and the lowest reliable AEL is 4.90 µg Hg/m^3^ (Wastensson et al. 2006, 2008). For selection of the studies to include in the estimate of the POD, all AELs that were <9 µg/m^3^ and all NAELs that were >4 µg/m^3^ were included in the calculation of the weighted mean. The NAELs and AELs for the principal studies that met the selection criteria are presented in Table A-6. Note that the Anglen et al. (2015) study was omitted for the following reasons: (1) during the 32-year retrospective period, mean UHg levels declined from 20 to 2 µg Hg/L, making it difficult to assign a central estimate UHg level to the outcome; and (2) tremor outcome was self-reported. The Echeverria et al. (2005) study was omitted because of the extremely low AEL and low confidence in the reported mean UHg levels being representative of the steady state, given the expected highly intermittent exposures of dentists to mercury vapor.

Table A-6 NAEL and AEL Values for Studies Defining the NAEL/AEL Boundary for Tremor

Study | Population | Number of subjects | POD | Estimated air concentration (μg Hg/m^3^)
Bast-Pettersen et al. 2005 | Chloralkali workers | 49 | NAEL | 4.57
Boogaard et al. 1996 | Gas production | 40 | NAEL | 8.74
Ellingsen et al. 2001 | Chloralkali workers | 47 | NAEL | 4.43
Langworth et al. 1992a | Chloralkali workers | 85 | NAEL | 7.03
Wastensson et al. 2006, 2008 | Chloralkali workers | 43 | NAEL | 4.90
Chapman et al. 1990 | Chloralkali workers | 18 | AEL | 4.92
Fawer et al. 1983 | Lamp and chloralkali workers | 26 | AEL | 5.57
Median: 4.92 μg/m^3^ (95% CI 3.02, 6.82)
Weighted median: 4.92 μg/m^3^ (95% CI 2.84, 7.00)

AEL = adverse-effect level; CI = confidence interval; NAEL = no-adverse-effect level; POD = point of departure

For the principal studies, the unweighted median estimated air concentration is 4.92 μg Hg/m^3^ (95% CI 3.02, 6.82) and the weighted median estimated air concentration is 4.92 μg Hg/m^3^ (95% CI 2.84, 7.00). The 95% lower confidence limit of the weighted median is 2.84 μg Hg/m^3^, which was selected as the POD for the MRL to account for uncertainty in the estimate of the median. Sensitivity of the POD to individual studies was tested by recomputing the POD after removing one of the studies. The POD was not highly influenced by removal of any single study. The mean of PODs calculated from censored data sets was 3.30 (range: 2.51–3.86).

Calculation of Estimated Air Concentration: Total mercury levels in urine (µg Hg/L or µg Hg/g creatinine) were used as the exposure metric for estimating human exposures (µg Hg/m^3^) to mercury vapor. The urine biomarker is considered to be a more accurate reflection of mercury body burden than reported measurements of room air or breathing zone mercury concentrations, which were likely to be highly intermittent and variable. Non-occupational sources, including diet and mercury amalgam dental restorations, are likely to have contributed to the urinary mercury observed in the occupational studies that provide the basis for the chronic inhalation MRL. However, occupational exposures are likely to have been the dominant source of urinary mercury in the principal studies and support the use of urinary mercury for estimating air exposure concentrations. For example, it is unlikely that diet could account for the urinary mercury levels observed in the principal studies. Based on the urinary levels, the estimated inhaled mercury doses in the principal studies ranged from 1 to 2 µg/kg/day (approximately 70–140 µg/day for a 70-kg adult). By contrast, dietary mercury intakes have been estimated to range from 1 to 10 µg/day (Section 5.6, General Population Exposure). Another possible contributor to urinary mercury in the occupational studies would have been mercury released from mercury amalgam restorations. However, total mercury absorption in a person having 13 restorations was estimated to be approximately 3 µg/day (range 0.6–9.3; Section 5.6, General Population Exposure). Based on these estimates, it is likely that the dominant source of urinary mercury in the principal studies was occupational exposure to mercury, predominantly inhalation of mercury vapor, given the working environments described in these studies.

Reported UHg levels (mean or median for the study population) were converted to equivalent exposure concentrations by applying a steady-state mass balance model which did the following: (1) converted the reported urine level (assumed to represent steady state) to an equivalent steady-state excretion rate (µg Hg/day/kg body weight), and (2) converted the steady-state excretion rate to an equivalent steady-state exposure (µg Hg/m^3^). The assumption of steady state requires that the exposures were relatively constant for periods >272 days. This is the exposure duration that would achieve 95% of steady-state body burden, assuming a terminal elimination half-time of 62 days (Jonsson et al. 1999; Equation 1):

T i m e t o s t e a d y s t a t e = (ln ( 1 − 0.95 ))/(k_e_) Eq. (1)

where 0.95 is the fraction of steady state and k_e_ is ln(2)/half-time.

An alternative to the steady-state mass balance model would be to implement the complete biokinetics model described by Jonsson et al. (1999). However, this is not needed for the epidemiology or clinical studies used in the derivation of the MRL because the steady-state assumption can be reasonably assured for the exposures in these study groups. However, it must be assumed that the mean or median urine levels in each study adequately represent the corresponding steady-state exposures. Although there is an unknown level of uncertainty in this assumption, the same assumption would also apply to the application of the complete biokinetic model.

The calculated exposure concentration represents the continuous exposure that would achieve a steady-state UHg level equal to the observed mean urinary mercury level. Calculated exposure concentrations based on urinary levels are likely to be less than measured air concentrations observed during the workday by at least a factor of 3, assuming an 8-hour workday, because continuous exposure is assumed to occur 7 days/week 24 hours/day.

Conversion of UHg levels to equivalent steady-state excretion rates. UHg levels reported as µg Hg/g creatinine were converted to equivalent excretion rates (µg Hg/day) assuming a standard steady-state excretion rate of creatinine per kg of lean body mass. A more detailed example of this approach is given in ATSDR (2012) where it was used in the derivation of MRLs for cadmium. The rate of excretion of mercury (Hg_ur_, µg Hg/day) was calculated as the product of the urinary level (µg Hg/g creatinine) and the urinary excretion rate of creatinine (g creatinine/day; Equation 2).

H g_u r_ = H g c o n c_u r_ ⋅ C r_u r_ Eq. (2)

where Hg_ur_ is the rate of excretion of mercury (µg/day), Hg conc_ur_ is the mercury concentration (µg/g creatinine) and Cr_ur_ is the rate of excretion of creatinine (g creatinine/day).

The rate of creatinine excretion (Cr_ur_; g creatinine/day) was calculated from the relationship between lean body mass (LBM) and Cr_ur_ (Equation 3):

L B M = 27.2 ⋅ C r_u r_ + 8.58 Eq. (3)

where the constants 27.2 and 8.58 are the sample size-weighted arithmetic mean of estimates of these variables from eight studies reported in Forbes and Bruining (1976). LBM was estimated as follows (ICRP 1981; Equation 4 and 5):

L B M o f a d u l t f e m a l e s = B W ⋅ 0.85 Eq. (4)

L B M o f a d u l t m a l e s = B W ⋅ 0.88 Eq. (5)

where the central tendency for adult body weight for males and females were assumed to be 70 and 58 kg for adult European/American males and females, respectively (ICRP 1981). Equation 5 predicts a lean body mass of 61.6 kg for a 70-kg male, which is similar to a mean lean body mass of 58.3 kg estimated for adults in the NHANES 1999–2006 (Lee et al. 2017c). These equations are applicable to higher average U.S. adult body weights (EPA 2011) because increases in average body weight in the United States derive primarily from increased body fat rather than increased average lean body mass (Hales et al. 2020). UHg levels reported as µg Hg/L were converted to equivalent excretion rates (µg Hg/day) assuming a standard rate of urine output of 1.5 L/day (approximately 1 L/day/kg body weight; CDC 2002; Equation 6).

H g_u r_ = H g c o n c_u r_ ⋅ V_u r_ Eq. (6)

where Hg conc_ur_ is the mercury concentration (µg/L) and V_ur_ is the urine output (L/day).

The validity of the above approach was evaluated based on data reported in Frumkin et al. (2001) that reported mean UHg levels in units of µg Hg/g creatinine and µg Hg/L for 147 exposed chloralkali workers and 132 referents. For workers, the mean urinary levels were 3.42 µg Hg/L and 2.76 µg Hg/creatinine. The model predicted 3.6 µg Hg/L for an assumed 2.76 µg Hg/g creatinine. For referents, the mean urinary levels were 3.12 µg Hg/L and 2.31 µg Hg/creatinine, and the model predicted 3.0 µg Hg/L for an assumed 2.31 µg Hg/g creatinine.

Conversion of mercury excretion rate (µg Hg/day/kg) to an equivalent steady-state exposure (µg Hg/m^3^). Steady-state exposures corresponding to steady-state rates of urinary excretion of mercury were calculated based on a simplified steady-state mass balance implementation of the biokinetic models reported by Jonsson et al. (1999). The simplified model is given by Equation 7:

H g_a i r_ = (H g_u r_)/(f_r_ ⋅ f_u_ ⋅ I R) Eq. (7)

where Hg_ur_ is the mercury excretion rate (µg Hg/day) calculated from UHg levels reported as µg Hg/g creatinine or µg Hg/L as described above; f_r_ is the fraction of the inhaled dose initially retained in the body (0.80; Leggett et al. 2001); f_u_ is the fraction of the retained mercury excreted in urine (0.55; Jonsson et al. 1999); and IR is the inhalation rate (16 m^3^/day; EPA 2011).

Results from the mass balance model were compared to the results obtained from the Jonsson et al. (1999) biokinetics model (implemented in MATLAB). Both models predicted 0.5 for the inhalation dose (µg Hg/day)/UHg excretion rate (µg Hg/day) ratio.

Predictions of dose conversion coefficients from the steady-state mass balance model. The model predicts the following steady-state relationships between exposure levels and UHg levels:

Steady-state air concentration ( μg Hg / m^3^ ) = steady-state UHg ( μg Hg / g creatinine ) × 0.258

Steady-state air concentration ( μg Hg / m^3^ ) = steady-state UHg ( μg Hg / L ) × 0.198

Example of conversion of steady-state UHg levels (20.1 µg Hg/g creatinine; Fawer et al. 1983) to equivalent steady-state air mercury levels (5.57 µg Hg/m^3^):

Convert body weight (BW, kg) to lean body mass (LBM, kg; Equation 5):

L B M o f a d u l t m a l e s = B W × 0.88

L B M = 70 × 0.88 = 61.6

where 0.88 is the proportionality coefficient for males at 70 kg body weight (ICRP 1981).

Convert lean body mass (LBM, kg) to rate of urinary excretion of creatinine (Cr_ur_; g creatinine/day; Equation 3):

L B M = 27.2 × C r_u r_ + 8.58

which rearranges to:

C r_u r_ = (L B M − 8.58)/(27.2)

C r_u r_ = (61.6 − 8.58)/(27.2) = 1.949

where the constants 27.2 and 8.58 are the sample size-weighted arithmetic mean of estimates of these variables from eight studies reported in (Forbes and Bruining 1976).

Convert urinary mercury (UHg_cr_, 20.1 µg Hg/g creatinine, Fawer et al. 1983) to rate of urinary excretion of mercury (Hg_ur_, µg/day; Equation 2):

H g_u r_ = U H g_c r_ × C r_u r_

H g_u r_ = 20.1 × 1.949 = 39.17

where f_r_ is the fraction of the inhaled dose initially retained in the body (0.80; Leggett et al. [2001]); f_u_ is the fraction of the retained mercury excreted in urine (0.55; Jonsson et al. 1999); and IR is the inhalation rate (16 m^3^/day; EPA 2011).

Convert rate of urinary excretion of mercury (Hg_ur_, µg Hg/day) to air concentration (Hg_air_, µg Hg/m^3^; Equation 7):

H g_a i r_ = (H g_u r_)/(f_r_ × f_u_ × I R)

H g_a i r_ = (39.17)/(0.80 × 0.55 × 16) = 5.57

Example of conversion of steady-state UHg levels (41.0 µg Hg/L; Boogaard et al. 1996) to equivalent steady-state air mercury levels (8.74 µg Hg/m^3^):

Convert urinary mercury (UHg_L_, 41.0 µg Hg/L, Boogaard et al. 1996) to rate of urinary excretion of mercury (Hg_ur_, µg/day; Equation 6):

H g_u r_ = U H g_L_ × U F R

H g_u r_ = 41.0 × 1.5 = 61.50

where UFR is the urine flow rate (1.5 L/day; approximately 1 L/day/kg body weight; CDC 2002).

Convert rate of urinary excretion of mercury (Hg_ur_, µg Hg/day) to air concentration (Hg_air_, µg Hg/m^3^; Equation 7):

H g_a i r_ = (H g_u r_)/(f_r_ × f_u_ × I R)

H g_a i r_ = (61.50)/(0.80 × 0.55 × 16) = 8.74

where f_r_ is the fraction of the inhaled dose initially retained in the body (0.80; Leggett et al. [2001]); f_u_ is the fraction of the retained mercury excreted in urine (0.55; Jonsson et al. 1999); and IR is the inhalation rate (16 m^3^/day; EPA 2011).

Uncertainty Factor: The 95% lower confidence limit (LCL) of the weighted median of the seven principal studies (Table A-6) is divided by a total uncertainty factor (UF) of 10.

- 10 for human variability

Weighted Median_95 % LCL_ ÷ UFs = MRL

2.84 μg Hg / m^3^ ÷ 10 = 0.28 μg Hg / m^3^ ≈ 0.3 μg Hg / m^3^

Other Additional Studies or Pertinent Information: A large number of studies in workers exposed to mercury vapor in various industries provide consistent evidence of the neurotoxicity of elemental mercury (Section 2.16.2, Elemental Mercury—Epidemiological Studies, for citations). A few shorter-term studies in animals also demonstrate neurotoxicity in animals exposed as adults; observed effects include impaired motor function and damage to the central nervous system (Ashe et al. 1953; Fukuda 1971; Sørensen et al. 2000; Stankovic 2006). Additionally, several animal studies have reported neurodevelopmental effects including altered motor activity and altered learning (Danielsson et al. 1993; Fredriksson et al. 1992, 1996; Yoshida et al. 2018).

Agency Contacts (Chemical Managers): Rae Benedict

## Elemental mercury Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Elemental mercury
CAS Number: | 7439-97-6
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for elemental mercury.

Rationale for Not Deriving an MRL: No acute-duration oral studies in humans or animals were identified.

Agency Contacts (Chemical Managers): Rae Benedict

## Elemental mercury Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Elemental mercury
CAS Number: | 7439-97-6
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for elemental mercury.

Rationale for Not Deriving an MRL: No intermediate-duration oral studies in humans or animals were identified.

Agency Contacts (Chemical Managers): Rae Benedict

## Elemental mercury Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Elemental mercury
CAS Number: | 7439-97-6
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for elemental mercury.

Rationale for Not Deriving an MRL: No chronic-duration oral studies in humans or animals were identified.

Agency Contacts (Chemical Managers): Rae Benedict

## Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide) Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide)
CAS Numbers: | 1600-27-7, 7487-94-7, 1344-48-5
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for inorganic mercury salts.

Rationale for Not Deriving an MRL: No human or animal studies evaluating acute-duration inhalation exposure to inorganic mercury salts or other inorganic mercury compounds were identified. Therefore, an acute-duration inhalation MRL was not derived.

Agency Contacts (Chemical Managers): Rae Benedict

## Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide) Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide)
CAS Numbers: | 1600-27-7, 7487-94-7, 1344-48-5
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for inorganic mercury salts.

Rationale for Not Deriving an MRL: No human studies or animal studies evaluating intermediate-duration inhalation exposure to inorganic mercury salts were identified. Two studies in rats evaluated effects of inhalation exposure to mercuric oxide on neurological (Altunkaynak et al. 2019) and female reproductive systems (Altunkaynak et al. 2016). In rats exposed to 1 mg Hg/m^3^ for 45 days (9 hours/day), cerebellar gliosis and perineuronal and perivascular vacuolization, reduced cerebellar volume, and decreased number and density of Purkinje cells were observed (Altunkaynak et al. 2019). Purkinje cells from treated animals showed irregular cellular boundaries, eosinophilic cytoplasm, and heterochromatic nuclei. In female rats exposed to 0.9 mg Hg/m^3^ for 45 days (24 hours/day), significant ovarian damage was observed, including thickened tunica albuginea, increased fibrils within connective tissue, congested capillaries and blood vessels, thinned walls of large and dilated veins, fibrin deposits in veins, edema and maldeveloped follicles in the stroma, and irregular oocyte borders within follicles (Altunkaynak et al. 2016). Treated females also showed reduced ovary volume and decreased number of follicles. Both studies evaluated a single exposure level and other systems were not evaluated. Therefore, effects of inhalation exposure to inorganic mercury have not been sufficiently characterized to derive an intermediate-duration inhalation MRL for inorganic mercury salts or other inorganic compounds.

Agency Contacts (Chemical Managers): Rae Benedict

## Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide) Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide)
CAS Numbers: | 1600-27-7, 7487-94-7, 1344-48-5
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for inorganic mercury salts.

Rationale for Not Deriving an MRL: No human or animal studies evaluating chronic-duration inhalation exposure to inorganic mercury salts or other inorganic mercury compounds were identified. Therefore, a chronic-duration inhalation MRL was not derived.

Agency Contacts (Chemical Manager): Rae Benedict

## Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide) Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide)
CAS Numbers: | 1600-27-7, 7487-94-7, 1344-48-5
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.002 mg Hg/kg/day (2×10^−3^ mg Hg/kg/day; 2 µg Hg/kg/day)
Critical Effect: | Renal effects
Reference: | Dieter et al. 1992; NTP 1993
Point of Departure: | BMDL_1SD_ of 0.29 mg Hg/kg/day (BMDL_ADJ_ of 0.21 mg Hg/kg/day)
Uncertainty Factor: | 100
LSE Graph Key: | 6
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.002 mg Hg/kg/day (2×10^−3^ mg Hg/kg/day; 2 µg Hg/kg/day) was derived based on renal effects (increased relative kidney weight) in male rats exposed to mercuric chloride by gavage for 5 days/week for 16 days (Dieter et al. 1992; NTP 1993). The MRL is based on a BMDL_1SD_ of 0.29 mg Hg/kg/day adjusted to a BMDL_ADJ_ of 0.21 mg Hg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from rats to humans, and 10 for human variability).

The acute-duration oral MRL based on mercuric chloride is expected to be protective for all inorganic mercury salts. Mercuric chloride is water soluble (Section 3.1, Toxicokinetics) and the bioavailability of mercury salts is directly related to their solubility. Other mercuric salts are less soluble than mercury chloride and are expected to have lower oral bioavailability and, therefore, lower toxicity. For example, acute-duration oral LOAELs for mercuric sulfide and mercuric acetate range from 5 to 86 mg/kg/day (Section 2.1, Table 2-3), compared to the LOAEL of 1.8 mg/kg/day observed in the critical study.

Selection of the Critical Effect: Effects associated with acute-duration exposure of humans to inorganic mercury is limited to accidental or intentional exposure to near-fatal or fatal doses. Therefore, human data are not suitable for derivation of an acute-duration oral MRL. Several acute-duration oral studies have been conducted in laboratory animals. To identify the critical effect, ATSDR focused on: (1) reported effects associated with clear biological significance, and (2) high-quality acute-duration studies including, at minimum, five animals. The most sensitive LOAELs meeting these criteria are summarized in Table A-7.

Table A-7 Select LOAELs for Acute-Duration Oral Exposure to Mercuric Chloride

Species (n) | Duration | NOAEL/LOAEL (mg Hg/kg/day) | | System: Effect | Reference
Species (n) | Duration | NOAEL | LOAEL | System: Effect | Reference
Rat; (n=5) | 16 days; (5 days/week) | 0.923 | 1.8 | Renal: 17% increase in relative kidney weight | Dieter et al. 1992; NTP 1993^a^
Rat; (n=6) | 3 or 7 days | ND | 3 | Reproductive: Decreased sperm number and motility; non-monotonic changes in serum testosterone | Boujbiha et al. 2009
Mouse; (n=16) | 2 weeks | ND | 3.7 | Endocrine: ~17% increase in baseline plasma insulin and ~60% decrease in fasting plasma insulin; ~15% decrease in blood glucose and impaired glucose tolerance; apoptosis in pancreatic islet cells | Chen et al. 2012
Mouse; (n=5) | 16 days; (5 days/week) | ND | 4 | Renal: 19% increase in relative kidney weight | NTP 1993 ^a^
Hamster; (n=3–10) | Once; (GD 7) | 2.5 | 5 | Developmental: Decreased crown-rump length | Gale 1974

a These 16-day studies were classified as acute-duration studies because exposure only occurred on 12 of 16 days.

GD = gestation day; LOAEL = lowest-observed-adverse-effect level; n = number; ND = not determined; NOAEL = no-observed-adverse-effect level

Renal toxicity was selected as the critical effect following acute-duration oral exposure to inorganic mercury because it represents the lowest reliable LOAEL (Dieter et al. 1992; NTP 1993). There is a preponderance of evidence that the kidney is a sensitive target for inorganic mercury salts, with substantial mechanistic support. Observed effects in acute-duration studies include elevated kidney weight at doses >1 mg Hg/kg/day (Dieter et al. 1992; Kim et al. 2003; NTP 1993) that progressed to histopathological changes (protein casts, cellular casts, interstitial sclerosis, necrosis) at ≥7.4 mg Hg/kg/day (Dieter et al. 1992; Lecavalier et al. 1994; Nielsen et al. 1991; NTP 1993). Nephrotoxicity of inorganic mercury is characterized primarily by damage to the pars recta segment of the proximal tubule, with involvement of the proximal convoluted tubule and distal tubule in severe toxicity (Berlin et al. 2015; Zalups and Diamond 2005). Damage to the pars recta segment of the proximal tubule is consistent with localized uptake of mercury in the renal cortex and outer stripe of the outer medulla (Section 3.1.2). In the proximal tubule, early changes include loss of the brush border membrane, resulting in urinary excretion of brush border enzymes, such as ALP and GGT. As damage to the proximal tubule becomes more severe and progresses to necrosis, intracellular enzymes, such as AAP and NAG, are excreted in the urine, and renal function declines. Substantial evidence from animal studies shows dose- and duration-dependent related damage to the kidneys.

Selection of the Principal Study: The acute-duration oral study in male rats reported by Dieter et al. (1992) and NTP (1993) was selected as the principal study because it identified the lowest LOAEL for the critical effect (renal toxicity).

Summary of the Principal Study:

- Dieter MP, Boorman GA, Jameson CW, . 1992. Development of renal toxicity in F344 rats gavaged with mercuric chloride for 2 weeks, or 2, 4, 6, 15, and 24 months. J Toxicol Environ Health 36(4):319–340. 10.1080/15287399209531642.1354752
- NTP. 1993. Toxicology and carcinogenesis studies of mercuric chloride (CAS no. 7487-94-7) in F344/N rats and B6C3F1 mice (gavage studies). Research Triangle Park, NC: National Toxicology Program. NTP TR 408. NIH publication no. 91-3139.

Fischer 344 rats (5/sex/group) were administered mercuric chloride for 16 days (5 days/week) at doses of 0, 1.25, 2.5, 5, 10, or 20 mg HgCl_2_/kg/day (equivalent to 0, 0.923, 1.8, 4, 7.4, or 15 mg Hg/kg/day) via gavage in deionized water. Body weights were measured and a complete necropsy was performed. Urinalysis was conducted in the control and 4 mg Hg/kg/day dose groups only. Organ weights were obtained for the brain, heart, kidney, liver, lung, and thymus. Histopathology was evaluated in all dose groups for kidney, stomach, preputial gland (males), and clitoral gland (females). Other organs were microscopically evaluated only in the high-dose group.

Two high-dose males died during the first week of exposure (exposure day 4 and 5). Body weight gains were significantly decreased by 17–18% at 7.4 mg Hg/kg/day and 30–41% at 15 mg Hg/kg/day. In females, final body weight was significantly decreased by 11% at 15 mg Hg/kg/day. Absolute and relative kidney weights were significantly increased by ≥17% in males at ≥1.8 mg Hg/kg/day and ≥28% in females at ≥4 mg Hg/kg/day. Decreases in other absolute organ weights in high-dose females is attributed to decreased body weight. Urinary ALP and AST were significantly elevated in males at 4 mg Hg/kg/day by approximately 80 and 83% (estimated from graphically presented data); these changes were not observed in females. No changes in urinary LDH or GGT were observed in males or females at 4 mg Hg/kg/day. Increased incidence and severity of acute renal necrosis was observed in males at ≥7.4 mg Hg/kg/day and in females at 15 mg Hg/kg/day. No histopathological findings in the stomach, preputial gland, or clitoral gland were reported.

Selection of the Point of Departure for the MRL: In order to identify the POD, BMD modeling was conducted for relative kidney weight data from the acute-duration oral study in the rat (Dieter et al. 1992; NTP 1993). Male rat relative kidney weight data (Table A-8) were fit to all available continuous models in EPA’s BMDS (version 3.2) using a BMR of 1 SD. Adequate model fit was judged by four criteria: goodness-of-fit statistics (chi-square p-value >0.1); visual inspection of the dose-response curve; BMDL that is not 10 times lower than the lowest non-zero dose; and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all the models providing adequate fit to the data, the lowest BMDL values were selected as potential PODs when the difference between the BMDL estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen.

Table A-8 Relative Kidney Weights in Male Rats Exposed to Mercuric Chloride via Gavage 5 days/week for 16 Days

Dose level (mg Hg/kg/day) | Number of animals | Relative kidney weight (mg/g body weight)
Dose level (mg Hg/kg/day) | Number of animals | Mean | Reported SE | Calculated SD
0 | 5 | 4.83 | 0.16 | 0.36
0.923 | 5 | 5.36 | 0.17 | 0.38
1.8 | 5 | 5.63^a^ | 0.10 | 0.22
4 | 5 | 5.74^a^ | 0.16 | 0.36
7.4 | 5 | 6.54^a^ | 0.46 | 1.03
15 | 5 | 6.89^a^ | 0.32 | 0.72

a Significantly different from control, p<0.05.

SD = standard deviation; SE = standard error

Source: Dieter et al. 1992; NTP 1993

For elevated relative kidney weight in male rats, the Exponential 4 and 5-degree and Hill models provided adequate fit to the data using non-constant variance. BMDLs were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Hill). The frequentist, restricted Hill model estimated a BMD_1SD_ and BMDL_1SD_ of 0.64 and 0.29 mg Hg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-9 and the model fit for the selected model is shown in Figure A-1.

The BMDL_1SD_ of 0.29 mg Hg/kg/day for increased relative kidney weight in male rats was selected as the POD for deriving an MRL for acute-duration oral exposure to inorganic mercury salts.

Table A-9 Results from BMD Analysis (Nonconstant Variance) of Relative Kidney Weight in Male Rats Exposed to Mercuric Chloride via Gavage 5 Days/Week for 16 Days (Dieter et al. 1992; NTP 1993)

Model | BMD_1SD_ (mg Hg/kg/day) | BMDL_1SD_ (mg Hg/kg/day) | Test 4 p-value^a^ | AIC | Scaled residuals^b^
Model | BMD_1SD_ (mg Hg/kg/day) | BMDL_1SD_ (mg Hg/kg/day) | Test 4 p-value^a^ | AIC | Dose below BMD | Dose above BMD
Exponential 2^c^ | | | 0.02 | 56.24 | 1.23 | 0.18
Exponential 3^c^ | | | 0.02 | 56.24 | 1.23 | 0.18
Exponential 4^c,^ | 0.75 | 0.37 | 0.27 | 50.10 | −0.57 | 0.75
Exponential 5^c^ | 0.75 | 0.37 | 0.27 | 50.10 | −0.57 | 0.76
Hill ^c^ ^,^ ^d^ | 0.64 | 0.29 | 0.29 | 49.98 | −0.40 | 0.62
Polynomial Degree 5^c^ | | | 0.04 | 54.41 | 1.28 | −0.01
Polynomial Degree 4^c^ | | | 0.04 | 54.41 | 1.28 | −0.01
Polynomial Degree 3^c^ | | | 0.04 | 54.41 | 1.28 | −0.01
Polynomial Degree 2^c^ | | | 0.04 | 54.41 | 1.28 | −0.01
Power^c^ | | | 0.04 | 54.41 | 1.28 | −0.01
Linear | | | 0.04 | 54.41 | 1.28 | −0.01

a Values <0.1 fail to meet adequate fit.

b Scaled residuals at doses immediately below and above the BMD.

c Restricted model.

d Recommended model. There was an adequate fit to the variance when assuming nonconstant variance. The Exponential 4- and 5-degree and Hill models provided adequate fit to the data. BMDLs were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Hill).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control); NA = not applicable, goodness-of-fit test could not be performed

Figure A-1 Fit of Hill Model to Data for Relative Kidney Weight in Male Rats Exposed to Mercuric Chloride via Gavage 5 days/week for 16 Days (Dieter et al. 1992; NTP 1993)

Adjustment for Intermittent Exposure: The BMDL_1SD_ was adjusted from intermittent exposure to account for a continuous exposure scenario:

BMDL_ADJ_ = 0.29 mg Hg / kg / day ppm × ( 5 days / 7 days ) = 0.21 mg Hg / kg / day

Uncertainty Factor: The BMDL_ADJ_ of 0.21 mg Hg/kg/day was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_ADJ_ ÷ UFs

MRL = 0.21 mg Hg / kg / day ÷ ( 10 × 10 )

MRL = 0.0021 mg Hg / kg / day ≈ 0.002 mg Hg / kg / day = 2 μg Hg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: There is strong evidence for adverse renal effects in laboratory animals following oral exposure to mercuric chloride. Findings in acute-duration studies in rats and mice exposed to mercuric chloride include increased relative kidney weight, proximal tubular damage, and acute renal necrosis (Dieter et al. 1992; Kim et al. 2003; Lecavalier et al. 1994; Nielsen et al. 1991; NTP 1993). Numerous intermediate-duration studies in mice and rats also report elevated kidney weight, markers of altered renal function or renal damage, histopathological changes, and nephropathy and/or nephrosis (Table A-11, Renal Effects in Laboratory Animals Exposed to Oral Mercuric Chloride for Intermediate-Durations in the intermediate-duration inorganic mercury oral MRL worksheet for citations). Chronic-duration oral studies in rats and mice observed increased relative kidney weight and degeneration and atrophy of the proximal tubule, and increased incidence and/or severity of renal nephropathy (Dieter et al. 1992; NTP 1993). Kidney toxicity has been observed in human case studies of acute poisoning from ingestion of inorganic mercury compounds (Cappelletti et al. 2019).

Agency Contacts (Chemical Manager): Rae Benedict

## Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide) Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide)
CAS Numbers: | 1600-27-7, 7487-94-7, 1344-48-5
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.00001 mg Hg/kg/day (1×10^−5^ mg Hg/kg/day; 0.01 µg Hg/kg/day)
Critical Effect: | Renal effects
Reference: | Apaydin et al. 2016
Point of Departure: | LOAEL of 0.015 mg Hg/kg/day
Uncertainty Factor: | 1,000
LSE Graph Key: | 37
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.00001 mg Hg/kg/day (1×10^−5^ mg Hg/kg/day; 0.01 µg Hg/kg/day) for inorganic mercury salts was derived based on renal effects (decreased renal function and histopathological changes) in rats exposed to mercuric chloride by gavage for 28 days (Apaydin et al. 2016). The MRL is based on a LOAEL of 0.015 mg Hg/kg/day and a total uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from rats to humans, and 10 for human variability).

The intermediate-duration oral MRL based on mercuric chloride is expected to be protective for all inorganic mercury salts. Mercuric chloride is water soluble (Section 3.1, Toxicokinetics) and the bioavailability of mercury salts is directly related to their solubility. Other mercuric salts are less soluble than mercury chloride and are expected to have lower oral bioavailability and, therefore, lower toxicity. For example, LOAELs for intermediate-duration oral exposure to mercuric sulfide, a poorly soluble salt, are approximately 3–380-fold greater than the corresponding LOAELs identified for mercuric chloride (Table A-10).

Selection of the Critical Effect: No epidemiological studies evaluating intermediate-duration oral exposure to mercuric salts were identified. Toxicity data for intermediate-duration oral exposure to mercuric chloride and mercuric sulfide are available from studies in animals; no intermediate-duration oral studies on other inorganic mercury salts were identified. The lowest NOAEL and LOAEL values reported for mercuric chloride and mercuric sulfide for each organ system are summarized in Table A-10.

Table A-10 Summary of Lowest LOAELs for Intermediate-Duration Oral Exposure to Mercuric Chloride and Mercuric Sulfide

Species | Duration | NOAEL/LOAEL (mg Hg/kg/day) | | System: Effect | Reference
Species | Duration | NOAEL | LOAEL | System: Effect | Reference
Mercuric chloride
Rat | 28 days | ND | 0.015 | Renal: Decreased renal function and histopathological changes | Apaydin et al. 2016
Rat | 21 days | ND | 0.033 | Hematological: Decreased clotting time, 13% decrease in erythrocyte count, 5% decrease in hemoglobin, and 17% increase in leukocyte count | Mahour and Saxena 2009
Rat | 12 weeks | ND | 0.07 | Cardiovascular: Increase in systolic blood pressure at 5 weeks but not 12 weeks | Takahashi et al. 2000b
Rat | 21 weeks | ND | 0.07 | Hepatic: Decreased plasma HDL cholesterol and triglycerides | Takahashi et al. 2000b
Mouse | 10 weeks | 0.07 | 0.118 | Immunological: Polyclonal B-cell activation | Hultman and Nielsen 2001; Nielsen and Hultman 2002
Mouse | 61–79 days | ND | 0.18 | Reproductive: Decreased fertility index | Khan et al. 2004
Rat | 45 days | ND | 0.277 | Neurological: Impaired motor coordination and balance; apoptosis and loss of neurons and astrocytes in motor cortex; decreased motor activity; impaired learning and memory | Teixeira et al. 2014, 2018
Rat | 7 weeks | ND | 0.4 | Developmental (neurodevelopmental): Decreased peripheral sensory nerve conduction velocity | Huang et al. 2011
Rat | 3 months | ND | 2.2 | Endocrine: Impaired thyroid function | Goldman and Blackburn 1979
Mercuric sulfide
Mouse | 4 weeks | ND | 6 | Endocrine: Decreased plasma T4 (28–41%) | Sin and Teh 1992
Mouse | 4 weeks | ND | 17 | Immunological: Altered T-cell populations in spleen | Son et al. 2010
Guinea pig | 21 days | ND | 86 | Neurological: Abnormal vestibular ocular reflex | Chuu et al. 2001b

HDL = high-density lipoprotein; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; T4 = thyroxine

For mercuric chloride, the most sensitive effect for intermediate-duration oral exposure is renal toxicity in rats, with the lowest LOAEL value of 0.015 mg Hg/kg/day; a NOAEL was not identified as only one dose level was tested in this study (Apaydin et al. 2016). The next lowest LOAEL of 0.033 mg Hg/kg/day was for hematological effects in rats (Mahour and Saxena 2009), and is approximately 2-fold higher than the LOAEL for renal effects. For mercuric sulfide, the lowest LOAEL identified was 6 mg Hg/kg body weight for endocrine effects in mice (Sin and Teh 1992). Available intermediate-duration oral studies on effects of mercuric sulfide did not evaluate renal effects. However, LOAEL values for mercuric sulfide for endocrine, immunological, and neurological effects are greater than corresponding LOAELs for mercuric chloride by approximately 3-, 144-, and 380-fold, respectively. Therefore, an MRL based on mercuric chloride is expected to be protective for exposure to mercuric sulfide.

Renal effects, long established as a sensitive target for inorganic mercury salts, were selected as basis for derivation of the intermediate-duration oral MRL. Nephrotoxicity of inorganic mercury is characterized primarily by damage to the pars recta segment of the proximal tubule, with involvement of proximal convoluted tubules and distal tubule in severe toxicity (Berlin et al. 2015; Zalups and Diamond 2005). Damage to the pars recta segment of the proximal tubule is consistent with localized uptake of mercury in the renal cortex and outer stripe of the outer medulla (Section 3.1.2). In the proximal tubule, early changes include loss of the brush border membrane, resulting in urinary excretion of brush border enzymes, such as ALP and GGT. As damage to the proximal tubule becomes more severe and progresses to necrosis, intracellular enzymes, such as AAP and NAG, are excreted in the urine, and renal function declines. Substantial evidence from animal studies shows dose- and duration-dependent related damage to the kidneys. Renal effects observed in intermediate-duration oral studies in laboratory animals are summarized in Table A-11.

Table A-11 Renal Effects in Laboratory Animals Exposed to Oral Mercuric Chloride for Intermediate-Durations

Effect | Species | References
Increased relative kidney weight | Rats and mice | Atkinson et al. 2001; Dieter et al. 1983, 1992; Jonker et al. 1993; Khan et al. 2004; NTP 1993; Takahashi et al. 2000a, 2000b; Wildemann et al. 2015a
Markers of altered renal function or renal damage (increased serum levels of urea, uric acid, and creatinine; elevated urine protein and/or ketones) | Rats | Apaydin et al. 2016; Carmignani et al. 1992; Jonker et al. 1993; Takahashi et al. 2000a
Histopathological changes (including tubular dilation and glomerular lobulation, tubular damage and degeneration, necrosis) | Rats and mice | Apaydin et al. 2016; Boscolo et al. 1989; Carmignani et al. 1989, 1992; Jonker et al. 1993; NTP 1993
Nephropathy and/or nephrosis | Rats and mice | Dieter et al. 1983, 1992; Jonker et al. 1993; NTP 1993

Selection of the Principal Study: The Apaydin et al. (2016) study provided the lowest LOAEL observed for renal effects in intermediate-duration animal studies and was selected as the principal study.

Summary of the Principal Study:

- Apaydin FG, Bas H, Kalender S, . 2016. Subacute effects of low dose lead nitrate and mercury chloride on kidney of rats. Environ Toxicol Pharmacol 41:219–224.26731605

Groups of six Wistar rats (90 days old; sex not specified) were administered distilled water or 0.02 mg/kg mercuric chloride in distilled water by gavage daily for 28 days (equivalent to 0.015 mg Hg/kg/day). At the end of the 28-day exposure period, blood samples were obtained and analyzed for serum urea, uric acid, and creatinine levels. Kidneys were examined microscopically, and renal levels of the following were determined: malondialdehyde, glutathione peroxidase (GPX), glutathione S-transferase (GST), superoxide dismutase (SOD), and catalase.

In rats treated with mercuric chloride, serum levels of urea, uric acid, and creatinine were significantly increased by 28, 54, and 17%, respectively, compared to controls, indicating decreased renal function. Histopathological assessment of the kidneys showed tubular dilation and glomerular lobulation compared to normal appearance in controls. Kidney activity of antioxidant enzymes, GPX, GST, SOD, and catalase were significantly decreased by approximately 31, 25, 32, and 41%, respectively, compared to controls (data presented graphically). Kidney malondialdehyde levels were significantly increased by approximately 69%, compared to controls (data presented graphically). Findings are consistent with oxidative stress and peroxidation of lipid membranes.

Selection of the Point of Departure for the MRL: The LOAEL of 0.015 mg Hg/kg/day for decreased renal function and histopathological alterations in the kidneys was selected as the POD for deriving a MRL for intermediate-duration oral exposure to inorganic mercury salts. BMD modeling was not considered for this dataset, as only one dose level was tested in the study. Existing PBPK models were not suitable for extrapolation of inorganic mercuric mercury dosimetry between rats and humans.

Uncertainty Factor: The LOAEL of 0.015 mg Hg/kg/day was divided by a total uncertainty factor of 1,000:

- 10 for use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = LOAEL ÷ UFs

MRL = 0.015 mg Hg / kg / day ÷ ( 10 × 10 × 10 )

MRL = 0.000015 mg Hg / kg / day ≈ 0.00001 mg Hg / kg / day = 0.01 μg Hg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: See Selection of the Critical Effect above for review of supporting evidence from intermediate-duration oral exposure studies in animals. In addition, acute- and chronic-duration oral studies in laboratory animals have observed renal toxicity. Findings in acute-duration studies in rats and mice exposed to mercuric chloride include increased relative kidney weight, proximal tubular damage, and acute renal necrosis (Kim et al. 2003; Lecavalier et al. 1994; Nielsen et al. 1991; NTP 1993). Chronic-duration oral studies in rats and mice observed increased relative kidney weight and degeneration and atrophy of the proximal tubule, and increased incidence and/or severity of renal nephropathy (Dieter et al. 1992; NTP 1993). Kidney toxicity has been observed in human case studies of acute poisoning from ingestion of inorganic mercury compounds (Cappelletti et al. 2019).

Agency Contacts (Chemical Managers): Rae Benedict

## Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide) Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mercury, inorganic salts (mercuric acetate, mercuric chloride, mercuric sulfide)
CAS Numbers: | 1600-27-7, 7487-94-7, 1344-48-5
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for inorganic mercury salts.

Rationale for Not Deriving an MRL: Epidemiological studies of chronic-duration oral exposure to inorganic mercury salts were not identified, and few studies have evaluated the effects of chronic-duration oral exposure to inorganic mercury salts in animals (Dieter et al. 1992; NTP 1993; Perry and Erlanger 1974). The lowest LOAELs identified for each study are summarized in Table A-12. The lowest LOAEL identified is 0.66 mg Hg/kg/day for increased systolic blood pressure in rats exposed to mercuric chloride in drinking water for 1 year, with a NOAEL of 0.33 mg Hg/kg/day (Perry and Erlanger 1974). The lowest chronic-duration LOAEL is 44-fold higher than the lowest intermediate-duration LOAEL of 0.015 mg Hg/kg/day that is the basis of the intermediate-duration oral MRL. Studies examining effects of chronic-duration oral exposure at lower levels were not identified. Therefore, a chronic-duration oral MRL was not derived for inorganic mercury.

Table A-12 Summary of LOAELs from Chronic-Duration Oral Studies in Laboratory Animals Exposed to Mercuric Chloride

Species | Duration | NOAEL/LOAEL^a^ (mg Hg/kg/day) | | | Effect | Reference
Species | Duration | NOAEL | LOAEL | SLOAEL | Effect | Reference
Rat | 1 year | 0.33 (F) | 0.66 (F) | ND | Increased systolic blood pressure | Perry and Erlanger 1974
Rat | 2 years | ND (M) | 1.8 (M) | 1.8 (M) | LOAEL: Decreased body weight, inflammatory lesions of the nasal mucosa, and epithelial hyperplasia of the forestomach; SLOAEL: Decreased survival, degeneration and atrophy of the renal tubular epithelium | Dieter et al. 1992; NTP 1993
Mouse | 2 years^b^ | ND | 4 | ND | Nephropathy and increased kidney weight | NTP 1993

a Unless otherwise specified, NOAEL and LOAEL values are for both males and females.

b Continuous mating study.

F = female; LOAEL = lowest-observed-adverse-effect level; M = male; ND = not determined; NOAEL = no-observed-adverse-effect level; SLOAEL = serious lowest-observed-adverse-effect level

Agency Contacts (Chemical Managers): Rae Benedict

## Methylmercury Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methylmercury
CAS Number: | 22967-92-6
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for methylmercury.

Rationale for Not Deriving an MRL: No human or animal studies evaluating acute-duration inhalation exposure to methylmercury were identified. Therefore, an acute-duration inhalation MRL was not derived.

Agency Contacts (Chemical Managers): Rae Benedict

## Methylmercury Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methylmercury
CAS Number: | 22967-92-6
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for methylmercury.

Rationale for Not Deriving an MRL: No human or animal studies evaluating intermediate-duration inhalation exposure to methylmercury were identified. Therefore, an intermediate-duration inhalation MRL was not derived.

Agency Contacts (Chemical Managers): Rae Benedict

## Methylmercury Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methylmercury
CAS Number: | 22967-92-6
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for methylmercury.

Rationale for Not Deriving an MRL: No human or animal studies evaluating chronic-duration inhalation exposure to methylmercury were identified. Therefore, a chronic-duration inhalation MRL was not derived.

Agency Contacts (Chemical Managers): Rae Benedict

## Methylmercury Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methylmercury
CAS Number: | 22967-92-6
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for methylmercury.

Rationale for Not Deriving an MRL: No studies examining effects of acute-duration oral exposure to methylmercury in humans were identified. Numerous studies in laboratory animals have investigated effects of acute-duration oral exposure to methylmercury. Table A-13 lists the lowest reported NOAELs and LOAELs for acute toxicity endpoints. The lowest LOAEL of 0.008 mg Hg/kg/day identified the developing nervous system as the most sensitive target for acute-duration oral exposure (Bornhausen et al. 1980). The associated NOAEL is 0.004 mg Hg/kg/day.

Table A-13 Summary of Lowest NOAELs and LOAELs for Acute-Duration Oral Exposure to Methylmercury

Species | Duration | NOAEL/LOAEL (mg Hg/kg/day) | | System: Effect | Reference
Species | Duration | NOAEL | LOAEL | System: Effect | Reference
Rat | 4 days; (GDs 6–9) | 0.004 | 0.008 | Developmental (neurodevelopmental): Impaired operant conditioning at 4 months | Bornhausen et al. 1980
Rat | 14 days | ND | 0.5 | Reproductive: Nonmonotonic sperm effects (decreased count and motility, increased abnormal); inflammatory foci and thickening of epithelium in prostate | Fossato da Silva et al. 2011, 2012
Rat | 1–2 weeks | ND | 0.7 | Neurological: Ultrastructural changes in dorsal root ganglia and cerebellum | Chang and Hartmann 1972
Mouse | 14 days | ND | 1.6 | Endocrine: Altered glucose homeostasis; apoptosis in pancreatic islet cells | Chen et al. 2012
Rat | 14 days | ND | 1.9 | Body weight: Decreased body weight (~10%) | Chuu et al. 2007
Rat | 14 days | 0.93 | 2.8 | Renal: Increased relative kidney weight (18%) | Fossato da Silva et al. 2011
Rat | 12 days | ND | 4 | Musculoskeletal: Muscle weakness and wasting | Usuki et al. 1998
Mouse | 14 days | ND | 5.6 | Hepatic: Elevated total cholesterol | Moreira et al. 2012
Rat | 2 days | ND | 12 | Cardiovascular: Decreased heart rate (10–18%) | Arito and Takahashi 1991

GD = gestation day; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Several animal studies provide support for neurodevelopmental effects as the most sensitive target of acute-duration oral exposure to methylmercury. Studies observing neurodevelopmental effects at doses ≤0.5 mg Hg/kg/day (the lowest LOAEL for reproductive effects, the second most sensitive target of acute-duration oral exposure to methylmercury) are summarized in Table A-14. Two neurodevelopmental studies reported similar LOAELs for neurodevelopmental effects: the Bornhausen et al. (1980) study in rats, with a LOAEL of 0.008 mg Hg/kg/day and the Montgomery et al. (2008) study in mice, with a LOAEL of 0.009 mg Hg/kg/day. The study in rats identified a NOAEL of 0.004 mg Hg/kg/day; however, the study in mice did not identify a NOAEL, as only one dose (0.009 mg Hg/kg/day) was tested.

Table A-14 Neurodevelopmental Effects in Laboratory Animals Exposed to Methylmercury Doses ≤0.5 mg Hg/kg/day for Acute Durations

Species | Duration | NOAEL/LOAEL (mg Hg/kg/day) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Rat | 4 days, GDs 6–9 | 0.004 | 0.008 | Impaired operant conditioning at 4 months | Bornhausen et al. 1980
Mouse | 11 days, GDs 8–18 | ND | 0.009 | Impaired learning and memory, decreased motor activity and coordination in adult offspring | Montgomery et al. 2008
Mouse | 5 days, PNDs 29–33 | ND | 0.2 | Impaired balance and motor coordination on PND 38 | Bellum et al. 2007
Mouse | Once, PND 10 | ND | 0.37 | Decreased motor activity and impaired learning and memory at 2–6 months of age | Fischer et al. 2008
Rat | 4 days, GDs 6–9 | 0.04 | 0.4 | Increased startle response in adult offspring; Effects at 4 mg Hg/kg/day: impaired swimming, impaired visual discrimination, decreased activity, and decreased habituation | Stoltenburg-Didinger and Markwort 1990

GD = gestation day; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level PND = postnatal day

The NOAEL of 0.004 mg Hg/kg/day in rats (Bornhausen et al. 1980) and the LOAEL of 0.009 mg Hg/kg/day in mice (Montgomery et al. 2008) were considered as possible PODs for an acute-duration oral MRL, as shown in Table A-15. Based on the NOAEL of 0.004 mg Hg/kg/day in rats and a total uncertainty factor of 100, the MRL would be 0.00004 mg Hg/kg/day (0.04 µg Hg/kg/day). Based on the LOAEL of 0.009 mg Hg/kg/day and a total uncertainty factor of 1,000, the MRL would be 0.000009 mg Hg/kg/day (0.009 µg Hg/kg/day). These acute-duration MRLs are less than the chronic-duration oral MRL for methylmercury of 0.1 µg Hg/kg/day based on data in humans. Therefore, an acute-duration oral MRL for methylmercury was not derived.

Table A-15 Possible Acute-Duration Oral Minimal Risk Levels (MRLs) for Methylmercury Based on Neurodevelopmental Effects

Species | MRL (µg Hg/kg/day) | Critical effect | Point of departure (mg Hg/kg/day) | Uncertainty factors | Reference
Rat | 0.04 | Impaired operant conditioning at 4 months | NOAEL: 0.004 | 100^a^ | Bornhausen et al. 1980
Mouse | 0.009 | Impaired learning and memory, and decreased motor activity and coordination in adult offspring | LOAEL: 0.009 | 1,000^b^ | Montgomery et al. 2008

a Total uncertainty factor = 100 (10 for extrapolation from rats to humans; 10 for human variability).

b Total uncertainty factor = 1,000 (10 for use of LOAEL; 10 for extrapolation from mice to humans; 10 for human variability).

LOAEL = lowest-observed-adverse-effect level; NOAEL = No-observed-adverse-effect level

Agency Contacts (Chemical Managers): Rae Benedict

## Methylmercury Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methylmercury
CAS Number: | 22967-92-6
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for methylmercury.

Rationale for Not Deriving an MRL: In humans, intermediate-duration oral exposure to methylmercury occurred in Iraq in 1972–1973 as a result of widespread consumption of bread made from wheat that had been treated with a methylmercuric fungicide (Al-Mufti et al. 1976; Bakir et al. 1973; Clarkson et al. 1976). BHg levels in poisoning cases measured approximately 65 days after exposure ranged from 10 to 3,000 µg Hg/L (Clarkson et al. 1976). Severe neurological and neurodevelopmental effects were observed in this population; therefore, findings in this population cannot be used to derive an intermediate-duration oral MRL for methylmercury.

Numerous studies in laboratory animals have investigated effects of intermediate-duration oral exposure to methylmercury. The lowest LOAELs for each system are summarized in Table A-16. The lowest dose of methylmercury tested in intermediate-duration oral studies was 0.0003 mg Hg/kg/day in rats exposed during pre-mating through PND 21 (Wild et al. 1997). At this dose, immunodevelopmental effects (enhanced lymphoproliferation in response to mitogens) were observed in offspring assessed on PND 84. This is the lowest LOAEL observed in intermediate-duration oral studies. The next lowest dose tested was 0.0004 mg Hg/kg/day in rats exposed for 8 weeks (Ortega et al. 1997a, 1997b); this dose is a LOAEL for immunological effects in adult rats (immune stimulation). The lowest LOAEL values for renal, neurological, and neurodevelopmental effects were 0.006, 0.0073, and 0.02 mg Hg/kg/day, respectively. Results of these studies indicate that the immune system is a sensitive target for methylmercury. Several animal studies provide support that the developing immunological system is the most sensitive target of methylmercury; studies are summarized in Table A-17. Immunodevelopmental effects have been observed at doses ranging from 0.0003 to 0.37 mg Hg/kg/day.

Table A-16 Summary of Lowest LOAELs for Intermediate-Duration Oral Exposure to Methylmercury

Species | Duration | NOAEL/LOAEL (mg Hg/kg/day) | | System: Effect | Reference
Species | Duration | NOAEL | LOAEL | System: Effect | Reference
Rat | 14–16 weeks premating to PND 21 | ND | 0.0003 | Immunodevelopmental: Altered functional immune function (enhanced lymphoproliferation in response to mitogens) in PND 84 offspring | Wild et al. 1997
Rat | 8 weeks | ND | 0.0004 | Immunological: Immune stimulation followed by immune suppression at higher doses | Ortega et al. 1997a, 1997b
Rat | 8 weeks | ND | 0.0004 | Endocrine: Increase in adrenocorticotrophic hormone | Ortega et al. 1997b
Rat | 4 weeks | 0.002 | 0.005 | Cardiovascular: Elevated systolic blood pressure and pulse pressure | Wildemann et al. 2015a
Rat | 4 weeks | 0.006 | 0.285 | Renal: Elevated urinary creatinine | Wildemann et al. 2016
Mouse | 2 months | 0.00046 | 0.0073 | Neurological: Impaired memory | Bourdineaud et al. 2011
Rat | 19 weeks^a^ | 0.0008 | 0.008 | Reproductive: No viable litters produced | Friedmann et al. 1998
Mouse | 10–17 weeks premating through PNDs 21–70 | ND | 0.02 | Neurodevelopmental: Decreased motor activity and impaired hearing and motor coordination in offspring | Huang et al. 2011
Rabbit | 14 weeks | 0.05 | 0.49 | Body weight: Decreased body weight gain | Koller et al. 1977
Mouse | 21 days | ND | 5.6 | Hepatic: Elevated plasma total cholesterol | Moreira et al. 2012

a Rats were dosed 2 times/week.

LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day

Table A-17 Summary of LOAELs for Immunodevelopmental Effects in Animals Exposed to Oral Methylmercury for Intermediate Durations

Species | Duration | NOAEL/LOAEL (mg Hg/kg/day) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Rat | 14–16 weeks (premating through PND 21) | ND | 0.0003 | Altered functional immune endpoints (enhanced lymphoproliferation in response to mitogens) in PND 12 offspring | Wild et al. 1997
Rat | 14–16 weeks (premating through PND 21) | ND | 0.0006 | Altered functional immune endpoints in PND 6–12 offspring (enhanced lymphoproliferation in response to mitogens; decreased NK cell activity) | Wild et al. 1997
Mouse^a^ | 5 weeks (GD 8 to PND 21) | ND | 0.06 | Cerebellar inflammation, attributed to autoimmune effects, at PNDs 21 and 70 | Zhang et al. 2011
Rat | 26 days (GD 6 to PND 10) | ND | 0.08 | Altered functional immune endpoints in PND 21–70 offspring (decrease in the primary KLH-specific IgG antibody response on PND 35) | Tonk et al. 2010
Mouse | 15–16 weeks (10 weeks premating through PND 15) | ND | 0.098 | Alterations in functional immune endpoints (increased primary antibody response to a viral antigen) and thymocyte cell populations in PNDs 10–22 offspring | Thuvander et al. 1996
Rat | 15 days (PNDs 1–15, via dam) | ND | 0.37 | 13% decrease in relative spleen weight; altered immune function in offspring (decreased splenic lymphoproliferative response to mitogen) | Ilback et al. 1991
Rat | ~15 weeks (11 weeks premating through GD 21) | ND | 0.37 | 45% increase in WBCs in offspring on PND 15 | Ilback et al. 1991
Rat | ~17 weeks (11 weeks premating through PND 15) | ND | 0.37 | Altered immune function in offspring (increased thymic lymphoproliferative response to mitogen, decreased cell-mediated cytotoxicity) | Ilback et al. 1991

a Immune susceptible mouse strain.

GD = gestational day; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NK = natural killer; NOAEL = no-observed-adverse-effect level; PND = postnatal day WBC = white blood cell

If an intermediate-duration oral MRL was derived based on the lowest LOAEL of 0.0003 mg Hg/kg/day (0.3 µg Hg/kg/day) for immunodevelopmental effects and a total uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability), the intermediate-duration oral LOAEL for methylmercury would be 0.0003 µg Hg/kg/day. This value is lower that the chronic-duration oral MRL of 0.1 µg Hg/kg/day; therefore, an intermediate-duration oral MRL for methylmercury was not derived.

Agency Contacts (Chemical Managers): Rae Benedict

## Methylmercury Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Methylmercury
CAS Number: | 22967-92-6
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.1 µg Hg/kg/day
Critical Effect: | Neurodevelopmental effects (decreased IQ)
Reference: | Axelrad et al. 2007a, 2007b
Point of Departure: | NAEL of 0.41 µg Hg/kg/day
Uncertainty Factor: | 3
LSE Graph Key: | 173
Species: | Human

MRL Summary: A chronic-duration oral MRL of 0.0001 mg Hg/kg/day (0.1 µg Hg/kg/day) was derived based on neurodevelopmental effects (decreased full-scale IQ) in humans chronically exposed to methylmercury from consumption of dietary fish (Axelrad et al. 2007a, 2007b). The MRL is based on a NAEL of 0.00041 mg Hg/kg/day (0.41 µg Hg/kg/day) and a total uncertainty factor of 3 for human variability.

Selection of the Critical Effect: Studies conducted in animals (nonhuman primates and rodents) and human epidemiological studies provide strong support for the developing nervous system being the most sensitive target of methylmercury. In humans, severe neurodevelopmental effects (congenital Minamata disease) occurred in association with maternal ingestion of methylmercury in seafood (Harada 1995) and from ingestion of wheat contaminated with a methylmercury fungicide (Iraq outbreak) (Amin-Zaki et al. 1974). In both incidents, exposure levels were sufficient to produce severe neurological effects in adults. Studies of lower levels of prenatal exposures have largely focused on populations that consume large amounts of marine fish. In these populations, the dominant source of the mercury body burden derives from consumption of methylmercury in fish, providing a strong basis for use of BHG or HHg as a biomarker of methylmercury exposure. Studies of general populations have also relied on biomarkers for assessing exposure; however, in these populations, BHg and HHg will be more greatly affected by exposures to other forms of mercury, including mercury released from mercury amalgam dental restorations. Therefore, general population studies that estimated oral intake of methylmercury are stronger designs for the purpose of dose-response assessments of methylmercury.

Cognitive and neurosensory effects have been observed in association with prenatal exposures to methylmercury via maternal fish consumption. Consistent findings have been observed at relatively high exposure levels (e.g., Iraq outbreak, Minamata outbreak). However, results of studies that have explored lower exposure levels have been inconsistent. Some studies found improved function or no associations with mercury, and some studies found non-monotonic responses (e.g., declines at lower levels of exposure and improvements at higher levels). Differences in effect estimates may be due to differences in confounders and how they were controlled in models. These variables include fish intake and related nutritional factors (e.g., 3-omega polyunsaturated long-chain fatty acids), co-exposure to other contaminants (e.g., lead, PCBs), and social variables affecting child development. In addition, presence of genetic susceptibility factors (of lack thereof) may act as effect measure modifiers, impacting the associations observed between mercury and a health outcome.

Several high fish consuming populations have been studied to evaluate possible associations between prenatal mercury exposure and neurodevelopment. These include populations in the Amazon River basin, Arctic Canada, Faroe Islands, North Island New Zealand, and Seychelle Islands. Studies conducted in the Faroe Islands, North Island New Zealand, and Seychelle Islands are particularly important because of several features: (1) prospective design; (2) relatively large sample populations in main cohort (approximately 700–1,000); (3) high quality assurance procedures for biomarker measurements; (4) multiple follow-ups at different ages; (5) multiple tests of cognitive and neurosensory performance that assessed a wide range of cognitive domains; (6) extensive exploration and control of confounding; (7) assessments of biomarker measurement error (Faroe Islands and Seychelle Islands studies); and (8) multiple analyses of the data, which included linear and non-linear regression, cross-sectional and longitudinal analyses, individual and aggregated outcome metrics, and BMD analyses. For each study, observed biomarkers of exposure (e.g., BHg) were converted to estimates of oral mercury doses and categorized as either an AEL if an adverse effect was observed or a NAEL if no adverse effect was observed (Appendix E for definitions of AEL and NAEL).

Selection of the Principal Study: Neurodevelopmental outcomes from studies conducted on populations from the Faroe Islands, North Island New Zealand, and Seychelle Islands are summarized below. A summary of a meta-analysis that includes data from the Faroe Islands, North Island New Zealand, and Seychelle Islands is also described (Axelrad et al. 2007a, 2007b). In addition, detailed summaries of two studies evaluating neurodevelopmental outcomes in a large general population from Norway are included (Vejrup et al. 2016, 2018).

Faroe Islands study. The Faroe Islands study followed a prospective cohort of high fish and marine mammal consumers (n=1,022 mother-infant pairs, recruited 1986–1987) from age 2 weeks to 22 years. The primary methylmercury prenatal exposure metric was total mercury in cord blood, which was predominantly (>80%) methylmercury (Grandjean et al. 1992). The median cord blood mercury concentration was 24 µg Hg/L and the IQR (25^th^ to 75^th^ percentile range) was 13–40 µg Hg/L; approximately 25% of the cord mercury levels were >40 µg Hg/L (Grandjean et al. 1992). Cord blood mercury levels (µg Hg/L) were approximately 5 times maternal HHg levels measured at parturition with a median of 4.5 µg Hg/g, and an IQR of 2.5–7.7 (Grandjean et al. 1992). In most studies, depending on the outcome measured, outcome associations were adjusted for covariates: child age, sex, birth weight; breastfeeding; maternal age, alcohol, tobacco use, medical history; and caregiver general intelligence (Raven’s Progressive Matrices). Other potential confounders were also explored (e.g., fish consumption, blood selenium, blood PCBs).

The study found associations between prenatal (cord) BHg and decreasing performance on tests of cognitive function assessed at age 7 years (Grandjean et al. 1997, 1998, 2003, 2014; Oulhote et al. 2019), 14 years (Debes et al. 2006; Julvez et al. 2010), and 22 years (Debes et al. 2016). The associations were not consistently observed in all tests of cognitive function. The associations tended to cluster into domains of fluid reasoning (e.g., identifying rules for visual similarities and differences), comprehension and knowledge (e.g., naming, word synonyms and antonyms), decision and reaction speed, and motor coordination (Debes et al. 2016). Latencies of brainstem auditory evoked potentials measured at age 7 or 14 years increased in association with increasing prenatal or child HHg levels (Grandjean et al. 1997; Murata et al. 2004a).

Exposure measurement error based on estimation of biomarker imprecision was estimated to exceed laboratory measurement error (Grandjean and Budtz-Jorgensen 2007; Grandjean et al. 2004b). The observed associations with cognitive test outcomes persisted after excluding subjects who had large variability in HHg levels during pregnancy (Grandjean et al. 2003). Findings from the Faroe Islands included:

- Postnatal HHg levels correlated with duration of breastfeeding, although breastfeeding was not a significant explanatory variable for cognitive test outcomes in the cohort (Grandjean et al. 1995; Jensen et al. 2005).
- Blood selenium levels correlated with BHg levels and whale consumption (Grandjean et al. 1992); however, prenatal selenium level (cord blood) was not a significant explanatory variable for cognitive test outcomes in the cohort (Choi et al. 2008b).
- Although cord blood PCB concentration correlated with BHg levels, associations between cord blood mercury levels and cognitive tests scores persisted after adjustment for cord blood PCB concentrations (Grandjean et al. 1997). Analysis of data from the 7-year follow-up found no evidence of interactions between mercury and exposure to PCBs and long-chain perfluoroalkyls (Oulhote et al. 2019).
- Adjustment for cord serum omega-3 long-chain polyunsaturated fatty acids (LCPUFA) strengthened associations between prenatal mercury exposure and cognitive test scores or brainstem evoked potential latencies (Choi et al. 2008b; Yorifuji et al. 2013).

Additional details for the Grandjean et al. (1997, 1999) studies are summarized in Table A-18. These studies were included in the Axelrad et al. (2007a, 2007b) meta-analysis.

Table A-18 Summary of the Grandjean et al. (1997) and Grandjean et al. (1999) Studies of the Faroe Islands Population

Study type and population: Prospective study of birth cohort, follow-up at age 7 years (n=917)
Biomarkers:; BHg (geometric mean µg Hg/L, IQR); - Cord: 22.9 (13.4–41.3); - Child (7 years): 8.82 (4.8–18.2); HHg (geometric mean µg Hg/g, IQR); - Maternal: 4.27 (2.6–7.7); - Child (12 months): 1.12 (0.69–1.88); - Child (7 years): 2.99 (1.7–6.1)
Estimated oral dose^a^: 0.34 µg Hg/kg/day (based on cord BHg)
Analysis: Data were analyzed using multiple regression analysis. Outcome associations were adjusted for age and sex for all analyses. Additional covariates included strabismus (abnormal eye alignment) and eye glasses (VEP); current middle ear infection (BAEP); height (postural sway), maternal cognitive function, maternal smoking and alcohol use, social background, and major medical risk factors such as low birth weight, small-for-gestational date, history of head trauma and meningitis (neuropsychological tests); and child’s acquaintance with computers and computer games (computer-assisted tests). Data from neuropsychological tests were also analyzed using the Peters-Belson approach. In this approach, any regression coefficients with p<0.1 in the lowest quartile of cord blood (<15 µg Hg/L) group were included in multiple regressing models for all children. By identifying potential confounders in the lowest quartile BHg group, rather than in the full cohort, this approach may provide a less biased estimate of the association between mercury exposure and outcomes in the presence of confounding.
Results ^b^ :
Adjusted regression coefficients between cord BHg and neurophysiological tests; - BAEPL at 40 Hz; ○ I = 0.043, p=0.10; ○ III = 0.053, p=0.06; ○ V = 0.059, p=0.01; - VEPL at 15 minutes; ○ N75 = 0.21, p=0.70; ○ P100 = −0.75, p=0.33; ○ N145 = −0.99, p=0.37; - Postural sway; ○ Eyes open = −0.04, p=0.90; ○ Eyes closed = −1.54, p=0.09; ○ Eyes open, on foam = −0.43, p=0.40; ○ Eyes closed, on foam = −0.19, p=0.86; - HRV R-R interval: −0.39, p=0.29; Adjusted regression coefficients between cord BHg and neuropsychological tests; - WISC-R; ○ Digit span^c^ = −0.27, p=0.05; ○ Similarities^c^ = −0.05, p=0.90; ○ Block design^c^ = −0.17, p=0.11; - CVLT; ○ Learning = −1.25, p=0.12; ○ Short-term^c^ = −0.57, p=0.02; ○ Long-term = −0.55, p=0.05; ○ Recognition = −0.29, p=0.15; - BNT; ○ No cues^c^ = −1.77, p=0.0003; ○ Cues = −1.91, p=0.0001; - BVMGT; ○ Copy error^c^ = 0.67, p=0.15; ○ Reproduction = −0.25, p=0.10; - NES FTT; ○ D hand = −1.10, p=0.05; ○ ND hand = −0.39, p=0.46; ○ Both hands = −1.67, p=0.14; - NES HECT = 0.034, p=0.19; - NES CPT; ○ Missed response = 0.12, p=0.02; ○ Reaction time = 40.3, p=0.001; - TPT (D hand) = −14.3, p=0.63; - NVAPMS; ○ Positive moods = 2.61, p=0.31; ○ Negative moods = −0.04, p=0.99 | Peters-Belson regression coefficients between cord BHg and neuropsychological tests; - NES FTT; ○ D hand =−1.18, p=0.03; ○ ND hand = −0.37, p=0.47; ○ Both hands = −1.86, p=0.08; - NES HECT = 0.033, p=0.20; - NES CPT; ○ Missed response = 0.14, p=0.007; ○ Reaction time = 38.2, p=0.0002; - WISC-R; ○ Digit span^c^ = −0.27, p=0.05; ○ Similarities^c^ = 0.14, p=0.70; ○ Block design^c^ = −0.25, p=0.02; - CVLT; ○ Learning = −1.30, p=0.11; ○ Short-term^c^ = −0.63, p=0.009; ○ Long-term = −0.64, p=0.02; ○ Recognition = −0.28, p=0.15; - BNT; ○ No cues^c^ = −1.66, p=0.0007; ○ Cues = −1.82, p=0.0002; - BVMGT; ○ Copy error^c^ = 1.04, p=0.03; ○ Reproduction = −0.16, p=0.31; - TPT (D hand) = −18.8, p=0.60; - NVAPMS; ○ Positive moods = 2.39, p=0.34; ○ Negative moods = 0.17, p=0.94; Adjusted regression coefficients between cord BHg and neuropsychological tests in low exposure children only (maternal HHg <10 µg Hg/g); - WISC-R; ○ Digit span^c^ = −0.31, p=0.05; ○ Similarities^c^ = 0.65, p=0.15; ○ Block design^c^ = −0.13, p=0.27; - CVLT; ○ Learning = −1.55, p=0.10; ○ Short-term^c^ = −0.74, p=0.009; ○ Long-term = −0.56, p=0.08; ○ Recognition = −0.22, p=0.34; - BNT; ○ No cues^c^ = −1.42, p=0.01; ○ Cues = −1.57, p=0.005; - BVMGT; ○ Copy error^c^ = 0.71, p=0.19; ○ Reproduction = −0.43, p=0.02; - CBCL; - NES FTT; ○ D hand = −0.68, p=0.29; ○ ND hand = −0.13, p=0.83; ○ Both hands = −0.62, p=0.63; - NES HECT = 0.033, p=0.28; - NES CPT; ○ Missed response = 0.21, p=0.0005; ○ Reaction time = 46.9, p=0.0003; - TPT (D hand) = −11.3, p=0.76; - NVAPMS; ○ Positive moods = 3.66, p=0.20; ○ Negative moods = 1.83, p=0.51

a See Calculations for how oral mercury doses were calculated.

b Interpretation of neurobehavioral test scores:

- Age of crawling, sitting, or walking: increase = delay in development
- BVMGT: higher score = lower performance
- BNT: higher score = higher performance
- CTRS: higher score = higher behavioral problems
- CVLT: higher score = higher performance
- Digit span: higher score = higher performance
- NES CPT: longer response time = lower performance
- NES FTT: higher score = higher performance
- NES HECT: higher score = higher performance
- Neurologic optimality score: higher score = higher performance
- NVAPMS: higher score = more negative mood
- Postural sway: higher score = lower performance
- RSPM: higher score = lower performance
- Spatial span: higher score = higher performance
- ST-BI copying: higher score = higher performance
- WFRT: higher score = higher performance
- WISC-R: higher score = higher performance
- WJTA: higher score = higher performance
- WMS: higher score = higher performance

c Metric included in the meta-analysis by Axelrad et al. (2007a, 2007b).

BAEPL = brain steam auditory evoked potential latencies; BHg = blood mercury; BNT = Boston Naming Test; BVMGT = Bender Visual Motor Gestalt Test; CBCL = Child Behavior Checklist; CPT = Continuous Performance Task; CVLT = California Verbal Learning Test; FTT = Finger Tapping Test; HECT = Hand-Eye Coordination Test; HHg = hair mercury; HRV R-R = Heart Rate Variability of electrocardiogram RR interval; IQR = interquartile range; NES = Neurobehavioral Evaluation System; NVAPMS = Nonverbal Analogue Profile of Mood States; TPT = Tactual Performance Test; VEPL = visual evoked potential; VEPL = visual evoked potential latencies; WISC-R = Weschler Intelligence Scale for Children, Revised

New Zealand study. The New Zealand study followed a prospective cohort to age 6 years (Kjellstrom et al. 1989). The original cohort consisted of 10,930 children and mother pairs recruited in 1978. Consumption of marine fish was the major contributor to methylmercury exposure in this population. The prenatal exposure metric was the average total mercury in maternal hair during pregnancy. A subset of 935 high consumer subjects was selected based on consumption ≥4 fish meals per week. HHg levels in this group ranged from 6 to 86 µg Hg/g. From the ≥4 fish meals per week group, a subset of 73 high consumers was selected based on HHg level >6 µg Hg/g, from which 38 were tested at age 4 years, along with a set of 31 matched referents from mothers who consumed no more than one fish meal per week and matched for maternal ethnic group, age, residence time in New Zealand, tobacco smoking, and child birth date and sex. Assessment of neurodevelopmental outcomes occurred at age 4 and 6 years. At age 4 years, children were assessed for performance on the DDST (function, language, and personal-social behavior), Sheridan-Gardiner Letter Matching Test or Miniature Toy Test (vision), and tactile sensory function (touch, temperature), and parents were surveyed with a questionnaire on child health and neurological signs (Kjellstrom et al. 1986). The OR for abnormal or questionable scores on the DDST at age 4 years (n=31, relative matched referents) was 6.5 (p<0.005). Performance of high exposure children on vision and sensory function tests were not different from matched referents.

At age 6 years, 61 children in the high exposure group were re-evaluated, along with a set of three referent groups (n=58–60), each matched with the high exposure group for maternal ethnic group, age, residence time in New Zealand, tobacco smoking, and child birth date and sex (Kjellstrom et al. 1989). The geometric mean maternal HHg level was 8.3 µg Hg/g (range 6–86 µg Hg/g) in the high exposure group. Geometric mean HHg levels in the three referent groups ranged from 2.0 to 4.5 µg Hg/g. Children were assessed for cognitive performance, academic attainment, language development, motor coordination, intelligence, and behavior. Language development was assessed from performance on the TOLD (phonology, syntax, semantics) and Peabody picture vocabulary test (word knowledge). Intelligence was assessed using the McCarthy Scales for Children’s Abilities (MSCA) and WISC. Increased maternal HHg was associated with lower scores on the TOLD spoken language quotient and WISC full-scale IQ and McCarthy perceptual scale. When the high exposure group (Group 1) was split into two maternal HHg categories, 6–<10 or ≥10 µg Hg/g, a larger fraction of variance in the TOLD and WISC tests was explained by that higher HHg category. Performance on the TOLD spoken language quotient was inversely associated with the HHg in lower category only (6–<10 µg Hg/g), whereas performance on both the TOLD spoken language quotient and WISC full scale were inversely associated with HHg in the higher category (≥10 µg Hg/g). Children scored as having an abnormal DDST at age 4 years had lower WISC full-scale IQ scores at age 6 years. Additional details of the Kjellstrom et al. (1989) study, which is included in the Axelrad et al. (2007a, 2007b) meta-analysis, are provided in Table A-19.

Table A-19 Summary of the Kjellstrom et al. (1989) Study of the North Island, New Zealand Population

Study type and population: Prospective study of birth cohort, follow-up at age 6 (n=238; 61 with high mercury exposure [maternal fish consumption ≥4 meals per week and HHg >6 µg Hg/L]) and matched referents from three referent populations (n=57 per group)
Biomarkers:; Maternal HHg (geometric mean µg Hg/g, range); - High mercury: 8.3 (6–86); - Referent 2 (≥4 fish meals/week): 4.5 (3–5.99); - Referent 3 (≥4 fish meals/week): 2.0 (0.1–2.99); - Referent 4 (≤3 fish meals/week): 2.0 (0.1–2.99)
Estimated oral dose^a^: 0.62 μg Hg/kg/day (based on high mercury group)
Analysis: Data were analyzed using robust weighted multiple regression analysis. This approach can decrease potential bias from outlier observations. Outcome associations were adjusted for significant covariates; variables explored included: maternal ethnic group, age, smoking and alcohol consumption, residence time in New Zealand, social class, language spoken at home, siblings, duration of breastfeeding, and child sex and birth weight, maturity at birth, and Apgar score.
Results ^b^ :; Adjusted regression coefficients between HHg (>6 µg Hg/g) and measures of intelligence; - WISC-R (FSIQ)^c^ = −4.41, p=0.019; - WISC-R (PIQ)^c^ = −3.79, p=0.072; - MSCA (perceptual scale)^c^ = −4.23, p=0.0034; Adjusted regression coefficients between HHg (>6 µg Hg/g) and measures of language development; - TOLD^c^ = −5.48, p=0.0064; Adjusted regression coefficients between HHg (>6 µg Hg/g) and measures of motor coordination; - MSCA (motor scale) = −2.36, p=0.074

a See Calculations for how oral mercury doses were calculated.

b Inverse associations indicate declining performance.

c Metric included in the meta-analysis by Axelrad et al. 2007a, 2007b.

HHg = hair mercury; FSIQ = Full-Scale Intelligence Quotient; MCSA = McCarthy Scale of Children’s Abilities; PIQ = Performance Intelligence Quotient; TOLD = Test of Language Development; WISC-R = Wechsler Intelligence Scales for Children, Revised

Seychelle Islands study. The Seychelle Islands study followed a prospective cohort of high fish consumers (n=779 mother-infant pairs, recruited 1989–1990) from age 6 months to 24 years. The primary methylmercury exposure metric was the average maternal gestational HHg level. Methylmercury accounted for >80% of total mercury in hair (Cernichiari et al. 1995). Annual median maternal HHg levels measured over the period 1986–1989 ranged from 5.9 to 8.2 µg Hg/g; the highest observed value was 36 µg Hg/g (Cernichiari et al. 1995). The main cohort, followed from age 6 months and later, had a median prenatal maternal level of 5.9 µg Hg/g (range 0.5–26.7 µg Hg/g) (Myers et al. 1995). Approximately half of the maternal HHg levels were ≤6 µg Hg/g, while the highest 15% (approximately 95 women) were >12 µg Hg/g; therefore, the power to discern significant associations was higher at HHg levels <12 µg Hg/g. Outcome associations were adjusted for covariates that included (in most studies): child sex, birth weight, birth order, gestational age, medical history and breastfeeding; maternal age, alcohol and tobacco use, and medical history; parental education, caregiver general intelligence (Raven’s Progressive Matrices), family income, family language, home learning, and social stimulation (HOME score).

The Seychelle Islands has not found consistent evidence for associations between prenatal exposure (maternal HHg) and neurodevelopmental outcomes at any age studied thus far. This conclusion is supported by cross-sectional follow-ups of the cohort from ages 6.5 months to 24 years (Davidson et al. 1995, 1998, 1999, 2008a, 2010, 2011; Huang et al. 2005; Myers et al. 1995, 1997, 2000, 2003, 2009, 2020; Orlando et al. 2014; Thurston et al. 2022; van Wijngaarden et al. 2009, 2013, 2017; Young et al. 2020), longitudinal analyses of individual outcome metrics (Axtell et al. 1998; Davidson et al. 1998; Myers et al. 1997), and longitudinal analysis of metrics of global cognition based on aggregation of outcome metrics (Davidson et al. 2006a). Accounting for error in measuring HHg levels (and other covariates) had no appreciable effect on dose-response models assessed at 66 months (Huang et al. 2003). Although linear regression models consistently found no association between exposure (maternal or child HHg) and cognitive development, nonlinear models of cognitive test scores suggested that performance improved or declined in association with prenatal maternal HHg or child HHg, depending on the hair level (Axtell et al. 1998, 2000; Davidson et al. 1998, 2006a; Huang et al. 2005, 2007, 2018; Myers et al. 1997, 2003, 2020). For some outcomes, performance declined at lower HHg levels (e.g., ≤7 µg Hg/g), but improved at higher levels, and, for some outcomes, the opposite pattern was observed. At age 66 months, lower performance was not evident in a subgroup of the cohort that had a mean HHg level of 15.3 µg Hg/g (>85^th^ percentile) (Davidson et al. 1998). It is uncertain if these nonlinear patterns reflect actual dose-level effects, differential statistical power across the HHg range, or, possibly, random outcomes from the numerous (>20) tests evaluated (Axtell et al. 2000; Davidson et al. 2006b; Huang et al. 2005, 2007). Age of walking increased with increasing prenatal maternal HHg over the range 1–7 µg Hg/g, however; the effect size was <1 day and the association was not evident at higher levels of HHg (Axtell et al. 1998). Aggregating scores of cognitive performance into metrics of global cognitive function (Davidson et al. 2006a) or dichotomizing test scores into a binomial metric (benchmark response) also revealed no associations in cognitive development and prenatal maternal HHg <20 µg Hg/g (Crump et al. 2000; van Wijngaarden et al. 2006, 2009). After correction of statistical significance criteria for multiple comparisons, no association was found between mercury exposure and general cognition or fine motor speed assessed at ages 9, 10.5, 17, 19, 22, or 24 years (Thurston et al. 2022). Associations between exposure and cognitive function were modified by an interaction with maternal omega-3 fatty acid status, a source of negative confounding through fish consumption (Strain et al. 2008, 2012, 2021). Study details for the Myers et al. (2003) studies are summarized in Table A-20. These studies were included in the Axelrad et al. (2007a, 2007b) meta-analysis.

Table A-20 Summary of the Myers et al. (2003) Study of the Seychelle Islands Population

Study type and population: Prospective study of birth cohort, follow-up at age 9 years (n=643 of 779 in cohort)
Biomarkers:; Maternal HHg (mean µg Hg/g, SD); - 6.9 (4.5)
Estimated oral dose^a^: 0.51 µg Hg/kg/day (based on mean maternal HHg)
Analysis: Data were analyzed using multiple regression analysis. Outcome associations were adjusted for sex, examiner, family resource scale, family status (number of biological parents in the home), Henderson early learning process scale, child’s age at testing, child’s medical history of IUGR or head circumference >2 SD from normal, maternal age, home observation for measurement of the environment (HOME) score, caregiver intelligence, socioeconomic status, and hearing.
Results ^b^ :
Adjusted regression coefficients (95% CI for a 10 μg Hg/g change in HHg) for measures of general intelligence, cognition and achievement; - WISC-III FSIQ^c^ = −0.13 (−3.3, 0.7), p=0.20; - CVLT; ○ Short^c^ = 0.013 (−0.1, 0.3), p=0.19; ○ Long = 0.011 (−0.1, 0.3), p=0.28; - BNT^c^ = −0.012 (−1.0, 0.8), p=0.79; - WJTA; ○ LWR = 0.19 (−5.8, 9.6), p=0.62; ○ AP = −0.057 (−3.5, 2.4), p=0.71; Adjusted regression coefficients (95% CI for a 10 μg Hg/g change in HHg) for measures of motor, perceptual motor, and memory; - VMI^c^ = −0.010 (−2.4, 2.2), p=0.93; - BOT = 0.093 (−0.2, 2.0), p=0.10; - HAPDT = −0.010 (−0.5, 0.3), p=0.60; - Grooved peg board; ○ D hand = 3.3×10^−5^ (91.4, 98.1), p=0.08; ○ ND hand, male = 6.5×10^−5^ (101.7, 112.9), p=0.01; ○ ND hand, female = −2.5×10^−5^ (100.0, 111.3), p=0.34; - FTT; ○ D hand = −0.050 (−1.5, 0.5), p=0.34; ○ ND hand = 0.016 (−0.6, 1.0), p=0.69; - WRAML^c^ = −0.021 (−0.8, 0.4), p=0.48 | Adjusted regression coefficients (95% CI for a 10 μg Hg/g change in HHg) for measures of attention and behavior; - CPT; ○ Reaction time = −0.13 (−4.4, 1.8), p=0.41; ○ Attention = −0.0063 (−2.1, 2.0), p=0.95; ○ Risk taking = 0.11 (−3.1, 5.4), p=0.60; - CBCL = −0.031 (−2.3, 1.7), p=0.76; - CTRS = −0.0067 (49.4, 54.1), p=0.004; Adjusted regression coefficients (95% CI for a 10 μg Hg/g change in HHg) for measures of motor, perceptual motor, and memory; - Trail making; ○ A = 0.0037 (32.5, 37.6), p = 0.33; ○ B = 0.0067 (79.1, 96.0), p=0.17; - FTT; ○ D hand = −0.050 (−1.5, 0.5), p=0.34; ○ ND hand = 0.016 (−0.6, 1.0), p=0.69; - WRAML^c^ = −0.021 (−0.8, 0.4), p=0.48

a See Calculations for how oral mercury doses were calculated.

b Interpretation of neurobehavioral test scores:

- Age of talking or walking: increase = delay in development
- Barkley ADHD: higher score = lower performance
- BNT: higher score = higher performance
- BOT: higher score = higher performance
- BVMGT: higher score = lower performance
- CANTAB: higher score = higher performance
- CVLT: higher score = higher performance
- FTII: higher score = higher performance
- BSID IBR: higher score = higher performance
- BSID MDI: higher score = higher performance
- BSID PDI: higher score = higher performance
- BVMGT: higher score = lower performance
- CBCL: higher score = lower performance
- CDI: higher score = higher performance
- CELF-5: higher score = higher performance
- CTRS: higher score = lower performance
- CVLT: higher score = higher performance
- DDST: milestones evaluated against a standard; below standard = delayed development
- DSA: higher score = higher performance
- Finger tapping: higher score = higher performance
- GPB: higher score = lower performance
- HAPDT: higher score = higher performance
- KBIT-2: higher score = higher performance
- MSCA: higher score = higher performance
- PLS: higher score = higher performance
- SCQ: higher score = higher performance
- SRS-2: higher score = higher performance
- Stroop interference: higher score = higher performance
- TSRSS: higher score = higher performance
- VEXP: higher score = higher performance
- WJTA: higher score = higher performance
- WRAML: higher score = higher performance

c Metric included in the meta-analysis by Axelrad et al. (2007a, 2007b).

AP = applied problems; BNT = Boston Naming Test; BOT = Bruininks-Oseretsky Test of Motor Proficiency; CBCL = Child Behavior Checklist; CI = confidence interval; CPT = Continuous performance task; CTRS = Connors’ Teacher Rating Scale (hyperactivity index); CVLT = California Verbal Learning Test; D = dominant; FSIQ = full-scale intelligence quotient; FTT = Finger Tapping Test; HAPDT = Haptic Discrimination Test; HHg = hair mercury; HOME = Home Observation Measurement of the Environment; IUGR = intrauterine growth retardation; LWR = letter word recognition; ND = non-dominant; SD = standard deviation; VMI = Visual Motor Integration; WJTA = Woodcock-Johnson Test of Achievement; WISC-III = Wechsler Intelligence Scales for Children, 3^rd^ ed.; WRAML = Wide Range Assessment of Memory and Learning

Meta-analysis of Faroe Islands, North Island, New Zealand, and Seychelles Islands studies. Two meta-analyses of the populations from the Faroe Islands, North Island, New Zealand, and Seychelles Islands have been conducted; these are reported in publications by Axelrad et al. (2007a, 2007b) Cohen et al. (2005), and Ryan (2008). In the more recent analysis, Axelrad et al. (2007a, 2007b; Ryan 2008) converted regression slopes for several cognitive test scores measured in each study into an IQ point scale (Axelrad et al. 2007a, 2007b). The meta estimate for the effect size was −0.18 IQ points per increase of 1 µg Hg/g hair (95% CI −0.378, −0.009). The meta-analysis is described in detail in the Summary of the Principal Study section. Ryan (2008) reported a sensitivity analysis of the meta-slope from Axelrad et al. (2007a, 2007b).

Cohen et al. (2005) used a similar analytical approach as Axelrad et al. (2007a, 2007b) in a meta-analysis of the Faroe Islands, North Island, New Zealand, and Seychelles Islands studies. However, Cohen et al. (2005) included results from a wider selection of cognitive tests. The meta estimate from Cohen et al. (2005) was an average decrease of 0.043 SDs in cognitive performance per increase of 1 µg Hg/g maternal hair. For a SD of 15 IQ points, the meta estimate corresponds to an equivalent change in IQ of 0.7 points per 1 µg Hg/g hair, with a plausible range of 0 to 1.5 points per 1 µg Hg/g hair (Cohen et al. 2005).

The Axelrad et al. (2007a, 2007b) meta-analysis was selected as the principal study over the Cohen et al. (2005) because bounds on the meta-estimate from the Cohen et al. (2005) meta-analysis were wider and included zero. A likely contributor to this difference was the inclusion of a wider selection of outcomes in the Cohen et al. (2005) metal-analysis.

Norwegian Mother and Child Cohort Study. In addition to the above studies of high fish consumers, a large prospective study of a general population found associations between dietary fish mercury intake and language proficiency (Vejrup et al. 2016, 2018, Table A-21). This study examined a birth cohort consisting of 46,750 mother-infant pairs recruited during the period 1999–2008 with outcomes measured at age 3 years (Vejrup et al. 2016) and 5 years (Vejrup et al. 2018). Dietary intake of mercury from fish consumption was estimated in each mother based on outcomes of a food frequency questionnaire completed during pregnancy and a survey of mercury levels in fish consumed by Norwegians (Jenssen et al. 2012). Median fish consumption was estimated to be 32 g/day. Median mercury intake from consumption of fish was estimated to be 0.14 µg Hg/kg/week. The 90^th^ percentile was 0.29 µg Hg/kg/week (Vejrup et al. 2016). Estimation of dietary intakes of mercury in fish (which is dominated by methylmercury) precluded reliance on biomarkers as dose metrics for methylmercury exposure. The study evaluated language proficiency and communication skills using parent-reported questionnaires. This study found associations between increasing dietary intake of mercury in fish with decreasing performance on language proficiency tests administered at age 3 and 5 years. These associations persisted after adjustment for known important confounders related to fish consumption, including fish consumption rate (adjustment strengthened the association with mercury), 3-omega LCPUFA consumption, and exposure to PCBs (Vejrup et al. 2016). The language outcomes associated with mercury intake (>0.29 µg Hg/kg/week) were described as “unintelligible speech” on the Dale and Bishop Grammar Rating and “weak communication development” on the Ages and Stages Communication Scale.

In a follow-up at age 5 years, children were assessed with three outcome tests: Ages and Stages Communication Scale, Speech and Language Assessment Scale, and Twenty Statements about Language-Related Difficulties. At age 5 years, in the full cohort (n=38,297) among women who consumed <400 g fish/week, both fish consumption and mercury intake were associated with improvement of scores (negative error scores) in the Ages and Stages Communication Scale and Speech and Language Assessment Scale. When the analysis was confined to matched siblings (n=7,404), dietary fish mercury intake at the 90^th^ percentile level (>3.18 µg Hg/day) was associated with decreasing performance on the Speech and Language Assessment Scale but not on the Ages and Stages Communication Scale or Language-Related Difficulties scale. No associations were observed with mid-pregnancy maternal BHg concentrations in a subcohort of the main cohort (2,239 subjects) in which BHg levels were measured (median 1.0 µg Hg/L; range 0, 14 µg Hg/L) (Vejrup et al. 2018). These results suggest that fish intake was a confounding variable in this study (correlation between dietary fish mercury intake and dietary seafood intake was 0.88) and may have attenuated associations between dietary methylmercury intake and delays in attainment of language skills. The absence of an association with maternal BHg may represent variance in BHg levels that is unrelated to dietary methylmercury intake (e.g., mercury from amalgam restorations).

Table A-21 Summary of the Vejrup et al. (2016, 2018) Studies of the Norwegian Population

Study: Vejrup et al. 2016
Study type and population: Prospective cohort of mother-infant pairs, follow-up at age 3 years (n=46,750)
Estimated oral dose: 0.041 μg Hg/kg/day (based on 90^th^ percentile weekly intake); - Maternal dietary mercury intake from fish (median):; ○ 1.3 µg Hg/day; ○ 0.14 µg Hg/kg/week; - 90^th^ percentile:; ○ 2.6 µg Hg/day; ○ 0.29 µg Hg/kg/week
Analysis: Maternal methylmercury was estimated based on fish intake reported in an FFQ administered mid-pregnancy. Outcomes evaluated were performance on the Dale Bishop Grammar Rating and Ages and Stages communication scale (ASQ). ORs were calculated to assess risk in children with high mercury exposure, defined as >90^th^ percentile (>2.64 µg Hg/day, >0.29 µg Hg/kg/week), compared to children with mercury exposure <90^th^ percentile. ORs were adjusted for parity, maternal education, paternal education, pre-pregnancy BMI, bilingual parents, and age of child when reporting language development. Additional models were further adjusted for intake of lean and oily fish, n-3 LCPUFA from diet, n-3 LCPUFA from supplements, and dioxin and PCB exposures.
Results:; Adjusted OR (95% CI) between high prenatal methylmercury exposure (>90^th^ percentile) and language development for Dale and Bishop Grammar rating (n=46,750); - Complete grammar (reference): 1; - Low grammar: 1.01 (0.93, 1.10); - Moderate delay: 1.06 (0.88, 1.26); - Unintelligible speech: 2.22 (1.31, 3.72); - Severe delay: 1.04 (0.69, 1.57); Further adjusted for intake of lean and oily fish; - Unintelligible speech: 3.02 (1.47, 6.21); Adjusted OR (95% CI) between high prenatal methylmercury exposure (>90^th^ percentile) and communication development (ASQ, n=45,332); - Normal skills (reference): 1; - Weak skills: 1.33 (1.03, 1.70); Further adjusted for intake of lean and oily fish; - Weak skills: 1.46 (1.07, 2.00)
Study: Vejrup et al. 2018
Study type and population: Prospective cohort of mother-infant pairs, follow-up at age 5 years (n=38,581)
Biomarker: Maternal BHg 1.03 µg Hg/L (median; n=2,239)
Estimated oral dose^a^: 0.049 μg Hg/kg/day (based on 90^th^ percentile adjusted for 65 kg body weight); - Maternal dietary mercury intake from fish; ○ Median: 0.15 µg Hg/kg/week; ○ 90^th^ percentile: 3.18 µg Hg/week
Analysis: Outcomes evaluated were performance on the Speech and Language Assessment Scale, Ages and Stages communication scale, and Twenty Statements about Language-Related Difficulties. Data were analyzed using multiple regression analysis. Outcome associations were adjusted for maternal age, education, parity, pre-pregnancy BMI, Hopkins Symptom Checklist-5 (SCL-5), total energy intake, eicosapentaenoic acid and docosahexaenoic acid (DHA) from total diet and/or supplement. A sibling fixed-effect analysis was also conducted.
Results:; Adjusted regression coefficients (95% CI) between maternal BHg and measures of language and communication (n=2,239), NS; - ASQ: −0.02 (−0.1, 0.03); - Language 20: 0.01 (−0.03, 0.05); - SLAS: −0.01 (−0.1, 0.03); Adjusted regression coefficients (95% CI) between dietary seafood mercury intake >400 g/week and measures of language and communication (n=4,375), NS; - ASQ: 0.1 (−0.1, 0.4); - Language 20: 0.31 (−0.01, 0.6); - SLAS: −0.17 (−0.4, 0.1); Adjusted regression coefficients (95% CI) between maternal seafood intake >400 g/week and measures of language and communication (n=38,297), p<0.05; - ASQ: −0.06 (−0.1, −0.01); - Language 20: −0.05 (−0.1, −0.01); - SLAS: −0.07 (−0.1, −0.03); Adjusted regression coefficients (95% CI) between >90^th^ percentile maternal dietary mercury intake and measures of language and communication in sibling fixed effect analysis (n=647); - ASQ: 0.03 (−0.1, 0.1), NS; - Language 20: 0.02 (−0.1, 0.1), NS; - SLAS: 0.1 (0.01, 0.2), p<0.05

a See Calculations for how oral mercury doses were calculated.

ASQ = Ages and Stages Communication Scale; BHg = blood mercury; BMI = body mass index; CI = confidence interval; DHA = docosahexaenoic acid; FFQ = food frequency questionnaire; Language 20 = Twenty Statements about Language-Related Difficulties; NS = not specified; OR = odds ratio; SLAS = Speech and Language Assessment Scale

Given the variable outcomes within and across the Faroe, New Zealand, and Seychelles studies of high fish consumers, selection of a single population as the basis for the MRL was not considered an ideal approach. Instead, the Axelrad et al. (2007a, 2007b) meta-analysis was considered a better representation of the weight of evidence from the three high fish consumer studies. The meta-analysis was selected over the Norwegian Mother and Child Cohort Study (Vejrup et al. 2016, 2018) as the principal study after weighing strengths and weaknesses of both studies (Table A-22). The key strength of the Axelrad et al. (2007a, 2007b) meta-analysis is that it included outcomes from multiple tests of cognitive performance from three independent prospective studies (approximately 1,800 subjects) after transforming the data into a global metric of full-scale IQ, which can be more readily generalized than individual test scores. The analysis included a test of language proficiency (New Zealand study, Test of Language Development). Language development was also evaluated in the Norwegian Mother and Child Cohort Study, using a different set of tests (Ages and Stages Communication, Dale Bishop Grammar Rating, Speech and Language Assessment Scale) (Vejrup et al. 2016, 2018). The studies included in the meta-analysis also provided biomarkers of exposure in each individual subject, which is likely to have decreased exposure misclassification inherent to using data from dietary recall and national data on mercury concentrations in recalled fish meals, as was used in the Norwegian Mother and Child Cohort Study.

Table A-22 Strengths and Weaknesses of Axelrad et al. (2007a, 2007b) and Vejrup et al. (2016, 2018) for Establishing a Point of Departure for the Chronic-Duration Oral MRL for Methylmercury

Study | Strengths | Weaknesses
Axelrad et al. 2007a, 2007b; meta-analysis of Faroes, New Zealand, and Seychelles studies of high fish consumers | - Utilized and weighted data from three independent prospective studies (total number ~1,800); - Direct measure of individual subject exposure from biomarker (hair mercury); - Subjects were high fish consumers, which strengthens association between biomarkers and exposure to methylmercury; - Included multiple tests of cognitive performance scaled to equivalent IQ points; - Language proficiency included as an outcome metric; - Sensitivity analysis indicated a narrow range for the effect size estimate; - Effect size reported as linear regression β that can be transformed into a di minimis change in the biomarker (or equivalent dose); e.g., change in dose above background dietary level associated with a 1-point change in IQ | - Pharmacokinetic model needed to transform biomarkers to equivalent mercury intakes; - To derive MRL, must select magnitude of change in IQ that corresponds to an IQ POD; - Effect size may have been depressed by negative confounding with nutritional benefits from high fish consumption
Vejrup et al. 2016, 2018; Norwegian Mother and Child Cohort Study of general population | - Large prospective study; - Larger size of cohort (~47,000 subjects) of general population, with lower fish consumption than high consumption studies | - Associations with dietary methylmercury intake were based on a semi-quantitative food survey and national data on fish mercury concentrations, rather than biomarkers of mercury exposure in individual subjects; - The association with dietary methylmercury intake predicted lower language proficiency at age 3 years, whereas the association predicted higher proficiency at age 5 years; - In a subset of the cohort with measurements of individual subject BHg levels, there was no association between language proficiency and BHg; - Outcome evaluation was limited language proficiency, which was assessed using a parental self-report survey of their children and not by unbiased experts

BHg = blood mercury; CI = confidence interval; FFQ = food frequency questionnaire; IQ = intelligence quotient; MRL = Minimal Risk Level; POD = point of departure

Summary of the Principal Study:

- Axelrad DA, Bellinger DC, Ryan LM, . 2007a. Dose-response relationship of prenatal mercury exposure and IQ: An integrative analysis of epidemiologic data. Environ Health Perspect 115(4):609–615. 10.1289/ehp.9303.17450232
- Axelrad DA, Bellinger DC, Ryan LM, . 2007b. Supplemental material: Dose-response relationship of prenatal mercury exposure and IQ: An integrative analysis of epidemiologic data. Environmental health perspectives. https://ehp.niehs.nih.gov/action/downloadSupplement?doi=10.1289%2Fehp.9303&file=9303_suppl.pdf. March 18, 2021.
- Ryan L. 2008. Combining data from multiple sources, with applications to environmental risk assessment. Statist Med 27:698–710. 10.1002/sim.3053.

The meta-analysis included outcomes from the Faroe Islands study at age 7 years, New Zealand study at age 6 years, and Seychelles Islands study at age 9 years (Axelrad et al. 2007a, 2007b). Outcomes included in the analysis are summarized in Table A-23. Additional study details are provided in Table A-24.

Table A-23 Cognitive Performance Tests^a^ Included in Meta-analysis of Faroe Islands, New Zealand, and Seychelle Islands Studies

Cognitive domain | Faroe Islands | New Zealand | Seychelles Islands
General intelligence | WISC-R (full-scale IQ) | WISC-R (full-scale IQ) WISC-R (performance IQ) | WISC-III (full-scale IQ)
Verbal learning and memory | CVLT (short term) | NE | CVLT (short term)
Visual-motor integration | BGT | NE | VMI
Visual memory | NE | NE | WRAML (design memory)
Confrontational naming | BNT (no cues) | NE | BNT (total score)
General development | NE | MSCA (perceptual) | NE
General verbal skills | NE | TOLD (spoken language coefficient) | NE
Visual memory | NE | NE | WRAML (design memory)

a Regression slopes derived in these tests were rescaled to full-scale IQ.

BGT= Bender Gestalt Test; BNT = Boston Naming Test; CVLT = California Verbal Learning Test; IQ = intelligence quotient; MSCA = McCarthy Scales of Children’s Abilities; NE = not evaluated; TOLD = Test of Language Development; VMI = Visual–Motor Integration; WISC-R = Wechsler Intelligence Scales for Children, Revised; WISC-III = Wechsler Intelligence Scales for Children, 3rd ed.; WRAML = Wide Range Assessment of Memory and Learning

Table A-24 Summary of the Axelrad et al. (2007a, 2007b) Meta-Analysis Study

Study type and population: Meta-analysis of prospective birth cohorts in Faroe Islands (n=917), Seychelles Islands (n=643), and New Zealand (n=237; Grandjean et al. 1997, 1999; Kjellstrom et al. 1989; Myers et al. 2003) with follow-up at age 7, 9, and 6 years, respectively
Estimated oral dose: 0.41 µg Hg/kg/day (based on 1 IQ point per 5.56 µg Hg/kg/day; −0.18 IQ points per µg Hg/g hair)
Analysis: Bayesian hierarchical modeling integrated data from the three study populations. A primary mercury-IQ dose-response analysis model was built using metrics with coefficients that were rescaled to be interpretable in the same scale as FSIQ estimates. FSIQ for the Faroe Islands data was estimated by combining three WISC subsets (Digit Span, Similarities, Block Design), which Axelrad et al. (2007a, 2007b) concluded would provide valid estimates of full-scale IQ.
Results:
Rescaled regression coefficients (SE) for cognitive endpoints from the Faroe Islands; - WISC-R (FSIQ) = −0.124 (0.057); - BGT = −0.104 (0.083); - BNT = −0.260 (0.086); - CVLT = −0.169 (0.093); Rescaled regression coefficients (SE) for cognitive endpoints from the Seychelle Islands; - WISC-III (FSIQ) = −0.17 (0.130); - CVLT = 0.19 (0.144); - BNT = −0.038 (0.144); - WRAML = −0.109 (0.15); - VMI = −0.013 (0.15); Rescaled regression coefficients (SE) for cognitive endpoints from New Zealand; - WISC-R (FSIQ) = −0.50 (0.268); - WISC-R (PIQ) = −0.51 (0.310); - TOLD = −0.56 (0.282); - MSCA = −0.80 (0.315) | Estimated IQ decrement per µg Hg/g maternal HHg (95% CI), at different R levels (ratio of study-to-study variability relative to endpoint-to-endpoint variability); - 4.0 = −0.188 (−0.398, −0.010); - 3.5 = −0.182 (−0.390, −0.007); - 3.0 = −0.180 (−0.378, −0.009); - 2.5 = −0.183 (−0.384, −0.017); - 2.0 = −0.178 (−0.371, −0.012); - 1.5 = −0.168 (−0.360, −0.003); - 1.0 = −0.165 (−0.338, −0.015); - 0.5 = −0.160 (−0.321, −0.026); - 0.25 = −0.151 (−0.283, −0.033)

BGT = Bender Gestalt Test; BNT = Boston naming test; CVLT = California Verbal Learning Test; FSIQ = Full-Scale Intelligence Quotient; HHg = hair mercury; IQ = intelligence quotient; MSCA = McCarthy Scales of Children’s Abilities; PIQ = performance intelligence quotient; SE = standard error; TOLD = Test of Language Development; VMI = Visual Motor Integration; WISC-R = Wechsler Intelligence Scales for Children, Revised; WISC-III = Wechsler Intelligence Scales for Children, 3rd ed.

Linear regression parameters, slope (β) and intercept (Int) for associations between mercury and scores on tests of cognitive performance were rescaled to IQ by adjusting the parameters by a scaling factor. The scaling factor was the ratio of the SDs for the full-scale IQ (SD_IQ_) and the test (SD_test_), SD_IQ_/SDtest, where SD_IQ_ was assigned a value of 15. The adjusted parameters were calculated as follows:

β^*^ = β × SD_IQ_ / SD_test_

Int^*^ = Int × SD_IQ_ / SD_test_

SE^*^ = SE × SD_IQ_ / SD_test_

where β^*^ and Int^*^ are the rescaled values for the slope and intercept, respectively.

The Faroe Islands parameters required additional factors. A factor of 10 adjusted the Faroe Islands log-normal model to a normal model (Budtz-Jorgensen et al. 2004). A factor of 200 µg Hg/kg per µg Hg/L was used to convert Faroe Islands cord BHg levels to HHg (Budtz-Jorgensen et al. 2004).

Meta-β estimates were weighted by study-to-study variance (σ^2^) in β and endpoint-to-endpoint variance endpoint outcomes, using a Bayesian approach with exploratory values for the variance ratio R (σ^2^_study_/σ^2^_endpoint_). The meta estimate for the effect size was −0.18 IQ points per µg Hg/g hair (95% CI −0.378, −0.009). Ryan (2008) conducted a sensitivity analysis of the Axelrad et al. (2007a, 2007b) meta-β to varying correlations between error (standard errors) of different outcomes measured in the same study. The analysis supports the estimate of the meta-β estimated by Axelrad et al. (2007a, 2007b). Increasing error correlation was predicted to decrease the estimated β. The range in the estimated β was −0.18 to −0.20 IQ points per µg Hg/g hair. The low end of the range, −0.18, was predicted when correlation of within study outcome error was ignored.

To determine the change in HHg levels, one IQ point is divided by the meta estimate of 0.18 µg Hg/g hair (as seen in Equation 6, below). Because the meta-β is a parameter of a linear regression equation, the change in IQ points is predicted to be proportional to the change in HHg levels near the center of the distribution of the HHg scale. The central estimates of HHg levels for the three contributing studies ranged from approximately 4 to 9 µg Hg/g hair. Therefore, the proportional relationship can be expected for HHg levels within this range. The corresponding estimates of the change in HHg level corresponding to a specific change in IQ are shown in Table A-25 (see the Calculations section for equation used to convert change in IQ or change in HHg). As can be ascertained from Table A-25, a change in HHg of 5.56 µg Hg/g hair is predicted to result in a 1-point decrease in IQ.

Table A-25 Estimates of the Change in Hair Mercury Level Corresponding to a Specific Change in IQ

Change in IQ (points) | Change in hair mercury (µg Hg/g)
−1 | 5.56
−2 | 11.1
−3 | 16.7
−4 | 22.2
−5 | 27.8

Selection of the Point of Departure for the MRL: The POD selected for derivation of the chronic-duration oral MRL for methylmercury is 5.56 µg Hg/g hair. This value is the change in HHg level that corresponds to a decrease of 1 point in full-scale IQ, based on the meta-β of −0.18 IQ points per 1 µg Hg/g hair (see Calculations). A decrease in full-scale IQ of ≤1 point is considered a NAEL.

Loss of IQ has been used as a metric for assessing the health burden of neurotoxicants, including methylmercury (Bellanger et al. 2013; Bellinger 2012; Bellinger et al. 2019; Chen et al. 2023c). While IQ losses ranging from 1 to 5 points are not significant for most children (the SD associated with IQ tests is approximately 5 points), these small decrements may represent meaningful intellectual and economic achievement at a population level (Bellanger et al. 2013, Bellinger et al. 2019; EPA 1998; Griffiths et al. 2007; Trasande et al. 2005). Based on the meta-β of −0.18 IQ points per µg Hg/g hair (Axelrad et al. 2007a, 2007b) and regional data on maternal HHg levels, the global disability life years attributed to methylmercury exposure was estimated to range from 7 per 100,000 to 44 per 100,000 (Bellinger et al. 2019). Using the same meta (−0.18 IQ points per µg Hg/g hair), Chen et al. (2023c) estimated the disability life years in China attributed to methylmercury exposure to be 3.67 per 1,000 births. The neurological impact of IQ score decrements (≥1, ≥2, and ≥3 IQ points) was used for the risk assessment of lead in paint, dust, and soil (EPA 1998) and estimates of the economic impact per 1-point decrease in IQ was used to estimate benefits of revisions of the National Ambient Air Quality Standards for Lead (EPA 2008). Risk assessments of fluoride exposure have been conducted based on IQ point losses of both 1 and 5 points (Hirzy et al. 2016).

Calculations:

Conversion of meta-β to HHg POD. The linear regression model predicts a proportional relationship between the change in IQ points and change in HHg. Therefore, the conversion of the meta-β to a mercury POD in units of HHg (POD_hair_) is as follows (Equation 8):

P O D_h a i r_ = (1 I Q point)/(0.18 I Q points p e r μ g H g / g h a i r) Eq. (8)

The POD in units of HHg from Equation 1 is 5.56 µg Hg/g hair.

Conversion of HHg level to oral mercury dose. HHg levels were converted to equivalent oral doses by applying a steady-state mass balance model, which did the following: (1) converted the hair level (µg Hg/g, assumed to represent steady state) to an equivalent steady-state BHg level (µg Hg/L) and (2) converted the steady-state BHg level to an equivalent steady-state oral dose (µg Hg/kg/day). Steady-state mass balance models have been used to reconstruct methylmercury intakes in human populations (Sirot et al. 2008). The assumption of steady state requires that the exposures were relatively constant (or intermittent with a constant frequency) for periods >300 days. This is the exposure duration that would achieve 95% of steady-state body burden, assuming a terminal elimination half-time of 65 days (Albert et al. 2010; Equation 9):

T i m e t o s t e a d y s t a t e = (ln ( 1 − 0.95 ))/(k_e_) Eq. (9)

where 0.95 is the fraction of steady state and k_e_ is ln(2)/half-time.

The steady-state model is based on Albert et al. (2010) and is given in Equation 10:

H g_b l_ = (H g_d o s e_ ⋅ A F ⋅ f_b l_ ⋅ B W)/(k_e_ ⋅ V_b l_) Eq. (10)

where Hg_bl_ is the steady-state BHg level (µg Hg/L), Hg_dose_ is the steady-state dose (µg Hg/kg/day) AF is the gastrointestinal absorption fraction, f_bl_ is the blood fraction of the mercury body burden, BW is body weight (kg), k_e_ is the terminal elimination rate constant for mercury and V_bl_ is the blood volume (L).

The corresponding steady-state HHg level was calculated assuming a hair/blood ratio (Equation 11):

H g_h a i r_ = H g_b l_ ⋅ H B R Eq. (11)

where Hg_hair_ is the HHg level (µg Hg/g hair) HBR is the hair/blood ratio (µg Hg/g per µg/L blood).

Parameter values for Equations 8 and 9 are presented in Table A-26. With these parameter values, the conversion factors for HHg and BHg are as follows (Equations 12 and 13):

D o s e = (H g_b l_)/(66.51) Eq. (12)

D o s e = (H g_h a i r_)/(13.50) Eq. (13)

where the dose is in units of µg Hg/kg/day, BHg in units of µg Hg/L and HHg in units of µg Hg/g.

Table A-26 Parameter Values for the Methylmercury Dose Equivalence Model^a^

Parameter | Unit | Value
Blood elimination half-time | Day | 65.4
Blood elimination rate constant | Day^−1^ | 0.0106
Steady-state external dose | µg Hg/kg/day | 1.00
Gastrointestinal absorption fraction | Fraction | 0.94
Blood fraction of body burden | Fraction | 0.060
Body weight | kg | 60
Blood fraction of body weight | L/kg | 0.080
Hair/blood ratio | µg Hg/kg per µg Hg/L | 203

a Parameter values from Albert et al. (2010).

Basis for parameter values. Albert et al. (2010) was used as the basis for parameter values in the dose equivalence model because it provided estimates for the full set model parameters in a sample of the critical population represented in the MRL, pregnant females. Albert et al. (2010) estimated values for parameters in Equations 8 and 9 based on HHg levels and dietary seafood mercury intakes in 125 pregnant women. Scalp and hair mercury levels were measured at weeks 12 and 32 of pregnancy. Dietary mercury intakes were estimated in each subject from a food frequency questionnaire with seafood items paired to a national (France) database on methylmercury content of foods (Verger et al. 2007). Values for parameters were assigned prior distributions based on various sources (Albert et al. 2010) and posterior distributions were estimated in Markov Chain Monte Carlo simulations. Studies similar to Albert et al. (2010) have also estimated the full set of parameters for the model in other adult populations (Jenssen et al. 2012; Jo et al. 2015).

Additional support for the individual parameter values in the dose equivalence model derive from a variety of sources summarized below.

Gastrointestinal absorption fraction. The value for the gastrointestinal absorption fraction used in the dose equivalence model is 0.94 (Albert et al. 2010). Studies conducted in humans, monkeys, and rodents have shown that gastrointestinal absorption of mercury is close to 100% following ingestion of methylmercury as the chloride salt or when incorporated into fish or other ingested protein (Aberg et al. 1969; Berlin et al. 1975; Clarkson 1971; Clarkson and Shapiro 1971; Miettinen et al. 1971; Mori et al. 2012; Nielsen 1992; Nielsen and Andersen 1991, Nielsen et al. 1992; Sundberg et al. 1999; Yannai and Sachs 1993).

Blood fraction of mercury body burden. The value for the blood fraction of the body burden used in the dose equivalence model is 0.06 (Albert et al. 2010). In clinical studies of known doses of methylmercury, BHg accounted for approximately 5–7% of the absorbed dose (Kershaw et al. 1980; Miettinen et al. 1971; Sherlock et al. 1984; Smith et al. 1994).

BHg elimination half-time. The value for the terminal blood elimination half-time used in the dose equivalence model is 65.4 days (Albert et al. 2010). The corresponding elimination rate constant used in Equation 8 is 0.0106 day^−1^. Population-based estimates of the blood half-time for methylmercury have relied on fitting biokinetics models to data on BHg or HHg levels to dietary methylmercury intakes (Albert et al. 2010; Jo et al. 2015). Albert et al. (2010) estimated half-times in 125 pregnant women from measurements of HHg and dietary methylmercury intake estimated from a dietary survey. When estimated assuming a point estimate for the population dietary intake, the mean half-time was 65.4 days (SD 6.0; 95% CI 54, 78). When interindividual variability in dietary mercury intake was included in the estimation of the half-time, the population mean half-time was 103 days (SD 9.5; 95% CI 83, 121). Jo et al. (2015) estimated half-times in 304 adults who were randomly selected from BHg quartiles of the KRIEFS cohort. The estimated population mean half-time (with interindividual variability in dietary intake included in the estimation) was 80.2 days (2.5–97.5 percentile range 64.0–97.4 days). The estimated mean half-time for males (n=167) was 81.6 days (range 66.0–98.8 days) and, for females (n=137), the estimated mean half-time was 78.9 days (range 62.8–96.4 days).

Hair/blood ratio. The value for the hair/blood ratio used in the dose equivalence model is 203 µg Hg/kg hair per µg Hg/L blood (Albert et al. 2010). The Faroe Islands study collected individual subject data on cord blood and parental hair at parturition (Budtz-Jorgensen et al. 2004). The median ratio (µg Hg/kg hair per µg Hg/L blood) was 190 (5^th^–95^th^ percentile: 74–442) for full-length hair and 201 (5^th^–95^th^ percentile: 89–439) for proximal hair (2-cm scalp segment). The hair/blood concentration ratio has been measured in numerous other studies and shows high inter-individual variability, with population means ranging from 100 to 400 (Akagi et al. 1995; Albert et al. 2010; Birke et al. 1972; Clarkson et al. 1988; Kershaw et al. 1980; Liberda et al. 2014; Muckle et al. 2001; Phelps et al. 1980; Sherlock et al. 1982; Yaginuma-Sakurai et al. 2012).

Blood volume. The value for the blood volume used in the dose equivalence model is 0.08 L/kg body weight (Albert et al. 2010). Data on blood volume in humans have been extensively reviewed (e.g., Brown et al. 1962; ICRP 1981; Stern 1997). These sources provide estimates that range from 0.06 to 0.08 L/kg. The upper end of the range is appropriate for the expanded blood volume that occurs during pregnancy (Hytten 1985).

Body weight. The value for body weight used in the dose equivalence model is 60 kg, based on ICRP (1981) and EPA (2011).

Evaluation of the dose equivalence model. The dose equivalence model was evaluated by comparing predicted doses with observed BHg or HHg levels in populations of pregnant women in which individual dietary methylmercury intakes were known or estimated (Pouzaud et al. 2010; Vejrup et al. 2018). The results of these comparisons are summarized below. The close agreement between the observed methylmercury intakes and dose equivalents predicted from BHG or HHG levels supports use of the model in derivation of the chronic-duration oral MRL.

Pouzaud et al. (2010) measured dietary scalp hair mercury levels in 137 pregnant women during weeks 12 and 32 of pregnancy and paired these data with estimates of dietary methylmercury intake from a dietary survey. The group mean hair level was 0.82 µg Hg/g at week 12 and 0.79 µg Hg/g at week 32. The corresponding mean dietary intakes were 0.56 µg Hg/kg/week (0.080 µg Hg/kg/day) and 0.67 µg Hg/kg/week (0.096 µg Hg/kg/day). The observed and predicted mercury doses for this study are as follows:

- Observed mean HHg: 0.82, 0.79 µg Hg/kg
- Observed mean mercury intake: 0.080, 0.096 µg Hg/kg/day
- Predicted mean dose equivalent: 0.061, 0.059 µg Hg/kg/day
- Predicted minus observed: −0.019, −0.037 µg Hg/kg/day

The differences between the predicted and observed mercury intakes ranged from 0.02 to 0.04 µg Hg/kg/day. Good agreement between the predicted and observed dietary methylmercury intakes are expected for this dataset, since it included data from 123 subjects used to estimate parameters for the dose equivalence model.

Vejrup et al. (2018) estimated median dietary fish mercury intakes and measured BHg levels for a subset of the full cohort of the Norwegian Mother and Child Cohort Study (n=2,239). The median maternal BHg level was 1.0 µg Hg/L (SD 0.9) and the median estimated dietary fish mercury intake was 0.15 µg Hg/kg/week (0.021 µg Hg/g/day). The observed and predicted mercury doses for this study are as follows:

- Observed median BHg: 1.0 µg Hg/L (SD 0.9)
- Observed median mercury intake: 0.021 µg Hg/kg/day
- Predicted median dose equivalent: 0.015 µg Hg/kg/day
- Predicted minus observed: −0.006 µg Hg/kg/day

The difference between the predicted and observed mercury intake was 0.006 µg Hg/kg/day.

Conversion of meta-β (IQ points per µg Hg/g hair) to POD_dose_ (µg/kg/day per 1 IQ point).

Calculate POD_hair_ (µg Hg/g hair per 1 IQ point) from meta-β (IQ points per µg Hg/g hair; Equation 8):

P O D_h a i r_ = ( I Q points ) / ( m e t a β )

P O D_h a i r_ = (1)/(0.18) = 5.56

Calculate ratio of BHg to dose (µg/L blood per µg Hg/kg/day; Equation 10):

R a t i o b l o o d : d o s e = ( A F × f_b l o o d_ × B W ) / ( k_e_ × V_b l o o d_ )

R a t i o b l o o d : d o s e = (0.94 × 0.060 × 60 k g)/(0.0106 d a y^− 1^ × 4.80 L) = 66.51

where AF is the absorption fraction, f_blood_ is the fraction of the dose transferred to blood, BW is body weight, k_e_ is the elimination rate constant (ln(2)/t_1/2_) and V_blood_ is the blood volume (0.080 × body weight).

Calculate ratio of HHg to dose (µg Hg/g hair per µg Hg/kg/day; Equations 11 and 13):

R a t i o h a i r : d o s e = ( R a t i o b l o o d : d o s e × R a t i o h a i r : b l o o d ) / 1,000

R a t i o h a i r : d o s e = 66.51 × (203)/(1,000) = 13.50

Calculate POD_dose_ (µg Hg/kg/day) from POD_hair_ (µg Hg/g hair):

P O D_d o s e_ = P O D_h a i r_ / R a t i o h a i r : d o s e

P O D_d o s e_ = (5.56)/(13.50) = 0.41

Uncertainty Factor: An uncertainty factor of 3 was applied to the POD of 0.41 µg Hg/kg/day to account for expected human variability in pharmacokinetics and dynamics. The uncertainty factor was reduced from the standard factor for 10 for the following reasons: (1) the principal study examined a highly sensitive target population, the fetus and (2) a well-supported biokinetic model was used to calculate the equivalent maternal dose from a well-supported biomarker of exposure to methylmercury in high fish consuming populations.

- 3 for human variability

MRL = POD ÷ UF

MRL = 0.41 μg Hg / kg / day ÷ 3

MRL = 0.1 μg Hg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The chronic-duration oral MRL based on the meta-analysis of the Faroe Islands, North Island New Zealand, and Seychelle Islands is 0.1 µg Hg/kg/day. The MRL is lower than the equivalent doses predicted in the individual contributing studies, which were 0.34 µg Hg/kg/day for the Faroe Islands cohort, 0.61 µg Hg/kg/day for the North Island New Zealand cohort, and 0.41 µg Hg/kg/day for the Seychelle Islands cohort. The equivalent doses from the Faroe Islands and North Island New Zealand cohorts are AELs, while the equivalent dose from the Seychelle Island cohort is a NAEL.

In addition to the epidemiological studies conducted in the Faroe Islands, North Island New Zealand, and Seychelle Islands, studies of other populations have found associations between exposures to methylmercury and neurodevelopmental outcomes (Section 2.16). These include studies of high fish consumers in the Amazon River basin (Chevrier et al. 2009; Cordier et al. 2002), Arctic Canada (Boucher et al. 2012a, 2012b, 2014, 2016; Despres et al. 2005; Ethier et al. 2012; Jacobson et al. 2015), fishing villages on the Mediterranean coast (Murata et al. 1999a, 2004b), and populations residing in the vicinity of artisanal gold mining operations (Counter 2003; Counter et al. 1998, 2002, 2006, 2012; Nyanza et al. 2021; Ramirez et al. 2000, 2003; Reuben et al. 2020).

The MRL is approximately 2 times higher than the dietary fish methylmercury intakes in the Norwegian Mother and Child Cohort Study that were associated with effects on language proficiency. However, a POD based on the dietary intakes estimated in this study would have lower confidence than the POD used in the derivation of the MRL for several reasons: (1) the associations with dietary methylmercury intake were based on a semi-quantitative food survey and national data on fish mercury concentrations, rather than biomarkers of mercury exposure in individual subjects; (2) the association with dietary methylmercury intake predicted lower language proficiency at age 3 years, whereas the association predicted higher proficiency at age 5 years (Vejrup et al. 2016, 2018); (3) in a subset of the cohort for which measurements of individual subject BHg levels were available, there was no association between language proficiency and BHg (Vejrup et al. 2018); and (4) language proficiency assessment was assessed from results of a parental self-report survey of their children rather than an assessment made by professional, non-biased observers. The outcomes of the Kobayashi et al. (2022) study also contribute to uncertainty in the interpretation of the language outcomes from the Norwegian Mother and Child Cohort Study. This large-scale prospective study conducted in Japan (n=48,731), found no evidence for an association between maternal BHg levels (median 3.64 μg/kg) and communication skills assessed from scores on of the Ages and Stages Questionnaire, a survey instrument that was used in the Norwegian Mother and Child Cohort Study (Kobayashi et al. 2022). The median maternal BHg level in the Kobayashi et al. (2022) study (3.64 μg/L) was higher than the median in the Norwegian Mother and Child Cohort Study (1.03 μg/L; Vejrup et al. 2018). The Kobayashi et al. (2022) study adjusted their regression models for maternal n-3 PUFA consumption and other potential confounders, as was done in the Norwegian Mother and Child Cohort Study.

Studies conducted in animals (nonhuman primates and rodents) provide strong support for the developing nervous system being most sensitive target of methylmercury (Section 2.16.1, Neurodevelopmental Effects for references and additional details). Studies conducted in monkeys have shown that gestational exposure to methylmercury resulted in sensorimotor dysfunction, and vision and hearing deficits. Gestational exposures in rodents produced sensorimotor dysfunction, vision and hearing deficits, impaired learning and memory, and neuropathological changes in the central and peripheral nervous systems.

Agency Contacts (Chemical Managers): Rae Benedict