# 9 REFERENCES

*Cited in text

*Aaron CK, Howland MA. 1998. Insecticides: Organophosphates and carbamates. In: Goldfrank LR, Flomenbaum NE, Lewin NA, ., eds. Goldfrank’s toxicologic emergencies. 6^th^ ed. Stanford, CT: Appleton and Lange, 1429–1449.
*Abdel-Rahman MS, Lechner DW, Klein KM. 1985. Combination effect of carbaryl and malathion in rats. Arch Environ Contam Toxicol 14:459–464.3929703
Abd-Elraof TK, Dauterman WC, Mailman RB. 1981. In vivo metabolism and excretion of propoxur and malathion in the rat: Effect of lead treatment. Toxicol Appl Pharmacol 59:324–330.7256771
*Abou-Donia MB. 1995. Organophosphorus Pesticides. In: Chang LW, Dyer RS, eds. Handbook of Neurotoxicology. New York, NY: M Decker, 419–473.
*Abou-Zeid MM, El-Barouty G, Abdel-Reheim E, . 1993. Malathion disposition in dermally and orally treated rats and its impact on the blood serum acetylcholine esterase and protein profile. J Environ Sci Health B28(4):413–430.
*Abraham SS, Manohar BM, Sundararaj A, . 1997. Genotoxicity of malathion- a sub-chronic study in mice. Indian Vet J 74:565–567.
*ACGIH. 1999. Documentation of the threshold limit values and biological indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 2000. Documentation of the threshold limit values and biological indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*Adgate JL, Barr DB, Clayton A, . 2001. Measurement of children’s exposure to pesticides: Analysis of urinary metabolite levels in a probability-based sample. Environ Health Perspect 109(6):583–590.11445512
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agarwal R, Matin MA. 1981. Effect of oximes and atropine on the concentration of cerebral glycogen and blood glucose in malathion-treated rats. J Pharm Pharmacol 33:795–796.6121855
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Atlanta GA. Federal Register 54(174):37618–37634.
*Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Atlanta, GA: Subcommittee on Biomarkers of Organ Damage and Dysfunction.
Agüera A, Contreras M, Fernández-Alba AR. 1993. Gas chromatographic analysis of organophosphorus pesticides of horticultural concern. J Chromatogr 655(2):293–300.
*Ahdaya S, Guthrie F. 1982. Stomach absorption of intubated insecticides in fasted mice. Toxicology 22:311–317.
*Ahdaya SM, Monroe RJ, Guthrie FE. 1981. Absorption and distribution of intubated insecticides in fasted mice. Pestic Biochem Physiol 16:38–46.
Ahmad N, Bugueno G, Guo L, . 1999. Determination of organochlorine and organophosphate pesticide residues in fruits, vegetables and sediments. J Environ Sci Health B 34(5):829–848.10466104
Akiyama Y, Yoshioka N, Tsuji M. 2000. Solid-phase extraction for cleanup of pesticide residues suspected as endocrine disruptors in foods. J Health Sci 46(1):49–55.
*Albright RK, Kram BW, White R. 1983. Malathion exposure associated with acute renal failure. JAMA 250(18):2469.
*Aldridge WN, Miles JW, Mount D, . 1979. The toxicological properties of impurities in malathion. Arch Toxicol 42:95–106.755464
Alexander M. 1981. Biodegradation of chemicals of environmental concern. Science 211:132–211.7444456
*Altman PL, Dittmer DS. 1974. In: Biological handbooks. Biology data book. Vol. III. 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Amer SM, Fahmy MA, Aly AE, . 2002. Cytogenitic studies on the effect of feeding mice with stored wheat grains treated with malathion. Mutat Res 513(1–2):1–10.11719084
*Ames RG, Brown SK, Rosenberg J, . 1989. Health symptoms and occupational exposure to flea control products among California pet handlers. Am Ind Hyg Assoc J 50(9):466–472.2801514
*Amos WC, Hall A. 1965. Malathion poisoning treated with protopam. Ann Int Med 62(5):1013–1016.14283379
Andersen HR, Nielsen JB, Grandjean P. 2000. Toxicologic evidence of developmental neurotoxicity of environmental chemicals. Toxicology 144:121–127.10781879
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
*Annual Pesticide Use Report. 1996. Sacramento, California Department of Pesticide Regulation, Information Systems Branch.
Antunes-Madeira MdC, Videira RA, Lopes V, . 1996. Toxicity of organophosphorus insecticides: Alteration of membrane fluidity. Med Sci Res 24:753–756.
Anwar WA. 1997. Biomarkers of human exposure to pesticides. Environ Health Perspect Suppl 105(4):801–806.9255564
*AOAC. 1990. Association of Official Analytical Chemists book of official methods of analysis. 15^th^ ed. Section 970.52. Arlington, VA: AOAC International.
*Asmatullah SA, Mufti A, Cheema AM, . 1993. Embryotoxicity and teratogenicity of malathion in mice. Punjab Univ J Zool 8:53–61.
*Atkinson R, Aschmann SM, Arey J, . 1989. Product formation from the gas-phase reactions of the OH radical with (CH_3_O)_3_PS and (CH_3_O)_2_P(S)SCH_3_. Environ Sci Technol 23(2):243–244.
Awad OME. 1984. Molecular mechanism for the inhibition of acetylcholinesterase enzyme by organophosphorothionates. Enzyme 32:193–200.6525997
*Baker EL, Warren M, Zack M, . 1978. Epidemic malathion poisoning in Pakistan malaria workers. Lancet 455:31–34.
*Baker SE, Barr D, Driskell WJ, . 2000. Quantification of selected pesticide metabolites in human urine using isotope dilution high-performance liquid chromatography/tandem mass spectrometry. J Expo Anal Environ Epidemiol 10:789–798.11138671
*Balaji M, Sasikala K. 1993. Cytogenetic effect of malathion in in vitro culture of human peripheral blood. Mutat Res 301:13–17.7677938
*Balasubramanian K, Ratnakar C, Ananthanarayanan PH, . 1987a. Histopathological changes in the testis of malathion treated albino rats. Med Sci Res 15:509–510.
*Balasubramanian K, Vijayan AP, Ananthanarayanan PH, . 1987b. Effect of malathion on the testis of male albino rats. Med Sci Res 15:229–230.
*Banerjee BD, Koner BC, Ray A. 1996. Immunotoxicity of pesticides: Perspectives and trends. Indian J Exp Biol 34:723–733.8979476
*Banerjee BD, Pasha ST, Hussain QZ, . 1998. A comparative evaluation of immunotoxicity of malathion after subchronic exposure in experimental animals. Ind J Exp Biol 36:273–282.
*Bardin PG, Van Eeden SF. 1990. Organophosphate poisoning: Grading the severity and comparing treatment between atropine and glycopyrrolate. Crit Care Med 18(9):956–960.2394119
*Bardin PG, Van Eeden S, Moolan J, . 1994. Organophosphate and carbamate poisoning. Arch Intern Med 154:1433–1441.8017998
*Barlas NE. 1996. Toxicological assessment of biodegraded malathion in albino mice. Bull Environ Contam Toxicol 57:705–712.8791544
*Barnabas IJ, Dean JR, Owen SP. 1994. Supercritical fluid extraction of analytes from environmental samples. A review. Analyst 119:2381–2394.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Bartha R, Lanzilotta R, Pramer D. 1967. Stability and effects of some pesticides in soil. Appl Microbiol 1967:67–75.
Bartholomew PM, Gianutsos G, Cohen SD. 1981. Differential cholinesterase inhibition and muscarinic receptor changes in Cd-1 mice made tolerant to malathion. Toxicol Appl Pharmacol 81:147–155.
BCPC. 1977. Malathion. In: Martin H, Worthing CR, eds. Pesticide manual, 5^th^ ed. British Crop Protection Council. The BCPC, Croydon, England. Lavenham, Suffolk: The Laveham Press.
*BCPC. 1983. Malathion. In: Worthing CR, Walker SB, eds. The Pesticide manual. A world compendium. 7^th^ ed. Lavenham, Suffolk: British Crop Protection Council. The Laveham Press Ltd., 337.
*Beattie G. 1994. A 13-week toxicity study of aerolized malathion administered by whole body inhalation exposure to the albino rat: Lab project No: 90729. Unpublished study prepared by Product Safety Assessment, Bio-Research Labs, Ltd. MRID 43266601. (As cited in EPA 2000a, 2000b).
*Beeson MD, Driscoll WJ, Barr DB. 1999. Isotope dilution high-performance liquid chromatography/tandem mass spectrometry method for quantifying urinary metabolites of atrazine, malathion, and 2,4-dichlorophenoxyacetic acid. Anal Chem 71:3526–3530.10464480
*Belanger A, Vincent C, de Oliveira D. 1990. A field study on residues of four insecticides used in strawberry protection. J Environ Sci Health B B25(5):615–625.
*Bell JP, Tsezos M. 1987. Removal of hazardous organic pollutants by adsorption on microbial biomass. Water Sci Technol 19:409–416.
*Beltran J, Lopez FJ, Cepria O, . 1998. Solid-phase microextration for quantitative analysis of organophosphorus pesticides in environmental water samples. J Chromatogr 808:257–263.
*Benslama A, Moutaouakkil S, Mjahed K, . 1998. Syndrome intermediare lors d’une intoxication aigue par le malathion. Presse Med 27:713–715.9767909
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Berteau PE, Deen WA. 1976. Changes in whole blood serotonin concentrations in rats exposed to insecticide aerosols. Toxicol Appl Pharmacol 37(1):134.
Berteau PE, Deen WA. 1978. A comparison of oral and inhalation toxicities of four insecticides to mice and rats. Bull Environ Contam Toxicol 19(1):113–120.75750
*Bhagwat VM, Ramachandran BV. 1975. Malathion A and B esterases of mouse Liver −1. Separation and properties. Biochem Pharmacol 24:1713–1717.14
*Bitsi GA, Singh K, Khan SU, . 1994. Fate of wheat bound malathion residues in rats during gestation. Chemosphere 29(3):451–455.7922151
Bladek J, Rostkowski A, Miszczak M. 1996. Application of instrumental thin-layered chromatography and solid-phase extraction to the analyses of pesticide residues in grossly contaminated samples of soil. J Chromatogr 754:273–278.
*Blasiak J, Stankowska D. 2001. Genotoxicity of malaoxon: Induction of oxidized and methylated bases and protective effect of alpha-tocopherol. Pestic Biochem Physiol 71(2):88–96.
*Blasiak J, Jaloszynski P, Andrzej T, . 1999. In vitro studies on the genotoxicity of the organophosphorus insecticide malathion and its two analogues. Mutat Res 445:275–283.10575436
*BNA. 2001. Environment and safety library on the web. States and territories. Washington, DC: Bureau of National Affairs, Inc. Http://www.esweb.bna.com/. June 4, 2001.
*Bossan D, Wortham H, Masclet P. 1995. Atmospheric transport of pesticides absorbed on aerosols I. Photodegradation in simulated atmosphere. Chemosphere 30(1):21–29.
*Bourke JB, Broderick EJ, Hackler LR, . 1968. Comparative metabolism of malathion-C^14^ in plants and animals. J Agric Food Chem 16(4):585–589.
*Bourquin AW. 1977. Degradation of malathion by salt-marsh microorganisms. Appl Environ Microbiol 33(2):356–362.192147
Boutsiouki P, Thompson JP, Clough GF. 2000. Effects of local blood flow on the percutaneous absorption of malathion in human skin in vivo. J Vasc Res 7:40.
*Boutsiouki P, Thompson JP, Clough GF. 2001. Effects of local blood flow on the percutaneous absorption of the organophosphorus compound malathion: A microdialysis study in man. Arch Toxicol 75(6):321–328.11570689
*Boyes WK, Hunter E, Gary C, . 1999. Topical exposure of the eye to the organophosphorus insecticide malathion: lack of visual effects. J Appl Toxicol 19:473–483.10547628
Boyes WK, Tandon P, Barone JR, . 1994. Effects of organophosphates on the visual system of rats. J Appl Toxicol 14(2):135–143.8027509
*Bradman MASA, Harnly ME, Draper W, . 1997. Pesticide exposures to children from California’s Central Valley: results of a pilot study. J Expo Anal Environ Epidemiol 7(2):217–234.9185013
*Bradman MASA, Harnly ME, Goldman LR, . 1994. Malathion and the malaoxon environmental levels used for exposure assessment and risk characterization of aerial applications to residential areas of southern California, 1989-1990. J Expo Anal Environ Epidemiol 4(1):49–63.7894268
*Bradway DE, Shafik TM. 1977. Malathion exposure studies. Determination of mono-and dicarboxylic acids and alkyl phosphates in urine. J Agric Food Chem 25(6):1342–1344.915135
*Brodeur J. 1967. Studies on the mechanism of phenobarbital-induced protection against malathion and EPN. Can J Physiol Pharmacol 45(6):1061–1069.6064053
Brodeur J, Dubois KP. 1967. Factors influencing the acute toxicity of malathion and malaoxon in rats. Can J Physiol Pharmacol 45:621–631.6035981
*Brown LM, Blair A, Gibson R, . 1990. Pesticide exposures and other agricultural risk factors for leukemia among men in Iowa and Minnesota. Can Res 50:6585–6591.
*Brown LM, Burmeister LF, Everett GD, . 1993a. Pesticide exposures and multiple myeloma in Iowa men. Cancer Causes Control 4:153–156.8481493
*Brown MA, Petreas MX, Okamoto HS, . 1991. Pilot study for the monitoring of malathion, malathion impurities, and their environmental transformation products on surfaces and in air during and after an aerial application in Garden Grove, California in May 1990. Berkely, CA: California Department of Health Services, Hazardous Materials Laboratories. .
*Brown MA, Petreas MX, Okamoto HS, . 1993b. Monitoring of malathion and its impurities and environmental transformation products on surfaces and in air following an aerial application. Environ Sci Technol 27:388–397.
*Bucks DAW, Marty JPL, Maibach HI. 1985. Percutaneous absorption of malathion in the guinea-pig: Effect of repeated topical application. Food Chem Toxicol 23(10):919–922.4065766
*Budavari S, O’Neil MJ, Smith A, . (eds.). 1996. The Merck index. An encyclopedia of chemical, drugs, and biologicals. 12^th^ ed. Whitehouse Station, NJ: Merck and Co., Inc., 927–973.
*Bulusu S, Chakravarty I. 1984. Augmented hepatic susceptibility to malathion toxicity in the rats on low protein diets. Environ Res 35:53–65.6489297
*Bulusu S, Chakravarty I. 1986. Subacute administration of organophosphorus pesticides and hepatic drug metabolizing enzyme activity in normal and malnourished rats. Bull Environ Contam Toxicol 36:73–80.3940570
*Buyuksonmez F, Rynk R, Hess TF, . 1999. Occurrence, degradation and fate of pesticides during composting: Part 1: Composting, pesticides and pesticide degradation. Compost Sci Util 7(4):66–82.
Cabello G, Valenzuela M, Vilaxa A, . 2001. A rat mammary tumor model induced by the organophosphorous pesticides parathion and malathion, possibly through acetylcholinesterase inhibition. Environ Health Perspect 109(5):471–479.11401758
Callaghan AU, Cohen SD, Murphy SD. 1972. Investigation of multiple mechanisms for potentiation of malaoxon (mx) bytriorthotolyl phosphate. Toxicol Appl Pharmacol 22(2):300.
*Camel V. 1997. The determination of pesticide residues and metabolites using supercritical fluid extraction. TrAC Trends Anal Chem (PersEd) 16(6):351–369.
Cano E, Jimenez A, Cabral JA, . 1999. Acute toxicity of malathion and the new surfactant “genapol oxd 080” on species of rice basins. Bull Environ Contam Toxicol 63:133–138.10423494
Cantor KP, Blair A, Brown LM, . 1993. Pesticides and other agricultural risk factors for non-Hodgkin’s lymphoma among men in Iowa and Minnesota. Cancer Res 53:2421.8329071
*Cantor KP, Blair A, Everett G, . 1992. Pesticides and other agricultural risk factors for non-Hodgkin’s lymphoma among men in Iowa and Minnesota. Cancer Res 52:2447–2455.1568215
*Carlton FB, Simpson WM, Haddad LM. 1998. The organophosphates and other insecticides. In: Haddad LM, Shannon MW, Winchester JF, eds. Clinical management of poisoning and drug overdose. 3^rd^ ed. Philadelphia, PA: WB Saunders Company, 836–845.
*Carman GE, Iwata Y, Dusch ME, . 1981. Residues of malathion and methidathion on and in fruit after dilute and low-volume spraying of orange trees. Bull Environ Contam Toxicol 27:864–868.7337859
*Casale GP, Cohen SD, DiCapua RA. 1983. The effects of organophosphate-induced cholinergic stimulation on the antibody response to sheep erythrocytes in inbred mice. Toxicol Appl Pharmacol 68:198–205.6857660
Castro Cano ML, Martinez Vidal JL, Egea Gonzalez FJ, . 2001. Gas chromatographic method for assessing the dermal exposure of greenhouse applicators to dimethoate and malathion. J Chromatogr Sci 39(8):345–350.11513277
*CDHS. 1991. Department of Health Services. Health risk assessment of aerial application of malathion-bait. Los Angeles, CA: California Department of Health Services, Pesticides and Environmental Toxicology Section.
Cerutti G, Zappavigna R, Gerosa S. 1975. Organochlorine and organophosphorus pesticide residues in milk and dairy products. Latte 3:161–165.
*Chang SK, Williams PL, Dauterman WC, . 1994. Percutaneous absorption, dermato-pharmacokinetics and related bio-transformation studies of carbaryl, lindane, malathion, and parathion in isolated perfused porcine skin. Toxicology 91:269–280.7521545
*Chapman RA, Cole CM. 1982. Observations on the influence of water and soil pH on the persistence of insecticides. J Environ Sci Health B 17(5):487–504.7175098
Chauhan UPS, Jaggi CB, Rastogi V. 1974. Hypertrophy of adrenals and ascorbic acid status in various tissues of malathion treated rats. Indian J Med Res 62:987–989.4435924
Chauhan UPS, Rastogi VK, Jaggi CB, . 1973. Effect of acute malathion poisoning on acetylcholinesterase in various tissues of rats. Indian J Exp Biol 11:576–578.4792758
Chen HH, Hseuth JL, Sirianni SR, . 1981. Induction of sister-chromatid exchanges and cell cycle delay in cultured mammalian cells treated with eight organophosphorus pesticides. Mutat Res 88(3):307–316.7254224
Chen HH, Sirianni SR, Huang CC. 1982. Sister chromatid exchanges in Chinese hamster cells treated with seventeen organophosphorus compounds in the presence of a metabolic activation system. Environ Mutagen 4:621–624.7140680
*Chen PR, Tucker WP, Dauterman WC. 1969. Structure of biologically produced malathion monoacid. J Agric Food Chem 17(1):86–90.
*Chhabra SK, Hashim S, Roa AR. 1993. Modulation of hepatic glutathione system of enzymes in suckling mouse pups exposed translactationally to malathion. J Appl Toxicol 13(6):411–416.8288844
*Chiou CT, Freed VH, Schmedding DW, . 1977. Partition coefficient and bioaccumulation of selected organic chemicals. Environ Sci Technol 11(5):475–478.
*Choi PTL, Quinonez LG, Cook DJ, . 1998. The use of glycopyrrolate in a case of intermediate syndrome following organophosphate poisoning. Can J Anaesth 45(4):337–340.9597208
*Chowdhury JS, Dudeja PK, Mehta SK, . 1980. Effect of a single oral dose of malathion on d-glucose and glycine uptake and on brush border enzymes in rat intestine. Toxicol Lett 6:411–415.7444981
*Chukwudebe A, March RB, Othman M, . 1989. Formation of trialkyl phosphorothioate esters from organophosphorus insecticides after exposure to either ultraviolet light or sunlight. J Agric Food Chem 37:539–545.
*Clark ER, Qazi IA. 1979. Evaluation of the modified colourimetric method for the determination of malathion: its application to the analysis of malathion residues in water. Water Res 14:1037–1040.
*Clark JR, Lewist MA, Pait AS. 1993. Pesticide inputs and risks in coastal wetlands. Environ Toxicol Chem 12:2225–2233.
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Clyne RM. 1972. Relative safety of malathion. N Engl J Med 287(16):824.
Cohen SD, Ehrich M. 1976. Cholinesterase and carboxylesterase inhibition by dichlorvos and interactions with malathion and triorthotolyl phosphate. Toxicol Appl Pharmacol 37:39–48.968905
Cohen SD, Callaghan JE, Murphy SD. 1972. Investigation of multiple mechanisms for potentiation of malaoxon’s anticholinesterase action by triorthotolyl phosphate (36899). Proc Soc Exp Biol Med 141:906–910.4645780
Colosio C, Corsini E, Barcellini W, . 1999. Immune parameters in biological monitoring of pesticide exposure: Current knowledge and perspectives. Toxicol Lett 108:285–295.10511273
Contreras HR. 1996. Effect of an organophosphorate insecticide on the testis, epididymis and preimplantational development and pregnancy outcome in mice. Int J Dev Biol (Suppl. 1):207S.9087763
Contreras HR, Bustos-Obregon E. 1999. Morphological alterations in mouse testis by a single dose of malathion. J Exp Zool 284:355–359.10404127
Corneliussen PE. 1972. Residues in food and feed: Pesticide residues in total diet samples. Pestic Monit J 5(4):313–330.4208741
*Cotham WEJ, Bidleman TF. 1989. Degradation of malathion, endosulfan, and fenvalerate in seawater and seawater/sediment microcosms. J Agric Food Chem 37:824–828.
*Coye MJ, Barnett PG, Midtling JE, . 1987. Clinical confirmation of organophosphate poisoning by serial cholinesterase analyses. Arch Int Med 147:338–342.
*CRIS. 2001. CRIS Database. Current Research Information System. Http://cristel.csrees.usda.gov/star/system.html. January 11, 2001.
*Crisp TM, Clegg ED, Cooper RL, . 1998. Environmental endocrine disruption: An effects assessment and analysis. Environ Health Perspect Suppl 106 (1):11–56.9539004
*Crowley WJJ, Johns TR. 1966. Accidental malathion poisoning. Arch Neurol 14(6):611–616.5935955
Cruz Marquez M, Arrebola FJ, Egea Gonzalez FJ, . 2001. Gas chromatographic-tandem mass spectrometric analytical method for the study of inhalation, potential dermal and actual exposure of agricultural workers to the pesticide malathion. J Chromatogr A 939(1–2):79–89.11806548
*Culver D, Caplan P, Batchelor GS. 1956. Studies of human exposure during aerosol application of malathion and chlorthion. AMA Arch Ind Health 13:37–50.13275138
*Cushman JR, Street JC. 1983. Allergic hypersensitivity to the insecticide malathion in BALB/c mice. Toxicol Appl Pharmacol 70:29–42.6612736
Czajkowska A, Walter Z. 1980. Effect of malathion on nucleic acid synthesis in phytohemagglutinin-stimulated human lymphocytes. Hum Genet 56:189–194.6161081
*Dagli AJ, Shaikh WA. 1983. Pancreatic involvement in malathion-anticholinesterase insecticide intoxication. A study of 75 cases. Br J Clin Pract 37(7–8):270–272.6192835
*Daly I. 1996a. A 24-month oral toxicity/oncogenicity study of malathion in the rat via dietary administration. Final report: Lab project No: 90-3641: J-11 90-3641. Unpublished study prepared by Huntington Life Sciences. MRID 43942901. (As cited in EPA 2000a, 2000b).
Daly I. 1996b. A 24-month oral toxicity/oncogenicity study of malaoxon in the rat via dietary administration. Lab study number 93-2224. Unpublished study prepared by Huntington Life Sciences. MRID43975201. (As cited in EPA 2000a, 2000b).
*Dary CC, Blancato JN, Castles M, . 1994. Dermal absorption and disposition of formulations of malathion in Sprague-Dawley rats and humans. ACS Symp Ser 542:231–263.
*Dary CC, Blancato JN, Saleh MA. 2001. Chemomorphic analysis of malathion in skin layers of the rat: Implications for the use of dermatopharmacokinetic tape stripping in exposure assessment to pesticides. Regul Toxicol Pharmacol 34(3):234–248.11754528
*Daston GP, Gooch JW, Breslin WJ, . 1997. Environmental estrogens and reproductive health: A discussion of the human and environmental data. Reprod Toxicol 1(4):465–481.
Datta C, Gupta J, Sengupta D. 1994. Interaction of organophosphorus insecticides phosphamidon and malathion on lipid profile and acetylcholinesterase activity in human erythrocyte membrane. Indian J Med Res 100:87–89.7927563
*Dauterman WC, Main AR. 1966. Relationship between acute toxicity and in vitro inhibition and hydrolysis of a series of carbalkoxy homologs of malathion. Toxicol Appl Pharmacol 9:408–418.5969424
Davidson PP. 1975. Dietary fat alteration of plasma cholinesterase response to malathion. Toxicology 5:113–115.1188955
*De Bleecker JL. 1995. The intermediate syndrome in organophosphate poisoning: An overview of experimental and clinical observations. Clin Toxicol 33(6):683–686.
*De Bleecker J, VanDenNeucker K, Willems J. 1992. The intermediate syndrome in organophosphate poisoning: Presentation of a case and review of the literature. Clin Toxicol 30(3):321–329.
De Domenech EEM, Domenech CE, Balegno HF, . 1980. Pesticide action: Different response of erythrocyte membrane acetylcholinesterase to inhibition by organophosphorus compounds under varied dietary conditions. Pestic Biochem Physiol 14:1–4.
*Degraeve N, Moutschen J. 1984. Genetic and cytogenetic effects induced in the mouse by an organophosphorus insecticide: Malathion. Environ Res 34:170–174.6723606
*Degraeve N, Chollet M-C, Moutschen J, . 1984. Genetic and cytogenic effects of chronic treatments with organophosphorous insecticides. Mutat Res 97:179–180.
Degraeve N, Gilot-Delhalle J, Moutschen J, . 1980. Comparison of the mutagenic activity of organophosphorus insecticides in mouse and in the yeast schizosac-charomyces pombe. Mutat Res 74:201–202.
Degraeve N, Moutschen J, Moutschen-Dahmen M, . 1979. Genetic effects of organophosphate insecticides in mouse. Mutat Res 64(2):131.
*Dementi B. 1993. Ocular effects of organophosphates: a historical perspective of Saku disease. J Appl Toxicol 14:119–129.
*Dennis GA, Lee PN. 1999. A phase I volunteer study to establish the degree of absorption and effect on cholinesterase activity of four head lice preparations containing malathion. Clin Drug Invest 18(2):105–115.
Desi I. 1983. Neurotoxicological investigation of pesticides in animal experiments. Neurobehav Toxicol Teratol 5:503–515.6664408
*Desi I, Dura G, Gonczi L, . 1976. Toxicity of malathion to mammals, aquatic organisms and tissue culture cells. Arch Environ Contam Toxicol 3:410–425.
Desi I, Varga L, Farkas I. 1978. Studies on the immunosuppressive effect of organochlorine and organophosphoric pesticides in subacute experiments. J Hyg Epidemiol Microbiol Immunol 22(1):115–122.
*Dikshith TSS, Srivastava MK, Raizada RB, . 1987. Interaction of hexachlorocyclohexane and malathion in male guinea pigs after repeated dermal application. Vet Hum Toxicol 29(2):138–143.2437688
*Dive A, Mahieu P, Van Binst R, . 1994. Unusual manifestations after malathion poisoning. Hum Exp Toxicol 13:271–274.8204314
*Doctor BP, Toker L, Roth E, Silman I. 1987. Microtiter assay for acetylcholinesterase. Anal Biochem 166:399–403.3434781
*Domagalski J. 1996. Pesticides and pesticide degradation products in stormwater runoff: Sacramento River Basin, California. Water Res Bull 32(5):953–964.
*Dong MH, Draper WM, Papanek PJ, . 1994. Estimating malathion doses in California’s medfly eradication campaign using a physiologically based pharmacokinetic model. Adv Chem Ser 241:189–208.
Dong MH, Ross JH, Thongsinthusak T, . 1996. Use of spot urine sample results in physiologically based pharmacokinetic modeling of absorbed malathion doses in humans. ACS Symp Ser 643:229–243.
Dong MH, Thongsinthusak T, Ross JH, . 1995. Validation of a physiologically based pharmacokinetic (PB-PK) model used to simulate absorbed malathion doses in humans. Am Chem Soc Abstr Pap 0-8412-3147-8.
*DOT. 2001a. Marine pollutant. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101, Appendix B. Http://www.dot.gov/. April 03, 2001.
*DOT. 2001b. List of hazardous substances and reportable quantities. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101, Appendix A. Http://www.dot.gov/. April 03, 2001.
*Draper WM, Wijekoon D, Stephens RD. 1991. Determination of malathion urinary metabolites by isotope dilution ion trap GC/MS. J Agric Food Chem. 39:1796–1801.
Drevenkar V, Frobe Z, Vasilic Z, . 1979. The rate of urinary excretion of phosalone residues in occupationally exposed persons. Sci Total Environ 13:235–243.538451
Dribben WH, Kirk MA. 2001. Organ procurement and successful transplantation after malathion poisoning. J Toxicol Clin Toxicol 39(6):633–636.11762673
*Dulout FN, Olivero OA, von Guradze H, . 1982. Cytogenetic effect of malathion assessed by the micronucleus test. Mutat Res 105(6):413–416.7155160
*Dulout FN, Pastori MC, Olivero OA. 1983. Malathion-induced chromosomal aberrations in bone-marrow cells of mice: Dose-response relationships. Mutat Res 122:163–167.6656807
Durham S, Imamura T. 1988. Morphogenesis of O,O,S-Trimethyl phosphorothioate-induced pulmonary injury in mice. Toxicol Appl Pharmacol 96:417–428.3206524
*Durham W, Wolfe H. 1962. Measurement of the exposure of workers to pesticides. Bull WHO 26:75–91.13888659
*Dzwonkowska A, Hubner H. 1986. Induction of chromosomal aberrations in the Syrian hamster by insecticides tested in vivo. Arch Toxicol 58:152–156.3964078
*Ecobichon DJ, ed. 1994. Pesticides and neurological diseases. 2^nd^ ed. Boca Raton, FL: CRC Press, 381.
Edmiston S, Maddy KT. 1987. Summary of illnesses and injuries reported in California by physicians in 1986 as potentially related to pesticides. Vet Hum Toxicol 29(5):391–397.2961120
Ehrich M, Cohen SD. 1977. DDVP (dichlorvos) detoxification by binding and interactions with DDT, dieldrin, and malaoxon. J Toxicol Environ Health 3(3):491–500.597376
Ehrich M, Correll L, Veronesi B. 1994. Neuropathy target esterase inhibition by organophosphorus esters in human neuroblastoma cells. Neurotoxicology 15(2):309–313.7991219
*Ehrich M, Jortner BS, Padilla S. 1995. Comparison of the relative inhibition of acetylcholinesterase and neuropathy target esterase in rats and hens given cholinesterase inhibitors. Fund Appl Toxicol 24:94–101.
*Ehrich M, Shell L, Rozum M, . 1993. Short-term clinical and neuropathologic effects of cholinesterase inhibitors in rats. J Am Coll Toxicol 12(1):55–68.
*Eitzer BD, Chevalier A. 1999. A landscape care pesticide residues in residential drinking water wells. Bull Environ Contam Toxicol 62:420–427.10094724
*Ekin FHJ. 1971. Accidental poisoning with malathion. Br Med J 3(5765):47.
*Ellman GL, Courtney KD, Andres V Jr, Featherstone RM. 1961. A new and rapid colorimetric determination of acetylcholinesterase activity. Biochem Pharmacol 7:88–95.13726518
*Enan EE. 1983. Comparative biochemical effects of three aliphatic organophosphorus insecticides on white rats. Int Pest Control 25:42–44.
EPA. 1978. Bioassay of malathion for possible carcinogenicity. Bethesda, MD: U.S. Department of Health, Education and Welfare, Public Health Service, U.S. Environmental Protection Agency.
*EPA. 1980. Analysis of pesticide residues in human and environmental samples: A compilation of methods selected for use in pesticide monitoring programs. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory, EPA-600/8-80-038; NTIS PB82-208752.
*EPA. 1982. Management of hazardous waste leachate. U.S. Environmental Protection Agency. EPA Contract No. 68-03-2766 pE,56,90.
*EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA 600/8-90/066A.
EPA. 1991. Drinking water health advisory for malathion. Washington, DC: Office of Science and Technology, Office of Water, U.S. Environmental Protection Agency.
*EPA. 1992. Pesticides in ground water database: A compilation of monitoring studies: 1971-1991 National Summary. Washington, DC: Prevention Pesticides and Toxic Substances, U.S. Environmental Protection Agency.
EPA. 1997a. Automated form R for Windows: User’s guide (RY97). Washington, DC: Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency.
EPA. 1997b. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: Risk Assessment Forum, U.S. Environmental Protection Agency. EPA/630/R-96/012.
*EPA. 1999. Malathion reregistration eligibility document. Environmental fate and effects chapter. U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/op/malathion/efed_part1.pdf. November 6, 2000.
*EPA. 2000a. Malathion. Re-registration eligibility decision. U.S. Environmental Protection Agency. Http:www.epa.gov/pesticides/red/malathion.html (Http://www.epa.gov/pesticides/red/malathion.html). November 6, 2000.
*EPA. 2000b. Evaluation of the carcinogenic potential of malathion. Cancer Assessment Review Committee, Health Effects Division, Office of Pesticides Programs. U.S. Environmental Protection Agency.
*EPA. 2000c. Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA 822-B-00-001.
*EPA. 2000d. Overview of malathion risk assessment. Office of Pesticide Programs. U.S. Environmental Protection Agency. www.epa.gov/pesticides/op/malathion/overview.htm.
*EPA. 2000e. Pesticides industry sale and usage: 1996 and 1997 market estimates. Table 9. Office of Pesticide Programs. U.S. Environmental Agency. www.epa.gov/oppbead1/pestsales/97pestsales/table9.htm.
*EPA 2001a. Pesticide programs. Applicability, description of the organic pesticide chemicals manufacturing subcategory. U.S. Environmental Protection Agency. Code of Federal Regulations 40CFR455.20. Http://ecfr.access.gpo.gov/otcg…=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. April 03, 2001.
*EPA. 2001b. Water programs. Designation of hazardous substance. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. Http://ecfr.access.gpo.gov/otcgi/cf…=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. April 03, 2001.
*EPA. 2001c. Water programs. Determination of reportable quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. Http://ecfr.access.gpo.gov.otcg…=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. April 03, 2001.
*EPA. 2001d. Methyl eugenol and malathion combination; exemption from the requirement of a tolerance. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455.20. Http://ecfr.access.gpo.gov/octgi/cf…=BSECCT&SUBSET&FROM=1. April 03, 2001.
*EPA. 2001e. Tolerances and exemptions from tolerances for pesticide chemicals in food. Tolerances for related pesticide chemicals. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.3. Http://ecfr.access.gpo.gov/otcg…=BSECCT&SUBSET=SUBSET&FROM=1&ITEM1. April 03, 2001.
*EPA. 2001f. Malathion. Tolerances for residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.111. Http://ecfr.access.gpo.gov/otcg…=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. April 03, 2001.
EPA. 2001g. NPDES. Permit application testing requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122, Appendix D. Http://ecfrback.access.gpo.gov.otcgi/cf…=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. April 03, 2001.
*EPA. 2001h. Interim status standards for owners and operators of hazardous waste treatment, storage, and disposal facilities. Compounds with Henry’s law constant less than 0.1 Y/X. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 265, Appendix VI. Http://ecfr.access.gpo.gov/otcgi/cf…=BAPPCT7SUBSET=SUBSET&FROM=1&ITEM=1. April 03, 2001.
*EPA. 2001i. Reportable Quantities. Malathion. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. https://www.ecfr.gov/current/title-40/chapter-I/subchapter-J/part-302#302.4. March 13, 2001.
*EPA. 2001j. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. Http://ecfrback.access.gpo.gov/otcgi…=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. April 03, 2001.
*Ernest K, Thomas M, Paulose M, . 1995. Delayed effects of exposure to organophosphorus compounds. Indian J Med Res 101:81–84.7729854
*Erney DR. 1995. Determination of organophosphorus pesticides in whole/chocolate/skim-milk and infant formula using solid-phase extraction with capillary gas chromatography/flame photometric detection. J High Resolut Chromatogr 18:59–62.
Fan AM, Jackson RJ. 1989. Pesticides and food safety. Regul Toxicol Pharmacol 9:158–174.2655038
*Faragó A. 1967. Fatal, suicidal malathion poisonings. Arch Toxicol 23:11–16.
Fatiadi A. 1984. Priority toxic pollutants in human urine: Their occurrence and analysis. Environ Int 10:175–205.
*Fazzalari FA, ed. 1978. Compilation of odor and taste threshold values data. ASTM Data Series DS 48A (Committee E-18). Philadelphia, PA: American Society for Testing and Materials.
*FDA. 1999. Pesticide analytical manual. U.S. Food and Drug Administration, Center for Food Safety and Applied Nutrition Office of Plant and Dairy Foods and Beverages. http://vm.cfsan.fda.gov/~frf/pami1.html.
*FEDRIP. 2002. Federal Research in Progress. Palo Alto, CA: Dialog Information Services, Inc.
*Feldman RJ, Maibach HT. 1974. Percutaneous penetration of some pesticides and herbicides in man. Toxicol Appl Pharmacol 28:126–132.4853576
*Fendinger NJ, Glotfelty DE. 1990. Henry’s law constants for selected pesticides, PAHs and PCBs. Environ Toxicol Chem 9:731–735.
*Fenske RA. 1988. Correlation of fluorescent tracer measurements of dermal exposure and urinary metabolite excretion during occupational exposure to malathion. Am Ind Hyg Assoc J 49(9):438–444.3177222
*Fenske RA, Leffingwell JT. 1989. Method for the determination of dialkyl phosphate metabolites in urine for studies of hymen exposure to malathion. J Agric Food Chem 37:995–998.
*Fischer J. 1988. 28-day oral toxicity study in beagle dogs. Lab project No. 0852AX883L2116. Unpublished study prepared by American Cyanamid Co. 158 p. MRID 45077703. (As cited in IPCS 1997).
*Flessel P, Quintana PJE, Hooper K. 1993. Genetic toxicity of malathion: A review. Environ Mol Mutagen 22:7–17.8339727
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Forcada M, Beltran J, Lopez FJ, . 2000. Multiresidue procedures for determination of triazine and organophosphorus pesticides in water by use of large-volume PTV injection in gas chromatography. Chromatographia 51(5/6):362–368.
*Foster TS. 1968. Effect of some pesticides on the adrenal glands in the rat. Can J Biochem 46:1115–1120.5687639
*Foster G, Lippa KA. 1996. Fluvial loadings of selected organonitrogen and organophosphorus pesticides to Chesapeake Bay. J Agric Food Chem 44:2447–2454.
*Fournier E, Sonnier M. 1978. Detection and assay of organophosphate pesticides in human blood by gas chromatography. Clin Toxicol 12(4):457–462.657759
Fournier M, Bernier J, Flipo D, . 1986. Evaluation of pesticide effects on humoral response to sheep erythrocytes and mouse hepatitis virus 2 by immunosorbent analysis. Pestic Biochem Physiol 26:352–364.
Francesconi R, Hubbard R, Mager M. 1983. Brief communication: Malathion administration: Effects on physiological and physical performance in the heat. Pharmacol Biochem Behav 19:1031–1035.6657721
*Frawley JP, Fuyat HN, Hagan EC, . 1957. Marked potentiation in mammalian toxicity from simultaneous administration of two anticholinesterase compounds. J Pharmacol Exp Therap 121:96–106.13481831
*Freed VH, Chiou C, Schmedding DW. 1979a. Degradation of selected organophosphate pesticides in water and soil. J Agric Food Chem 27(4):706–708.
Freed VH, Schmedding D, Kohnert R, . 1979b. Physical-chemical properties of several organophosphates: Some implications in environmental and biological behavior. Pestic Biochem Physiol 10:203–211.
Fukuto TR, Metcalf RL. 1969. Metabolism of insecticides in plants and animals. Ann N Y Acad Sci 160(1):97–113.4389895
*Gaines TB. 1960. The acute toxicity of pesticides to rats. Toxicol Appl Pharmacol 2:88–99.13825957
*Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 14:515–534.5787520
*García AM, Benavides FG, Fletcher T, . 1998. Paternal exposure to pesticides and congenital malformations. Scand J Work Environ Health 24(6):473–480.9988089
*Garcia-Repetto R, Martinez D, Repetto M. 1995. Malathion and dichlorvos toxicokinetics after the oral administration of malathion and trichlorfon. Vet Hum Toxicol 37(4):306–309.8540214
*Garry VF, Nelson RL, Griffith J, . 1990. Preparation for human study of pesticide applicators: Sister chromatid exchanges and chromosome aberrations in cultured human lymphocytes exposed to selected fumigants. Teratogen Carcinogen Mutagen 10:21–29.
*Gartrell MJ, Craun JC, Podrebarac DS, . 1985. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1979-September 1980. J Assoc Off Anal Chem 68(6):1184–1197.4086442
*Gartrell MJ, Craun JC, Podebarac DS, . 1986. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980- March 1982. J Assoc Off Anal Chem 69(1):146–161.3949687
Geyer HJ, Schramm K-W, Feicht EA, . 2002. Half-lives if tetra-,penta-, hexa-, hepta-, and octachlorodibenzo-p-dioxin in rats, monkeys, and humans-a critical review. Chemosphere 48:631–644.12143938
Ghezal F, Bennaceur M. 1996. Mobility and degradation of ^14^C-malathion in soil. X-Symposium Pesticide Chemistry-Last Minute Communication.
*Gianessi LP, Anderson JE. 1997. Pesticide use in U.S. crop production: National Summary Report. Washington, DC: National Center for Food and Agricultural Policy, 1995.
*Gibson WP, Burns RG. 1977. The breakdown of malathion in soil and soil components. Microb Ecol 3:219–230.24233575
*Giri S, Prasad SB, Giri A, . 2002. Genotoxic effects of malathion: An organophosphorus insecticide, using three mammalian bioassays in vivo. Mutat Res 514(1–2):223–231.11815260
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Goldfrank LR, Flomenbaum NE, Lewin NA, ., eds. 1998. Goldfrank’s toxicologic emergencies. 6^th^ ed. Stamford, CT: Appleton and Lange.
*Golz HH. 1959. Controlled human exposures to malathion aerosols. AMA Arch Ind Health 19:53–59.
*Goodman MA, Aschmann SM, Atkinson R, . 1988. Kinetics of the atmospherically important gas-phase reactions of a series of trimethyl phosphorothioates. Arch Environ Contam Toxicol 17:281–288.
*Grech JL. 1965. Alterations in serum enzymes after repeated exposure to malathion. Br J Ind Med 22:67–71.14261708
*Grether JK, Harris JA, Neutra R, . 1987. Exposure to aerial malathion application and the occurrence of congenital anomalies and low birthweight. AJPH 77(8):1009–1010.
*Griffin DE, Hill WE. 1978. In vitro breakage of plasmid DNA by mutagens and pesticides. Mutat Res 52:161–169.368611
*Gunderson EL. 1995a. Dietary intakes of pesticides, selected elements, and other chemicals: FDA total diet study, June 1984-April 1986. J AOAC Int 78(4):910–921.7580329
*Gunderson EL. 1995b. FDA total diet study, July 1986-April 1991, dietary intakes of pesticides, selected elements, and other chemicals. J AOAC Int 78(6):1353–1363.8664570
Gunier RB, Harnly ME, Reynolds P, . 2001. Agricultural pesticide use in California: Pesticide prioritization, use densities, and population distributions for a childhood cancer study. Environ Health Perspect 109(10):1071–1078.11689348
Gupta J, Datta C, Sarkar A, . 1992. Effect of malathion on antioxidant defense system in human fetus. An in vitro study. Indian J Exp Biol 30:352–354.1459609
*Gupta RC. 1995. Environmental agents and placental toxicity: Anticholinesterases and other insecticides. In: Rama Sastry BV, ed. Placental Toxicology. Boca Raton, FL: CRC Press.
Gupta RC, Paul BS. 1978. Influence of malathion (O,O’-dimethyl dithiophosphate of diethyl mercaptosuccinate) on body enzymes in dermal subacute toxicity studies in Bubalus bubalis species. Bull Environ Contam Toxicol 20:811–818.219925
*Gupta RC, Welsch F, Thornburg JE, . 1983. Effect of chloramphenicol pretreatment on malathion-induced acute toxicity in the rat. J Toxicol Environ Health 11:897–905.6620420
*Güven M, Bayram F, Unluhizarci K, . 1999. Endocrine changes in patients with acute organophosphate poisoning. Hum Exp Toxicol 18:598–601.10557009
Guy RH, Hadgraft J, Maibach HI. 1983. Percutaneous absorption: Multidose pharmacokinetics. Int J Pharm 17:23–28.
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haddad LM, Shannon MW, Winchester JF, eds. 1998. Clinical management of poisoning and drug overdose. 3^rd^ ed. Philadelphia, PA: WB Saunders Company.
Hague N, Rizvi SJ, Khan MB. 1987. Malathion induced alterations in the lipid profile and the rate of lipid peroxidation in rat brain and spinal cord. Pharmacol Toxicol 61:12–15.3628175
Hamilton DJ, Holland PT, Ohlin B, . 1997. Optimum use of available residue data in the estimation of dietary intake of pesticides. Pure Appl Chem 69(6):1373–1410.
*Hansch C, Leo AD. 1995. Exploring QSAR-hydrophobic, electronic and steric constants. Washington, DC: American Chemical Society.
*Harman-Fetcho JA, McConnell LL, Rice CP, . 2000. Wet deposition and air -water gas exchange of currently used pesticides to a subestuary of the Chesapaeke Bay. Environ Sci Technol 34(8):1462–1468.
*Hassan A, Dauterman WC. 1968. Studies on the optically active isomers of O,O-diethyl malathion and O,O-diethyl malaoxon. Biochem Pharmacol 17:1431–1439.5659786
Hayasaka M, Kawabata S, Haba A, . 1996. Distribution of malathion metabolites in rats. Jpn J Forensic Toxicol 14(3):221–227.
*HazDat. 2003. Agency of Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. February 28, 2003.
Hazleton LW, Holland EG. 1949. Toxicity of malathion. AMA Arch Ind Hyg Occup Med 8:399–405.
*Healy JK. 1959. Ascending paralysis following malathion intoxication: A case report. Med J Aust 1:765–767.13666174
*Hermanowicz A, Kossman S. 1984. Neutrophil function and infectious disease in workers occupationally exposed to phosphoorganic pesticides: Role of mononuclear-derived chemotactic factor for neutrophils. Clin Immunol Immunopathol 33:13–22.6478653
Hirvonen M-R, Komulainen H, Paljarvi L, . 1989. Time-course of malaoxon-induced alterations in brain regional inositol-1-phosphate levels in convulsing and nonconvulsing rats. Neurochem Res 14(2):143–147.2725814
Hirvonen M-R, Paljarvi L, Savolainen KM. 1993. Malaoxon-induced neurotoxicity in old rats: alterations in cerebral inositol lipid signaling, brain tissue calcium levels and early neuronal injury. Toxicology 79:157–167.8497869
*Hoda Q, Azfer MA, Sinha SP. 1993. Modificatory effect of vitamin C and vitamin B-complex on meiotic inhibition induced by organophosphorus pesticide in mice Mus musculus. Internat J Vit Nutr Res 63:48–51.
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
*Hopper ML. 1999. Automated one-step supercritical fluid extraction and clean-up system for the analysis of pesticide residues in fatty matrices. J Chromatogr 840:93–105.
Howe FP, Knight RL, McEwen LC, . 1996. Direct and indirect effects of insecticide applications on growth and survival of nestling passerines. Ecol Appl 6(4):1314–1324.
*Howard PH. 1991. Handbook of environmental degradation rates. Chelsea, MI: Lewis Publishers.
*Howard PH, Neal M. 1992. Dictionary of chemical names and synonyms. Lewis Publishers, Inc. I-298-299.
*HSDB. 2001. Malathion. National Library of medicine. National Toxicology Information Program. Bethesda, MD: Hazardous Substances Data Bank. Http://toxnet.nlm.nih.gov/cgi/sis/search. April 18, 2001.
*Huff JE, Bates R, Eustis SL, . 1985. Malathion and malaoxon: Histopathology reexamination of the national cancer institute’s carcinogenesis studies. Environ Res 37:154–173.3996335
*Husain K, Ansari RA. 1990. Effectiveness of certain drugs in acute malathion intoxication in rats. Ecotoxicol Environ Saf 19:271–275.2364909
*Husain K, Ansari RA, Gupta PK. 1987. Effect of sub-chronic exposure of malathion on blood and tissue enzyme activities in female rats. J Environ Biol 8(2):137–142.
*IARC. 1983. International Agency for Research on Cancer. In: Miscellaneous Pesticides. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to humans. Lyon, France: World Health Organization. IARC 30:103, 107.
*IARC. 2001. Malathion (Group 3). International Agency for Research on Cancer. http://193.51.164.11/htdocs/Monographs/Vol30/Malathion.html. April 18, 2001.
Imamura T, Gandy J. 1988. Pulmonary toxicity of phosphorothioate impurities found in organophosphate insecticides. Pharmacol Ther 38:419–427.3057516
*Imamura T, Hasegawa L. 1984. Subcellular distribution of malathion, phenthoate, and diethylsuccinate carboxylesterases in rat lungs. Pestic Biochem Physiol 22:321–328.
*Imamura T, Talcott RE. 1985. Mutagenic and alkylating activities of organophosphate impurities of commercial malathion. Mutat Res 155:1–6.3881662
Imamura T, Gandy J, Fukuto TR, . 1983. An impurity of malathion alters the morphology of rat lung bronchiolar epithelium. Toxicology 26:73–79.6829031
*IPCS. 1997. Pesticide residues in food. Toxicological and environmental evaluations 1994. Internationl Programme on Chemical Safety.
*IRIS. 2003. Malathion. U.S. Environmental Protection Agency. Integrated Risk Information System. http://www.epa.gov/IRIS/subst/0248.htm. March 26, 2001.
*Ito G, Kilgore WW, Seabury JJ. 1979. Effect of freezer storage on alkyl phosphate metabolites in urine. Bull Environ Contam Toxicol 22:530–535.39650
Jackson CJ, Lindahl IL, Reynolds P, . 1975. Effects of methoxychlor and malathion on semen characteristics of rams. J Anim Sci 40:514–517.234932
*Jadhav RK, Sharma VK, Rao GJ, . 1992. Distribution of malathion in body tissues and fluids. Forensic Sci Int 52:223–229.1601353
Jamal GA. 1997. Neurological syndromes of organophosphorus compounds. Adverse Drug React Toxicol Rev 16(3):133–170.9512762
*Jegier Z. 1984. Health hazards in insecticide spraying of crops. Arch Environ Health 8:670–674.
Jianmongko S, Marable BR, Berkman CE, . 1999. Kinetic evidence for different mechanisms of acetylcholinesterase inhibition by (1R)- and (1S)-stereoisomers of isomalathion. Toxicol Appl Pharmacol 155:43–53.10036217
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
John S, Kale M, Rathore N, . 2001. Protective effect of vitamin E in dimethoate and malathion induced oxidative stress in rat erythrocytes. J Nutr Biochem 12:500–504.11834209
Johnson JA, Wallace KB. 1987. Species-related differences in the inhibition of brain acetylcholinesterase by paraoxon and malaoxon. Toxicol Appl Pharmacol 88:234–241.3564042
Johnson JC, VanEmon JM, Pullman DR, . 1998. Development and evaluation of antisera for detection of the O,O-diethyl phosphorothionate and phosphorothionothiolate organophosphorus pesticides by immunoassay. J Agric Food Chem 46:3116–3123.
*Johnson VJ, Rosenberg AM, Lee K, . 2002. Increased T-lymphocyte dependent antibody production in female SJL/J mice following exposure to commercial grade malathion. Toxicology 170(1–2):119–129.11750089
Jongenotter GA, Kerkhoff MAT, van der Knaap HCM, . 1999. Automated on-line GPC-GC-FPD involving co-solvent trapping and the on-column interface for the determination of organophosphorus pesticides in olive oils. J High Resolut Chromatogr 22(1):17–23.
Jorgenson TA, Rushbrook CJ, Newell GW. 1976. In vivo mutagenesis investigations of ten commercial pesticides. Toxicol Appl Pharmacol 37(1):109.
*Jušić A, Milić S. 1978. Neuromuscular synapse testing in two cases of suicidal organophosphorus pesticide poisoning. Arch Environ Health 33:240–243.568457
*Jušić A, Jurenić D, Milić S. 1980. Electromyographical neuromuscular synapse testing and neurological findings in workers exposed to organophosphorus pesticides. Arch Environ Health 35(3):168–175.6247983
Kacew S, Akhtar MH, Khan SU. 1996. Bioavailability of bound pesticide residues and potential toxicologic consequences-An update. Proc Soc Exp Biol Med 211:62–68.8594619
*Kahn E, Berlin M, Deane M, . 1992. Assessment of acute health effects from the medfly eradication project in Santa Clara County, California. Arch Environ Health 47(4):279–284.1497381
*Kalow W, Marton A. 1961. Second-generation toxicity of malathion in rats. Nature 192(4801):464–465.14453368
Kamal MA. 1997. Effect of malathion on kinetic parameters of acetylcholinesterase (EC 3.1.1.7) in vitro. Biochem Mol Biol Int 43(1):89–97.9315286
*Kamel F, Boyes WK, Gladen BC, . 2000. Retinal degeneration in licensed pesticide applicators. Am J Ind Med 37:618–628.10797505
*KAN-DO Office and Pesticides Team. 1995. Accumulated pesticide and industrial chemical findings from a ten-year study of ready-to-eat foods. J AOAC Int 78(3):614–630.7756874
Kang J, Zettel VH, Ward NI. 1995. The organophosphate pesticides. J Nutr Environ Med 5:325–339.
Karalliedde L, Henry JA. 1993. Effects of organophosphates on skeletal muscle. Hum Exp Toxicol 12:289–296.8104006
Kashyap SK, Gupta SK. 1971. The effect of occupational exposure to organophosphorus pesticides on blood cholinesterase. Indian J Med Res 59(2):289–293.5579245
Kaur I, Mathur RP, Tandon SN. 1998. Degradation of some organophosphorus pesticides under different field conditions. Environ Technol 19:97–102.
Kay K, Monkam L, Windlah JP. 1952. Parathion exposure and cholinesterase response of Quebec apple growers. AMA Arch Ind Hyg Occup Med 6:252–262.14952051
*Keadtisuke S, Fukuto R. 1987. Dysproteinuria induced in rats by O,O,S-trimethyl phosphorothioate. Toxicol Lett 37:33–39.3590228
*Keadtisuke S, Dheranetra W, Fukuto TR. 1989. Detection of kidney damage by malathion impurities using a microdissection technique. Toxicol Lett 47:53–59.2652380
Keadtisuke S, Dheranetra W, Nakatsugawa T, . 1990. Liver damage induced in rats by malathion impurities. Toxicol Lett 52:d35–d46.
Keim SA, Alavanja MCR. 2001. Pesticide use by persons who reported a high pesticide exposure event in the agricultural health study. Environ Res 85(3):256–259.11237514
*Kennedy ER, Abell MT, Reynolds J, . 1994. A sampling and analytical method for the simultaneous determination of multiple organophosphorus pesticides in air. Am Ind Hyg Assoc J 55(12):1172–1177.7825517
*Keplinger ML, Deichmann WB. 1967. Acute toxicity of combinations of pesticides. Toxicol Appl Pharmacol 10:586–595.6059673
*Ketterman AJ, Pond SM, Becker CE. 1987. The effects of differential induction of cytochrome P-450, carboxylesterase and glutathione S-transferase activities on malathion toxicity in mice. Toxicol Appl Pharmacol 87:389–392.3564013
*Khan S, Khan NN. 1986. The mobility of some organophosphorus pesticides in soils as affected by some soil parameters. Soil Sci 142(4):214–222.
*Khera KS, Whalen C, Trivett G. 1978. Teratogenicity studies of linuron, malathion, and methoxychlor in rats. Toxicol Appl Pharmacol 45:435–444.705783
*Kim YH, Woodrow JE, Seiber JN. 1984. Evaluation of a gas chromatographic method for calculating vapor pressures with organophosphorus pesticides. J Chromatogr 314:37–53.
*Kimbrough RA, Litke DW. 1996. Pesticides in streams draining agricultural and urban areas in Colorado. Environ Sci Technol 30:908–916.
Kimbrough RD, Gaines TB. 1968. Effect of organic phosphorus compounds and alkylating agents on the rat fetus. Arch Environ Health 16:805–808.5654550
*Knaack JB, Maddy KT, Jackson T, . 1978. Cholinesterase activity in blood samples collected from field workers and non-field workers in California. Toxicol Appl Pharmacol 45:755–770.725930
Koelle GB. 1994. Pharmacology of organophosphates. J Appl Toxicol 14(2):105–109.8027504
Koizumi A, McCloud L, Imamura T. 1986. Increased resorption of embryos in O,O,S-trimethyl phosphorothioate-treated rats. Toxicol Lett 32:185–194.3775802
*Kolpin D, Barbash JE, Gilliom RJ. 1998. Occurrence of pesticides in shallow groundwater of the United States: Initial results from the national water-quality assessment program. Environ Sci Technol 32:558–566.
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
*Konrad JG, Chesters G, Armstrong DE. 1969. Soil degradation of malathion, a phosphorodithioate insecticide. Soil Sci Soc Am Proc 33:259–262.
*Kramer BK, Ryan PB, MacIntosh DL. 1999. Initial investigation of analytical extraction techniques for the determination of bioavailability of pesticides in soil [Abstract]. Proc Conf Hazard Waste Res: Gateways Environ Solutions, 19–26.
*Krapac G, Roy W, Smyth CA, . 1995. Occurrence and distribution of pesticides in soil at agrichemical facilities in Illinois. J Soil Contam 4(3):209–226.
*Krause W. 1977. Influence of DDT, DDVP and malathion on FSH, LH and testosterone concentration in testis. Bull Environ Contam Toxicol 18(2):231–242.890160
*Krause W, Hamm K, Weissmuller J. 1976. Damage to spermatogenesis in juvenile rat treated with DDVP and malathion. Bull Environ Contam Toxicol 15(4):458–462.1260153
Krazen C, Bloomer A, Welch R, . 1974. Persistence of pesticides on the hands of some occupationally exposed people. Arch Environ Health 29:315–318.4279630
*Krieger RI, Dinoff TM. 2000. Malathion deposition, metabolite clearance, and cholinesterase status of date dusters and harvesters in California. Arch Environ Contam Toxicol 38:546–553.10787107
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3^rd^ ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Krzysztof K, Trottier B, Jolicoeur P, . 1987. Macrophage functional activities versus cellular parameters upon sublethal pesticide exposure in mice. Mol Toxicol 1:247–259.2835675
*Kucklick JR, Bidleman T. 1994. Organic contaminants in Winyah Bay, South Carolina I: Pesticides and polycyclic aromatic hydrocarbons in subsurface and microlayer waters. Mar Environ Res 37:63–78.
Kulkarni AP, Fabacher DL, Hodgson E. 1980. Pesticides as inducers of hepatic drug-metabolizing enzymes--II. Glutathione s-transferases. Gen Pharmacol 11:437–441.7419036
*Kumar D, Khan PK, Sinha SP. 1995. Cytogenetic toxicity and no-effect limit dose of pesticides. Food Chem Toxicol 33:309–314.7537710
Kumar R, Uppal RP. 1986. Effect of malathion on oestrus cycle and reproductive performance of rat. J Environ Biol 71(1):35–39.
Kumar S, Nath A. 1997. Effect of an organophosphorus insecticide malathion on spermatocytes of mice. Environ Ecol 15(1):161–165.
Kurtz PJ. 1977. Dissociated behavioral and cholinesterase decrements following malathion exposure. Toxicol Appl Pharmacol 42:589–594.601800
*Kutz FW, Cook BT. 1992. Selected pesticide residues and metabolites in urine from a survey of the US general population. J Toxicol Environ Health 37:277–291.1404486
*LaCorte S, Lartiges S, Garrigues P, . 1995. Degradation of organophosphorus pesticides and their transformation products in estuarine waters. Environ Sci Technol 29:431–438.22201390
*Lamb I. 1994a. An acute neurotoxicity study of malathion in rats. Final report: Lab project No. WIL/206005. Unpublished study prepared by WIL Research Labs., Inc. MRID 43146701. (As cited in EPA 2000a, 2000b).
*Lamb I. 1994b. A subchronic (13-week) neurotoxicity study of malathion in rats: Final Report: Lab project No. WIL-206006. Unpublished study prepared by WIL Research Labs., Inc. MRID 43269501. (As cited in EPA 2000a, 2000b).
*Larson SJ, Capel PD, Goolsby DA, . 1995. Relations between pesticide use and riverine flux in the Mississippi river basin. Chemosphere 31:3305–3321.
Lartiges SB, Garrigues PP. 1995. Degradation kinetics of organophosphorus and organonitrogen pesticides in different waters under various environmental conditions. Environ Sci Technol 29:1246–1254.22192018
Laurent CH, Jadot P, Chabut CH. 1996. Unexpected decrease in cytogenetic biomarkers frequencies observed after increased exposure to organophosphorus pesticides in a production plant. Int Arch Occup Environ Health 68:399–404.8891775
*Laveglia J, Dahm PA. 1997. Degradation of organophosphorus and carbamate insecticides in the soil and by soil microorganisms. Annu Rev Entomol 22:483–513.
*Lebel GL, Williams DT, Griffith G, . 1979. Isolation and concentration of organophosphorus pesticides from drinking water at the ng/L level, macrorecticular resin. J Assoc Off Anal Chem 62:241–24.447594
*Lechner DW, Abdel-Rahman MS. 1984. A teratology study of carbaryl and malathion mixtures in rat. J Toxicol Environ Health 14:267–278.6438344
*Lechner D, Abdel-Rahman S. 1985. Alterations in rat liver microsomal enzymes following exposure to carbaryl and malathion in combination. Arch Environ Contam Toxicol 14:451–457.3929702
*Lechner DW, Abdel-Rahman MS. 1986. Kinetics of carbaryl and malathion in combination in the rat. J Toxicol Environ Health 18:241–256.3086564
*Lee P, Tai DYH. 2001. Clinical features of patients with acute organophosphate poisoning requiring intensive care. Intensive Care Med 27(4):694–699.11398695
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
*LeNoir JS, McConnell LL, Fellers GM, . 1999. Summertime transport of current-use pesticides from California’s Central Valley to the Sierra Nevada Mountain Range, USA. Environ Toxicol Chem 18(12):2715–2722.
*Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Levanon D. 1993. Roles of fungi and bacteria in the mineralization of the pesticides atrazine, alachlor, malathion and carbofuran in soil. Soil Biol Biochem 25(8):1097–1105.
*Lewis DL, Paris DF, Baughman GL. 1975. Transformation of malathion by a fungus, aspergillusoryzae, isolated from a fresh water pond. Bull Environ Contam Toxicol 13(5):596–601.1148416
*Lewis RG, Fortmann RC, Camann DE. 1994. Evaluation of methods for monitoring the potential exposure of small children to pesticides in the residential environment. Arch Environ Contam Toxicol 26:37–46.8110022
*Lin PT, Main AR, Motoyama N, . 1984a. Hydrolysis of malathion homologs by rabbit liver oligomeric and monomeric carboxylesterases. Pestic Biochem Physiol 21:110–116.
*Lin PT, Main AR, Tucker WP, . 1984b. Studies on organophosphorus impurities in technical malathion: Inhibition of carboxylesterases and the stability of isomalathion. Pestic Biochem Physiol 21:223–231.
*Lin S, Marshall EG, Davidson GK. 1994. Potential parental exposure to pesticides and limb reduction defects. Scand J Work Environ Health 20:166–179.7973488
*Lin Y, Hee SSQ. 1998. Permeation of malathion through glove materials. Appl Occup Environ Hyg 13(3):158–165.
*Linhout D, Hageman G. 1987. Amyoplasia congenita-like condition and maternal malathion exposure. Teratology 36:7–9.3672379
*Lipscomb GQ. 1968. Residues in food and feed: Pesticide residues in prepared baby foods in the US. Pestic Monit J 2(3):104–108.5729620
Liu PS, Kao LS, Lin MK. 1994. Organophosphates inhibit catecholamine secretion and calcium influx in bovine adrenal chromaffin cell. Toxicology 90:81–91.8023345
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
*Lochry E. 1989. A development toxicity study with CA 6,601 in rats. Argus Research Laboratories Protocol 101-005. Unpublished study prepared by Argus Research Laboratories, Inc. MRID 41160901. (As cited in EPA 2000a).
*Lores EM Bradway DE. 1977. Extraction and recovery of organophosphorus metabolites from urine using an anion exchange resin. J Agric Food Chem 25:75–79.
Lores EM, Bradway DE, Moseman RF. 1978. Organophosphorus pesticide poisonings in humans: Determination of residues and metabolites in tissues and urine. Arch Environ Health 33(5):270–276.81664
*Lovell RA, McChesney DG, Price WD. 1996. Organohalogen and organophosphorus pesticides in mixed feed rations: Findings from FDA’s domestic surveillance during fiscal years 1989-1994. J AOAC Int 79(2):544–548.8920144
*Lox CD. 1983. Effects of acute pesticide poisoning on blood clotting in the rat. Ecotoxicol Environ Saf 7:451–454.6641583
*Lox, CD. 1985. Short term malathion ingestion and blood clotting in the rat. J Environ Pathol Toxicol Oncol 6:51–55.4067834
*Lox CD, Davis JR. 1983. The effects of long-term malathion or diazinon ingestion on the activity of hepatic synthesized clotting factors. Ecotoxicol Environ Saf 7:546–551.6662056
*Lu FC, Jessup DC, Lavallee A. 1965. Toxicity of pesticides in young versus adult rats. Fd Cosmet Toxicol 3:591–596.
*Luke M, Masumoto HT, Cairns T, . 1988. Levels and incidences of pesticide residues in various foods and animal feeds analyzed by the Luke Multiresidue Methodology for fiscal years 1982-1986. J Assoc Off Anal Chem 71(2):415–420.3384794
*Lyon J, Taylor H, Ackerman B. 1987. A case report of intravenous malathion injection with determination of serum half-life. Clin Toxicol 25(3):243–249.
*Machin MGA, McBride WG. 1989a. Teratological study of malathion in the rabbit. J Toxicol Environ Health 26:249–253.2926827
*Machin MGA, McBride WG. 1989b. Placental transfer of malathion in the rabbit. Med Sci Res 17:743–744.
*MacIntosh DL, Hammerstrom K, Ryan PB. 1999a. Longitudinal exposure to selected pesticides in drinking water. Hum Ecol Risk Assess 5(3):575–588.
*MacIntosh DL, Needham LL, Hammerstrom KA, . 1999b. A longitudinal investigation of selected pesticide metabolites in urine. J Exp Anal Environ Epidemiol 9:494–501.
*Mackison FW, Stricoff RS, Partridge LJ Jr. (eds.). 1981. Occupational health guidelines for chemical hazards. NIOSH/OSHA PublicationNo. 81-123. Washington, DC: U.S. Government Printing Office.
*MacNamara G, Toth S. 1970. Adsorption of linuron and malathion by soils and clay mineral. Soil Sci 109(4):234–240.
Maddy KT, Edmiston S, Richmond D. 1990. Illnesses, injuries, and deaths from pesticide exposures in California 1949-1988. Rev Environ Contam Toxicol 114:57–123.2403691
*Maibach HI, Feldmann RJ, Milby TH, . 1971. Regional variation in percutaneous penetration in man. Arch Environ Health 23:208–211.5123154
*Main AR, Braid PE. 1962. Hydrolysis of malathion by ali-esterases in vitro and in vivo. Biochem J 84:255–263.14468518
*Main AR, Dauterman WC. 1967. Kinetics for the inhibition of carboxylesterase by malaoxon. Can J Biochem 45:757–771.6034697
*Majewski MS, Foreman WT, Goolsby DA, . 1998. Airborne pesticide residues along the Mississippi River. Environ Sci Technol 32:3689–3698.
*Malik JK, Summer KH. 1982. Toxicity and metabolism of malathion and its impurities in isolated rat hepatocytes: Role of glutathione. Toxicol Appl Pharmacol 66(1):69–76.7157385
*Mallipudi NM, Talcott RE, Ketterman A, . 1980. Properties and inhibition of rat malathion carboxylesterases. J Toxicol Environ Health 6:585–596.7420466
*Markowitz JS, Gutterman EM, Link BG. 1986. Self-reported physical and psychological effects following a malathion pesticide incident. J Occup Med 28(5):377–383.3712117
*Maroni M, Colosio C, Ferioli A, . 2000. Organophosphorus pesticides. Toxicol 143:9–37.
*Marty MA, Dawson SV, Bradman MASA, . 1994. Assessment of exposure to malathion and malaoxon due to aerial application over urban areas of Southern California. J Expo Anal Environ Epidemiol 4(1):65–81.7894269
Masten SJ, Tian M, Upham BL, . 2001. Effect of selected pesticides and their ozonation by-products on gap junctional intercellular communication using rat liver epithelial cell lines. Chemosphere 44(3):457–465.11459151
*Mathews MS, Devi KS. 1994. Effect of chronic exposure of pregnant rats to malathion and/or estrogen and/or progesterone on xenobiotic metabolizing enzymes. Pestic Biochem Physiol 48:110–122.
*Matsukawa S, Hashimoto Y, Kato M, . 1997. An evaluation of neuromuscular reversal with edrophonium in a patient with malathion intoxication. Tohoku J Exp Med 181:467–469.9210253
*Matsumura F, Ward CT. 1966. Degradation of insecticides by the human and the rat liver. Arch Environ Health 13:257–261.5968509
*Matsumura F. 1985. Toxicology of insecticides, 2^nd^ ed. New York, NY: Plenum Press, 269.
*Mattson AM, Sedlak VA. 1960. Ether-extractable urinary phosphates in man and rats derived from malathion and similar compounds. J Agric Food Chem 8:107–110.
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McCann J, Choi E, Tamasaki E, . 1975. Detection of carcinogens as mutagens in the Salmonella/microsome test: Assay of 300 chemicals. Proc Natl Acad Sci 72:5135–5139.1061098
*McConnell LL, Lenoir JS, Datta S, . 1998. Wet deposition of current-use pesticides in the Sierra Nevada mountain range, California, USA. Environ Toxicol Chem 17(10):1908–1916.
*McDuffie HH, Pahwa P, McLaughlin JR, . 2001. Non-Hodgkin’s lymphoma and specific pesticide exposures in men: Cross-Canada study of pesticides and health. Cancer Epidemiol Biomarkers Prev 10(11):1155–1163.11700263
*Menczel E, Bucks D, Maibach H, . 1983. Malathion binding to sections of human skin: Skin capacity and isotherm determinations. Arch Dermatol Res 275:403–406.6660913
*Mendoza CE. 1976. Toxicity and effects of malathion on esterases of suckling albino rats. Toxicol Appl Pharmacol 35:229–238.1265743
*Mendoza CE, Shields JB. 1976. Effects of hexachlorobenzene on malathion LD_50_ and on cholinesterase and carboxylesterase activities in organs of the suckling albino rat. Toxicol Appl Pharmacol 35:447–453.1265759
*Mendoza CE, Shields JB. 1977. Effects on esterases and comparison of I_50_ and LD_50_ values of malathion in suckling rats. Bull Environ Contam Toxicol 17:9–15.836980
*Menzer RE, Best NH. 1968. Effect of phenobarbital on the toxicity of several organophosphorus insecticides. Toxicol Appl Pharmacol 13:37–42.
*Merkel GJ, Perry JJ. 1977. Increased cooxidative biodegradation of malathion in soil via cosubstrate enrichment. J Agric Food Chem 25(5):1011–1012.893821
Metcalf RL. 1981. Insect control technology. In: Grayson M, Eckroth D, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 1. 3^rd^ ed. New York, NY: John Wiley & Sons, Inc., 441.
*Midtling JE, Barnett PG, Coye MJ, . 1985. Clinical management of field worker organophosphate poisoning. West J Med 142(4):514–518.4013266
*Milby TH, Epstein WL. 1964. Allergic contact sensitivity to malathion. Arch Environ Health 9:434–437.14185548
*Miles CJ, Takashima S. 1991. Fate of malathion and O,O,S-Trimethyl phosphorothioate by-product in Hawaiian soil and water. Arch Environ Contam Toxicol 20:325–329.
*Moeller HC, Rider JA. 1962. Plasma and red blood cell cholinesterase activity as indications of the threshold of incipient toxicity of ethyl-p-nitrophenyl thionobenzenephosphonate (EPN) and malathion in human beings. Toxicol Appl Pharmacol 4:123–130.14474998
Mohn G. 1973a. Comparison of the mutagenic activity of eight organophosphorus insecticides in Escherichia coli. Mutat Res 21:196.
Mohn G. 1973b. 5-Methyltryptophan resistance mutations in Escherichia coli D-12: Mutagenic activity of monofuctional alkylating agents including organophosphorus insecticides. Mutat Res 20:7–15.4357387
*Monje Argiles A, Lison D, Lauwerys R, . 1990. Acute polyneuropathy after malathion poisoning. Acta Neurol Belg 90:190–199.2124029
*Moody RP, Franklin CA, Riedel D, . 1985. A new GC on-column methylation procedure for analysis of DMTP (O,O-dimethyl phosphorothioate) in urine of workers exposed to fenitrothion. J Agric Food Chem 33:464–467.
Moody RP, Franklin CA, Riedel D, . 1986. A new GC on-column methylation procedure for analysis of DMTP (O,O-dimethyl phosphorothioate in urine of workers exposed to fenitrothion. J Agric Food Chem 33:464–467.
*Moreno O. 1989. 21-Day dermal toxicity study with AC 6,601 in rabbits: Laboratory report No MB88-0101. Unpublished study prepared by MB Laboratories, Inc. MRID 41054201. (As cited in EPA 2000a, 2000b).
*Morgade C, Barquet A. 1982. Body distribution of malathion and its metabolites in a fatal poisoning by ingestion. J Toxicol Environ Health 10(2):321–325.7143485
Moriya M, Ohta T, Watanabe T. 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116(3–4):185–216.6339892
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
*Mortensen SR, Hooper MJ, Padilla S. 1998. Rat brain acetylcholinesterase activity: Developmental profile and maturational sensitivity to carbamate and organophosphorus inhibitors. Toxicology 125:13–19.9585096
*Muan B, Nafstad I. 1989. Distribution and elimination of [^14^C]malathion in the rat. J Agric Food Chem 37:210–213.
*Muan B, Skare JU. 1989. A method for the determination of malathion in biological samples. J Agric Food Chem 37:1081–1085.
*Mühlman Von R, Schrader G. 1957. Hydrolyse der insektiziden phosphorsäureester. Z Natürforschg 12:196–208.
Mukherjee I, Gopla M. 1996. Insecticide residues in baby food, animal feed, and vegetables by gas liquid chromatography. Bull Environ Contam Toxicol 56:381–388.8825959
*Mulla MS, Mian LS, Kawecki JA. 1981. Distribution, transport, and fate of the insecticides malathion and parathion in the environment. Residue Rev 81:1–172.7038805
Murphy SD. 1980. Toxic interactions with dermal exposure to organophosphate insecticides [Abstract]. Dev Toxicol Environ Sci 8:615–621.7308071
*Murphy SD, Cheever KL. 1968. Effect of feeding insecticides. Arch Environ Health 17:749–758.5687272
*Nabb DP, Whitfield F. 1967. Determination of cholinesterase by an automated pH-stat method. Arch Environ Health 15:147–154.4951705
*Nakatsugawa T. 1992. Hepatic disposition of organophosphorus insecticides: A synthesis of in vitro, in situ and in vivo data. In: Organophosphates: Chemistry, fate, and effects. Academic Press, Inc.
Nalin DR. 1973. Epidemic of suicide by malathion poisoning in Guyana. Trop Geographl Med 25:8–14.
*Namba T, Greenfield M, Grob D. 1970. Malathion poisoning. A fatal case with cardiac manifestations. Arch Environ Health 21:533–540.4917521
Narain S, Kumar B. 1992. 5’-Nucleotidase activity in certain tissues of the fish heteropneustes fossils under toxic stress. Acta Histochem Cytochem 25(1&2):169–174.
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
NCI. 1977. Bioassay of malathion for possible carcinogenicity. National Cancer Institute. NTIS PB-278 527/7GA. DHEW/PUB/NIH-78-824.
*NCI. 1978. Bioassay of malathion for possible carcinogenicity. Technical Report Series No. 24. U.S. Department of Health. Education and Welfare. Public Health Service. National Institute of Health. National Cancer Institute.
*NCI. 1979a. Bioassay of malathion for possible carcinogenicity. National Cancer Institute. National Cancer Inst Carcinog Tech Rep Ser, Vol 192.
*NCI. 1979b. Bioassay of malaoxon for possible carcinogenicity. National Cancer Institute. NCI Tech Rep Ser, 135.
Newcombe DS, Esa AH. 1992. Immunotoxicity of organophosphorus compounds. In: Rose NR, Bloom JC, eds. Clinical immunotoxicology. New York, NY: Raven Press, 349–363.
*Nicholas AM, Vienne M, Van Den Berghe H. 1979. Induction of sister-chromatid exchanges in the cultured human cells by an organophosphorus insecticide: Malathion. Mutat Res 67(2):167–172.470971
*Niimi AJ. 1987. Biological half-lives of chemicals in fishes. Rev Environ Contam Toxicol 99:1–46.3303179
NIOSH. 1976. Criteria for a recommended standard…occupational exposure to malathion. National Institute for Occupational Safety and Health. HEW Publication No. 76-205.
NIOSH. 1980. Projected number of occupational exposures to chemical and physical hazards. Cincinnati, OH: National Institute for Occupational Safety and Health. (As cited as IARC 1983).
*NIOSH. 1981. National occupational hazard survey. Cincinnati, OH: National Institute for Occupational Safety and Health. 3–4, 361, 561–562.
NIOSH. 1997. Pocket guide to chemical hazards. Washington, DC: National Institute for Occupational Safety and Health. DHHS (NIOSH) publication No. 97-140.
*NIOSH. 2001. Documentation for immediately dangerous to life or health concentrations. Malathion. National Institute for Occupational Safety and Health. Http://www.cdc.gov/niosh/npg/npgd0334.html. March 26, 2001.
*Nishio A, Uyeki EM. 1981. Induction of sister chromatid exchanges in Chinese hamster ovary cells by organophosphate insecticides and their oxygen analogs. J Toxicol Environ Health 8:939–946.7338954
*Nomeir AA, Dauterman. 1978. In vitro degradation of malathion by mouse liver. Biochem Pharmacol 27(24):2975–2976.736992
*NRC. 1993. Pesticides in the diets of infants and children. National Research Council. Washington, DC: National Academy Press.
*O’Brien RD. 1967. Effects of induction by pentobarbital upon susceptibility of mice to insecticides. Bull Environ Contam Toxicol 2(3):162–168.
*O’Brien RD, Dannelley CE. 1965. Penetration of insecticides through rat skin. J Agric Food Chem 13(3):245–247.
Ojha S, Norton SP, Shrivastava N, . 1991. Effect of dietary malathion in three successive generations of albino rats. Environ Ecol 9(4):1007–1010.
*Ojha S, Norton SP, Shrivastava N, . 1992. Toxic effect of malathion on the reproductive system of albino rats. Environ Ecol 10(4):833–836.
Okey AB. 1972. Dimethylbenzanthracene-induced mammary tumors in rats: Inhibition by DDT. Life Sci 11(1):833–843.
O’Malley M. 1997. Clinical evaluation of pesticide exposure and poisonings. Lancet 349:1161–1166.9113024
*Osaba LA, Alonso A, Graf U. 1999. Genotoxicity testing of six insecticides in two crosses of the Drosophila wing spot test. Mutat Res 439:49–61.10029675
Osfor MMH, Abd El Wahab AM, El Dessouki SA. 1998. Occurrence of pesticides in fish tissues, water and soil sediment from Manzale Lake and River Nile. Nahrung Nr 1(S):39–41.
*OSHA. 2001a. Limits for air contaminants. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000, Table Z-1. Http://www.osha-slc.gov/OshStd_data/1910_1000_TableZ-1.html. March 26, 2001.
*OSHA. 2001b. Threshold limit values of airborne contaminants for construction. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. Http://www.osha-slc.gov/Osh_data/1926_0055_APP_A.html. March 26,2001.
*OSHA. 2001c. Air contaminants. Shipyards. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000, Table Z. Http://www.osha-slc.gov/OshStd_data/1. March 26, 2001.
*Osmundson M. 1998. Insecticides and pesticides. In: Viccellio P, Bania T, Brent J, ., eds. Emergency toxicology 2^nd^ ed. Philadelphia, Pa: Lippincott-Raven Publishers, 401–413.
Ostrea E, Alana M, Tan E, . 1998. Biomarker of fetal exposure to pesticides and their correlates to outcome [Abstract]. Pediatr Res 43(4)(part 2):224A.
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Ozmen G, Akay MT. 1993. The effects of malathion on some hormone levels and tissues secreting these hormones in rats. Vet Hum Toxicol 35(1):22–24.8434444
Paris DF, Lewis DL. 1975. Rates and products of degradation of malathion by bacteria and fungi from aquatic systems. Environ Qual Saf Suppl 3:288–291.
*Parker GF, Chattin WR. 1955. A case of malathion intoxication in a ten year old girl. J Indiana State Med Assoc:491–492.14367876
Pawar SS, Makhija SJ. 1975. Effect of insecticide intoxication on the hepatic microsomal electron transport reactions, during dietary protein variations in young rats. Bull Environ Contam Toxicol 14(2):197–204.1174730
*Pednekar MD, Gandhi SR, Netrawali MS. 1987. Evaluation of mutagenic activities of endosulfan, phosalone, malathion, and permethrin, before and after metabolic activation, in the Ames Salmonella test. Bull Environ Contam Toxicol 38:925–933.3555658
*Peedicayil J, Ernest K, Thomas M, . 1991. The effect of organophosphorus compounds on serum pseudocholinesterase levels in a group of industrial workers. Hum Exp Toxicol 10:275–278.1679650
*Pellegrini G, Santi R. 1972. Potentiation of toxicity of organophosphorus compounds containing carboxylic ester functions toward warm-blooded animals by some organophosphorus impurities. J Agric Food Chem 20(5):944–950.5057442
Pierce JT. 1998. “The action level”. Appl Occup Environ Hyg 13(3):156–165.
*Piramanayagam S, Manohar BM. 2002. Histological changes induced by malathion in rats. Indian Vet J 79(2):114–117.
*Piramanayagam S, Manohar BM, Sundararaj A. 1996. Pathology of malathion toxicity in rats. Indian Vet J 73(7):734–737.
*Pluth JM, Nicklas JA, O’Neill JP, . 1996. Increased frequency of specific genomic deletions resulting from in vitro malathion exposure. Cancer Res 56:2393–2399.8625317
*Pluth JM, O’Neill JP, Nicklas JA, . 1998. Molecular bases of hprt mutations in malathion-treated human T-lymphocytes. Mutat Res 397:137–148.9541638
*Pogoda JM, Preston-Martin S. 1997. Household pesticides and risk of pediatric brain tumors. Environ Health Perspect 105(11):1214–1220.9370522
*Prabhakaran S, Devi KS. 1993. Impact of protein deficiency and exposure to hexachlorocyclohexane or malathion on lipid metabolism in pregnant rats. Ind J Biochem Biophys 30:234–238.
*Prabhakaran S, Shameem F, Devi KS. 1993. Influence of protein deficiency on hexachlorocyclohexane and malathion toxicity in pregnant rats. Vet Hum Toxicol 35(5):429–433.7504364
Pradhan SN, Miatre RM. 1970. Effects of two anticholinesterases on behavior and cholinesterase activity in rats. Res Commun Chem Pathol Pharmacol 1(5):682–690.5524270
Quinn MA, Kepner RL, Walgenbach DD, . 1991. Effect of habitat characteristics and perturbation from insecticides on the community dynamics of ground beetles (coleoptera:carabidae) on mixed-grass rangeland. Environ Entomol 20(5):1285–1294.
*Rabovsky J, Brown JP. 1993. Malathion metabolism and disposition in mammals. J Occup Med Toxicol 2(1):131–168.
*Ramu A, Slonim AE, London M, . 1973. Hyperglycemia in acute malathion poisoning. Isr J Med Sci 9(5):631–634.4717946
*Reeves JD, Driggers DA, Kiley VA. 1981. Household insecticides associated aplastic anaemia and acute leukaemia in children. Lancet 11:300–301.
Reidy GE, Rose HA, Stacey NH. 1982. Effect of length of exposure to malathion on xenobiotic biotransformation in male rat liver. Toxicol Lett 38:193–199.
*Reifenrath WG, Chellquist EM, Shipwash EA, . 1984. Percutaneous penetration in the hairless dog, weanling pig and grafted athymic nude mouse: Evaluation of models for predicting skin penetration in man. Br J Dermatol III(Suppl. 27):123–135.
Reifenrath WG, Hawkins GS, Kurtz MS. 1991. Percutaneous penetration and skin retention of topically applied compounds: An in vitro-in vivo study. J Pharm Sci 80(6):526–532.1941541
*Relford RL, Ainsworth AJ, Harkness JE. 1989. Effects of a commercial malathion dip preparation on the cellular and humoral immune response of BALB/c mice. Lab Anim Sci 39(1):56–59.2918686
Reuber MD. 1985. Carcinogenicity and toxicity of malathion and malaoxon. Environ Res 37:119–153.3996333
*Rice C. 1996. Pesticides in fogwater. Pestic Outlook 7(2):31–36.
Rider JA, Moeller HC, Swader J, . 1959. A study of the anticholinesterase properties of EPN and malathion in human volunteers. Clin Res 1:81.
*Ritter WF. 1990. Pesticide contamination of ground water in the United States-A review. J Environ Sci Health B 25(1):1–29.2187918
*Rivett K, Potgieter PD. 1987. Diaphragmatic paralysis after organophosphate poisoning. S Afr Med J 72(12):881–882.3424038
Robens JF, Jitco T. 1978. Tests for possible carcinogenicity of 20 pesticides in Osborne- Mendel rats and B6C3F1 mice. Toxicol Appl Pharmacol 45:236.
Rodgers K. 1995. The immunotoxicity of pesticides in rodents. Hum Exp Toxicol 14:111–113.7538314
Rodgers KE. 1997. Effects of oral administration of malathion on the course of disease in MRL-IPR mice. J Tenn Acad Sci Journal of Autoimmunity(10):367–373.
Rodgers KE, Ellefson DD. 1988. Effects of acute administration of O,O,S-trimethyl phosphorothioate on the respiratory burst and phagocytic activity of splenic and peritoneal leukocytes. Agents Actions 24(1.5):152–160.2841830
*Rodgers KE, Ellefson DD. 1990. Modulation of respiratory burst activity and mitogenic response of human peripheral blood mononuclear cells and murine splenocytes and peritoneal cells by malathion. Fundam Appl Toxicol 14:309–317.2318355
*Rodgers K, Ellefson D. 1992. Mechanism of the modulation of murine peritoneal cell function and mast cell degranulation by low doses of malathion. Agents Actions 35:58–63.
*Rodgers KE, Xiong S. 1996. Contribution of mast cell mediators to alterations in macrophage function after malathion administration. Fundam Appl Toxicol 33:100–108.8812242
*Rodgers K, Xiong S. 1997a. Contribution of inflammatory mast cell mediators to alterations in macrophage function after malathion administration. Int J Immunopharmacol 19(3):149–156.9306154
*Rodgers K, Xiong S. 1997b. Effect of acute administration of malathion by oral and dermal routes on serum histamine levels. Int J Immunopharmacol 19(8):437–441.9568549
*Rodgers K, Xiong S. 1997c. Effect of administration of malathion for 90 days on macrophage function and mast cell degranulation. Toxicol Lett 93:73–82.9381485
*Rodgers K, Xiong S. 1997d. Effect of administration of malathion for 14 days on macrophage function and mast cell degranulation. Fundam Appl Toxicol 37:95–99.9193927
*Rodgers KE, Leung N, Ware CF, . 1986. Lack of immunosuppressive effects of acute and subacute administration of malathion on murine cellular and humoral immune responses. Pestic Biochem Physiol 25:358–365.
*Rodgers K, St. Amand K, Xiong S. 1996. Effects of malathion on humoral immunity and macrophage function in mast cell-deficient mice. Fundam Appl Toxicol 31:252–258.8789791
*Roggi C, Mazzei B, Berselli E, . 1991. Riflessi della contaminazione ambientale sul latte materno. L’Igiene Moderna 96:1–16.
*Roinestad KS, Louis JB, Rosen JD. 1993. Determination of pesticides in indoor air and dust. J AOAC Int 76(5):1121–1126.8241815
Ross JH, Dong MH, Krieger RI. 2000. Conservatism in pesticide exposure assessment. Regul Toxicol Pharmacol 31:53–58.10715224
Roy RR, Albert RH, Wilson P, . 1995. U.S. Food and Drug Administration pesticide program: Incidence/level monitoring of domestic and imported pears and tomatoes. J AOAC Int 78(4):930–940.7580331
*Roy RR, Wilson P, Laski RR, . 1997. Monitoring of domestic and imported apples and rice by the U.S. Food and Drug Administration Pesticide Program. J AOAC Int 80(4):883–894.9241850
Rupa DS, Reddy PP, Reddi OS. 1991a. Clastogenic effect of pesticides in peripheral lymphocytes of cotton-field workers. Mutat Res 261:177–180.1719409
*Rupa DS, Reddy PP, Reddi OS. 1991b. Reproductive performance in population exposed to pesticides in cotton fields in India. Environ Res 55:123–128.1868815
*Ruth JH. 1986. Odor thresholds and irritation levels of several chemical substances: A review. Am Ind Hyg Assoc J 47(3):A142–A151.3706135
*Ryan DL, Fukuto TR. 1985. The effect of impurities on the toxicokinetics of malathion in rats. Pestic Biochem Biophys 23:413–424.
Sadeghi DJ, Guiti N. 1970. Pralidoxime iodine (PAM) and toxogonin as antidotes in acute malathion intoxication in the dog. Isr J Med Sci 6(1):154–155.5472887
*Sakai K, Matsumura F. 1968. Esterases of mouse brain active in hydrolyzing organophosphate and carbamate insecticides. J Agric Food Chem 16(5):803–807.
*Safe S, Connor K, Ramamoorthy K, . 1997. Human exposure to endocrine-active chemicals: Hazard assessment problems. Reg Toxicol Pharmacol 26:52–58.
*Saleh MA, Ahmed AE, Kamel A, . 1997. Determination of the distribution of malathion in rats following various routes of administration by whole-body electronic autoradiography. Toxicol Ind Health 13(6):751–758.9399420
*Salvadori DMF, Ribeiro LR, Pereira CAB, . 1988. Cytogenetic effects of malathion insecticide on somatic and germ cells of mice. Mutat Res 204:283–287.3343978
*Sams C, Mason HJ. 1999. Detoxification of organophosphates by A-esterases in human serum. Hum Exp Toxicol 18:653–658.10602389
*Santodonato J. 1985. Monograph on human exposure to chemicals in the workplace: Malathion. Govt Reports Announce & Index.
Sare WM, Awamutu T. 1972. Chronic poisoning by a phosphate ester insecticide, malathion. N Z Med J 75(477):93–94.4502703
Savage EP, Keefe TJ, Wheeler HW, . 1981. Household pesticide usage in the United States. Arch Environ Health 36:304–309.7316568
Savolainen KM, Hirvonen MR. 1992. Effects of malaoxon on phosphatidylinositol signaling in convulsing and nonconvulsing non-pregnant and pregnant female rats and their offspring. Neurotoxicology 12(4):816.
Sawyer TW, Weiss MT, Dickinson T. 1996. Effect of metabolism on the anticholinesterase activity of carbamate and organophosphate insecticides in neuron culture. In Vitro Toxicol 9(4):343–352.
*Schanker HM, Rachelefsky G, Siegal S, . 1992. Immediate and delayed type hypersensitivity to malathion. Ann Allergy 69:526–528.1471787
*Schroeder R. 1990. A two generation (two litters) reproduction study with AC 6,601 to rats. Study No. 87-3243. Unpublished prepared by Bio/Dynamics, Inc. MRID 41583401. (As cited in EPA 2000a, 2000b).
Segal LM, Fedoroff S. 1989a. The acute and subchronic effects of organophosphorus and carbamate pesticides on cholinesterase activity in aggregate cultures of neural cells from the foetal rat brain. Toxicol in Vitro 3(2):111–112.20702308
Segal LM, Fedoroff S. 1989b. Cholinesterase inhibition by organophosphorus and carbamate pesticides in aggregate cultures of neural cells from the foetal rat brain: The effects of metabolic activation and pesticide mixtures. Toxicol in Vitro 3(2):123–128.20702309
*Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Sever L, Arbuckle TE, Sweeney A. 1997. Reproductive and developmental effects of occupational pesticide exposure: The epidemiologic evidence. Occup Med 12(2):305–325.9220488
Shafik MT, Enos HF. 1969. Determination of metabolic and hydrolytic products of organophosphorus pesticide chemicals in human blood and urine. J Agric Food Chem 17:1186–1189.
*Shah PV, Monroe RJ, Guthrie FE. 1981. Comparative rates of dermal penetration of insecticides in mice. Toxicol Appl Pharmacol 59:414–423.6791307
Sharara FI, Seifer DB, Flaws JA. 1998. Environmental toxicants and female reproduction. Fertil Steril 70(4):613–622.9797086
*Sheridan RS, Meola JR. 1999. Analysis of pesticide residues in fruit, vegetables and milk by gas chromatography/tandem mass spectrometry. J Assoc Anal Chem Int 82:982–990.
*Shiau SY, Huff RA, Wells BC, . 1980. Mutagenicity and DNA-damaging activity for several pesticides tested with Bacillus subtilis mutants. Mutat Res 71:169–179.6771645
*Siglin J. 1985. A teratology study with AC 6,601 in rabbits: FDRL Study No. 8171: Unpublished study prepared by Food and Drug Research Laboratories. (Incorporates a range-finding study). MRID 00152569. (As cited in EPA 2000a, 2000b).
Silinskas K, Okey AB. 1975. Protection by 1,1,1-trichloro-2,2-bis(p-chlorophenyl) ethane(DDT) against mammary tumors and leukemia during prolonged feeding of 7,12-dimethylbenza anthracene to female rats. J Natl Cancer Inst 55(3):653–657.808643
*Simionescu L, Oprescu M, Sâhleanu V, . 1977. The serum and pituitary prolactin variations under the influence of a pesticide in the male rat. Rev Roum Med 15(3):181–188.
Simmon VF, Poole DC, Newell GW. 1996. In vitro mutagenic studies of twenty pesticides [Abstract]. Toxicol Appl Pharmacol 37:109.
*Singaravelu G, Mahalingam S, Arunagiri Muthu P. 1998. Effects of malathion on hemoglobin content and its genotoxicity in occupationally exposed field workers of Vellore. J Environ Biol 19(3):187–192.
Singh AK, Seth PK. 1989. Degradation of malathion by microorganisms isolated from industrial effluents. Bull Environ Contam Toxicol 43:28–35.2758137
Singh NN, Srivastava AK. 1993. Biochemical changes following malathion treatment in the freshwater Indian catfish, Heteropneustes fossilis. J Adv Zool 14(2):103–108.
*Sittig, M. (ed.). 1980. Pesticide manufacturing and toxic materials control encyclopedia. Park Ridge, NJ: Noyes Data Corporation, 474–481.
*Sittig M (ed). 1985. Handbook of toxic and hazardous chemicals and carcinogens. 2^nd^ ed. Park Ridge, NJ: Noyes Data Corporation, 474.
*Slauter R. 1994. 18-Month oral (dietary) oncogenicity study in mice: Malathion. Lab project No. 668-001. Unpublished study prepared by International Research and Development Corp. MRID 43407201. (As cited in EPA 2000a, 2000b).
*Smith RK. 1994. Handbook of environmental analysis. Schenectady, NY: Genium Publishing, C–4.
*Sobti RC, Krishan A, Pfaffenberger CD. 1982. Cytokinetic and cytogenetic effects of some agricultural chemicals on human lymphoid cells in vitro: Organophosphates. Mutat Res 102:89–102.6981766
SRI. 1984. Directory of chemical producers. Menlo Park, CA: Stanford Research Institute International, 172.
SRI. 1998. Directory of chemical producers. Menlo Park, CA: Stanford Research Institute International, 796.
*SRI. 2000. Directory of chemical producers. Menlo Park, CA: Stanford Research Institute International, 789.
Srivastava AK, Srivastava AK. 1988. Effects of aldrin and malathion on blood chloride in the Indian catfish. J Environ Biol 9(Suppl 1):91–95.
*Stålberg E, Hilton-Brown P, Kolmodin-Hedman B, . 1978. Effect of occupational exposure to organophosphorus insecticides on neuromuscular function. Scand J Work Environ Health 4:255–261.212825
Stevens JT. 1974. Effect of malathion on hepatic microsomal metabolism of the male mouse. Pac Sci Pharmacology(11):330–335.
*Stevens JT, Greene FE. 1973. Response of the mixed function oxidase system of rat hepatic microsomes to parathion and malathion and their oxygenated analogs. Life Sci 13:1677–1691.4149666
Street JC, Sharma RP. 1975. Alteration of induced cellular and humoral immune responses by pesticides and chemicals of environmental concern: Quantitative studies of immunosuppression by DDT, Aroclor 1254, carbaryl, carbofuran, and methyl parathion. Toxicol Appl Pharmacol 32:587–602.50651
*Su MQ, Kinoshita FA, Frawley JP, . 1971. Comparative inhibition of aliesterases and cholinesterase in rats fed eighteen organophosphorus insecticides. Toxicol Appl Pharmacol 20:241–249.5133254
*Sudakin DL, Mullins ME, Horowitz BZ, . 2000. Intermediate syndrome after malathion ingestion despite continuous infusion of pralidoxime. Clin Toxicol 38(1):47–50.
*Sujatha CH, Chacko J. 1991. Malathion sorption by sediments from a tropical estuary. Chemosphere 23(2):167–180.
Sweeney MI, Lyon ME. 1999. Selective effect of malathion on blood coagulation versus locomotor activity. J Environ Pathol Toxicol Oncol 18(3):203–211.15281233
*Swift JE. 1976. Organophosphate exposure from agricultural usage. U.S. EPA Office of Research Development.
*Syed MA, Arshad JH, Mat S. 1992. Biological activity of grain bound ^14^C-malathion residues in rats. J Environ Sci Health B27(4):347–354.
Sylianco CYL. 1978. Some interactions affecting the mutagenicity potential of dipyrone, hexachlorophene, thiodan and malathion. Mutat Res 53:271–272.
*Tafuri J, Roberts J. 1987. Organophosphate poisoning. Ann Emer Med 16(2):93–102.
*Talcott RE. 1979. Hepatic and extrahepatic malathion carboxylesterase. Assay and localization in the rat. Toxicol Appl Pharmacol 47:145–150.425112
*Talcott RE, Denk H, Mallipudi NM. 1979b. Malathion carboxylesterase activity in human liver and its inactivation by isomalathion. Toxicol Appl Pharmacol 49:373–376.494286
*Talcott RE, Mallipudi NM, Fukuto TR. 1977. Malathion carboxylesterase titer and its relationship to malathion toxicity. Toxicol Appl Pharmacol 50:501–504.
*Talcott RE, Mallupudi NM, Umetsu N, . 1979a. Inactivation of esterases by impurities isolated from technical malathion. Toxicol Appl Pharmacol 49:107–112.473195
*Talcott RE, Pond SM, Ketterman A, . 1982. Ethylesterases as indicators of liver damage I. Studies on malathion carboxylesterases. Toxicol Appl Pharmacol 65:69–74.7147257
*Taylor P. 1996. Anticholinesterase agents. In: Wonsiewicz MJ, McCurdy P, eds. Goodman & Gilman’s the pharmacological basis of therapuetics. New York, NY: McGraw Hill, 161–176.
Thomas D, Goldhaber M, Petitti D, . 1990. Reproductive outcome in women exposed to malathion [Abstract]. Am J Epidemiol 132:794–795.
*Thomas DC, Petitti DB, Goldhaber M, . 1992. Reproductive outcomes in relation to malathion spraying in the San Francisco Bay Area, 1981-1982. Epidemiology 3(1):32–39.1554808
Thomas PT. 1995. Pesticide-induced immunotoxicity: Are Great Lakes residents at risk? Environ Health Perspect 103(9):55–61.
Thompson HM. 1999. Esterases as markers of exposure to organophosphates and carbamates. Ecotoxicology 8:369–384.
*Thongsinthusak T, Ross JH, Saiz SG, . 1999. Estimation of dermal absorption using the exponential saturation model. Regul Toxicol Pharmacol 29:37–43.10051417
*Titenko-Holland N, Windham G, Kolachana P, . 1997. Genotoxicity of malathion in human lymphocytes assessed using the micronucleus assay in vitro and in vivo: A study of malathion-exposed workers. Mutat Res 388:85–95.9025795
*Toia RF, March RB, Umetsu N, . 1980. Identification and toxicological evaluation of impurities in technical malathion and fenthion. J Agric Food Chem 28:599–604.7391407
*Tomlin CDS (ed.). 1997. The pesticide manual: A world compendium. 11^th^ ed. Surrey, UK: British Crop Protection Council.
*Townsend BA, Carlson GP. 1980. Effect of halogenated benzenes on malathion and malaoxon toxicity and metabolism in mice. Pharmacologist 22(3):174.
*Townsend BA, Carlson GP. 1981. Effect of halogenated benzenes on the toxicity and metabolism of malathion, malaoxon, parathion, and paraoxon in mice. Toxicol Appl Pharmacol 60:52–61.7281175
*TRI00. 2002. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Offices of Environmental Information. U.S. Environmental Protection Agency. Toxic Release Inventory. Http://www.epa.gov/triexplorer/. June 8, 2001.
*Tsuda T, Aoki S, Kojima M, . 1989. Bioconcentration and excretion of diazinon, IBP, malathion and fenitrothion by willow shiner. Toxicol Environ Chem 24:185–190.
Tsuzuki M. 2000. Thermodynamic estimation of vapor pressure for organophosphorus pesticides. Environ Toxicol Chem 19(7):1717–1726.
*Tuthill JWG. 1958. Toxic hazards. Malathion poisoning. N Engl J Med 258(20):1018–1019.13541706
Tyl RW. 1992. Development and reproductive toxicity of anticholinesterases. In: Ballantyne B, Marrs TC, eds. Clinical and experimental toxicology of organophosphates and carbamates. Oxford, England: Butterworth-Heinemann, Ltd., 241–257.
Uluitu M, Boca A, Petec GH, . 1981. The influence of malathion on the brain serotonin and reproductive function in rats. Physiologie 18(3):167–174.6796975
*Umetsu N, Grose FH, Allahyari R, . 1977. Effect of impurities on the mammalian toxicity of technical malathion and acephate. J Agric Food Chem 25(4):946–953.881519
Umetsu N, Mallipudi NM, Toia RF, . 1981. Toxicological properties of phosphorothioate and related esters present as impurities in technical organophosphorus insecticides. J Toxicol Environ Health 7:481–497.7288900
*United Nations. 1985. Treatment and disposal methods for aaste chemicals (IRPTC File). Data Profile Series No. 5. Geneva, Switzerland: United Nations Environmental Programme, Dec. 1985.
Uppal RP, Garg BD, Ahmad A. 1983. Effect of malathion & DDT on the action of some tranquilizers on learning & memory traces in rats. Indian J Exp Biol 21:617–619.6676184
USDA. 1968. Quantities of pesticides used by farmers in 1964. Agricultural Economic Report No. 131. Washington, DC: Economic Research Service, United States Department of Agricultures.
USDA. 1978. Farmers use of pesticides in 1976. Agricultural Economic Report No. 418. Washington, DC: Economics, Statistics and Cooperative Service, United States Department of Agriculture.
USDA. 1983. Inputs outlook and situation. IOS-2, October 1983. Washington, DC: Economic Research Service, United States Department of Agriculture.
*USDA. 2001. Federal seed act regulations. Labeling treated seed. United States Department of Agriculture. Code of Federal Regulations. 7 CFR 201.31a. http://squid.law.cornell.edu/cgi-bi…LE-7&PART=201&SECTION=31a&TYPE=TEXT. April 03, 2001.
*USITC. 1978. Imports of benzenoid chemicals and products. Washington, DC: United States International Trade Commission. USITC Publications 900.
*USTC. 1953. Synthetic organic chemicals. United States Production and Sales. Washington, DC: United States Tariff Commission. Report No. 190. Second Series.
Vaittinen S-L, Komulainen H, Vartiainen T, . 1992. Pharmacokinetics of 3-chloro-4-(dichloromethyl)-5-hydroxy-2(5H)-furanone(MX) in Wistar rats after a single dose. Hum Exp Toxicol 11(5):425–426.
Vale JA. 1998. Toxicokinetic and toxicodynamic aspects of organophosphorus (OP) insecticide poisoning. Toxicol Lett 102–103:649–652.
*van Bao T, Szabo I, Ruzieska P, . 1974. Chromosome aberrations in patients suffering acute organic phosphate insecticide intoxication. Humangenetik 24:33–37.4426631
Van Dijk HG, Guicherit R. 1999. Atmospheric dispersion of current-use pesticides: A review of the evidence from monitoring studies. Water Air Soil Pollut 115:21–70.
*Vasilic Z, Stengl B, Drevenkar V. 1999. Dimethyphosphorus metabolites in serum and urine of persons poisoned by malathion or thiometon. Chem Biol Interact 119–120:479–487.
*Velázquez A, Creus A, Xamena N, . 1987. Lack of mutagenicity of the organophosphorus insecticide malathion in Drosophila melanogaster. Environ Mutagen 9:343–348.3106025
*Verschoyle RD, Reiner E, Bailey E, . 1982. Dimethylphosphorothioates. Arch Toxicol 49:293–301.7092568
Verschueren, K. 1983. Handbook of environmental data on organic chemicals. 2^nd^ ed. New York, NY: Van Nostrand Reinhold Co., 799.
*Vestweber JG, Kruckenberg SM. 1972. The effect of selected organophosphorus compounds on plasma and red blood cell cholinesterase in the dog. Vet Med Small Anim Clin 67(7):803–806.4483127
Vial T, Nicolas B, Descotes J. 1996. Clinical immunotoxicity of pesticides. J Toxicol Environ Health 48:215–229.8656446
Viccellio P, Bania T, Brent J, ., eds. 1998. Emergency toxicology. 2^nd^ ed. Philadelphia, PA: Lippincott-Raven Publishers.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver. Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
*Vijayakumar TS, Selvarajan VR. 1990. Heterogeneity in response of different areas of rabbit brain to malathion. Bull Environ Contam Toxicol 44:721–728.2344478
Voccia I, Blakley B, Brousseau P, . 1999. Immunotoxicity of pesticides: A review. Toxicol Ind Health 15:119–132.10188195
*von Rumker R, Lawless EW, Meiners AF. 1974. Production, distribution, use and environmental impact potential of selected pesticides. Prepared for the Council on Environmental Quality, Washington, DC, 173–180. NTIS PB238 795.
*Wali RK, Dudeja PK, Sarkar AK, . 1984. Subchronic malathion treatment effects on rat intestinal functions. Bull Environ Contam Toxicol 33:289–294.6089940
Waliszewsky SM, Pardío VT, Waliszewksy KN, . 1997. Low cost monitoring method for the organophosphorus and carbamate pesticide residues determination. Rev Int Contam Ambient 13(1):41–45.
*Walter Z, Czajkowska A, Lipecka K. 1980. Effect of malathion on the genetic material of human lymphocytes stimulated by phytohemagglutinin (PHA). Hum Genet 53:375–381.6154640
*Warren M, Spencer HC, Churchill FC, . 1985. Assessment of exposure to organophosphate insecticides during spraying in Haiti: Monitoring of urinary metabolites and blood cholinesterase levels. Bull WHO 63(2):353–360.3874716
*Watanabe T. 1993. Relationship between volatilization raters and physiocochemical properties of some pesticides. J Pestic Sci 18:201–209.
*Weeks MH, Lawson MA, Angerhofer RA, . 1977. Preliminary assessment of the acute toxicity of malathion in animals. Arch Environ Contam Toxicol 6:23–31.907373
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Wester RC, Maibach HI. 1985. In vivo percutaneous absorption and decontamination of pesticides in humans. J Toxicol Environ Health 16:25–37.4068054
*Wester RC, Noonan PK. 1980. Relevance of animal models for percutaneous absorption. Int J Pharm 7:99–110.
*Wester RC, Maibach HI, Bucks AW, . 1983. Malathion percutaneous absorption after repeated administration to man. Toxicol Appl Pharmacol 68:116–119.6845371
Wester RC, Quan D, Maibach HI. 1996. In vitro percutaneous absorption of model compounds glyphosate and malathion from cotton fabric into and through human skin. Food Chem Toxicol 34:731–735.8883475
*Whitmore R, Immerman FW, Camann DE, . 1994. Non-occupational exposures to pesticides for residents of two US cities. Arch Environ Contam Toxicol 26:47–59.8110023
*Wiaderkiewicz R, Walter Z, Reimschussel W. 1986. Sites of methylation of DNA bases by the action of organophosphorus insecticides. Acta Biochim Pol 33(2):73–85.3766014
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York, NY: Academic Press.
*Wilson BW, Sanborn JR, O’Malley MA, . 1997. Monitoring the pesticide-exposed worker. Occup Med 12:347–363.9220490
*Windham GC, Titenko-Holland N, Osorio AM, . 1998. Genetic monitoring of malathion-exposed agricultural workers. Am J Ind Med 33:164–174.9438049
*Wolf CR, Miles JS, Gough A, . 1990. Molecular genetics of the human cytochrome P-450 system. Biochem Soc Trans 18:21–24.2185079
*Wolfe HR, Armstrong DC, Staiff SW, . 1972. Exposure of spraymen to pesticides. Arch Environ Health 25:29–31.5033279
*Wolfe HR, Durham WF, Armstrong JF. 1967. Exposure of workers to pesticides. Arch Environ Health 14:622–633.6024487
*Wolfe HR, Staiff DC, Armstrong JF. 1978. Exposure of formulating plant workers to ethion and malathion. Bull Environ Contam Toxicol 20:778–781.749976
*Wolfe MF, Seiber JN. 1993. Environmental activation of pesticides. Occup Med 8(3):561–574.8272979
*Wolfe NL, Zepp RG, Baughman GL, . 1975. Kinetic investigation of malathion degradation in water. Bull Environ Contam Toxicol 13(6):707–713.237593
*Wolfe N, Zepp RG, Gordon JA, . 1977. Kinetics of chemical degradation of malathion in water. Environ Sci Technol 11:88–93.
*Wong PK, Wai CC, Liong E. 1989. Comparative study on mutageneticities of organophosphorus insecticides in salmonella. Chemosphere 18(11/12):2413–2422.
*Wright CG, Leidy RB. 1980. Insecticide residues in the air of buildings and pest control vehicles. Bull Environ Contam Toxicol 24:582–589.6155163
*Wright CG, Leidy RB, Dupree HE. 1996. Insecticide residues in the ambient air of commercial pest control buildings, 1993. Bull Environ Contam Toxicol. 56:21–28.9026153
Yarsen E, Tanyuksel M, Celik S, . 1999. Effects of aldicarb and malathion on lipid peroxidation. Bull Environ Contam Toxicol 63:575–581.10541675
*Yess NJ, Gunderson EL, Roy R. 1993. U.S. Food and Drug Administration monitoring of pesticide residues in infant foods and adult foods eaten by infants/children. J AOAC Int 76(3):492–507.8318840
Yess NJ, Houston MG, Gunderson EL. 1991. Food and Drug Administration pesticide residue monitoring of foods: 1983-1986. J AOAC Int 74(2):273–280.
Yoder J, Watson M, Benson WW. 1973. Lymphocyte chromosome analysis of agricultural workers during extensive occupational exposure to pesticides. Mutat Res 21:335–340.4779319
*Zahm SH. 1997. Mortality study of pesticide applicators and other employees of a lawn care service company. J Occup Environ Med 39(11):1055–1067.9383716
*Zahm SH, Ward MH, Blair A. 1997. Pesticides and cancer. Occup Med 12:269–289.9220486
*Zahm SH, Weisenburger DD, Saal RC, . 1993. The role of agricultural pesticide use in the development of non-Hodgkin’s lymphoma in women. Arch Environ Health 48(5):353–358.8215601
*Zhong Y, Rafnsson V. 1996. Cancer incidence among Icelandic pesticide users. Int J Epidemiol 25(6):1117–1124.9027514
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zimmerman N. 1990. Non-neurotoxic effects of malathion and malathion formulations. Comments Toxicol 4(1):39–58.
*Zimmerman HJ, Henry JB, eds. 1984. Clinical diagnosis and management-by laboratory methods. 17^th^ ed. Philadelphia, PA: WB Saunders Co., 271–272.
*Zivot U, Castorena JL, Garriot C. 1993. A case of fatal ingestion of malathion. Am J Forensic Med Pathol 14(1):51–53.8493970
*Zweig G, Devine JM. 1969. Determination of organophosphorus pesticides in water. Res Rev 26:17–36.