# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding malathion in air, water, and other media are summarized in Table 8-1.

ATSDR has derived an acute inhalation MRL of 0.2 mg/m^3^ for malathion based on a NOAEL of 65 mg/m^3^ for inhibition of erythrocyte cholinesterase activity in rabbits (Weeks et al. 1977). The LOAEL was 123 mg/m^3^. An uncertainty factor of 100 was used (10 for animal to human extrapolation and 10 for the protection of sensitive human groups). A conversion factor was used to adjust from intermittent exposure to continuous exposure (6/24hours).

ATSDR has derived an intermediate inhalation MRL of 0.02 mg/m^3^ for malathion based on a LOAEL of 100 mg/m^3^ for upper respiratory tract effects in rats (Beattie 1994). An uncertainty factor of 1,000 was used (10 for animal to human extrapolation, 10 for the use of a LOAEL, and 10 for the protection of sensitive human groups). A conversion factor was used to adjust from intermittent exposure to continuous exposure (5/7x6/24 hours).

ATSDR has derived an intermediate oral MRL of 2x10^-2^ mg/kg/day for malathion based on a NOAEL of 0.23 mg/kg/day for inhibition of plasma and red blood cell cholinesterase activities in humans (Moeller and Rider 1962). The LOAEL was 0.34 mg/kg/day. An uncertainty factor of 10 was used for the protection of sensitive human groups.

ATSDR has derived a chronic oral MRL of 2x10^-2^ mg/kg/day for malathion based on a NOAEL of 2 mg/kg/day for inhibition of plasma and red blood cell cholinesterase activities in male rats administered malathion in the diet for 2 years (Daly 1996a). The LOAEL was 29 mg/kg/day. An uncertainty factor of 100 was used (10 for extrapolation from animal to humans and 10 for the protection of sensitive populations).

EPA (IRIS 2003) has derived an RfD of 2x10^-2^ mg/kg/day for malathion based on a NOAEL 0.23 mg/kg/day for inhibition of plasma and red blood cell cholinesterase activities in humans (Moeller and Rider 1962). The LOAEL was 0.34 mg/kg/day. An uncertainty factor of 10 was used for the protection of sensitive human groups.

Table 8-1 Regulations and Guidelines Applicable to Malathion

Agency | Description | Information | References
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | Group 3^a^ | IARC 2001
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV-TWA^b^ | 10 mg/m^3^ | ACGIH 2000
NIOSH | REL (TWA) | 10 mg/m^3^ | NIOSH 2001
NIOSH | IDLH | 250 mg/m^3^ | NIOSH 2001
OSHA | PEL (8-hour TWA) | | OSHA 2001a; 29CFR1910.1000 Table Z-1
OSHA | General industry (total dust) | 15 mg/m^3^ | OSHA 2001a; 29CFR1910.1000 Table Z-1
OSHA | PEL (8-hour TWA) | | OSHA 2001b; 29CFR1926.55 Appendix A
OSHA | Construction industry (total dust) | 15 mg/m^3^ | OSHA 2001b; 29CFR1926.55 Appendix A
OSHA | PEL (8-hour TWA) | | OSHA 2001c; 29CFR1915.1000 Table Z
OSHA | Shipyard industry (total dust) | 15 mg/m^3^ | OSHA 2001c; 29CFR1915.1000 Table Z
b. Water
DOT | Marine pollutant | | DOT 2001a; 49CFR172.101 Appendix B
EPA | Drinking water guideline | 0.2 mg/L | HSDB 2001
EPA | Health advisories | | EPA 2000c
EPA | 1 Day (10-kg child) | 0.2 mg/L | EPA 2000c
EPA | 10 Day (10-kg child) | 0.2 mg/L | EPA 2000c
EPA | DWEL | 0.7 mg/L | EPA 2000c
EPA | Lifetime | 0.1 mg/L | EPA 2000c
EPA | Pesticide chemicals—effluent limitations for BPT | | EPA 2001a; 40CFR455.20(b)
EPA | Water programs—designation of hazardous substance | | EPA 2001b; 40CFR116.4
EPA | Water programs—determination of reportable quantity | 100 pounds | EPA 2001c; 40CFR117.3
EPA | Reportable quantity | | EPA 2001c; 40CFR117.3
c. Food
EPA | Methyl eugenol combination (pesticide) residue tolerances of agricultural commodities; ratio of parts of methyl eugenol to technical malathion is 3:1; eugenol and malathion maximum dosage per application per acre | 28.35 g methyl eugenol and 9.45 g malathion | EPA 2001d; 40CFR180.1067
EPA | Pesticides—where residues from two or more chemicals in the same class are present in or on a raw agricultural commodity, the tolerance for the total of such residues shall be the same as that for the chemical having the lowest numerical tolerance in this class, unless a higher tolerance level is provided | | EPA 2001e; 40CFR180.3(e)(5)
EPA | Pesticides—tolerances for residues (ppm) | | EPA 2001f; 40CFR180.111
EPA | Alfalfa | 135 | EPA 2001f; 40CFR180.111
EPA | Almond hulls | 50 | EPA 2001f; 40CFR180.111
EPA | Almonds | 8 | EPA 2001f; 40CFR180.111
EPA | Almonds, shells | 50 | EPA 2001f; 40CFR180.111
EPA | Apples | 8 | EPA 2001f; 40CFR180.111
EPA | Apricots | 8 | EPA 2001f; 40CFR180.111
EPA | Asparagus | 8 | EPA 2001f; 40CFR180.111
EPA | Avocados | 8 | EPA 2001f; 40CFR180.111
EPA | Barley (grain) | 8 | EPA 2001f; 40CFR180.111
EPA | Beans | 8 | EPA 2001f; 40CFR180.111
EPA | Beets (tops) | 8 | EPA 2001f; 40CFR180.111
EPA | Beets (sugar, roots) | 1 | EPA 2001f; 40CFR180.111
EPA | Beets (sugar tops) | 8 | EPA 2001f; 40CFR180.111
EPA | Birdsfoot trefoil (forage and hay) | 135 | EPA 2001f; 40CFR180.111
EPA | Blackberries | 8 | EPA 2001f; 40CFR180.111
EPA | Blueberries | 8 | EPA 2001f; 40CFR180.111
EPA | Boysenberries | 8 | EPA 2001f; 40CFR180.111
EPA | Carrots | 8 | EPA 2001f; 40CFR180.111
EPA | Cattle (fat, meat byproducts, meat) | 4 | EPA 2001f; 40CFR180.111
EPA | Chayote (fruit and roots) | 8 | EPA 2001f; 40CFR180.111
EPA | Cherries | 8 | EPA 2001f; 40CFR180.111
EPA | Chestnuts | 1 | EPA 2001f; 40CFR180.111
EPA | Clover | 135 | EPA 2001f; 40CFR180.111
EPA | Corn, forage and grain | 8 | EPA 2001f; 40CFR180.111
EPA | Corn, fresh (including sweet) | 2 | EPA 2001f; 40CFR180.111
EPA | Cottonseed | 2 | EPA 2001f; 40CFR180.111
EPA | Pesticides—tolerances for residues (ppm) | | EPA 2001f; 40CFR180.111
EPA | Cowpea (forage and hay) | 135 | EPA 2001f; 40CFR180.111
EPA | Cranberries | 8 | EPA 2001f; 40CFR180.111
EPA | Cucumbers | 8 | EPA 2001f; 40CFR180.111
EPA | Currants | 8 | EPA 2001f; 40CFR180.111
EPA | Dates | 8 | EPA 2001f; 40CFR180.111
EPA | Dewberries | 8 | EPA 2001f; 40CFR180.111
EPA | Eggplants | 8 | EPA 2001f; 40CFR180.111
EPA | Eggs (from application to poultry) | 0.1 | EPA 2001f; 40CFR180.111
EPA | Figs | 8 | EPA 2001f; 40CFR180.111
EPA | Filberts | 1 | EPA 2001f; 40CFR180.111
EPA | Flax seed | 0.1 | EPA 2001f; 40CFR180.111
EPA | Flax straw | 1 | EPA 2001f; 40CFR180.111
EPA | Garlic | 8 | EPA 2001f; 40CFR180.111
EPA | Goats (fat, meat byproducts, meat) | 4 | EPA 2001f; 40CFR180.111
EPA | Gooseberries | 8 | EPA 2001f; 40CFR180.111
EPA | Grapefruit | 8 | EPA 2001f; 40CFR180.111
EPA | Grapes | 8 | EPA 2001f; 40CFR180.111
EPA | Grass (including hay) | 135 | EPA 2001f; 40CFR180.111
EPA | Guavas | 8 | EPA 2001f; 40CFR180.111
EPA | Hogs (fat, meat byproducts, meat) | 4 | EPA 2001f; 40CFR180.111
EPA | Hops | 1 | EPA 2001f; 40CFR180.111
EPA | Horseradish | 8 | EPA 2001f; 40CFR180.111
EPA | Horses (fat, meat byproducts, meat) | 4 | EPA 2001f; 40CFR180.111
EPA | Kumquats | 8 | EPA 2001f; 40CFR180.111
EPA | Leeks | 8 | EPA 2001f; 40CFR180.111
EPA | Lemons | 8 | EPA 2001f; 40CFR180.111
EPA | Lentils | 8 | EPA 2001f; 40CFR180.111
EPA | Lespedeza (hay and straw) | 135 | EPA 2001f; 40CFR180.111
EPA | Lespedeza (seed) | 8 | EPA 2001f; 40CFR180.111
EPA | Limes | 8 | EPA 2001f; 40CFR180.111
EPA | Loganberries | 8 | EPA 2001f; 40CFR180.111
EPA | Lupine (seed) | 8 | EPA 2001f; 40CFR180.111
EPA | Macadamia nuts | 1 | EPA 2001f; 40CFR180.111
EPA | Mangos | 8 | EPA 2001f; 40CFR180.111
EPA | Melons | 8 | EPA 2001f; 40CFR180.111
EPA | Milk, fat (from application to dairy cows) | 0.5 | EPA 2001f; 40CFR180.111
EPA | Mushrooms | 8 | EPA 2001f; 40CFR180.111
EPA | Nectarines | 8 | EPA 2001f; 40CFR180.111
EPA | Oats (grain) | 8 | EPA 2001f; 40CFR180.111
EPA | Okra | 8 | EPA 2001f; 40CFR180.111
EPA | Onions (including green tops) | 8 | EPA 2001f; 40CFR180.111
EPA | Oranges | 8 | EPA 2001f; 40CFR180.111
EPA | Papayas | 1 | EPA 2001f; 40CFR180.111
EPA | Parsnips | 8 | EPA 2001f; 40CFR180.111
EPA | Pesticides—tolerances for residues (ppm) | | EPA 2001f; 40CFR180.111
EPA | Passion fruit | 8 | EPA 2001f; 40CFR180.111
EPA | Peaches | 8 | EPA 2001f; 40CFR180.111
EPA | Peanut (forage and hay) | 135 | EPA 2001f; 40CFR180.111
EPA | Peanuts | 8 | EPA 2001f; 40CFR180.111
EPA | Pears | 8 | EPA 2001f; 40CFR180.111
EPA | Peas | 8 | EPA 2001f; 40CFR180.111
EPA | Peavine (including hay) | 8 | EPA 2001f; 40CFR180.111
EPA | Pecans | 8 | EPA 2001f; 40CFR180.111
EPA | Peppermint | 8 | EPA 2001f; 40CFR180.111
EPA | Peppers | 8 | EPA 2001f; 40CFR180.111
EPA | Pineapple | 8 | EPA 2001f; 40CFR180.111
EPA | Plums | 8 | EPA 2001f; 40CFR180.111
EPA | Potatoes | 8 | EPA 2001f; 40CFR180.111
EPA | Poultry (fat, meat byproducts, meat) | 4 | EPA 2001f; 40CFR180.111
EPA | Prunes | 8 | EPA 2001f; 40CFR180.111
EPA | Pumpkins | 8 | EPA 2001f; 40CFR180.111
EPA | Quinces | 8 | EPA 2001f; 40CFR180.111
EPA | Radishes | 8 | EPA 2001f; 40CFR180.111
EPA | Raspberries | 8 | EPA 2001f; 40CFR180.111
EPA | Rice (grain and wild) | 8 | EPA 2001f; 40CFR180.111
EPA | Rutabagas | 8 | EPA 2001f; 40CFR180.111
EPA | Rye (grain) | 8 | EPA 2001f; 40CFR180.111
EPA | Safflower (seed) | 0.2 | EPA 2001f; 40CFR180.111
EPA | Salsify (including tops) | 8 | EPA 2001f; 40CFR180.111
EPA | Shallots | 8 | EPA 2001f; 40CFR180.111
EPA | Sheep (fat, meat byproducts, meat) | 4 | EPA 2001f; 40CFR180.111
EPA | Sorghum (forage and grain) | 8 | EPA 2001f; 40CFR180.111
EPA | Soybeans (dry and succulent) | 8 | EPA 2001f; 40CFR180.111
EPA | Soybeans (forage and hay) | 135 | EPA 2001f; 40CFR180.111
EPA | Spearmint | 8 | EPA 2001f; 40CFR180.111
EPA | Squash (summer and winter) | 8 | EPA 2001f; 40CFR180.111
EPA | Strawberries | 8 | EPA 2001f; 40CFR180.111
EPA | Sunflower seeds | 8 | EPA 2001f; 40CFR180.111
EPA | Sweet potatoes | 1 | EPA 2001f; 40CFR180.111
EPA | Tangerines | 8 | EPA 2001f; 40CFR180.111
EPA | Tomatoes | 8 | EPA 2001f; 40CFR180.111
EPA | Turnips (including tops) | 8 | EPA 2001f; 40CFR180.111
EPA | Vegetables (leafy, including Brassica) | 8 | EPA 2001f; 40CFR180.111
EPA | Vetch (hay and straw) | 135 | EPA 2001f; 40CFR180.111
EPA | Vetch (seed) | 8 | EPA 2001f; 40CFR180.111
EPA | Walnuts | 8 | EPA 2001f; 40CFR180.111
EPA | Wheat (grain) | 8 | EPA 2001f; 40CFR180.111
USDA | Agriculture—labeling of treated seed shall not be deemed harmful when present at a rate less than indicated | 8 ppm | USDA 2001; 7CFR201.31a
d. Other
ACGIH | BEI—organophosphorus cholinesterase inhibitors (cholinesterase activity in red cells) | 70% of individual’s baseline | ACGIH 1999
ACGIH | Carcinogenicity classification | A4^c^ | ACGIH 2000
DOT | Superfund—reportable quantity | 100 pounds | DOT 2001b; 49CFR172.101 Appendix A
EPA | RfD | 2x10^-2^ mg/kg/day | IRIS 2001
EPA | NPDES—permit application testing requirements; toxic pollutants and hazardous substances required to be identified by existing dischargers if expected to be present | | EPA 2001g; 40CFR122 Appendix D Table V
EPA | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | EPA 2001h; 40CFR265 Appendix VI
EPA | Superfund—reportable quantity | 10 pounds | EPA 2001i; 40CFR302.4
EPA | Toxic chemical release reporting; Community Right-toKnow—effective date | 01/01/95 | EPA 2001j; 40CFR372.65
[underlined: STATE]
Regulations and Guidelines:
a. Air
Alaska | Air contaminant standard | | BNA 2001
Alaska | Total dust | 10 mg/m^3^ | BNA 2001
Alaska | Respirable fraction | 5 mg/m^3^ | BNA 2001
California | Airborne contaminant | | BNA 2001
Colorado | Standards applicable to surface water | | BNA 2001
Colorado | Human health based (water supply) | 140 µg/L | BNA 2001
Colorado | Aquatic life based (chronic) | 0.1 µg/L | BNA 2001
Connecticut | HAP—hazard limiting value | | BNA 2001
Connecticut | 8 Hours | 200 µg/m^3^ | BNA 2001
Connecticut | 30 Minutes | 1,000 µg/m^3^ | BNA 2001
Hawaii | Air contaminant (PEL-TWA) | | BNA 2001
Hawaii | Total dust | 10 mg/m^3^ | BNA 2001
Idaho | Toxic air pollutant | | BNA 2001
Idaho | OEL | 10 mg/m^3^ | BNA 2001
Idaho | EL | 6.67x10^-1^ pounds/hour | BNA 2001
Idaho | AAC | 0.5 mg/m^3^ | BNA 2001
Illinois | Toxic air contaminant | | BNA 2001
Kentucky | TAL | 40 mg/m^3^ | BNA 2001
Kentucky | Average time | 8 hours | BNA 2001
Kentucky | Significant levels | 2.551x10^-3^ pounds/hour | BNA 2001
Michigan | Air contaminant (PEL-TWA) | | BNA 2001
Michigan | Total dust | 15 mg/m^3^ | BNA 2001
Michigan | Occupational air contaminant | | BNA 2001
Michigan | MAC | 15 mg/m^3^ | BNA 2001
Montana | Occupational air contaminant^b^ | 15 mg/m^3^ | BNA 2001
New Hampshire | Toxic air pollutant | | BNA 2001
New Hampshire | OEL | 10 mg/m^3^ | BNA 2001
New Jersey | Toxic air pollutant | | BNA 2001
New Jersey | OEL | 10 mg/m^3^ | BNA 2001
New Jersey | Emissions | 6.67x10^-1^ pounds/hour | BNA 2001
New York | Dangerous air contaminant | | BNA 2001
New York | TLV^b^ | 15 mg/m^3^ | BNA 2001
New York | Total dust | | BNA 2001
New York | Transitional limits (PEL)^b^ | 15 mg/m^3^ | BNA 2001
New York | Final rule limits (TWA)^b^ | 10 mg/m^3^ | BNA 2001
North Carolina | General industry standards | | BNA 2001
North Carolina | Total dust | 10 mg/m^3^ | BNA 2001
Oregon | Air contaminant | 10 mg/m^3^ | BNA 2001
South Carolina | Toxic air emissions | | BNA 2001
South Carolina | MAC | 100 µg/m^3^ | BNA 2001
Texas | TLV^b^ | 15 mg/m^3^ | BNA 2001
Washington | Air contaminant (TWA) | | BNA 2001
Washington | Total dust | 10 mg/m^3^ | BNA 2001
Washington | Toxic air pollutant | | BNA 2001
Washington | ASIL (24-hour average) | 33 µg/m^3^ | BNA 2001
b. Water
Alaska | Water quality standards—toxic substance | | BNA 2001
Arizona | Drinking water guideline | 140 µg/L | HSDB 2001
Arizona | Groundwater protection list | | BNA 2001
California | Drinking water guideline | 160 µg/L | HSDB 2001
Connecticut | Water pollution control— hazardous substance | | BNA 2001
Delaware | Surface water quality standards—toxic substance | | BNA 2001
Delaware | Fresh (chronic) | 0.1 µg/L | BNA 2001
Delaware | Marine (chronic) | 0.1 µg/L | BNA 2001
Florida | Drinking water guideline | 140 µg/L | HSDB 2001
Florida | Surface water quality criteria | | BNA 2001
Florida | Potable water supply | 0.1 µg/L | BNA 2001
Florida | Shellfish propagation or harvesting | 0.1 µg/L | BNA 2001
Florida | Predominantly fresh waters | 0.1 µg/L | BNA 2001
Georgia | Hazardous site response—groundwater criteria concentration | 0.2 mg/L | BNA 2001
Hawaii | Water quality criteria | | BNA 2001
Hawaii | Freshwater (chronic) | 0.1 µg/L | BNA 2001
Hawaii | Saltwater (chronic) | 0.1 µg/L | BNA 2001
Kansas | Surface water quality criteria | | BNA 2001
Kansas | Aquatic life (chronic) | 0.1 µg/L | BNA 2001
Kansas | Agriculture (livestock) | 100 µg/L | BNA 2001
Maine | Drinking water guideline | 40 µg/L | HSDB 2001
Maine | Private water systems | | BNA 2001
Maine | Maximum exposure guideline | 0.04 mg/L | BNA 2001
Maine | Action level | 0.02 mg/L | BNA 2001
Massachusetts | Environmental toxicity values | | BNA 2001
Massachusetts | Freshwater (chronic) | 0.1 µg/L | BNA 2001
Massachusetts | Marine (chronic) | 0.1 µg/L | BNA 2001
Minnesota | Water quality standards | | BNA 2001
Minnesota | Drinking water supply | 200 µg/L | BNA 2001
Minnesota | Groundwater | 200 µg/L | BNA 2001
Minnesota | Protection of aquatic life | 0.1 µg/L | BNA 2001
Nebraska | Standards for water quality | | BNA 2001
Nebraska | Aquatic life (chronic) | 0.1 µg/L | BNA 2001
Nebraska | Water quality standards for wetlands | 0.1 µg/L | BNA 2001
Nebraska | Aquatic life (chronic) | | BNA 2001
Nevada | Standards for toxic materials applicable to designated waters | | BNA 2001
Nevada | Aquatic life | 0.1 µg/L | BNA 2001
New Hampshire | Water quality criteria | | BNA 2001
New Hampshire | Fresh (chronic) | 0.1 µg/L | BNA 2001
New Hampshire | Marine (chronic) | 0.1 µg/L | BNA 2001
New Jersey | Groundwater quality criteria | 200 µg/L | BNA 2001
New Jersey | PQL | 5 µg/L | BNA 2001
New York | Groundwater quality standards | | BNA 2001
New York | MAC | 7.0 µg/L | BNA 2001
Ohio | Surface water quality standards | 0.1 µg/L | BNA 2001
Ohio | Outside mixing zoning average | | BNA 2001
Oklahoma | Surface water quality criteria | | BNA 2001
Oklahoma | Fish and wildlife propagation (chronic) | 0.1 µg/L | BNA 2001
Oregon | Water quality | | BNA 2001
Oregon | Fresh (chronic) | 0.1 µg/L | BNA 2001
Oregon | Marine (chronic) | 0.1 µg/L | BNA 2001
South Dakota | Surface water—toxic pollutant | | BNA 2001
Texas | Water quality | | BNA 2001
Texas | Freshwater (chronic) | 0.01 µg/L | BNA 2001
Utah | Water quality—hazardous substances required to be identified by existing dischargers if expected to be present | | BNA 2001
Virginia | Criteria for surface water | | BNA 2001
Virginia | Freshwater (chronic) | 0.1 µg/L | BNA 2001
Virginia | Saltwater (chronic) | 0.1 µg/L | BNA 2001
Wyoming | Water quality criteria | | BNA 2001
Wyoming | Aquatic life (chronic) | 0.1 µg/L | BNA 2001
c. Food | | No data
d. Other
Alabama | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
Arizona | Soil remediation levels | | BNA 2001
Arizona | Residential | 1,300 mg/kg | BNA 2001
Arizona | Non-residential | 14,000 mg/kg | BNA 2001
Arkansas | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
California | Chemicals required to have been tested for potential to cause cancer or reproductive toxicity, but which have not been adequately tested as required (data requirements) | Oncogenicity | BNA 2001
California | Hazardous substance | | BNA 2001
California | Pesticide field worker safety— restricted entry intervals | | BNA 2001
California | Citrus | 1 day | BNA 2001
California | Grapes | 1 day | BNA 2001
California | Peaches/nectarines | 1 day | BNA 2001
California | Pesticide registration—active ingredients | | BNA 2001
Colorado | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
Delaware | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
Delaware | Reportable quantity | 100 pounds | BNA 2001
Florida | Toxic substance in the workplace | | BNA 2001
Georgia | Hazardous site response— regulated substance | | BNA 2001
Illinois | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
Louisiana | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
Maine | Identification of hazardous waste —hazardous constituent | | BNA 2001
Maine | Screening standards for beneficial use (waste concentration) | 2,000 mg/kg dry weight | BNA 2001
Massachusetts | Containers adequately labeled pursuant to federal law | | BNA 2001
Massachusetts | Human health based toxicity values (chronic oral RfD) | 2.0x10^-2^ mg/kg/day | BNA 2001
Massachusetts | Oil and hazardous material | | BNA 2001
Michigan | Identification and listing of hazardous waste | | BNA 2001
Minnesota | Toxic pollutant and hazardous substance | | BNA 2001
Mississippi | Packaging dates for malathion | Must mark all retail containers with a code or batch number from which the date of packaging may be determined | BNA 2001
Nebraska | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
Nebraska | Pesticide classes | Class III^d^ | BNA 2001
New Jersey | Hazardous substance | | BNA 2001
New York | Pesticide control—use of chemicals for the control or elimination of aquatic insects | Not to exceed 0.5 pounds/acre (active ingredient) | BNA 2001
New York | Reportable quantity | | BNA 2001
New York | Air | 100 pounds | BNA 2001
New York | Land/water | 1 pound | BNA 2001
South Carolina | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
Tennessee | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
Texas | Risk-based exposure limits— soil dermal contact | | BNA 2001
Texas | Gastrointestinal absorption factor | 5.00x10^-1^ | BNA 2001
Texas | Dermal absorption factor | 1.00x10^-1^ | BNA 2001
Washington | Hazardous substance required to be identified by existing dischargers if expected to be present | | BNA 2001
Washington | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
West Virginia | Hazardous substance required to be identified by existing dischargers if expected to be present | | BNA 2001
West Virginia | RfD | 2.00x10^-2^ mg/kg/day | BNA 2001
Wyoming | Standards for hazardous waste TSD facilities—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001

a Group 3: not classifiable as to its carcinogenicity to humans

b Skin notation: danger of cutaneous absorption

c A4: not classifiable as a human carcinogen

d Class III: oral LD50 greater than 900 mg/kg^-1^

AAC = acceptable ambient concentrations; ACGIH = American Conference of Governmental Industrial Hygienists; ASIL = acceptable source impact levels; BEI = biological exposure index; BNA = Bureau of National Affairs; BPT = best practical technology; CFR = Code of Federal Regulations; DOT = Department of Transportation; DWEL = drinking water equivalent level; EL = emissions level; EPA = Environmental Protection Agency; HAP = hazardous air pollutant; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life and health; IRIS = Integrated Risk Information System; MAC = maximum allowable concentration; NIOSH = National Institute of Occupational Safety and Health; NPDES = National Pollutant Discharge Elimination System; OEL = occupational exposure limit; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; PQL = practical quantitation level; REL = recommended exposure limit; RfD = oral reference dose; TAL = threshold ambient limits; TLV = threshold limit value; TSD = treatment, storage, and disposal; TWA = time-weighted average; USDA = United States Department of Agriculture