# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of malathion is located in Table 4-1.

Malathion is manufactured in the United States as a technical-grade concentrate that is >90% pure malathion and contains approximately 5% of impurities consisting largely of reaction byproducts and degradation products. As many as 14 impurities have been identified in technical-grade malathion. The identities of the impurities and their percent (w/w) in technical grade malathion were found to be as follows: S-1,2-ethyl-O,S-dimethyl phosphorodithioate (isomalathion; 0.2%), S-1,2-bis(ethoxycarbonyl)-ethyl-O,O-dimethyl phosphorothioate (malaxon; 0.1%), diethylfumarate (DEF; 0.9%), O,S,S-trimethyl phosphorodithioate (0.003–1.2%), O,O,S-trimethyl phosphorothioate (0.04%), O,O,S-trimethyl phosphorodithioate (1.2%), O,O,O-trimethyl phosphorothioate (0.45%), diethylhydroxysuccinate (0.05%), ethyl nitrite (0.03%), diethyl mercaptosuccinate (0.15%), diethyl methylthiosuccinate (1.0%), O,O-dimethylphosphorothioate (0.05%), diethyl ethylthiosuccinate (0.1%), and sulfuric acid (0.05%). Malathion is formulated as an emulsifiable concentrate (EC), a dust (D), a wettable powder (WP), a ready-to-use (RTU) liquid, and a pressurized liquid. The quantity of active ingredient (ai) in EC and RTU formulations is variable and can contain up to 82 and 95%, respectively (Brown et al. 1993b; EPA 2001a).

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of malathion is located in Table 4-2.

Table 4-1 Chemical Identity of Malathion

Characteristic | Information | Reference
CAS Nomenclature | Diethyl[(dimethoxyphosphino-thioyl)thio]butanedioate | CAS 2001
Common name | Malathion | Howard and Neal 1992
Synonym(s) | 1,2-Di(ethoxycarbonyl)ethyl O,O-dimethyl phosphorodithioate | Howard and Neal 1992
Registered trade name(s) | Cekumal; Fyfanon^®^; Malixol^®^; Maltox^®^ | Farm Chemicals Handbook 2000; Howard and Neal 1992; Farm Chemicals Handbook 2000; Howard and Neal 1992
Chemical formula | C_10_H_19_O_6_PS_2_ | Howard and Neal 1992
Chemical structure | [image]; Butanedioic acid, [(dimethoxyphosphinothioyl) thio]-, diethyl ester (malathion)
Identification numbers:
CAS registry | 000121-75-5 | Howard and Neal 1992
NIOSH RTECS | WM8400000 | HSDB 2001
EPA hazardous waste
OHM/TADS
DOT/UN/NA/IMCO shipping | NA 2783; Malathion 665 | HSDB 2001; HSDB 2001
HSDB
NCI

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substance

Table 4-2 Physical and Chemical Properties of Malathion

Property | Information | Reference
Molecular weight | 330.36 | Howard and Neal 1992
Color | Colorless liquid (pure form) | Matsumura 1985
Color | Deep brown to yellow | Budavari 1996; NIOSH 1997
Physical state | Liquid | Matsumura 1985
Melting point | 2.9 °C | Budavari 1996
Boiling point | 156–157 °C | Budavari 1996
Boiling point pressure | 0.7 torr
Density:
at 25 °C | 1.23 g/cm^3^ | Budavari 1996
Odor | Garlic-like | NIOSH 1997
Odor | Mercaptan | Farm Chemicals Handbook 1999
Odor threshold:
Water 60 °C | 1.0 mg/L | Fazzalari 1978
Air | 13.5 mg/m^3^ (low) and 13.5 mg/m^3^ (high) | Ruth 1986
Solubility:
Water at 20 °C | 145 mg/L
Organic solvent(s) | Miscible with alcohols, esters, ketones, ethers, aromatics, and vegetable oil; limited solubility in paraffin hydrocarbons | Tomlin 1997; Budavari 1996
Partition coefficients:
Log K_ow_ | 2.36 | Hansch et al. 1995
Log K_ow_ | 2.89 | Chiou et al. 1977; Freed et al. 1978
Log K_oc_ | 3.25 | Buyuksonmez 1999
Vapor pressure
at 25 °C | 5.03x10^-6^ torr | Watanabe 1993
at 30 °C | 3.38x10^-6^ torr | SRC 2000
at 25 °C | 7.9x10^-6^ torr | Kim et al. 1984
Henry’s law constant (25 °C) | 4.9x10^-9^ atm m^3^/mol | Fendinger et al. 1990
Autoignition temperature | No data
Flashpoint | 163 °C^a^ | Farm Chemicals Handbook 1989
Flammability limits | No data
Conversion factors^b^ | No data
Explosive limits | Containers of malathion may explode in a fire | U.S. Coast Guard 1984–1985

a Pensky-Martens closed cup test

b The conversion factor for ppm to mg/m^3^ is: ppm = (mg/m^3^) (24.45 L/mole)/(g/mole).