# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop E-29, Atlanta, Georgia 30333.

## Malathion Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Malathion
CAS Number: | 121-75-5
Date: | March 20, 2003
Profile Status: | Final Draft Post Public
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 2h
Species: | Rabbits

Minimal Risk Level: 0.2 [ ] mg/kg/day [X] mg/m^3^

Reference: Weeks MH, Lawson MA, Angerhofer RA, . 1977. Preliminary assessment of the acute toxicity of malathion in animals. Arch Environ Contam Toxicol 6:23–31.907373

Experimental design: The purpose of the study was to compare the acute effects of two different malathion aerosols on the activity of plasma and erythrocyte (RBC) cholinesterase from rabbits. Groups of male New Zealand rabbits (6/exposure level) were exposed for 6 hours to 0 (chamber air), 6, 34, 65, or 123 mg malathion/m^3^ as an aerosol generated from a technical malathion formulation (95% pure). Blood was collected at 10 minutes, 24 hours, 72 hours, and 7 days postexposure for determination of cholinesterases activities. Tissues were also removed for histopathological examination. In a parallel experiment, rabbits were similarly exposed to aerosols generated from a formulation containing 6% malathion and a fuel oil mixture. The malathion concentration in the air in the latter case was 0 (controls), 8, 24, 30, 66, or 128 mg/m^3^.

Effects noted in study and corresponding doses: There were no signs of toxicity or deaths in the group exposed to 95% technical malathion. Exposure to 128 mg/m^3^ aerosol generated from the 6% formulation resulted in four out of six rabbits dying 24 hours after exposure. Exposure to the highest concentration of the 95% formulation inhibited plasma cholinesterase by 37% 24 hours postexposure and 41% 72 hours postexposure. No other significant differences were seen. RBC cholinesterase was inhibited by 38, 48, and 48% by the high exposure concentration at 24 hours, 72 hours, and 7 days postexposure, respectively. Exposure to the aerosol generated from the 6% formulation resulted in 38% inhibition of plasma cholinesterase with the 66 mg/m^3^ concentration 72 hours after exposure and 71% inhibition with the 128 mg/m^3^ concentration 10 minutes postexposure. With this formulation, RBC cholinesterase was inhibited 61 and 46% with the 128 mg/m^3^ concentration 10 minutes and 24 hours, respectively, postexposure. Without providing any further details, the authors stated that exposure to malathion caused no histopathological alterations in the organs examined (not specified).

Exposure concentration and end point used for MRL derivation: 65 mg/m^3^; NOAEL for neurological effects (inhibition of RBC cholinesterase activity).

[X] NOAEL [ ] LOAEL

Uncertainty Factors used in MRL derivation:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from humans to animals
- [X] 10 for human variability

Was a conversion factor used from ppm in food or water to a mg/body weight dose? Not applicable.

If an inhalation study in animals, list conversion factors used in determining human equivalent concentration:

A human equivalent concentration was not determined due to lack of information on the size distribution of the aerosol particles in the study.

Was a conversion used from intermittent to continuous exposure?

Yes, 6/24.

Other additional studies or pertinent information that lend support to this MRL: Malathion is an organophosphate pesticide and as such, its main target of toxicity is the nervous system (Abou-Donia 1995; Ecobichon 1994; Koelle 1994; Taylor 1996). Within the nervous system, malathion and its active metabolite, malaoxon, inhibit acetylcholinesterase, the enzyme that terminates the action of the neurotransmitter acetylcholine. The effects of malathion have been well documented in studies in animals and also in humans, although in the latter case, mostly from case reports of accidental or intentional ingestion of high amounts of malathion. A 42-day controlled-exposure study in volunteers reported nasal and eye irritation after 5–10 minutes of exposure to 85 mg/m^3^ malathion (Golz 1959); subjects were exposed 2 hours/day. Neither plasma nor RBC cholinesterase activities were significantly altered during the study.

Agency Contact (Chemical Manager): Jewell D. Wilson, Ph.D.

## Malathion Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Malathion
CAS Number: | 121-75-5
Date: | March 20, 2003
Profile Status: | Final Draft Post Public
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 4r
Species: | Rat

[underlined: Minimal Risk Level]: 0.02 [ ] mg/kg/day [X] mg/m^3^

[underlined: Reference]: Beattie G. 1994. A 13-week toxicity study of aerolized malathion administered by whole body inhalation exposure to the albino rat: Lab project No: 90729. Unpublished study prepared by Product Safety Assessment, Bio-Research Labs, Ltd. MRID 43266601.

[underlined: Experimental design:] Groups of male and female Sprague-Dawley rats (15/sex/exposure level) were exposed whole body to malathion (96.4% pure) aerosols at concentrations of 0 (air control), 100, 450, or 2010 mg/m^3^ 6 hours/day, 5 days/week, for 13 weeks. Rats were monitored for clinical signs and body weight changes. At termination, gross necropsies were conducted, and tissues (unspecified in the summary available) were processed for microscopical evaluation. Cholinesterase activity was determined in plasma, red blood cells (RBC), and brain.

[underlined: Effects noted in study and corresponding doses]: There were no malathion-related effects on survival, body weight, or food intake. Adverse clinical signs consisting of urogenital staining, excessive salivation, and ungroomed fur were seen mostly in the high-exposure group, but also occurred sporadically in the other exposed groups. I appears that histopathological treatment-related alterations were restricted to the respiratory epithelium. Exposure-concentration-related lesions in the nasal cavity and the larynx of both sexes were seen. The lesions in the nasal cavity consisted of slight to moderate degeneration and/or hyperplasia of the olfactory epithelium. The lesions in the larynx consisted of epithelial hyperplasia with squamous keratization seen in some rats. The effects on cholinesterase activities were concentration-related and effects on females seemed more pronounced than in males. Plasma cholinesterase activity was decreased 30 and 70% in the mid-level and high-level females, respectively. RBC cholinesterase activity was decreased 22% and 27% in mid-level males and females, respectively, and 43 and 44% in high-level males and females, respectively. Brain cholinesterase activity was decreased 41% in high-level females.

[underlined: Exposure concentration and end point used for MRL derivation]: 100 mg/m^3^; LOAEL for respiratory effects (hyperplasia of the olfactory epithelium and of the larynx epithelium).

[] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent][underlined: concentration:] A human equivalent concentration was not determined due to lack of information on the size distribution of the aerosol particles in the summary of the study available.

[underlined: Was a conversion used from intermittent to continuous exposure?]

Yes, 5/7 x 6/24.

[underlined: Other additional studies or pertinent information that lend support to this MRL:] Malathion is an organophosphate pesticide and as such, its main target of toxicity is the nervous system (Abou-Donia 1995; Ecobichon 1994; Koelle 1994; Taylor 1996). A 42-day controlled-exposure study in volunteers exposed to up 85 mg/m^3^ malathion 2 hours/day reported no signs of toxicity during the study except for occasional nose and eye irritation 5–10 minutes into the exposure session (Golz 1959). No significant changes in plasma or RBC cholinesterase activities were seen throughout that study.

[underlined: Agency Contact (Chemical Manager):] Jewell D. Wilson, Ph.D.

## Malathion Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Malathion
CAS Number: | 121-75-5
Date: | March 20, 2003
Profile Status: | Final Draft Post Public
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 72
Species: | Humans

[underlined: Minimal Risk Level]: 0.02 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Moeller HC, Rider JA. 1962. Plasma and red blood cell cholinesterase activity as indications of the threshold of incipient toxicity of ethyl-p-nitrophenyl thionobenzenephosphorate (EPN) and malathion in human beings. Toxicol Appl Pharmacol 4:123–130.14474998

[underlined: Experimental design:] A three-phase study was conducted in humans. In the first phase, five male volunteers were administered daily capsules containing malathion (purity not reported) in corn oil that provided an approximate dose of 0.11 mg malathion/kg/day for 32 days. In the second phase, which started 3 weeks after the first phase had terminated, five male volunteers received daily capsules with malathion providing about 0.23 mg malathion/kg/day for 47 days. In the third phase, five new subjects received approximately 0.34 mg malathion/kg/day for 56 days. Plasma and red blood cell (RBC) cholinesterase was determined twice weekly before, during, and after administration of malathion. Routine blood counts and urinalyses were conducted at the end of each study period.

[underlined: Effects noted in study and corresponding doses]: Administration of 0.11 mg malathion/kg/day for 32 days or 0.23 mg/kg/day for 47 days did not produce any significant depression of plasma or RBC cholinesterase activity, nor did it alter blood counts or urinalyses, or induce clinical signs. In phase three, 0.34 mg malathion/kg/day for 56 days caused a depression of about 10% in plasma cholinesterase activity during treatment and a maximum depression of about 25% approximately 3 weeks after cessation of treatment. RBC cholinesterase activity did not appear to be significantly affected during treatment, but was depressed also by about 25% 3–4 weeks after treatment with malathion ceased. No clinical signs were seen in the volunteers.

[underlined: Dose and end point used for MRL derivation]: 0.23 mg/kg/day; NOAEL for neurological effects (inhibition of plasma and RBC cholinesterase activities).

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from humans to animals
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure?] No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Malathion is an organophosphate pesticide and as such, its main target of toxicity is the nervous system (Abou-Donia 1995; Ecobichon 1994; Koelle 1994; Taylor 1996). Within the nervous system, malathion and its active metabolite, malaoxon, inhibit acetylcholinesterase, the enzyme that terminates the action of the neurotransmitter acetylcholine. The effects of malathion have been well documented in studies in animals and also in humans, although in the latter case, mostly from case reports of accidental or intentional ingestion of high amounts of malathion. The study by Moeller and Rider (1962) was the only available study of controlled ingestion of malathion in humans for review. Most of the studies in animals, while supporting the human data, have been conducted with higher dose levels of malathion.

[underlined: Agency Contact (Chemical Manager)]: Jewell D. Wilson, Ph.D.

## Malathion Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Malathion
CAS Number: | 121-75-5
Date: | March 20, 2003
Profile Status: | Final Draft Post Public
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 95r
Species: | Rat

[underlined: Minimal Risk Level]: 0.02 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Daly I. 1996a. A 24-month oral toxicity/oncogenicity study of malathion in the rat via dietary administration: Final Report: Lab Project Number:90-3461:J-11 90-3641 Unpublished study prepared by Huntington Life Sciences. MRID 43942901.

[underlined: Experimental design:] Groups of male and female Fischer-344 rats (90/sex/dose level) were administered malathion (97.1%) in the diet at levels of 0, 50/100, 500, 6,000, or 12,000 ppm for 2 years. The lowest dietary concentration was reduced from 100 to 50 ppm because of inhibition of RBC cholinesterase activity. The mean intakes of malathion estimated by the investigator were approximately 0, 2, 29, 359, or 739 mg malathion/kg/day to males and 0, 3, 35, 415, or 868 mg/kg/day to females. Ten rats/sex/group were sacrificed at 3 and 6 months primarily for ocular tissue evaluation. Additional sacrifices were conducted at 12 months for more complete assessments. End points evaluated included clinical signs, body weight, food consumption, hematology and clinical chemistry, and gross and microscopical appearance of main tissues and organs.

[underlined: Effects noted in study and corresponding doses]: Administration of malathion significantly increased mortality in males at 6,000 ppm and in both sexes at 12,000 ppm. Body weight gain was reduced both in males and females at the two highest exposure levels, but food intake was not decreased. Hemoglobin, hematocrit, mean corpuscular volume (MCV), and mean cell hemoglobin were also reduced at the two highest dietary levels of malathion in both males and females. Absolute and relative liver and kidney weights were increased in males and females from the 6,000 and 12,000 ppm groups. Relative absolute thyroid and parathyroid weights were increased in males at 6,000 ppm at 12 months and in females at 6,000 and 12,000 ppm at termination. At 24 months, at the 500 ppm malathion dietary level (29 mg/kg/day for males, 35 mg/kg/day for females), plasma cholinesterase activity was reduced 29 and 18% in males and females, respectively, RBC cholinesterase was reduced 17 and 27%, respectively, and brain cholinesterase was reduced 3 and 1%, respectively. At the 6,000 ppm level, plasma cholinesterase in males and females was reduced 64 and 61%, respectively, and brain cholinesterase was reduced 21 and 18%, respectively. No significant reduction in enzyme activities was observed at the lowest dietary level of malathion, 2 mg/kg/day for males and 3 mg/kg/day for females.

[underlined: Dose and end point used for MRL derivation]: 2 mg/kg/day; NOAEL for neurological effects (inhibition of RBC cholinesterase activity).

[X] NOAEL [] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Yes, conversions from dietary ppm to mg/kg/day doses were done by the study author.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure?] No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Malathion is an organophosphate pesticide and as such, its main target of toxicity is the nervous system (Abou-Donia 1995; Ecobichon 1994; Koelle 1994; Taylor 1996). Within the nervous system, malathion and its active metabolite, malaoxon, inhibit acetylcholinesterase, the enzyme that terminates the action of the neurotransmitter acetylcholine. The effects of malathion have been well documented in studies in animals and also in humans, although in the latter case, mostly from case reports of accidental or intentional ingestion of high amounts of malathion. No data were located regarding effects of chronic oral exposure to malathion in humans. Few additional long-term studies have been conducted with malathion in rats and mice (NCI 1978, 1979a; Slauter 1994), but the one by Daly (1996a) used the widest dose range. The studies conducted by NCI (1978, 1979a) did not measure cholinesterase activities. An 18-month dietary study in mice identified a NOAEL of approximately 20 mg/kg/day for plasma and RBC cholinesterase inhibition (Slauter 1994), and this was the highest NOAEL below a LOAEL. However, ATSDR’s policy and guidance for MRL derivation is to always use the most sensitive species and the database indicates that rats are more sensitive than mice for malathion.

[underlined: Agency Contact (Chemical Manager)]: Jewell D. Wilson, Ph.D.