# 8 REFERENCES

* Cited in text

*ACGIH. 1994. Threshold limit values and biological exposure indices for 1994-1995. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*Aelion CM, Bradley PM. 1991. Aerobic biodegradation potential of subsurface microorganisms from a jet fuel-contaminated aquifer. Appl Environ Microbial 57:57–63.
*Air Force. 1974. Chronic inhalation toxicity of ‘JP-4 jet fuel. In: Toxic hazards research unit annual technical report: 1974. Report no. AMRL-TR-74-78. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Division, Air Force Systems Command, 5–26.
Air Force. 1975. Toxicity of high density jet fuel components. Report no. AMRL-TR-75-125. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command.
*Air Force. 1976. Chronic inhalation toxicity of JP-4 jet fuel. In: Toxic hazards research unit annual technical report: 1976. Report no. AMRL-TR-76-57. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Division, Air Force Systems Command. Document no. AD-A031860, 17-19.
*Air Force. 1977. Military specification: Turbine fuel, low volatility, JP-7. Report no. MIL-T-38219A. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Division, Air Force Systems Command.
*Air Force. 1978a. Mutagen and oncogen study on JP-4. Report no. AMRL-TR-78-24. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Division, Air Force Systems Command. Document no. AD-A064952.
Air Force. 1978b. Toxic hazards research unit annual technical report: 1978. Report no. AMRL-TR-78-55. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-A062138.
Air Force. 1979a. Analysis of the emissions from storage tanks during JP-4 fuel transfer operations: Phase I. Warm weather conditions. Kelly Air Force Base, TX: San Antonio Air Logistics Center. Document no. AD-A069339.
*Air Force. 1979b. Cytologic effects of Air Force chemicals. Report no. AMRL-TR-79-55. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-A075605/6.
*Air Force. 1980. Evaluation of the toxic effect of a 90-day continuous inhalation exposure to petroleum JP-4 vapor. In: Toxic hazards research unit annual technical report: 1980. Report no. AMRL-TR-80-79. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Division, Air Force Systems Command. Document no. AD-A091617, 32-45.
Air Force. 1981a. Analysis and environmental fate of Air Force distillate and high density fuels. Report no. ESL-TR-81-54. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. Document no. AD-A115949.
*Air Force. 1981b. Atmospheric chemistry of hydrocarbon fuels. Volume I: Experiments, results and discussion. Report no. ESL-TR-81-53. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. Document no. AD-Al 15526.
Air Force. 1981c. Identification and quantification of the water soluble components of JP-4 and a determination of their biological effects upon selected freshwater organisms. Document no. AD-Al 13009/5.
Air Force. 1981d. The biological degradation of spilled jet fuels: A literature review. Report no. ESL-TR-81-50. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. Document no. AD-Al 10758.
*Air Force. 1981e. Environmental fate and biological consequences of chemicals related to Air Force activities. Bolling Air Force Base, Washington, DC: Air Force Office of Scientific Research. Document no. AD-Al 11927/O.
*Air Force. 1981f. Hydrocarbon fuel chemistry: Sediment water interaction. Report no. AFESC/ESL-TR-82-06. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. Document no. AD-Al 17928.
*Air Force. 1981g. Military specification: Turbine fuel, low volatility, JP-7. Report no. MIL-T-38219A. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Air Force Medical Division, Air Force Systems Command.
*Air Force. 1981h. An industrial hygiene evaluation of aircraft refueling inside closed aircraft shelters. Report no. BEES(w)-81-03. APO, NY: U.S. Air Force Hospital Wiesbaden/SGP. Document no. AD-A098708/1.
*Air Force. 1981i. The experimental determination of the oncogenic effects of one-year exposure to petroleum JP-4 vapor. In: Toxic hazards research unit annual technical report: 1981. Report no. AFAMRL-TR-81-126. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Air Force Medical Division, Air Force Systems Command. Document no. AD-A110587, p.52–57.
*Air Force. 1982a. Analytical techniques for aromatic components in aircraft fuels. Report AFWAL-TR-82-2015. Wright-Patterson Air Force Base, OH: Aerospace Propulsion Laboratory, Air Force Wright Aeronautical Laboratory, Air Force Systems Command. Document no. AD-A118838.
*Air Force. 1982b. Environmental quality research - fate of toxic jet fuel components in aquatic systems. Report no. AFAMRL-TR-82-64. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command.
*Air Force. 1982c. Environmental fate and biological consequences of chemicals related to air force activities. Report no. AFOSR-TR-82-0974. Bolling Air Force Base, DC: Air Force Office of Scientific Research. Document no. AD-A121288.
*Air Force. 1982d. The chemical and physical properties of JP-4 for 1980-1981. Report no. AFWAL-TR-82-2052. Wright-Patterson Air Force Base, OH: Aerospace Propulsion Laboratory, Air Force Wright Aeronautical Laboratories, Air Force Systems Command. Document no. AD-A122965.
*Air Force. 1982e. High altitude jet fuel photochemistry. Report no. ESL-TR-82-38. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. Document no. AD-A125035.
*Air Force. 1982f. The experimental determination of the oncogenic effects of one-year exposure to petroleum JP-4 vapor. In: Toxic hazards research unit annual technical report: 1982. Report no. AFAMRL-TR-82-62. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-A121717, 22–28.
*Air Force. 19828. Evaluation of the oncogenic potential of JP-7 jet fuel. In: Toxic hazards research unit annual technical report: 1982. Report no. AFAMRL-TR-82-62. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-A121717, 59–72.
*Air Force. 1983a. Installation restoration program: Phase I - records search. Niagara Falls Air Force Reserve Facility, New York. Robins Air Force Base, GA: U.S. Air Force Headquarters, Air Force Reserve. Document no. AD-A137196.
*Air Force. 1983b. Installation restoration program: Phase I - records search. O’Hare Air Reserve Forces Facility, Illinois. Robins Air Force Base, GA: U.S. Air Force Headquarters, Air Force Reserve. Document no. AD-A137373.
Air Force. 1983c. Partitioning equilibria of volatile pollutants in three-phase systems. Report no. ESL-TR-83-51. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. Document no. AD-A137207.
*Air Force. 1983d. Rationale for a threshold limit value (TLV)R for JP-4/jet B wide-cut aviation turbine fuel. Report no. OEHL-83-128EHlllDGA. Brooks Air Force Base, TX: U.S. Air Force Occupational and Environmental Health Laboratory, Aerospace Medical Division. Document no. AD-A134814.
*Air Force. 1983e. Evaluation of the chronic toxicity of JP-7 jet fuel. In: Toxic hazards research unit annual technical report: 1983. Report no. AFAMRL-TR-83-64. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-A136170, 57–63.
*Air Force. 1983f. Degradation of jet fuel hydrocarbons by aquatic microbial communities. Report no. ESL-TR-83-26. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. Document no. AD-A139791.
*Air Force. 1984a. The acute irritation and sensitization potential of JP-4, JP-7, JP-8, and JP-TS jet fuels. In: Toxic hazards research unit annual technical report: 1984. Report no. AMRL-TR-84-001. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-A147857/7.
*Air Force. 1984b. Ninety-day continuous inhalation exposure to petroleum JP-4 jet fuel. In: Toxic hazards research unit annual technical report: 1984. Report no. AMRL-TR-84-001. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-A14785717, 46-62.
*Air Force. 1984c. Ninety-day continuous inhalation exposure of rats and mice to shale JP-4 jet fuel. In: Toxic hazards research unit annual technical report: 1984. Report no. AMRL-TR-84-001. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-A147857/7, 63–73.
*Air Force. 1984d. Evaluation of strain susceptibility to chronic nephritis in rats exposed to shale derived JP-4 jet fuel. In: Toxic hazards research unit annual technical report: 1984. Report no. AMRL-TR-84-001. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-A137857/7, 73–84.
*Air Force. 1985a. Installation restoration program: Phase II -confirmation/quantification. Stage 1: Final Report for Robins Air Force Base, GA and Air Force Logistics Command, Wright-Patterson Air Force Base, OH. Brooks Air Force Base, TX: Occupational Health Laboratory, U.S. Air Force. Document no. AD-Al 57087/8.
*Air Force. 1985b. Ninety-day continuous inhalation exposure of rats and mice to shale-JP-4 jet fuel. In: Toxic hazards research unit annual technical report: 1985. Report no. AAMRL-TR-85-058. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-A161558, p.69–76.
*Air Force. 1985c. Pulmonary mechanics, dynamics, and gas exchange in male rats with emphysema, fibrosis or pneumonia compared with rats exposed to shale JP-4 jet fuel. In: Toxic hazards research unit annual technical report: 1985. Report no. AAMRL-TR-85-058. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-Al61558.
Air Force. 1985d. Evaluation of strain susceptibility to chronic nephritis in rats exposed to shale derived JP-4 jet fuel. In: Toxic hazards research unit annual technical report: 1985. Report no. AAMRL-TR-85-058. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-A161558, p.84–88.
Air Force. 1987a. Hydrocarbon fuel spill dispersion on water: Literature review. Report no. ESL-TR-86-64. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center, U.S. Air Force.. Document no. AD-A192486/9.
*Air Force. 1987b. Degradation of jet and missile fuels by aquatic microbial communities. Report no. ESL-TR-86-59. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. Document no. AD-A188065/7.
*Air Force. 1988a. Military specification: Turbine fuel, aviation, grades JP-4 and JP-5. Report no. MIL-T-5624M. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command.
*Air Force. 1988b. Environmental fate and effects of shale-derived jet fuel. Report no. ESL-TR-87-09. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. U.S. Environmental Protection Agency, Environmental Research Laboratory, Gulf Breeze, FL. Document no. AD-A197683. ~1-19, 80–87.
*Air Force. 1988c. Fuel-additive system for test cells. Report no. ESL-TR-8817. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. Document no. AD-A200801.
*Air Force. 1988d. Hydrocarbon fuel spill dispersion on water. Report no. ESL-TR-88-19. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. Document no. AD-A201721.
Air Force. 1989a. Mutagenic responses of some petroleum-base obscurants in the Ames test. Report no. CRDEC-TR-071. Aberdeen Proving Grounds, MD: Chemical Research Development and Engineering Center. Document no. AD-A214201.
*Air Force. 1989b. The installation restoration program toxicology guide. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. DOE interagency agreement no. 1891-A076-Al.
*Air Force. 1989c. Military specification: Turbine fuel, aviation, grades JP-4, JP-5, and JP-YJP-8 ST. Report no. MIL-T-5624N. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command.
*Air Force. 1990. Military specification: Turbine fuel, aviation, grades JP-4, JP-5 and JP-5/JP-8 ST. Report no. MIL-T-5624N. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command.
*Air Force. 1991. Tumorigenic evaluation of jet fuels JP-TS and JP-7. Report no. AAMRL-TR-91-0020. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command.
*Air Force. 1992. Test plan and technical protocol for a field treatability test for bioventing. Prepared for Air Force Center for Environmental Excellence, Brooks AFB, TX by Battelle, Cincinnati, OH. May 1992. PB93-209146. p.l-6, 42-59.
*Alden CL. 1986. A review of unique male rat hydrocarbon nephropathy. Toxicol Path01 14:109–111.
Anderson S. 1992. Written communication (July 14) to Diane Mandell, Clement Associates, Inc., regarding chemical components of JP-7. U.S. Air Force, Wright Patterson Chemical Laboratory, Wright Patterson Air Force Base, OH.
*ASTM. 1982. Standard method for comparison of waterborne petroleum oils by fluorescence analysis. Method no. D-3650-78. In: Annual book of ASTM standards, Vol. 11.02. American Society for Testing and Materials 05.01:D1019.
*ATSDR. 1990. Toxicological profile for toluene. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*ATSDR. 1991a. Toxicological profile for benzene. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*ATSDR. 1991b. Toxicological profile for polycyclic aromatic hydrocarbons. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*ATSDR. 1991c. Toxicological profile for xylenes. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Bishop EC. 1982. Evaluating health hazards associated with aircraft fuel cell maintenance. Proceedings of the Conference on Environmental Toxicology 12: 192–202.
*Bradley PM, Aelion CM, Vroblesky DA. 1992. Influence of environmental factors on denitrification in sediment contaminated with JP-4 jet fuel. Ground Water 30:843–848.
*Bruner RH. 1984. Pathologic findings in laboratory animals exposed to hydrocarbon fuels of military interest. Advancements in Modem Environmental Toxicology 7:133–140.
*Bruner RH, Kinkead ER, O’Neill TP, 1993. The toxicologic and oncogenic potential of JP-4 jet fuel vapors in rats and mice: 12-month intermittent inhalation exposures. Fund Appl Toxicol 20:97-l 10.
*Carter WP L, Atkinson R, Winer AM. 1984. Effects of temperature and pressure on the photochemical reactivity of a representative aviation fuel. Environ Sci Technol 18:556–561.
*CHRIS. 1986. Jet Fuels: JP-4. Chemical Hazard Response Information System - hazardous chemical data. Washington, DC: U.S. Coast Guard.
*Cifone MA. 1982a. Mutagenicity evaluation of L13B in the mouse lymphoma forward mutation assay. Washington DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8100388.
*Cifone MA. 198213. Mutagenicity evaluation of L14-B in the mouse lymphoma forward mutation assay. Washington DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8100388.
*Clark CR, Ferguson PW, Katchen MA, 1989. Comparative acute toxicity of shale and petroleum derived distillates. Toxicol Ind Health 5: 1005–1016.2626753
*Clark CR, Walter MK, Ferguson PW, 1988. Comparative dermal carcinogenesis of shale and petroleum-derived distillates. Toxicol Ind Health 4: 1 l-22.3388442
*Clarke RH, Chung WM, Wang 0, 1991. Determination of aromatic composition of fuels by laser raman spectroscopy. Journal of Raman Spectroscopy 22:79–82.
*Coho JW. 1990. Biodegradation of jet fuel in vented columns of water-unsaturated sandy soil. Miami, FL: University of Florida. Document no. AD-A224705/4.
*CONCAWE. 1985. Health aspects of petroleum fuels - general principles. Report no. 2/85. The Hague, Netherlands: Oil Companies’ European Organization for Environmental and Health Protection. Document no. PB85-230480.
*CRC. 1984. Handbook of aviation fuel properties. Atlanta, GA: Coordinating Research Council, Inc. Report no. 53.
*Davies NE. 1964. Jet fuel intoxication. Aerospace Med 35:481–482.14170936
*Dean-Ross D. 1993. Fate of jet fuel JP-4 in soil. Bull Environ Contam Toxicol 51:596–599.8400664
*Dennis MW. 1982a. Acute dermal LD50 toxicity study E-2B, E-6B, E-8, E-14B, E-10, E-11, E-12 with cover letter dated 03/31/82. Washington DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8100360.
*Dennis MW. 1982b. Primary dermal irritation study of petroleum fuels,E-2B, E-6B, E-8B, E-10, E-l 1, E-12, E-14B with cover letter dated 02/18/82. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8100348.
*Dennis MW. 1982c. Primary eye irritation study E-2B, E-6B, E-8B, E-14B, E-10, E-11, E-12 with cover letter dated 03/08/82. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8100354.
*Di Sanzo FP, Yoder RE. 1991. Determination of aromatics in jet and diesel fuels by supercritical fluid chromatography with flame ionization detection (SFC-FID): A quantitative study. J Chromatogr Sci 29:4–7.
*Dickson CL, Woodward PW. 1987. Aviation turbine fuels, 1986. NIPER 149 PPS. Bartlesville, OK: National Institute for Petroleum and Energy Research.
Dickson CL, Woodward PW. 1988. Aviation turbine fuels, 1987. NIPER 154 PPS. Bartlesville, OK: National Institute for Petroleum and Energy Research.
*Dietrich DR, Swenberg JA. 1991. NCI-black reiter (NBR) male rats fail to develop renal disease following exposure to agents that induce alpha-2u-globulin (alpha-2p) nephropathy. Fundam Appl Toxicol 16:749–762.1715830
*DOE. 1981. Hydrocarbon type analysis of jet fuels by 1H and 13-C NMR. Laramie, WY: Laramie Energy Technology Center, U.S. Department of Energy. Document no. DOE/LETC/RI-81-1.
*DOT. 1989. Hazardous materials table. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101.
*Dukek WG. 1978. Aviation and other gas turbine fuels. In: Grayson M., ed. Kirk-Othmer encyclopedia of chemical technology. 3rd ed., vol. 3. New York, NY: John Wiley & Sons, 328–351.
*Elliott MG, DePaoli DW. 1990. In-situ venting of jet-fuel contaminated soil. Proceedings of the Industrial Waste Conference 44: 1–9.
*EPA. 1978. Methods for chemical analysis of water and wastes. Petroleum hydrocarbons, total recoverable. Method 418.1 (spectrophotometric, infrared). Environmental Monitoring and Support Laboratory, Cincinnati, OH.
*EPA. 1982a. Overview summary compound L13-B. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8100388.
*EPA. 1982b. Overview summary compound L14-B. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8100388.
EPA. 1982c. Second interim report for carcinogenic potential of petroleum fuels in the mouse. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8300439.
EPA. 1982d. Compendium of reported physical and chemical characterization data for petroleum and synthetic fuel products. Volume 1: Petroleum and shale oil products. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. EPA-560/4-84-OOlA.
*EPA. 1982e. Control of air pollution from aircraft and aircraft engines. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 87.
*EPA. 1982f. Control of air pollution from aircraft and aircraft engines. U.S. Environmental Protection Agency. Federal Register 47:58470.
*EPA. 1985. Biodegradation of jet fuel by aquatic microbial communities. Report no. EPA/600/D-85-084. Gulf Breeze, FL: U.S. Environmental Protection Agency, Environmental Research Laboratory. Document no. PB85-191971.
*EPA. 1986a. Quality criteria for water. Washington, DC: U.S. Environmental Protection Agency. EPA-440/5-86-011.
*EPA. 1986b. Guidelines for carcinogen risk assessment. U.S. Environmental Protection Agency. Federal Register 51(185):33993–34003.
*EPA. 1988a. Soil-gas and geophysical techniques for detection of subsurface organic contamination. Las Vegas, NV: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory, Office of Research and Development. EPA/600/4-88/019.
*EPA 1988b. General pretreatment regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403.2 Appendix B.
*EPA 1988c. Conventional pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.16.
EPA. 1988d. Environmental fate and effects of shale-derived jet fuel. Report no. ESL-TR-87-09. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. U.S. Environmental Protection Agency, Environmental Research Laboratory, Gulf Breeze, FL. Document no. AD-A197683. c1-19, 80–87.
*EPA 1988e. Technical standards and corrective action requirements for owners and operators of underground storage tanks. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 280.
EPA. 1990a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency. EPA-600/8-90/066A.
*EPA. 1990b. Superfund record of decision (EPA region 2), FAA (Federal Aviation Administration) Technical Center, Atlantic county, New Jersey, September 1989. First remedial action. Washington, DC: U.S. Environmental Protection Agency. Document no. PB90-178203.
*EPA. 1991. Alpha-2y-globulin: Association with chemically-induced renal toxicity and neoplasia in the male rat. Review draft. Washington, DC: U.S. Environmental Protection Agency. Document no. 625/3-91/019A.
Fajen JM, McCammon CS. 1988. Exposure characterization study of workers exposed to hydrazines. In: Proceedings of the Fourth NCIiEPA/NIOSH Collaborative Workshop: Progress on joint environmental and occupational cancer studies, April 22-23, 1988. Rockville, MD: NIH publication no. 88-2960, 261–295.
*FEDRIP. 1994. Federal Research in Progress: Jet fuels. Dialog Information Service, Inc.
*Galloway SM. 1982a. Mutagenicity evaluation of L13-B in an in vitro cytogenetic assay measuring chromosome aberration frequencies in Chinese hamster ovary (CHO) cells. Washington DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8100388.
*Galloway SM. 1982b. Mutagenicity evaluation of L14-B in an in vitro cytogenetic assay measuring chromosome aberration frequencies in Chinese hamster ovary (CHO) cells. Washington DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8100388.
*Gleason CC, Martone JA. 1979. Pollutant emission characteristics of future aviation jet fuels. J Air Pollut Control Assoc 29:1243–1245.
*HazDat. 1994. Database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*Hoffman HL. 1983. Petroleum and its products. Chapter 14 In: Kent JA, ed. Riegel’s handbook of industrial chemistry. 8th ed. New York, NY: Van Nostrand Reinhold Company, 488–492.
Holm S, Norbaeck D, Frenning B, 1987. Hydrocarbon exposure from handling jet fuel at some Swedish aircraft units. Stand J Work Environ Health 13:438–444.
*Hutchins SR, Sewell GW, Kovacs DA, 1991. Biodegradation of aromatic hydrocarbons by aquifer microorganisms under denitrifying conditions. Environ Sci Technol 25:68–76.
*IARC 1989. IARC monographs on the evaluation of carcinogenic risk of chemical to humans: Occupational exposures in petroleum refining, crude oil and major petroleum fuels. Vol. 45:119-158, 203–218. Lyon, France: World Health Organization, International Agency for Research on Cancer.
*ITC. 1985. TSCA Interagency Testing Committee. Information review: Petroleum middle distillate fuels. No. IR-470. Rockville, MD: CRCS, Inc., Dynamac Corp.
*Jagannath DR. 1982. Mutagenicity evaluation of L13-B in the Ames salmonella/microsome plate test. Washington DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8100388.
*Kinkead ER, DiPasquale LC, Vernot EH, 1974. Chronic toxicity of JP-4 jet fuel. Proceedings of the Annual Conference of Environmental Toxicology 5: 145–154.
*Klein SA, Jenkins D. 1983. The toxicity of jet fuels to fish: II. The toxicity of JP-8 to flagfish (Jordanella floridae) and rainbow trout (Salmo gairdneri) and golden shiners (Noternigonus crysoleucas). Water Research 17(10):1213–1220.
*Knave B, Olson BA, Elofsson S, 1978. Long-term exposure to jet fuel: II. A cross-sectional epidemiologic investigation on occupationally exposed industrial workers with special references to the nervous system. Stand J Work Environ Health 4:19–45.
*MacNaughton MG, Uddin DE. 1984. Toxicology of mixed distillate and high-energy synthetic fuels: Renal effects of petroleum hydrocarbons. Adv Mod Environ Toxicol 7:121–132.
*Martel CR. 1992. Written communication (June 4) to Diane Mandell, Clement Associates Inc., regarding physical characteristics of JP-4 and JP-7. Retired, U.S. Air Force, Aero Propulsion and Power Directorate, Wright Laboratory, Wright-Patterson Air Force Base, OH.
Martone JA. 1986. USAF toxicology research on petroleum and shale-derived aviation gas turbine fuels. Journal of Engineering for Gas Turbines and Power 198:387–390.
*McMullen PT, Regan RW. 1992. Thermophilic composting of a synthetic JP-4 fuel mixture. In: 46th Purdue Industrial Waste Conference Proceedings. Chelsea, MI: Lewis Publishers, Inc.
Moler JL, Steward EM. 1989. Thermal-decomposition studies of jet fuel components: Dodecane, octane, 2-methylundecane, and bicyclohexyl. Abstracts of Papers of the American Chemical Society 198:P18-PETR.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/ National Research Council. Washington, DC: National Academy Press, 15–35.
NASA. 1980. Analysis of NASA JP-4 fire tests data and development of a simple fire model. Hampton, VA: National Aeronautics and Space Association, Langley Research Center. Issue NASA-CR-159209, 58.
*Newton PE, Becker SV, Hixon CJ. 1991. Pulmonary function and particle deposition and clearance in rats after a 90-day exposure to shale-oil-derived jet fuel JP-4. Inhalation Toxicol 3:195–210.
*NFPA. 1986. Jet fuels. In: Fire protection guide on hazardous materials. 9th edition. 325M:623–624. Quincy, MA: National Fire Protection Association.
*NIOSH. 1984. NIOSH manual of analytical methods. 3rd edition. Washington, DC: U.S. Government Printing Office, National Institute for Occupational Safety and Health, 2: 1550-l-5. Publication no. 84-100.
*NIOSH. 1989. Industrial hygiene survey report of defense fuel support point. Cincinnati, OH: Centers for Disease Control, National Institute of Occupational Safety and Health, Division of Surveillance, Hazard Evaluations, and Field Studies.
*NOES. 1990. National Occupational Exposure Survey (1981-1983). Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
Odkvist LM, Arlinger SD, Edling C, 1987. Audiological and vestibulo-oculomotor findings in workers exposed to solvents and jet fuel. Scandinavian Audiology 16:75–81.3498206
*OHM/TADS. 1985. JP-4. Oil and Hazardous Material/Technical Assistance Data System. Chemical Information Systems, Inc., Baltimore, MD. December, 1985.
*Olson MJ, Johnson JT, Reidy CA. 1990. A comparison of male rat and human urinary proteins: Implications for human resistance to hyaline droplet nephropathy. Toxicol Appl Pharmacol 102:524–536.1690459
*OSHA. 1989. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR part 1910.1000.
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*Puyear RL, Fleckenstein KJ, Montz WE Jr, 1981. Use of reverse phase C-18 minicolumns for concentrating water-soluble hydrocarbons. Bull Environ Contam Toxicol 27:790–797.7337851
*Rabenold C. 1982. Mutagenicity evaluation of L14-B in the Ames salmonella/microsome plate test. Washington DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8100388.
Rifai HS, Bedient PB, Wilson JT, 1988. Biodegradation modeling at aviation fuel spill site. Journal of Environmental Engineering 114(5): 1007–1029.
*Roberts AJ, Thomas TC. 1986. Characterization and evaluation of JP-4, jet A and mixtures of these fuels in environmental water samples. Environ Toxicol Chem 5:3-l 1.
*RTECS. 1994a. JP-4. Registry of Toxic Effects of Chemical Substances. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Washington, DC.
*RTECS. 1994b. JP-7. Registry of Toxic Effects of Chemical Substances. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Washington, DC.
*Sammons JH, Armstrong JM. 1986. Aviation fuel contamination of groundwater: A case history of containment and management actions. In: Ludwigson J, ed. 1986 Hazardous Material Spills Conference, St. Louis, MO, May 5-8, 1986. Rockville, MD: Government Institutes, Inc., 265–275.
Sax N, RJ Lewis Sr. 1989. Jet Fuels. In: Dangerous properties of industrial material. 7th ed. New York, NY: Van Nostrand Reinhold, 3:2075.
Sewell G, Smith G, Gibson S. 1989. Biodegradation of jet fuel under anaerobic conditions. In: 89th Annual Meeting of the American Society for Microbiology, New Orleans, LA, May 14-18, 1989. Abstract Annual Meeting for the American Society of Microbiology 89:331.
Shabad LM, Smirnov GA. 1976. Aviation and environmental benzo(a)pyrene pollution. In: Environmental pollution and carcinogenic risks. Volume 52. Lyon, France: International Agency for Research on Cancer. IARC scientific publication no. 13, INSERM symposia series.
*Shapiro LE, Sachchidananda J. 1982. Regulation of proteins by thyroid hormone and glucocorticoid: The responses of hepatic alpha-2p-globulin and pituitary growth hormone differ in adult male hypothyroid rats. Endocrinology 8:653–660.
*Short BG, Burnett VL, Cox MG, 1987. Site-specific renal cytotoxicity and cell proliferation in male rats exposed to petroleum hydrocarbons. Lab Invest 57:564–577.3682766
*Smith JH, Harper JC, Jaber H. 1981. Analysis and environmental fate of air force distillate and high density fuels. Engineering and Services Laboratory, Air Force Engineering and Services Center, Tyndall Air Force Base, FL. ESL-TR-81-54.
*Song H-G, Bartha R. 1990. Effects of jet fuel spills on the microbial community of soil. Appl Environ Microbial 56:646–651.
*Song H-G, Wang X, Bartha R. 1990. Bioremediation potential of terrestrial fuel spills. Appl Environ Microbial 56:652–656.
*Stallard CW Jr, Krautter GR. 1984. Toxicology of large-scale refining of shale oil. In: Jacobs VA, ed. Proceedings of the 5th Life Sciences Symposium: Synthetic Fossil Fuel Technology, Gatlinburg, TN, October 24-27, 1982. Boston, MA: Butterworth, 137–148.
Struwe G, Knave B, Mindus P. 1983. Neuropsychiatric symptoms in workers occupationally exposed to jet fuel -a combined epidemiological and casuistic study. Acta Psychiat Stand 67 Suppl 303:55–67.
*Swenberg JA, Short B, Borghoff S, 1989. The comparative pathobiology of alpha-2n-globulin nephropathy. Toxicol Appl Pharmacol 97:35–46.2464861
*Talts A, Bauer J, Martin C, 1977. Discovery, containment and recovery of a jet fuel storage tank leak: A case history. In: Proceedings of the 1977 Oil Spill Conference, New Orleans. Washington, DC: American Petroleum Institute, 259–263.
*Thomas TC, Richardson AI. 1981. An infrared analysis method for the determination of hydrocarbons collected on charcoal tubes. American Chemical Society Symposium Series 149:37–48.
*TRI. 1993. Toxic Chemical Release Inventory: National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Tupper CR. 1989. Chemical hazards in aeromedical aircraft. Aviat Space Environ Med 60:73–75.2923600
*Twenter FK, Cummings TR, Grannemann NG. 1985. Groundwater contamination in East Bay Township Michigan. Report no. 854064. Denver, CO: U.S. Geological Survey Water Resources Investigations.
*Van Doren G, Mertens B, Heyns W, 1983. Different forms of alpha-2p-globulin in male and female rat urine. Eur J Biochem 134:175–181.6190651
*Vandegrift SA, Kampbell DH. 1988. Gas chromatographic determination of aviation gasoline and JP-4 jet fuel in subsurface core samples. J Chromatogr Sci 26:566–569.
*Walter MK. 1982a. Primary eye irritation study E-l, E-3, E-5, and E-13B. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8200416.
Walter MK. 1982b. Quality assurance inspections of primary dermal irritation study of petroleum fuels E-l, E-3, E-5, E-13B for Union 76 oil company. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8200416.
*Walter MK. 1982c. Skin sensitization study E-l, E-3, E-5, and E-13B. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. Document no. 88-8200416.
*Wang X, Bartha R. 1990. Effects of bioremediation on residues: Activity and toxicity in soil contaminated by fuel spills. Soil Biology and Biochemistry 22:501–506.
*Weiss G, ed. 1986. Hazardous chemicals databook. 2nd ed. Park Ridge, NJ: Noyes Data Corporation, 612.
*Yong RN, Mourato D. 1987. Stimulation of microbial biodegradation in a jet fuel contaminated soil. In: Proceedings of the Second International Conference on New Frontiers for Hazardous Waste Management. Cincinnati, OH: U.S. Environmental Protection Agency, 131–147.