# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding JP-4 and JP-7 in air, water, and other media are summarized in Table 7-1. There are only a few regulations that are specific to JP-4 and JP-7, but there are more regulations on the major components of JP-4 and JP-7.

ATSDR has derived an intermediate-duration inhalation MRL of 9 mg/m^3^ for JP-4, based on an increase in hepatic toxicity observed in mice at 500 mg/m^3^ (Air Force 1984b).

ATSDR has derived a chronic-duration inhalation MRL of 0.3 mg/m^3^ for JP-7, based on an increase in hepatic toxicity observed in rats at 150 mg/m^3^ (Air Force 1991).

Under the Hazardous Materials Transportation Act, aviation fuel is designated as a hazardous substance subject to special requirements for packaging, labeling, and transportation (DOT 1989). EPA has established guidelines to control air pollution from aircraft and aircraft engines (EPA 1982e, 1982f) and underground storage tank regulations for petroleum products (EPA 1988e).

Table 7-1 Regulations and Guidelines Applicable to Jet Fuels^a^

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
IARC | Carcinogenic classification of jet fuel | Group 3^b^ | IARC 1989
[underlined: NATIONAL]
Regulations:
a. Air:
AFOSH | PEL TWA (petroleum distillates [naphtha]) | 400 ppm | Air Force 1989b
| STEL (15 minutes) (petroleum distillates [naphtha]) | 500 ppm | Air Force 1989b
OSHA | PEL TWA (petroleum distillates [naphtha]) | 500 ppm | OSHA 1989 (29 CFR 1910.1000)
b. Other
DOT | Hazardous Material Transportation Act: Aviation fuel is designated as a hazardous material subject to requirements for packaging, shipping, and transporting. (See fuel, aviation) | Yes | DOT 1989 (49 CFR 172.101 Appendix A)
EPA | Technical Standards and Corrective Action Requirements for Owners and Operators of Underground Storage Tanks (UST) | Yes | 40 CFR 280 EPA 1988e
Guidelines:
a. Air
ACGIH | TLV TWA (gasoline) STEL (15 minutes) (gasoline) | 300 ppm 500 ppm | ACGIH 1994 ACGIH 1994
EPA | Control of air pollution from aircraft and aircraft angines | Yes | EPA 1982e (40 CFR 87), 1982f
USAF OEHL | TLV TWA (informal guideline) -JP-4; STEL (informal guldeline)-JP4 | 200 ppm 300 ppm | Air Force 1983d; Air Force 1983d
c. Other
EPA | Domestic water supply must be virtually free from oil and grease, particularly from the tastes and odors that emanate from petroleum products. | Yes | EPA 1986a
| Clean Water Act: Oil and grease are designated as conventional pollutants. Effluent limitations for oil and grease (polynuclear aromatic hydrocarbons) exist for almost all point sources under the general pretreatment standards for new and existing sources. | Yes | EPA 1988b (40 CFR 403.2), 1988c (40 CFR 401.16)

a International, national, and State regulations and guidelines regardlng JP-4 and JP-7 in air, water and other media.

b Group 3 = Not classifiable as to human carcinogenicity.

ACGIH = American Conference of Govemmental Industrial Hygienists; AFOSH = Air Force Office of Safety and Health; CFR = Code of Federal Regulations; DOT = Department of Transportation; EPA = Environmental Protection Agency; IARC = International Agency for Research on Cancer; JP-4 = jet propellant-4; JP-7 = jet propellant-7; OEHL = Occupational and Environmental Health Laboratory; OSHA = Occupational Safety and Health Administration; PEL = Permissible Exposure Llmlt; STEL = Short-Term Exposure Limit; TLV = Threshold Limit Value; TWA = Time-Weighted Average; USAF = United States Air Force