# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

The composition of aviation fuels has been established by the U.S. Air Force (Air Force 1977, 1981g, 1982d, 1988a, 1989c, 1990) using specifications that are based primarily on the characteristics that give the maximum performance of the aircraft for which the fuel is used (CRC 1984). JP-4 and JP-7 were developed for use by the U.S. Air Force. JP-4 is called a wide-cut fuel because it is produced from a broad distillation temperature range and contains a wide array of carbon chain--lengths, from 4 to 16 carbons long. It was initially developed for broad availability in times of need. The composition of JP-4 is approximately 13% (v/v) aromatic hydrocarbons, 1.0% olefin hydrocarbons, and 86% saturated hydrocarbons (ITC 1985). It has a distillation temperature range of 60 to 270 °C (MacNaughton and Uddin 1984). JP-7 was developed for use in advanced supersonic aircraft because of its thermal stability and high flashpoint (CRC 1984; Dukek 1978). It has a distillation temperature range of 182 to 288 °C and contains a maximum of 5% (by volume) aromatic compounds (see Table 3-7).

Aviation fuels consist primarily of hydrocarbon compounds (paraffins, cycloparaffins or naphthenes, aromatics, and olefins) and contains additives that are determined by the specific uses of the fuel (CRC 1984; Dukek 1978; IARC 1989). Paraffins and cycloparaffins are the major components. Paraffins have a high hydrogen-to-carbon ratio, with a high heat release per unit of weight and a cleaner burn than other hydrocarbons. Cycloparaffins have a lower hydrogen-to-carbon ratio, which results in less heat released per unit of weight but increases the fuel’s density. These components reduce the freezing point of the fuel. Aromatic hydrocarbons are a good energy source but produce smoke when burned; therefore, the maximum levels are restricted (20-25% by volume in JP--4, 5% by volume in JP-7). Finally, olefins are similar to the paraffins but are unsaturated with lower hydrogento- carbon ratios. They are the most reactive of the hydrocarbons and are permitted at only 5% by volume in JP-4 (CRC 1984). Benzene, present in wide-cut fuels such as JP-4, is an ineffectual contaminant usually present below 0.5% (CONCAWE 1985; IARC 1989). Nonhydrocarbon compounds such as sulfur and sulfur compounds are also found. Additives such as antioxidants, metal deactivators, fuel system icing inhibitors, corrosion inhibitors, and static dissipator additives are all present in limited quantities in jet fuels in order to improve performance (CRC 1984).

Information regarding the chemical identity of JP-4 and JP-7 is located in Tables 3-1 and 3-2, respectively.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of JP-4 and JP-7 is located in Tables 3-3 and 3-4, respectively. Information regarding the major components of JP-4 derived from petroleum and shale oil is presented in Table 3-5. Depending on the origin of the crude and the production method, there could be considerable compositional variability between fuel oils of the same grade (Air Force 1988b). This variation is reflected in the allowed military specifications (mil spec) for JP-4 and JP-7 fuel oils as shown in Tables 3-6 and 3-7, respectively, and in the compositional variability of JP-4 fuels as shown in Tables 3-5 and 3-8.

TABLE 3-1 Chemical Identity of JP-4^a^

Characteristic | Information | Reference
Chemical name | JP-4 | OHM/TADS 1985
Synonym(s) | Jet fuel-4 | OHM/TADS 1985
Registered trade name(s) | MI L-T-5624-L-Amd. 1 wide cut; JP-4 military (gasoline type) | Air Force 1990; Dickson and Woodward 1987; Dukek 1978; IARC 1989
Chemical formula | NA^a^
Chemical structure^a^ | NA^a^
Identification numbers:
CAS Registry | 50815-00-4 | OHM/TADS 1985
NIOSH RTECS | NY9340000 | RTECS 1994a
EPA Hazardous Waste | No data
OHM/TADS | 7217071 | OHM/TADS 1985
DOT/UN/NA/IMCO Shipping | 1863 | CHRIS 1986
HSDB | No data
NCI | No data

a JP-4 is a mixed compound composed primarily of hydrocarbons (i.e., alkanes, cycloalkanes, alky-benzenes, indan/tetralins, and naphthalenes).

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; JP-4 = jet propellant-4; NA = Not Applicable; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Chemical Identity of JP-7^a^

Characteristic | Information | Reference
Chemical name | JP-7 | RTECS 1994b
Synonym(s) | Jet fuel-7 | RTECS 1994b
Registered trade name(s) | MIL-T-38219A-Amd. 2, kerosene, low volatility | IARC 1989
Chemical formula | NA^a^
Chemical structure^a^ | NA^a^
Identification numbers:
CAS Registry | No data
NIOSH RTECS | SE7548500 | RTECS 1994b
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO Shipping | No data
HSDB | No data
NCI | No data

a JP-7 is a mixed compound composed primarily of hydrocarbons (i.e., alkanes, cycloalkanes, alky-benzenes, indan/tetralins, and naphthalenes).

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; JP-7 = jet propellant-7; NA = Not Applicable; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-3 Physical and Chemical Properties of JP-4^a^

Property | Information | Reference
Molecular weight | Not applicable^b^
Color | Colorless to straw colored | CHRIS 1986; Martel 1992
Physical State | Liquid | CHRIS 1986
Melting point | −46 °C | OHM/TADS 1985
| −40–72 °C | ITC 1985
Boiling point (1 atm) | 50–270 °C | Air Force 1989b
| 90–300 °C | ITC 1985
| 45–280 °C | Dickson and Woodward 1987
Density:
at 15 °C | 751–802 kg/m^3^ (specification)
Odor | Like gasoline and/or kerosene
Odor threshold:
Water | No data
Air | 1 ppm | CHRIS 1986
Solubility:
Water at 20 °C | 57 mg/L | CRC 1984
Organic solvent(s) | Since many of the components are organic solvents, the fuel is generally miscible with organic solvents | ITC 1985
Partition coefficients:
Log K_ow_ | Major components range from 3 to 4.5 | ITC 1985
Log K_oc_ | No data
Vapor pressure at 20 °C | 91 mm Hg | Air Force 1989b
Henry’s law constant | 1.00×10^−4^–1.00×10^+1^ atm-m^3^/mol | Air Force 1989b
Autoignition temperature | 246 °C | CRC 1984
Flashpoint | −23–1 °C | NFPA 1986
Flammability limits | 1.3% lower; 8.0% upper | NFPA 1986
Explosive limits | No data

a JP-4, or jet propellant-4, is a mixed compound composed primarily of hydrocarbons (i.e., alkanes, cycloalkanes, alky-benzenes, indan/tetralins, and naphthalenes).

b Jet fuels are blends prepared to meet certain gross property specifications. Most characteristic data only reflect gross properties covered in the specifications. Proportions and values vary with the type of crude oil from which the final fuel is derived and the refining process used.

TABLE 3-4 Physical and Chemical Properties of JP-7^a^

Property | Information | Reference
Molecular weight | Not applicable^b^
Color | Colorless | Mattel 1992
Physical State | Liquid | CHRIS 1986
Melting point | −30 °C | ITC 1985
Boiling point (1 atm) | 182–288 °C (specification) | Air Force 1977; CRC 1984
| 205–300 °C | ITC 1985
| 150–200 °C | Dickson and Woodward 1987
Density:
at 15 °C | 779–806 kg/m^3^ (specification) | Air Force 1977; CRC 1984; Dukek 1978
Odor | Like kerosene | Martel 1992
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20 °C | 38.4 mg/L | CRC 1984
Organic solvent(s) | Generally miscible with organic solvents (e.g., benzene, Freon® 113, cyclohexane) | ASTM 1982; IARC 1989
Partition coefficients:
Log K_ow_ | No data
Log K_oc_ | No data
Vapor pressure;
at 149 °C | 1.55×10^2^ mm Hg | Air Force 1977
at 260 °C | 2.48×10^3^ mm Hg | Air Force 1977
Henry’s law constant | No data
Autoignition temperature | 241 °C | CRC 1984
Flashpoint | 43–66 °C | NFPA 1986
| 60 °C (specification) | Air Force 1977; CRC 1984
Flammability limits | 0.6% lower; 4.6% upper | Dukek 1978
Explosive limits | No data

a JP-7, or jet propellant-7, is a mixed compound composed primarily of hydrocarbons (i.e., alkanes, cycloalkanes, alky-benzenes, indan/tetralins, and naphthalenes).

b Jet fuels are blends prepared to meet certain gross property specifications. Most characteristic data only reflect gross properties covered in the specifications. Proportions and values vary with the type of crude oil from which the final fuel is derived and the refining process used.

TABLE 3-5 Composition (weight %) of Shale-Derived and Petroleum-Derived JP-4

Constituents | Shale-derived | Petroleum-derived
N-alkanes
Heptane | 4.73 | 15.76
Octane | 7.48 | 6.60
Nonane | 7.24 | 2.54
Decane | 11.25 | 2.24
Indane | 0.42 | 0.17
Undecane | 16.62 | 4.17
Dodecane | 11.49 | 5.25
Tridecane | 6.07 | 4.71
Tetradecane | 3.19 | 1.02
Pentadecane | 0.96 | 1.35
Total | 69.45 | 43.81
Monosubstituted alkanes
3-Methyl hexane | 3.05 | 14.39
2-Methyl heptane | 3.08 | 6.14
3-Methyl heptane | 1.64 | 7.19
Total | 7.77 | 27.72
Disubstituted alkane
2,3-Dimethyl pentane | — | —
2,5-Dimethyl pentane | 0.18 | 1.48
2,4-Dimethyl pentane | 0.63 | 2.52
Total | 0.81 | 4.00
Cyclohexanes
Cyclohexane | 1.52 | 2.13
Methyl cyclohexane | 5.68 | 2.17
Ethyl cyclohexane | — | —
Total | 7.20 | 4.30
Monosubstituted aromatics
Methyl benzene | 3.77 | 3.41
Disubstituted aromatics (xylenes)
m-Xylene | 2.60 | 2.71
p-Xylene | 1.70 | 1.63
o-Xylene | 2.00 | 1.89
Total | 6.30 | 6.23
Multisubstituted aromatics
1,3,5-Trimethylbenzene | 1.52 | 1.09
1,2,4-Trimethylbenzene | 2.00 | 3.52
1,2,3-Trimethylbenzene | 0.30 | 1.04
Total | 3.82 | 5.65
Overall total | 99.12 | 95.12

Source: Air Force 1988b

TABLE 3-6 U.S. Military Specifications for JP-4 Fuel

| Issuing agency:; Specification:; Revision date:; Grade designation:; Fuel type: | | USAF; MIL-T-5624-N; 22 March 1990; JP-4; Wide-cut | Test method; ASTM FTMS 791
Composition | Acidity, total (mg KOH/g) | Max. | 0.015 | D 3242
| Aromatics (vol%) | Max. | 25.0 | D 1319
| Olefins (vol%) | Max. | 5.0 | D 1319
| Sulfur, mercaptan (wt%) (1) | Max. | 0.00 | D 3227
| Sulfur, total (wt%) | Max. | 0.4 | D 1266/D 2622/D 3120
| Color, saybolt | Max. | Report | D 156
Volatility | Distlllation
| Temp. Init. BP (°C) | Max. | Report | D 86/D 2887
(D 2887 limits in parentheses) | Temp. 10% Rec (°C) | Max. | Report
| 20% Rec (°C) | Max. | 145 (130)
| 50% Rec (°C) | Max. | 190 (185)
| 90% Rec (°C) | Max. | 245 (250)
| Final BP (°C) | Max. | 270 (320)
| Residue (vol%) (for D 86) | Max. | 1.5
| Loss (vol%) (for D 86) | Max. | 1.5
| Explosiveness (%) | Max.
| Flash point (°C) | Max. | | D 93
| Gravity, °API (15 °C) | Max. | 45–57 | D 1298
| Density, 15 °C (kg/m^3^) | Max. | 751–802 | D 1298
| Vapor pressure (37.8 °C) kPa (psi) | | 14–21 (2.03–3.0) | D 323/D 2551
Fluidity | Freezing point, °C (F) | Max. | −58 (−72) | D 2336
| Viscosity @ −20 °C (cSt) | Max. | — | D 445
Combustion | Aniline-gravity product; or | Min. | 5250 | D 1405
| Net heat of comb., MJ/kg (Btu/lb) | Min. | 42.8 (18,400) | D 2382/D 3328/D 240
| Smoke point; or | Min. | 20.0 | D 1322
| Hydrogen content (wt%) | Min. | 13.5 | D 1018/D 3343/
| | | | D 3701
Corrosion | Copper strip (2 hr @ 100 °C) | Max. | 1 | D 130
Stability | JFTOT ΔP (mm Hg) | Max. | 25 | D 3241 (5)
| JFTOT tube color code | Max. | <3
Contaminants | Existent gum (mg/100 mL) | Max. | 7 | D 381
| Partlculates (mg/L) | Max. | 1 | D 2276 (2)
| Water reaction Interface | Max. | 1b | D 1094
| Water separation index modified | Min. | 70 (3) | D 2550
| Flitration time (minutes) | Max. | 10 | (2)
Additives | Anti-icing (vol%) | | 0.10–0.15 | 5330, 5340,
| Antioxidant | | Required (4) | 3527 FED STD 791
| Corrosion inhibitor | | Required
| Metal deactivator | | Option
| Antistatic | | Required
Other | Conductivity (pS/m) at <29.4 °C | | 150–600 | D 2624/D 4308
| Service | | All
| NATO code No. | | F-40

Notes: (1) The mercaptan sulfur determination may be waived if fuel “Doctor Sweet.”

(2) Minimum one-gallon sample. Filtration time in accordance with D 2276 particulate.

(3) With all additives except electrical conductivity additive.

(4) If hydrogen treated blend stocks used—optional if no hydrotreating used.

(5) Test at 260 °C tube temperature.

Source: Air Force 1990; CRC 1984.

TABLE 3-7 U.S. Military Specifications for JP-7 Fuel

| Issuing agency:; Specification:; Revision date:; Grade designaron:; Fuel type: | | USAF; MILT-38219A - Amd. 2; 26 January 1981; JP-7; Low volatility | Test method; ASTM
Composition | Acidity, total (mg KOH/g) | Max. | | D 3242
| Aromatics (vol%) | Max. | 5 | D 1319
| Olefins (vol%) | Max. | | D 1319
| Sulfur, mercaptan (wt%); or | Max. | 0.001 | D 3227
| Doctor test, N = negative | Max. | N | D 1266, D 2622 or D 3120
| Sulfur, total (wt%) | | 0.1
Volatility | Distillation
| Temp. Init. BP (°C) | | 182 min. | D 86 or D 2887
| 10% Rec (°C) | | 196 min.
| 20% Rec (°C) | | 206 min.
| 50% Rec (°C) | | Report
| 90% Rec (°C) | | 260 max.
| Final BP (°C) | | 288 max.
| Residue (vol%) | | 1.5 max. | D 86
| Loss (vol%) | | 1.5 max. | D 86
| Flash point (°C) | | 60 min. | D 56 or D 93
| Gravity, °API (15 °C) | | 44–50 | D 1298
| Density, 15 °C (kg/m^3^) | | 779–806 | D 1298
| Vapor pressure @ 149° (kPa) | Max. | 20.7 (1)
| Vapor pressure @ 260° (kPa) | Max. | 331 (1)
Fluidity | Freezlng point, (°C) | Max. | −43.5 | D 2386
| Viscosity @ −40 °C (cSt) | Max. | | D 445
| Viscosity @ −34.5 °C (cSt) | Max. | 15.0
Combustion | Net heat of comb., MJ/kg | Min. | 43.5 | D 240, D 2382, or D 3338
| Luminometer No. | Min. | 75(2) | D 1740
| Smoke point | Min. | | D 1322
| Hydrogen content (wt%) | Min. | (2) | D 3343
Corrosion | Copper strip (2hrs @ 100 °C) | Max. | 1b | D 130
Thermal stability | (JFTOT or coker)
| JFTOT TDR | Max. | 12 (3) | D 3241
| JFTOT (mm Hg pressure diff.) | Max. | 25 (3) | D 3241
| Coker, tube deposit | | <3 (4) | D 1660 (TS only)
| Coker (mm Hg pressure diff.) | Max. | 76 (4) | D 1660 (TS only)
Contaminants | Existent gum (mg/100 mL) | Max. | 5.0 | D 381
| Particulate matter (mg/L) | | | D 2776
| FOB origin deliveries | Max. | .3 | (5)
| FOB destination deliveries | Max. | .5
| WSIM | Min. | 85 | D 2550 or D 3948
Additives | JFA-5 (mg/L)
| Anti-icing (vol%) | | 0.10 to 0.15 | FTMS 791, 5327, or 5340
| Antioxidant | | Option
| Metal deactivator | | Option
| Lubricity (ppm) | | 200–250
Other | Thermal precipitaron rating | Max. | B-2 (6)

Notes: (1) Vapor pressure test in accordance with Appendix C, MIL-T-38219A.

(2) If luminometer No. between 70 and 75, fuel acceptable—If hydrogen content is not less than 14.4 wt% as calculated by ASTM D 3343.

(3) Test by D 3241—conditions as specified in MIL-T-38219A Amd. 2 and tube rating in Appendix D.

(4) Research fuel coker—conditions as specified in MIL-T-38219A Amd. 2

(5) Minimum sample size of 3.785 L (1 gal) shall be filtered.

(6) Test by Appendix B. MIL-T-38219A.

Source: CRC 1984.

TABLE 3-8 Typical Hydrocarbon Composition of JP-4 Fuel^a^

Compound | JP-4^b^
N-alkanes
Butane | 0.12
Pentane | 1.06
Hexane | 2.21
Heptane | 3.67
Octane | 3.80
Nonane | 2.25
Decane | 2.16
Undecane | 2.32
Dodecane | 2.00
Tridecane | 1.52
Tetradecane | 0.73
Pentadecane | —
Hexadecane | —
Heptadecane | —
Octadecane | —
Isoalkanes
Isobutane | 0.66
2,2-Dimethylbutane | 0.10
2-Methylpentane | 1.28
3-Methylpentane | 0.89
2,2-Dimethylpentane | 0.25
2-Methylhexane | 2.35
3-Methylhexane | 1.97
2,2,3,3-Tetramethylbutane | 0.24
2,5-Dimethylhexane | 0.37
2,4-Dimethylhexane | 0.58
3,3-Dimethylhexane | 0.26
2,2-Dimethylhexane | 0.71
2-Methylheptane | 2.70
4-Methylheptane | 0.92
3-Methylheptane | 3.04
2,5-Dimethylheptane | 0.52
2,4-Dimethylheptane | 0.43
4-Ethylheptane | 0.18
4-Methyloctane | 0.86
2-Methyloctane | 0.88
3-Methyloctane | 0.79
2-Methylundecane | 0.64
2,6-Dimethylundecane | 0.71
2,4,6-Trimethylheptane | —
4-Methyldecane | —
2-Methyldecane | —
2,6-Dimethyldecane | —
2-Methylundecane | —
2,6-Dimethylundecane | —
Cycloparaffins
Methylcyclopentane | 1.16
Cyclohexane | 1.24
t-1,3,-Dimethylcyclopentane | 0.36
c-1,3,-Dimethylcyclopentane | 0.34
c-1,2-Dimethylcyclopentane | 0.54
Methylcyclohexane | 2.27
Ethylcyclopentane | 0.26
1,2,4-T rimethylcyclopentane | 0.25
1,2,3-T rimethylcyclopentane | 0.25
c-1,3-Dimethylcyclohexane | 0.42
1-Methyl-3-ethylcyclohexane | 0.17
1-Methyl-2-ethylcyclohexane | 0.39
Dimethylcyclohexane | 0.43
1,3,5-T rimethylcyclohexane | 0.99
1,1,3-Trimethylcyclohexane | 0.48
1-Methyl-4-ethylcyclohexane | 0.48
n-Butylcyclohexane | 0.70
Propylcyclohexane | —
Hexylcyclohexane | —
Heptylcyclohexane | —
Aromatic hydrocarbons
Benzene | 0.50
Toluene | 1.33
Ethylbenzene | 0.37
m-Xylene | 0.96
p-Xylene | 0.35
o-Xylene | 1.01
Isopropylbenzene | 0.30
n-Propylbenzene | 0.71
1-Methyl-3-ethylbenzene | 0.49
1-Methyl-4-ethylbenzene | 0.43
1,3,5-Trimethylbenzene | 0.42
1-Methyl-2-ethylbenzene | 0.23
1,2,4-T rimethylbenzene | 1.01
1,3-Diethylbenzene | 0.46
1,4-Diethylbenzene | —
1-Methyl-4-propylbenzene | 0.40
1,3-Dimethyl-5-ethylbenzene | 0.61
1-Methyl-2-isopropylbenzene | 0.29
1,4-Dimethyl-2-ethylbenzene | 0.70
1,2-Dimethyl-4-ethylbenzene | 0.77
1,2,3,4-Titramethylbenzene | 0.75
1-Ethylpropylbenzene | —
1,2,4-T riethylbenzene | —
1,3,5-T riethylbenzene | —
Phenylcyclohexane | —
1-t-Butyl-3,4,5-trimethylbenzene | —
n-Heptylbenzene | —
Naphthalene | 0.50
2-Methylnaphthalene | 0.56
1-Methylnaphthalene | 0.78
2,6-Dimethylnaphthalene | 0.25
Biphenyl | —
1-Ethylnaphthalene | —
2,3-Dimethylnaphthalene | —
n-Octylbenzene | —

a Smith et al. 1981

b Concentrations in weight percent