# 9 REFERENCES

* Not cited in text

Abu-Ekteish F. 2002. Kerosene poisoning in children: A report from northern Jordan. Trop Doct 32(1):27–29.11991021
ACGIH. 2013. Kerosene/jet fuels (CASRN 8008–20-6). Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists. http://www.acgih.org/home.htm. January 08, 2014.
Acher AJ, Boderie P, Yaron B. 1989. Soil pollution by petroleum products: I. Multiphase migration of kerosene components in soil columns. J Contam Hydrol 4(4):333–345.
Adlercreutz H. 1995. Phytoestrogens: Epidemiology a nd a possible role in cancer protection. Environmental Health Perspectives Supplement 103(7):103–112.
Agarwal V, Gupta A. 1974. Accidental poisonings in children. Indian Pediatr 11(9):617–621.4443066
AIHA. 2013. Emergency response planning guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Pages/default.aspx. January 08, 2014.
Air Force. 1978a. Mutagen and oncogen study on JP-8. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command, AD-A064–948/3.
Air Force. 1978b. Toxic hazards research unit annual technical report: 1978. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. ADA062–138.
Air Force. 1981a. An industrial hygiene evaluation of aircraft refueling inside closed aircraft shelters. Report no. BEES(W)-81–03. APO, NY: U.S. Air Force Hospital Wiesbaden/SGP. ADA098708/1.
Air Force. 1981b. Atmospheric chemistry of hydrocarbon fuels. Volume I: Experiments, results, and discussion. Report no. ESL-TR-81–53. ADA115526.
Air Force. 1982a. Environmental fate and biological consequences of chemicals related to Air Force activities. Final technical report for period 1 August 1979 – 31 July 1982. Washington, DC: Air Force Office of Scientific Research. ADA121–28815.
Air Force. 1982b. High altitude jet fuel photochemistry. Report no. ESL-TR-82–38. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. ADA125035.
Air Force. 1985. Evaluation of the 90-day inhalation toxicity of petroleum and oil shale JP-5 jet fuel. Wright-Patterson Air Force Base, OH: Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. ADA156–815.
Air Force. 1987a. Cost savings possible with Air Force conversion to JP-8 as its primary fuel. Summary report for period January 1987 - April 1987. Wright-Patterson Air Force Base, OH: Aero Propulsion and Power Laboratory, Wright Research and Development Center, Air Force Systems Command. ADA183–784/8/XAB.
Air Force. 1987b. Military jet fuels, 1944–1987. Wright-Patterson AFB, OH: U.S. Air Force, Aero Propulsion Laboratory. ADA186752.
Air Force. 1988. Hydrocarbon fuel spill dispersion on water. Report no. ESL-TR-88–19. Tyndall Air Force Base, FL: Engineering and Services Laboratory, Air Force Engineering and Services Center. ADA201721.
Air Force. 1989a. Properties of F-34 (JP-8) fuel for 1988. Summary report for period January 1988 December 1988. Wright-Patterson Air Force Base, OH: Aero Propulsion and Power Laboratory, Wright Research and Development Center, Air Force Systems Command. ADA210188/9ixAB.
Air Force. 1989b. The installation restoration program toxicology g uide. Volume 4. Oak Ridge, TN: Biomedical and Environmental Information Analysis. ADA215002.
Air Force. 1991. Supercritical fluid fractionation of JP-8. Final report for period August 1990 - June 1991. Wright-Patterson Air Force Base, OH: Aero Propulsion and Power Directorate, Wright Research and Development Center, Air Force Systems Command. ADA247–835.
Air Force. 1994. The chronic effects of JP-8 jet fuel exposure on the lungs. Washington, DC: Life and Environmental Sciences Directorate, U.S. Air Force Office of Scientific Research. ADA280–982.
Air Force. 2001. JP-8 Final risk assessment. Brooks City-Base, TX: Air Force Institute for Occupational Health. IOH-RS-BR-SR-2005–003. .
Air Force. 2013. Jet fuel switch saves big bucks. U.S. Air Force, Tinker Air Force Base. http://www.tinker.af.mil/news/story.asp?id=123374189. August 10, 2014.
Aislabie J, McLeod M, Fraser R. 1998. Potential for biodegradation of hydrocarbons in soil from the Ross Dependency, Antarctica. Appl Microbiol Biotechnol 49(2):210–214.
Aislabie JM, Balks MR, Foght JM, 2004. Hydrocarbon spills on Antarctic soils: Effects and management. Environ Sci Technol 38(5):1265–1274.15046325
Akamaguna AI, Odita JC. 1983. Radiology of kerosene poisoning in young children. Ann Trop Paediatr 3(2):85–88.6197013
Alden CL. 1986. A review of unique male rat hydrocarbon nephropathy. Toxicol Pathol 14(1):109–111.2424069
Aldy D, Siregar R, Siregar H. 1978. Accidental poisoning in children with special reference to kerosene poisoning. Paediatr Indones 18(1–2):45–50.652367
Algren J, Rodgers G. 1992. Intravascular hemolysis associated with hydrocarbon poisoning. Pediatr Emerg Care 8(1):34–35.1603687
Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies of Experimental Biology, 1987–2008, 2041.
*Amitai I, Mogle P, Godfrey S, 1983. Pneumatocele in infants and children: Report of 12 cases. Clin Pediatr 22(6):420–422.
Andersen ME, Clewell HJ, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York, NY: Marcel Dekker, Inc., 9–25
Andrasko J. 1983. The collection and detection of accelerant vapors using porous polymers and Curie point pyrolysis wires coated with active carbon. J Forensic Sci 28(2):330–344.
Annobil SH. 1983. Chest radiographic patterns following kerosene poisoning in Ghanaian children. Clin Radiol 34(6):643–646.6673884
Annobil SH. 1988. Skin bullae following kerosene poisoning. Ann Trop Pediatr 8(1):45–47.
Annobil SH, Ogunbiyi OA. 1991. Pulmonary radiology changes in kerosene poisoning in the Asir region of Saudi Arabia. Ann Trop Paediatr 11(4):391–395.1721801
API. 1991. Basic petroleum data book: Petroleum industry statistics. Washington, DC: American Petroleum Institute 11(3):Section VII.
API. 2010b. Kerosene/jet fuel category assessment document. American Petroleum Institute. 201–16846As. http://www.epa.gov/hpv/pubs/summaries/kerjetfc/c15020ad2.pdf. August 10, 2014.
API. 2010a. Robust summary of information on kerosene/jet fuel. American Petroleum Institute. 201–16846B. http://www.epa.gov/hpv/pubs/summaries/kerjetfc/c15020rr2.pdf. August 10, 2014.
*Arif JM, Khan SG, Aslam M, 1991. Early biochemical changes in kerosene exposed rat lungs. Chemosphere 22(8):705–712.
Arif JM, Khan SG, Aslam M, 1992. Diminution in kerosene-mediated induction of drug metabolizing enzymes by asbestos in rat lungs. Pharmacol Toxicol 71(1):37–40.1326107
Army. 1988. A survey of JP-8 and JP-5 properties. Interim Report BFLRF No. 253. Fort Belvoir, VA: U.S. Army Belvoir research, Development and Engineering Center, Materials, Fuels, and Lubricants Laboratory. ADA-207–721.
Army. 1989. Potential benefits from the use of JP-8 fuel in military ground equipment. Fort Belvoir, VA: U.S. Army Belvoir research, Development and Engineering Center, Materials, Fuels, and Lubricants Laboratory. AD-A217–860/6/XAB.
Army. 2001. Female reproductive effects of exposure to jet fuel at U.S. Air Force bases. Fort Detrick, MD: U.S. Army Medical Research and Material Command.
Arthur M, O’Brien G, Marsh S, 1992. Evaluation of innovative approaches to simulate degradation of jet fuels in subsoils and groundwater. Battelle Columbus Labs, OH 92:35.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 1995. Toxicological profile for polycyclic aromatic hydrocarbons. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp.asp?id=122&tid=25. January 9, 2014.
ATSDR. 1999. Toxicological profile for total petroleum hydrocarbons (TPH). Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/ToxProfiles/tp123.pdf. October 13, 2015.
ATSDR. 2005. Toxicological profile for naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/ToxProfiles/tp67.pdf. October 13, 2015.
ATSDR. 2007a. Toxicological profile for benzene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp.asp?id=40&tid=14. January 9, 2014.
ATSDR. 2007b. Toxicological profile for xylene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp.asp?id=296&tid=53. January 9, 2014.
ATSDR. 2010. Toxicological profile for ethylbenzene. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/ToxProfiles/tp110.pdf. October 13, 2015.
ATSDR. 2015a. JP-5, JP-8 and Jet A. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. November 15, 2016.
ATSDR. 2015b. Toxicological profile for toluene (Draft for Public Comment). Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp56.pdf. October 13, 2015.
Azizi BHO, Henry RL. 1990. Effects of indoor air pollution on lung function of primary school children in Kuala Lumpur. Pediatr Pulmonol 9(1):24–29.2388776
Azizi BHO, Henry RL. 1991. The effects of indoor environmental factors on respiratory illness in primary school children in Kuala Lumpur. Int J Epidemiol 20(1):144–150.2066213
Baker W, English J, Dodd D, 1999. Repeated dose skin irritation study on jet fuels - preliminary dose range finding study. Wright-Patterson, AFB, OH: Air Force Research Laboratory. AFRL-HE-WP-TR-1999–0008.
*Baldachin BJ, Malmed PM. 1964. Clinical and therapeutic aspects of kerosene poisoning: A series of 200 cases. Br Med J 2:28–30.14147771
Baldwin RE. 1977. Adsorption-elution technique for concentration of hydrocarbon vapors. Arson Anal News 11(6):9–12.
Baldwin CM, Figueredo AJ, Wright LS, 2007. Repeated aerosol-vapor JP-8 jet fuel exposure affects neurobehavior and neurotransmitter levels in a rat model. J Toxicol Environ Health A 70(14):1203–1213.17573634
Baldwin CM, Houston FP, Podgornik MN, 2001. Effects of aerosol-vapor JP-8 jet fuel on the functional observational battery, and learning and memory in the rat. Arch Environ Health 56(3):216–226.11480497
Balme KH, Roberts JC, Glasstone M, 2012. The changing trends of childhood poisoning at a tertiary children’s hospital in South Africa. S Afr Med J 102(3 Pt 1):142–146.22380907
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barrientos A, Ortuno MT, Morales JM, 1977. Acute renal failure after use of diesel fuel as shampoo. Arch Intern Med 137:12–17.
Bartha R, Atlas RM. 1977. The microbiology of aquatic oil spills. Adv Appl Microbiol 22:225–226.337769
Baynes RE, Brooks JD, Budsaba K, 2001. Mixture effects of JP-8 additives on the dermal disposition of jet fuel components. Toxicol Appl Pharmacol 175(3):269–281.11559026
*Behera D, Jindel SK. 1991. Respiratory symptoms in Indian women using domestic cooking fuels. Chest 100(2):355–358.
Belkin F, Esposito GG. 1986. Dynamic thermal stripping procedure for the analysis of jet fuel no. 2 and kerosene in water. J Chromatogr Sci 24:216–219.
Bell IR, Brooks AJ, Baldwin CM, 2005. JP-8 Jet fuel exposure and divided attention test performance in 1991 Gulf War veterans. Aviation, space, and environmental medicine 76(12):1136–1144.16385767
Benois A, Petitjeans F, Raynaud L, 2009. Clinical and therapeutic aspects of childhood kerosene poisoning in Djibouti. Trop Doct 39(4):236–238.19762580
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
B’Hymer C, Keil DE, Cheever KL. 2005. A test procedure for the determination of (2-methoxyethoxy)acetic acid in urine from jet fuel-exposed mice. Toxicol Mech Methods 15(5):367–373.20021058
B’Hymer C, Krieg E, Cheever KL, 2012a. Evaluation and comparison of urinary metabolic biomarkers of exposure for the jet fuel JP-8. J Toxicol Environ Health A 75(11):661–672.22712851
B’Hymer C, Mathias P, Krieg E, 2012b. (2-Methoxyethoxy)acetic acid: A urinary biomarker of exposure for jet fuel JP-8. Int Arch Occup Environ Health 85(4):413–420.21809101
Bianchi AP, Vamey MS, Phillips J. 1991. Analysis of industrial solvent mixtures in water using a miniature purge-and-trap device with thermal desorption and capillary gas chromatography-mass spectrometry. J Chromatogr 557(1–2):429–439.
Biles R, McKee R, Lewis S, 1988. Dermal carcinogenic activity of petroleum-derived middle distillate fuels. Toxicology 53:301–314.3212789
Blackburn GR, Deitch RA, Schreiner CA, 1986. Predicting carcinogenicity of petroleum distillation fractions using a modified Salmonella mutagenicity assay. Cell Biol Toxicol 2:63–84.3267446
Blakeslee JR, Elliot AM, Carter LJ. 1983. In vitro effects of polynuclear aromatic hydrocarbons on FeSV transformation of human cells. In: Cooke M, Dennis AJ, eds. Proceedings of the Seventh International Symposium on polynuclear aromatic hydrocarbons: Formation, metabolism, and measurement. Columbus, OH: Battelle Press, 123–133.
Bogo V, Young RW, Hill TA, 1983. The toxicity of petroleum and shale JP-5. Proceedings of the 1st toxicology of petroleum hydrocarbons symposium, Armed Forces Radiobiology Institute, Bethesda, MD, 46–66.
Boulares AH, Contreras FJ, Espinoza LA, 2002. Roles of oxidative stress and glutathione depletion in JP-8 jet fuel-induced apoptosis in rat lung epithelial cells. Toxicol Appl Pharmacol 180(2):92–99.11969376
Boylan DB, Tripp BW. 1971. Determination of hydrocarbons in seawater extracts of crude oil and crude oil fractions. Nature 230(5288):44–47.4930964
*Breglia R, Bui Q, Burnett D, 2014. A 13-week dermal repeat-dose neurotoxicity study of hydrodesulfurized kerosene in rats. Int J Toxicol 33 (Suppl 1):68S-77S.24351872
Brown J, Burke B, Dajani AS. 1974. Experimental kerosene pneumonia: Evaluation of some therapeutic regimens. J Pediatr 84(3):396–401.4149566
Bruner RH. 1984. Pathologic findings in laboratory animals exposed to hydrocarbon fuels of military interest. In: Mehlman MA, Hemstreet GP, Thorpe JJ, , eds. Advances in modem environmental toxicology. Volume VII: Renal effects of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, 133–140.
*Buch N, Ahmed K, Sethi A. 1991. Poisoning in children. Indian Pediatr 28(5):521–524.1752680
Buckley EN, Jonas RB, Pfaender FK. 1976. Characterization of microbial isolates from an estuarine ecosystem: Relationship of hydrocarbon utilization to ambient hydrocarbon concentrations. Appl Environ Microbiol 32(2):232–237.788639
Bunin GR, Buckley JD, Boesel CP, 1994. Risk factors for astrocytic glioma and primitive neuroectodermal tumor of the brain in young children: A report from the children’s cancer group. Cancer Epidemiol Biomarkers Prev 3:197–204.8019366
Butt AI, Riazuddin S, Shakoori AR, 1988. Isolation and identification of petroleum hydrocarbon degrading bacteria from the local environments. Pak J Zool 29(4):391–399.
Campbell JL, Fisher JW. 2007. A PBPK modeling assessment of the competitive metabolic interactions of JP-8 vapor with two constituents, m-xylene and ethylbenzene. Inhal Toxicol 19(3):265–273.17365029
Carpenter CP, Geary DL, Myers RC, 1976. Petroleum hydrocarbon toxicity studies: XI. Animal and human response to vapors of deodorized kerosene. Toxicol Appl Pharmacol 36(3):443–456.941146
Carpenter CP, Kinkead ER, Geary DL Jr, 1975. Petroleum hydrocarbon toxicity studies: I. Methodology. Toxicol Appl Pharmacol 32:246–262.1154392
Casaco A, Garcia M, Gonzalez R, 1985a. Induction of acetylcholinesterase inhibition in the guinea pig trachea by kerosene. Respiration 48(1):46–49.4023437
Casaco A, Gonzalez R, Arruzazabala L, 1982. Studies on the effects of kerosine aerosol on airways of rabbits. Allergol Immunopathol 10(5):361–366.
Casaco A, Gonzalez R, Arruzazabala L, 1985b. Kerosene aerosol induces guinea pig airway hyperreactivity to acetylcholine. Respiration 47(3):190–195.4001575
Chan WC, Colbourne MJ, Fung SC, 1979. Bronchial cancer in Hong Kong 1976–1977. Br J Cancer 39(2):182–192.435367
Chang D, Lopez I. 1992. Determination of kerosene and #2 diesel in soil by purge and trap vs. extraction procedure. J Soil Contam 1(3):239.
Chao YC, Gibson RL, Nylander-French LA. 2005. Dermal exposure to jet fuel (JP-8) in US Air Force personnel. Ann Occup Hyg 49(7):639–645.16006502
Chao YC, Kupper LL, Serdar B, 2006. Dermal exposure to jet fuel JP-8 significantly contributes to the production of urinary naphthols in fuel-cell maintenance workers. Environ Health Perspect 114(2):182–185.16451852
Chao YC, Nylander-French LA. 2004. Determination of keratin protein in a tape-stripped skin sample from jet fuel exposed skin. Ann Occup Hyg 48(1):65–73.14718347
Chatterjee A, Babu RJ, Klausner M, 2006. In vitro and in vivo comparison of dermal irritancy of jet fuel exposure using EpiDerm (EPI-200) cultured human skin and hairless rats. Toxicol Lett 167(2):85–94.17049765
Chen H, Witten ML, Pfaff JK, 1992. JP-8 jet fuel exposure increases alveolar epithelial permeability in rats [Abstract]. FASEB J 6(4):A1064.
Chevron. 2006. Aviation fuels technical review. Chevron Corporation. https://www.cgabusinessdesk.com/document/aviation_tech_review.pdf. August 10, 2014.
Chun LT. 1998. Accidental poisoning in children with special reference to kerosene poisoning. 1951. Hawaii Med J 57(3):433–436.9581046
Clark C, Walter M, Ferguson P, 1988. Comparative dermal carcinogenesis of shale and petroleum derived distillates. Toxicol Ind Health 4:11–22.3388444
*Clark CR, Ferguson PW, Katchen MA, 1989. Comparative acute toxicity of shale and petroleum derived distillates. Toxicol Ind Health 5(6):1005–1017.2626753
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Coast Guard. 1985. Chemical Hazard Response Information System (CHRIS): Hazard assessment handbook. Washington, DC: U.S. Department of Transportation, U.S. Coast Guard. Commandant Instruction M.16465.12A.
Coleman WE, Melton RG, Slater RW, 1981. Determination of organic contaminants by the Grob closed-loop-stripping technique. J Am Water Works Assoc 71:119–125.
Coleman WE, Munch JW, Streicher RP, 1984. The identification and measurement of components in gasoline, kerosene, and No. 2 jet fuel that partition into the aqueous phase after mixing. Arch Environ Contam Toxicol 13:171–178.
Commonwealth of Virginia. 1988. Commonwealth of Virginia State Water Control Board Regulations, Richmond, VA: Commonwealth of Virginia State Water Control Board Regulations, Water Quality Standards.
Conaway CC, Schreiner CA, Cragg ST. 1984. Mutagenicity evaluation of petroleum hydrocarbons. In: MacFarland HN, Holdsworth CE, MacGregor JA, , eds. Advances in modern toxicology. Volume VI: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, 89–107.
Connell DW, Miller GJ. 1980. Petroleum hydrocarbons in aquatic ecosystems: Behavior and effects of sublethal concentrations: Part 1. Crit Rev Environ Control 11(1):37–104.
Cooney JJ, Silver SA, Beck EA. 1985. Factors influencing hydrocarbon degradation in three freshwater lakes. Microbiol Ecol 11(2):127–137.
*Cooper J, Mattie D. 1993. Developmental toxicity of JP-8 jet fuel in the rat. Toxicologist 13(1):78.
Cooper JR, Mattie DR. 1996. Developmental toxicity of JP-8 jet fuel in the rat. J Appl Toxicol 16(3):197–200.8818858
Cooper RE, Hedrick HG. 1976. Activity of soil bacteria on petroleum waste adjacent to an active oil well. Soil Sci 122(6):331–338.
Coruh M, Inal H. 1966. Kerosene poisoning in children with special reference to lung complication. Turk J Pediatr 8(1):36–42.5915005
Costa LG, Aschner M, Vitalone A, 2004. Developmental neuropathology of environmental agents. Annu Rev Pharmacol Toxicol 44:87–110.14744240
Cowan MJ, Jenkins LJ. 1981. Navy toxicity study of shale and petroleum JP-5 aviation fuel and diesel fuel marine. In: Griest WH, Guerin MR, Coffin DL, eds. Health effects investigation of oil shale development. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 129–139.
*Cowan MJ, Jenkins LJ, Lawrence JF. 1981. The toxicity of grade JP-5 aviation turbine fuel: A comparison between petroleum and shale-derived fuels. In: Toxic hazards in aviation. Conference proceedings of the Advisory Group for Aerospace Research and Development, 1981. B2/1-B2/7.
Crawford DW, Bonnevie NL, Wenning RJ. 1995. Sources of pollution and sediment contamination in Newark Bay, New Jersey. Ecotoxicol Environ Saf 30:85–100.7540541
Cundell AM, Traxler RW. 1976. Psychrophilic hydrocarbon-degrading bacteria from Narragansett Bay, Rhode Island, U.S.A. Material Organismen 11(l):l-17.
Custance SR, McCaw PA, Kopf AC, 1992. Environmental fate of the chemical mixtures: Crude oil, JP-5, mineral spirits, and diesel fuel. J Soil Contam 1(4):379–386.
Danielson LL, Gentner WA. 1970. Effect of solvent composition on inactivation of several phenyl and thio carbamate herbicides in soil. Proceedings of the Northeastern Weed Control Conference 24:308–312.
*Das PS, Sharan P, Saxena S. 1992. Kerosene abuse by inhalation and ingestion [letter to the editor]. Am J Psych 149:710a-710.
Dean-Ross D, Mayfield H, Spain J. 1992. Environmental fate and effects of jet fuel JP-8. Chemosphere 24(2):219–228.
Deichmann WB, Kitzmiller KV, Withemp BS, 1944. Kerosene intoxication. Ann Intern Med 21:803–823.
Dell’Acqua R, Bush B. 1973. Microdetermination of gasoline in potable waters by gas chromatography. Int J Environ Anal Chem 3:141–146.4793347
D’Este C, Attia JR, Brown AM, 2008. Cancer incidence and mortality in aircraft maintenance workers. Am J Ind Med 51(1):16–23.18033721
Dibble JT, Bartha R. 1979. Rehabilitation of oil-inundated agricultural land: A case history. Soil Sci 128(1):56–60.
Dice WH, Ward G, Kelley J, 1982. Pulmonary toxicity following gastrointestinal ingestion of kerosene. Ann Emerg Med 11:138–142.7065488
DOD. 1992. Military specification: Turbine fuel, aviation, grades JP-4, JP-5, and JP-5/JP-8 ST. U.S. Department of Defense. Document no. MIL-T-5624P.
DOD. 2013. Detail specification: Turbine fuel, aviation, kerosene type, JP-8 (NATO F-34), NATO F-35, and JP-8+100 (NATO F-37). U.S. Department of Defense. Document no. MIL-DTL-83133H.
DOE. 2012. Protective action criteria (PAC). Oak Ridge, TN: U.S. Department of Energy and Subcommittee on Consequence Assessment and Protective Actions (SCAPA). http://orise.orau.gov/emi/scapa/chem-pacs-teels/default.htm. January 08, 2014.
Dow RL, Hurst JW, Mayo DW, 1975. The ecological, chemical and histopathological evaluation of an oil spill site. Marine Pollut Bull 6:164–173.
Drake MG, Witzmann FA, Hyde J, 2003. JP-8 jet fuel exposure alters protein expression in the lung. Toxicology 191(2–3):199–210.12965123
Dudin AA, Rambaud-Cousson A, Thalji A, 1991. Accidental kerosene ingestion: A three-year prospective study. Ann Trop Paediatr 11(2):155–161.1715147
Dudley AC, Peden-Adams MM, EuDaly J, 2001. An aryl hydrocarbon receptor independent mechanism of JP-8 jet fuel immunotoxicity in Ah-responsive and Ah-nonresponsive mice. Toxicol Sci 59(2):251–259.11158718
Dukek WG, Winans DR, Ogston A R. 1969. Milestones in aviation fuels. Astrodynamics Conference. American Institute of Aeronautics and Astronautics. Guidance, navigation, and control and co-located conferences. AIAA Aircraft Design and Operations Meeting July 14–16, 1969, Los Angeles, CA AIAA Paper 69–779.
Easley JR, Holland JM, Gipson LC, 1982. Renal toxicity of middle distillates of shale oil and petroleum in mice. Toxicol Appl Pharmacol 65:84–91.7147259
Edgerton SA, Coutant RW, Henley MV. 1987. Hydrocarbon fuel spill dispersion on water: A literature review. Chemosphere 16(7):1475–1487.
Edwards T. 2003. Liquid fuels and propellants for aerospace propulsion, 1903–2003. Journal of Propulsion and Power 19(6):1089–1107.
Egeghy PP, Hauf-Cabalo L, Gibson R, 2003. Benzene and naphthalene in air and breath as indicators of exposure to jet fuel. Occup Environ Med 60:969–976.14634191
EIA. 2013a. Weekly imports and exports. Petroleum and other liquids. Kerosene-type jet fuel. U.S. Energy Information Administration. http://www.eia.gov/dnav/pet/pet_move_wkly_dc_NUS-Z00_mbblpd_w.htm. December 18, 2013.
EIA. 2013b. Petroleum and other liquids. Exports. Kerosene-type jet fuel. U.S. Energy Information Administration. http://www.eia.gov/dnav/pet/pet_move_exp_dc_NUS-Z00_mbbl_m.htm. December 18, 2013.
EIA. 2013c. Annual energy outlook 2013 with projection to 2040. Washington, DC: U.S. Energy Information Administration, U.S. Department of Energy, Office of Integrated and International Energy Analysis. DOE/EIA-0383. http://www.eia.gov/forecasts/archive/aeo13/pdf/0383(2013).pdf. January 17, 2014.
EIA. 2014a. Production-kerosene-type jet, military. Weekly inputs, utilization & production. U.S. Energy I nformation Administration. August 5, 2014.
EIA. 2014b. Weekly U.S. imports of kerosene-type jet fuel. U.S. Energy Information Administration. http://www.eia.gov/dnav/pet/hist/LeafHandler.ashx?n=PET&s=WKJIMUS2&f=W. August 5, 2014.
EIA. 2014c. U.S. exports of kerosene-type jet fuel (thousand barrels). Petroleum & other liquids. U.S. Energy Information Administration. http://www.eia.gov/dnav/pet/hist/LeafHandler.ashx?n=PET&s=MKJEXUS1&f=M. August 5, 2014.
Ek CJ, Dziegielewska KM, Habgood MD, 2012. Barriers in the developing brain and neurotoxicology. Neurotoxicology 33(3):586–604.22198708
Elliot MG, DePaoli DW. 1990. In situ venting of jet-fuel contaminated soil. Proceedings of the Industrial Waste Conference 44:1–9.
EPA. 1982. Control of air pollution from aircraft and aircraft engines. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 87.
EPA. 1983. Degradation of jet fuel hydrocarbons by aquatic microbial communities. Gulf Breeze, FL: U.S. Environmental Protection Agency, Office of Research and Development. EPA600/X-83–059.
EPA. 1984. Permeability of compacted soils to solvents mixtures and petroleum products. In: Proceedings of the tenth annual research symposium for land disposal of hazardous waste, Ft. Mitchell, Kentucky, April 3–5, 1984. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Municipal Environmental Research Laboratory, 124–137.
EPA. 1986. Quality criteria for water. Washington, DC: U.S. Environmental Protection Agency. EPA 440/5–86-001.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development. EPA600890066A. PB90238890.
EPA. 1991a. Alpha _2u_-globulin: Association with chemically induced renal toxicity and neoplastia in the male rat. Washington, DC: U.S. Environmental Protection Agency. EPA625391019F.
EPA. 1991b. Method 602 - Purgeable aromatics; Method 610 - Polynuclear aromatic hydrocarbons; Method 625 - Base/neutrals and acids. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136, Appendix A.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. EPA600890066F. Research Triangle Park, NC. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=71993. August 14, 2014.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency Office of Pollution Prevention and Toxics. EPA630R96012.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
EPA. 2006. Method 8260C. Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS). Test methods for evaluating solid waste, physical/chemical methods. U.S. Environmental Protection Agency. http://www.epa.gov/osw/hazard/testmethods/pdfs/8260c.pdf. January 17, 2014.
EPA. 2009a. Drinking water contaminant candidate list. U.S. Environmental Protection Agency. Fed Regist 74 FR 51850:51850–51862. http://www.gpo.gov/fdsys. January 08, 201 4.
EPA. 2009b. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. EPA816F090004. http://water.epa.gov/drink/contaminants/. January 08, 2014
EPA. 2010. Kerosene (petroleum). Non-confidential 2006 IUR records by chemical, including manufacturing, processing and use information. U.S. Environmental Protection Agency. http://cfpub.epa.gov/iursearch/. January 19, 2014.
EPA. 2012a. Chemical Data Reporting. U.S. Environmental Protection Agency. http://epa.gov/cdr/. January 20, 2014.
EPA. 2012b. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. http://water.epa.gov/drink/standards/hascience.cfm. January 08, 2014.
EPA. 2013a. Toxic Substances Control Act. Chemical lists and reporting periods. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 712.30. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013b. Toxic Substances Control Act. Health and safety data reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 716.120. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013c. Acute exposure guideline levels (AEGLs). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/. January 08, 2014.
EPA. 2013d. Designated as hazardous substances in accordance with section 311(b)(2)(a) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013e. Identification and listing of hazardous waste. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 261, Appendix VIII. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013f. Reportable quantities of hazardous substances designated pursuant to section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013g. Standards for owners and operators of hazardous waste TSD facilities. Groundwater monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 264, Appendix IX. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013h. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013i. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 355, Appendix A. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013j. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2014a. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. January 08, 2014.
EPA. 2014b. Inert ingredients permitted for use in nonfood pesticide products. Washington, DC: U.S. Environmental Protection Agency. http://iaspub.epa.gov/apex/pesticides/f?p=124:1. January 08, 2014.
EPA. 2014c. Master testing list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/chemtest/pubs/mtl.html. January 08, 2014.
EPA. 2014d. National Ambient Air Quality Standards (NAAQS). Washington, DC: Office of Air and Radiation, U.S. Environmental Protection Agency. http://www.epa.gov/air/criteria.html. January 08, 2014.
EPA. 2014e. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. January 08, 2014.
Erdem O, Sayal A, Eken A, 2012. Evaluation of genotoxic and oxidative effects in workers exposed to jet propulsion fuel. Int Arch Occup Environ Health 85(4):353–361.21755367
Espinoza LA, Smulson ME, Chen Z. 2007. Prolonged poly(ADP-ribose) polymerase-1 activity regulates JP-8-induced sustained cytokine expression in alveolar macrophages. Free Radic Biol Med 42(9):1430–1440.17395016
Espinoza LA, Tenzin F, Cecchi AO, 2006. Expression of JP-8-induced inflammatory genes in AEII cells is mediated by NF-κB and PARP-1. Am J Respir Cell Mol Biol 35(4):479–487.16690985
ExxonMobil. 2005. World jet fuel specifications with Avgas supplement. 2005 edition. ExxonMobil Aviation. http://www.exxonmobil.com/AviationGlobal/Files/WorldJetFuelSpecifications2005.pdf. August 10, 2014.
FAA. 2009. Technical report. Near-term feasibility of alternative jet fuels. Arlington, VA: Federal Aviation Administration. Rand Corporation and Massachusetts Institute of Technology. http://web.mit.edu/aeroastro/partner/reports/proj17/altfuelfeasrpt.pdf. August 12, 2014.
*Fagbule D, Joiner K. 1992. Kerosene poisoning in childhood: A 6-year prospective study at the University of Ilorin Teaching Hospital. West Afr J Med 11(2):116–121.1390371
FDA. 2014. Everything Added to Food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. January 08, 2014.
Fechter LD, Fisher JW, Chapman GD, 2012. Subchronic JP-8 jet fuel exposure enhances vulnerability to noise-induced hearing loss in rats. J Toxicol Environ Health A 75(5):299–317.22409492
Fechter LD, Gearhart C, Fulton S, 2007. JP-8 jet fuel can promote auditory impairment resulting from subsequent noise exposure in rats. Toxicol Sci 98(2):510–525.17483120
Fechter LD, Gearhart CA, Fulton S. 2010. Ototoxic potential of JP-8 and a Fischer-Tropsch synthetic jet fuel following subacute inhalation exposure in rats. Toxicol Sci 116(1):239–248.20378580
Flamm WG, Lehman-McKeeman LD. 1991. The human relevance of the renal tumor-inducing potential of d-limonene in male rats: Implications for risk assessment. Regul Toxicol Pharmacol 13:70–86.2024047
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Frankenberger WT. 1988. Use of urea as a nitrogen fertilizer in bioreclamation of petroleum hydrocarbons in soil. Bull Environ Contam Toxicol 40(1):66–68.2830930
Frankenberger WT, Johanson JB. 1982. Influence of crude oil and refined petroleum products on soil dehydrogenase activity. J Environ Qual 11(4):602–607.
Freeman J, Federici T, McKee R. 1993. Evaluation of the contribution of chronic skin irritation and selected compositional parameter to the tumorigenicity of petroleum middle distillates in mouse skin. Toxicology 38:103–112.
Freeman JJ, McKee RH, Phillips RD, 1990. A 90-day toxicity study of the effects of petroleum middle distillates on the skin of C3H mice. Toxicol Ind Health 6:475–491.2237931
Galin T, Gerstl Z, Yaron B. 1990. Soil pollution by petroleum products: III. Kerosene stability in soil columns as affected by volatilization. J Contam Hydrol 5(4):375–385.
Gallucci RM, O’Dell SK, Rabe D, 2004. JP-8 jet fuel exposure induces inflammatory cytokines in rat skin. Int Immunopharmacol 4(9):1159–1169.15251112
Garcia M, Gonzalez R. 1985. Uncoupling of the calcium pump of the sarcoplasmic reticulum by kerosene. Toxicol Lett 28(1):59–64.4060196
Garcia M, Casaco A, Arruzazabala L, 1988a. Role of chemical mediators in bronchoconstriction induced by kerosene. Allergol Immunopathol 16(6):421–423.
Garcia M, Gonzalez R, Casaco A. 1988b. Biochemical mechanisms in the effects of kerosene on airways of experimental animals. Allergol Immunopathol 16(5):363–367.
Gaworski CL, MacEwen JD, Vernot EH, 1984. Comparison of the subchronic inhalation toxicity of petroleum and oil shale JP-5 jet fuels. In: MacFarland HN, Holdsworth CE, MacGregor JA, , eds. Advances in modern environmental toxicology. Volume VI: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, 33–47.
Gaworski CL, MacEwen JD, Vernot EH, 1985. Evaluation of 90-day inhalation toxicity of petroleum and oil shale JP-5 jet fuel. Wright-Patterson Air Force Base, OH: U.S. Navy. ADA156815.
*Gerarde HW. 1959. Toxicological studies on hydrocarbons: V. Kerosene. Toxicol Appl Pharmacol 1:462–474.13827408
Gerarde HW. 1963. Toxicological studies on hydrocarbons: IX. The aspiration hazard and toxicity of hydrocarbons and hydrocarbon mixtures. Arch Environ Health 6:329–341.13947290
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Supp 2):65–71.7902273
Goodwin SR, Berman LS, Tabeling BB, 1988. Kerosene aspiration: Immediate and early pulmonary and cardiovascular effects. Vet Human Toxicol 30(6):521–524.
Grant GM, Jackman SM, Kolanko C J, 2001. JP-8 jet fuel-induced DNA damage in H4IIE rat hepatoma cells. Mutat Res 490(1):67–75.11152973
*Green DO. 1977. Intravenous energine: A case report. Clin Toxicol 10(3):283–286.862361
Gregg SD, Fisher JW, Bartlett MG. 2006. A review of analytical methods for the identification and quantification of hydrocarbons found in Jet Propellant 8 and related petroleum based fuels. Biomed Chromatogr 20(6–7):492–507.16779790
Guiney PD, Sykora JL, Keleti G. 1987a. Environmental impact of an aviation kerosene spill on stream water quality in Cambria County, Pennsylvania. Environ Toxicol Chem 6(12):977–988.
Guiney PD, Sykora JL, Keleti G. 1987b. Qualitative and quantitative analyses of petroleum hydrocarbon concentrations in a trout stream contaminated by an aviation kerosene spill. Environ Toxicol Chem 6:105–114.
Gummin DD. 2015. Hydrocarbons. In: Hoffman RS, Howland MA, Lewin NA, , eds. Goldfrank’s toxicologic emergencies. 10th ed. New York, NY: McGraw Hill Education, 1334–1345.
Gupta S, Govil YC, Misra PK, 1998. Trends in poisoning in children: Experience at a large referral teaching hospital. Natl Med J India 11(4):166–168.9808971
Guthrie OW, Wong BA, McInturf SM, 2015. Inhalation of hydrocarbon jet fuel suppress central auditory nervous system function. J Toxicol Environ Health A 78(18):1154–1169. 10.1080/15287394.2015.1070389.26408153
Guthrie OW, Xu H, Wong BA, 2014. Exposure to low levels of jet-propulsion fuel impairs brainstem encoding of stimulus intensity. J Toxicol Environ Health A 77:261–280.24588226
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Hadaller OJ, Johnson JM. 2006. World fuel sampling program. Jet fuel and alternative fuels meetings Dayton, OH; meeting materials; resource materials; composition data. Coordinating Research Council, Inc.; American Petroleum Institute. CRC Report No. 647. http://mycommittees.api.org/rasa/jfm/default.aspx. August 11, 2014.
Hanas JS, Bruce Briggs G, Lerner MR, 2010. Systemic molecular and cellular changes induced in rats upon inhalation of JP-8 petroleum fuel vapor. Toxicol Mech Methods 20(4):204–212.20233090
Hansen J. 1999. Cleanup plan for fuel spills at air operations ramp, Diego Garcia, British Indian Ocean Territory. Brooks City-Base, TX: Air Force Center for Environmental Excellence.
Hara K, Kageura M, Hieda Y, 1988. Application of wide-bore capillary gas chromatography to analyze volatile compounds in body fluids. Jpn J Legal Med 42(2):142–146.
Hard GC, Rogers IS, Baetcke KP, 1993. Hazard evaluation of chemicals that cause accumulation of α2u-globulin, hyaline droplet nephropathy, and tubule neoplasia in the kidneys of male rats. Environ Health Perspect 99:313–349.7686485
Harris DT, Sakiestewa D, He X, 2007b. Effects of in utero JP-8 jet fuel exposure on the immune systems of pregnant and newborn mice. Toxicol Ind Health 23(9):545–552.18681240
Harris DT, Sakiestewa D, Robledo RF, 1997a. Immunotoxicological effects of JP-8 jet fuel exposure. Toxicol Ind Health 13(1):43–55.9098949
Harris DT, Sakiestewa D, Robledo RF, 1997b. Protection from JP-8 jet fuel induced immunotoxicity by administration of aerosolized substance P. Toxicol Ind Health 13(5):571–588.9284531
Harris DT, Sakiestewa D, Robledo RF, 1997c. Short-term exposure to JP-8 jet fuel results in long-term immunotoxicity. Toxicol Ind Health 13(5):559–570.9284530
Harris DT, Sakiestewa D, Robledo RF, 2000a. Effects of short-term JP-8 jet fuel exposure on cell-mediated immunity. Toxicol Ind Health 16(2):78–84.10798625
Harris DT, Sakiestewa D, Titone D, 2000b. Jet fuel-induced immunotoxicity. Toxicol Ind Health 16(7–8):261–265.11693943
Harris DT, Sakiestewa D, Titone D, 2000c. Substance P as prophylaxis for JP-8 jet fuel-induced immunotoxicity. Toxicol Ind Health 16(7–8):253–259.11693942
Harris DT, Sakiestewa D, Titone D, 2002. JP-8 jet fuel exposure results in immediate immunotoxicity, which is cumulative over time. Toxicol Ind Health 18(2):77–83.12868796
Harris DT, Sakiestewa D, Titone D, 2007c. JP-8 jet fuel exposure potentiates tumor development in two experimental model systems. Toxicol Ind Health 23(10):617–623.18717520
Harris DT, Sakiestewa D, Titone D, 2007a. JP-8 jet fuel exposure rapidly induces high levels of IL-10 and PGE2 secretion and is correlated with loss of immune function. Toxicol Ind Health 23(4):223–230.18429382
Harris DT, Sakiestewa D, Titone D, 2008. JP-8 jet fuel exposure suppresses the immune response to viral infections. Toxicol Ind Health 24(4):209–216.19022873
Hays AM, Lantz RC, Witten ML. 2003. Correlation between in vivo and in vitro pulmonary responses to jet propulsion fuel-8 using precision-cut lung slices and a dynamic organ culture system. Toxicol Pathol 31(2):200–207.12696580
Hays AM, Parliman G, Pfaff JK, 1995. Changes in lung permeability correlate with lung histology in a chronic exposure model. Toxicol Ind Health 11(3):325–336.7482572
Herrin BR, Haley JE, Lantz RC, 2006. A reevaluation of the threshold exposure level of inhaled JP-8 in mice. J Toxicol Sci 31(3):219–228.16960432
Hettiarachchi J, Kodithuwakku GCS. 1989. Pattern of poisoning in rural Sri Lanka. Int J Epidemiol 18(2):418–422.2767856
Hilgaertner JW, He X, Camacho D, 2011. The influence of hydrocarbon composition and exposure conditions on jet fuel-induced immunotoxicity. Toxicol Ind Health 27(10):887–898.21402657
*Hirota Y, Tadeshita S, Kataoka K, 1992. Individual and environmental characteristics related to influenza-like illness among children: A school-based case-control study. Nippon Eiseigaku Zasshi 47(2):587–599.1513053
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
HSDB. 2012. Kerosene. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology I nformation Program. January 8, 2014.
Hurley JM, Wagner D, Sterner TR, 2011. Acute dermal irritation study of JP-8 and S-8 in New Zealand White rabbits. Wright-Patterson AFB, OH: U.S. Air Force Research Laboratory, WIL Research Laboratories LLC. AFRL-RH-WP-TR-2011–0054.
IARC. 1989. IARC monographs on the evaluation of carcinogenic risks to humans. Vol. 45: Occupational exposures in petroleum refining: Crude oil and major petroleum fuels. Lyon, France: World Health Organization, International Agency for Research on Cancer.
IARC. 2013. Agents classified by the IARC monographs. Volumes 1–109. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. January 08, 2014.
Ingram A, King D, Grasso P, 1993. The early changes in mouse skin following topical application of a range of middle distillate oil products. J Appl Toxicol 13(4):247–257.8376725
IRIS. 2015. Integrated Risk I nformation System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/. January 21, 2015.
Jackman SM, Grant GM, Kolanko CJ, 2002. DNA damage assessment by comet assay of human lymphocytes exposed to jet propulsion fuels. Environ Mol Mutagen 40(1):18–23.12211072
Jacobziner H, Raybin HW. 1963. Accidental chemical poisonings: Kerosene and other petroleum distillate poisonings. NY State J Med 63:3428–3430.
*Jaeger RW, DeCastro F, Blair J, 1978. The brain in hydrocarbon intoxication. Vet Hum Toxicol 20(2):103.
Jee SH, Wang JD, Sun CC, 1985. Prevalence of probable kerosene dermatoses among ball-bearing factory workers. Scand J Work Environ Health 12(1):61–65.
*JG. 1977. The long term effects of kerosine pollution on the microflora of a moorland soil. J Appl Bacteriol 43(1):123–128.
Kabbur MB, Rogers JV, Gunasekar PG, 2001. Effect of JP-8 jet fuel on molecular and histological parameters related to acute skin irritation. Toxicol Appl Pharmacol 175(1):83–88.11509030
Kang-Sickel JC, Butler MA, Frame L, 2011. The utility of naphthyl-keratin adducts as biomarkers for jet-fuel exposure. Biomarkers 16(7):590–599.21961652
Kanikkannan N, Burton S, Patel R, 2001. Percutaneous permeation and skin irritation of JP-8+100 jet fuel in a porcine model. Toxicol Lett 119(2):133–142.11311575
Kanikkannan N, Jackson T, Sudhan Shaik M, 2000. Evaluation of skin sensitization potential of jet fuels by murine local lymph node assay. Toxicol Lett 116(1–2):165–170.10906434
Kanikkannan N, Locke BR, Singh M. 2002. Effect of jet fuels on the skin morphology and irritation in hairless rats. Toxicology 175(1–3):35–47.12049834
Karthikeyan R, Davis LC, Mankin KR, 1999. Biodegradation of jet fuel (JP-8) in the presence of vegetation. In: Proceedings of the 1999 Conference on Hazardous Waste Research, 243–256.
Kearns GL, Abdel-Rahman SM, Alander SW, 2003. Developmental pharmacology--drug disposition, action, and therapy in infants and children. N Engl J Med 349(12):1157–1167.13679531
Keil D, Dudley A, EuDaly J, 2004. Immunological and hematological effects observed in B6C3F1 mice exposed to JP-8 jet fuel for 14 days. J Toxicol Environ Health A 67(14):1109–1129.15205027
Keil DE, Warren DA, Jenny MJ, 2003. Immunological function in mice exposed to JP-8 jet fuel in utero. Toxicol Sci 76(2):347–356.14514957
Kim D, Andersen ME, Chao YC, 2007. PBTK modeling demonstrates contribution of dermal and inhalation exposure components to end-exhaled breath concentrations of naphthalene. Environ Health Perspect 115(6):894–901.17589597
Kim D, Andersen ME, Nylander-French LA. 2006a. Dermal absorption and penetration of jet fuel components in humans. Toxicol Lett 165(1):11–21.16497449
Kim D, Andersen ME, Nylander-French LA. 2006b. A dermatotoxicokinetic model of human exposures to jet fuel. Toxicol Sci 93(1):22–33.16801332
Kim D, Farthing MW, Miller CT, 2008. Mathematical description of the uptake of hydrocarbons in jet fuel into the stratum corneum of human volunteers. Toxicol Lett 178(3):146–151.18423910
Kimura K, Nagata T, Hara K, 1988. Gasoline and kerosene components in blood: A forensic analysis. Hum Toxicol 7(4):299–305.3410478
Kimura K, Nagata T, Kudo K, 1991. Determination of kerosene and light oil components in blood. Biol Mass Spectrom 20(8):493–497.1768706
Klein SA, Jenkins D. 1983. The toxicity of jet fuels to fish-II: The toxicity of JP-8 to flagfish and rainbow-trout and golden shiners. Water Res 17(10): 1213–1220.
Knave B, Olson BA, Elofson S, 1978. Long term exposure to jet fuel: II. A cross-sectional epidemiologic investigation on occupationally exposed industrial workers with special reference to the nervous system. Scand J Work Environ Health 4: 19–45.644265
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Krieg EF, Mathias PI, Toennis CA, 2012. Detection of DNA damage in workers exposed to JP-8 jet fuel. Mutat Res 747(2):218–227.22617435
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Lang T, Thuo N, Akech S. 2008. Accidental paraffin poisoning in Kenyan children. Trop Med Int Health 13(6):845–847.18363584
Larabee JL, Hocker JR, Lerner MR, 2005. Stress induced in heart and other tissues by rat dermal exposure to JP-8 fuel. Cell Biol Toxicol 21(5–6):233–246.16323059
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
+*Lesnik R, Kligman L, Kligman A. 1992. Agents that cause enlargement of sebaceous glands in hairless mice. Arch Dermatol Res 284(2):100–105.1610208
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
*Lillienberg L, Hogstedt B, Jarvholm B, 1992. Health effects at tank cleaners. Am Ind Hygiene Assoc 53(6):375–380.
Limón-Flores AY, Chacon-Salinas R, Ramos G, 2009. Mast cells mediate the immune suppression induced by dermal exposure to JP-8 jet fuel. Toxicol Sci 112(1):144–152.19726579
*R, Nilsson B, Eklund G, 1991. Acute leukemia in professional drivers exposed to gasoline and diesel. Eur J Haematol 47(2):98–103.1889488
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Lucas GN. 1994. Kerosene oil poisoning in children: A hospital-based prospective study in Sri Lanka. Indian J Pediatr 61:683–687.7721373
Lupulescu AP, Birmingham DJ. 1975. Effect of lipid solvents on protein, DNA, and collagen synthesis in human skin: An electron microscopic autoradiographic study. J Invest Dermatol 65(5):419–422.1194707
Lupulescu AP, Birmingham DJ. 1976. Effect of protective agent against lipid-solvent-induced damages: Ultrastructural and scanning electron microscopial study of human epidermis. Arch Environ Health 31(1):33–36.128331
Lupulescu AP, Birmingham DJ, Pinkus H. 1973. An electron microscopic study of human epidermis after acetone and kerosene administration. J Invest Dermatol 60(1):33–45.4684159
*MacNaughton MG, Uddin DE. 1984. Toxicology of mixed distillate and high-energy synthetic fuels. Adv Mod Environ Toxicol 7:121–132.
Mahdi AH. 1988. Kerosene poisoning in children in Riyadh. J Trop Pediatr 34(6):316–318.3221417
Majeed HA, Bassyouni H, Kalaawy M, 1981. Kerosene poisoning in children: A clinico-radiological study of 205 cases. Ann Trop Pediatr 1(2):123–130.
Maltoni C, Ciliberti A, Pinto C, 1997. Results of long-term experimental carcinogenicity studies of the effects of gasoline, correlated fuels, and major gasoline aromatics on rats. Ann NY Acad Sci 837:15–52.9472329
Mann CM, Peachee VL, Trimmer GW, 2008. Immunotoxicity evaluation of Jet A jet fuel in female rats after 28-day dermal exposure. J Toxicol Environ Health A 71(8):495–504.18338284
Mann MD, Pirie DJ, Wolfsdorf J. 1977. Kerosene absorption in primates. J Pediatr 91(3):495–498.408472
Martin SA, Campbell JL, Tremblay RT, 2012. Development of a physiologically based pharmacokinetic model for inhalation of jet fuels in the rat. Inhal Toxicol 24(1):1–26.
Mattie DR. 2013. Memorandum for Division of Toxicology and Human Health Sciences Agency for Toxic Substances and Disease Registry. Comments for the update to the ATSDR Toxicological profile for JP-5 and JP-8 occurring in FY-14. Wright-Patterson Air Force Base, OH: Department of the Air Force.
Mattie DR, Alden CL, Newell TK, 1991. A 90-day continuous vapor inhalation toxicity study of JP-8 jet fuel followed by 20 or 21 months of recovery in Fischer 244 rats and C57BL/6 mice. Toxicol Pathol 19(2):77–87.1771370
Mattie DR, Merit GB, Cooper JR, 2000. Reproductive effects of JP-8 jet fuel on male and female Sprague-Dawley rats after exposure by oral gavage. Wright-Patterson AFB, OH: Air Force Research Laboratory. AFRL-HE-WP-TR-2000–0067. http://www.dtic.mil/dtic/tr/fulltext/u2/a453146.pdf. January 20, 2014.
Mattie DR, Cooper JR, Sterner TR, 2001. Developmental neurobehavioral effects on JP-8 jet fuel on pups from female Sprague-Dawley rats exposed by oral gavage. Wright-Patterson, AFB: OH: Air Force Research Laboratory. 22. ARFL-HE-WP-TR-2001–0186. ADA428272.
Mattie DR, Mat-it GB, Flemming CD, 1995. The effects of JP-8 jet fuel on male Sprague-Dawley rats after a 90-day exposure by oral gavage. Toxicol Ind Health 11(4):423–435.8748423
Mattorano DA, Kupper LL, Nylander-French LA. 2004. Estimating dermal exposure to jet fuel (naphthalene) using adhesive tape strip samples. Ann Occup Hyg 48(2):139–146.14990435
Maule AL, Heaton KJ, Rodrigues E, 2013. Postural sway and exposure to jet propulsion fuel 8 among US Air Force personnel. J Occup Environ Med 55(4):446–453.23532195
Maule AL, Proctor SP, Blount BC, 2016. Volatile organic compounds in blood as biomarkers of exposure to JP-8 jet fuel among US Air Force personnel. J Occup Environ Med 58(1):24–29. 10.1097/jom.0000000000000611.26716845
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
McDougal JN, Robinson PJ. 2002. Assessment of dermal absorption and penetration of components of a fuel mixture (JP-8). Sci Total Environ 288(1–2):23–30.12013544
McDougal JN, Garrett CM, Amato CM, 2007. Effects of brief cutaneous JP-8 jet fuel exposures on time course of gene expression in the epidermis. Toxicol Sci 95(2):495–510.17085751
McDougal JN, Pollard DL, Weisman W, 2000. Assessment of skin absorption and penetration of JP-8 jet fuel and its components. Toxicol Sci 55(2):247–255.10828255
McGuire S, Bostad E, Smith L, 2000. Increased immunoreactivity of glutathione-S-transferase in the retina of Swiss Webster mice following inhalation of JP8+100 aerosol. Arch Toxicol 74:276–280.10959803
McKee RH, Amoruso MA, Freeman JJ, 1994. Evaluation of the genetic toxicity of middle distillate fuels. Environ Mol Mutagen 23(3):234–238.8162898
Mehm WJ, Feser CL. 1984. Biological analysis of progressive toxicity of shale-derived vs. petroleum derived fuels in rats. In: Cowser K, ed. Synthetic fossil fuel technologies. Boston, MA: Butterworth, 491–503.
Merchant-Borna K, Rodrigues EG, Smith KW, 2012. Characterization of inhalation exposure to jet fuel among U.S. Air Force personnel. Ann Occup Hyg 56(6):736–745.22433121
Merrill EA. 1998. TPH criteria working group field demonstration: Harrier jet crash site, Fairborn, OH. Wright-Patterson AFB, OH: Air Force Research Laboratory. AFRL-HE-TR-1999–0026. www.dtic.mil/dtic/tr/fulltext/u2/a451771.pdf. January 19, 2015.
Midkiff CR Jr, Washington WD. 1972. Gas chromatographic determination of traces of accelerants in physical evidence. J Assoc Off Anal Chem 55(4):840–845.
*Mishad MM. 1969. Kerosene poisoning. Ain Shams Med J 20(2)125–128.
Monteiro-Riviere N, Inman A, Riviere J. 2001. Effects of short-term high-dose and low-dose dermal exposure to Jet A, JP-8 and JP-8+100 jet fuels. J Appl Toxicol 21(6):485–494.11746196
Monteiro-Riviere NA, Inman AO, Riviere JE. 2004. Skin toxicity of jet fuels: Ultrastructural studies and the effects of substance P. Toxicol Appl Pharmacol 195(3):339–347.15020196
Morrison I, Sprague P. 1976. Kerosene pneumonia: Its incidence in Perth and case history of a recent fatality. Australas Radiol 20(2):118–121.1021119
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
Mosconi G, Migliori M, Greco V, 1988. Kerosene “burns”: A new case. Contact Dermatitis 19(4):314–315.3219847
Muhammad F, Monteiro-Riviere NA, Baynes RE, 2005b. Effect of in vivo jet fuel exposure on subsequent in vitro dermal absorption of individual aromatic and aliphatic hydrocarbon fuel constituents. J Toxicol Environ Health A 68(9):719–737.16020199
Muhammad F, Monteiro-Riviere NA, Riviere JE. 2005a. Comparative in vivo toxicity of topical JP-8 jet fuel and its individual hydrocarbon components: Identification of tridecane and tetradecane as key constituents responsible for dermal irritation. Toxicol Pathol 33(2):258–266.15902969
Muralidhara Krishnakumari MK, Ramesh HP, 1982. Toxicity of some petroleum fractions used in pesticidal emulsions to albino rats. J Food Sci Technol 19(6):260–262.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
Navy. 1988. Biodegradation of JP-5 aviation fuel by subsurface microbial communities for the period January 1, 1987 to March 15, 1987. Port Hueneme, CA: Naval Civil Engineering Laboratory. AD-Al 92–743/3KAB.
Nessel CS, Freeman JJ, Forgash RC, 1999. The role of dermal irritation in the skin tumor promoting activity of petroleum middle distillates. Toxicol Sci 49:48–55.10367341
Nessel CS, Priston RA, McKee RH, 1998. A comprehensive evaluation of the mechanism of skin tumorigenesis by straight-run and cracked petroleum middle distillates. Toxicol Sci 44(1):22–31.9720137
NIOSH. 1989. Industrial hygiene survey report of defense fuel support point. Cincinnati, OH: Centers for Disease Control, National Institute of Occupational Safety and Health, Division of Surveillance, Hazard Evaluations, and Field Studies.
NIOSH. 1994. Manual of analytical methods. 4th ed. Eller PM, ed. Cincinnati, OH: National Institute for Occupational Safety and Health. Publication no. 94–113, Method 1550.
NIOSH. 2014. Kerosene (CASRN 8008–20-6). NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. January 08, 2014.
Noa M, Illnait J. 1987a. Changes in the aorta of guinea pigs exposed to kerosene. Acta Morphologica Hungarica 35(1–2):59–69.2449038
Noa M, Illnait J. 1987b. Induction of aortic plaques in guinea pigs by exposure to kerosene. Arch Environ Health 42:31–36.3566348
*Noa M, Sanabria J. 1984. Tracheal ultrastructure in kerosene treated guinea pigs: A preliminary report. Allergol Immunopathol 12(1):33–36.
*Noa M, Illnait J, Gonzalez R. 1985. Cytologic and biochemical changes in pulmonary washings of guinea pigs exposed to kerosene. Allergol Immunopathol 13(3):193–196.
Nouri L, Al-Rahim K. 1970. Kerosene poisoning in children. Postgrad Med J 46(532):71–75.5416507
Nouri L, Sordelli DO, Cerquetti MC, 1983. Pulmonary clearance of Staphylococcus areus and plasma angiotensin-converting enzyme activity in hydrocarbon pneumonitis. Pediatr Res 17(8):657–661.6310474
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press. PB93216091.
NRC. 2003. Toxicologic assessment of Jet-Propulsion Fuel 8. Washington, DC: National Research Council. National Academy Press. http://www.nap.edu/catalog/10578.html. August 14, 2014.
NTP. 2011. Report on carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. January 08, 2014.
NTP/NIH. 1986. National toxicology program technical report series no. 310: Toxicology and carcinogenesis studies of marine diesel fuel and JP-5 navy fuel in B6C3Fl mice (dermal studies). Research Triangle Park, NC: National Toxicology Program/National Institutes of Health. NIH Publication No. 86–2566.
*Nussinsovitch M, Amir J, Arsano I. 1992. Chemical pneumonia and dermatitis caused by kerosene. Clinical Pediatrics 31(9):574.1468179
OHM/TADS. 1985. Oil and Hazardous Materials/Technical Assistance Data System. Baltimore, MD: Chemical Information Systems, Inc. December, 1985.
Olson MJ, Johnson JT, Reidy CA. 1990. A comparison of male rat and human urinary proteins: Implications for human resistance to hyaline droplet nephropathy. Toxicol Appl Pharmacol 102:524–536.1690459
OSHA. 2013a. List of highly hazardous chemicals, toxics, and reactives. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.119, Appendix A. http://www.osha.gov/law-regs.html. January 08, 2014.
OSHA. 2013b. Toxic and hazardous substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.1000, Table Z-1. http://www.osha.gov/law-regs.html. January 08, 2014.
Oviatt C, Frithsen J, Gearing J, 1982. Low chronic additions of No. 2 jet fuel: Chemical behavior, biological impact and recovery in a simulated estuarine environment. Mar Ecol Prog Ser 9:121–136.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Papini RPG. 1991. ‘Is all that’s blistered burned?’… a case of kerosene contact burns. Burns 17:415–416.1760114
Parent ME, Hua Y, Siemiatycki J. 2000. Occupational risk factors for renal cell carcinoma in Montreal. Am J Ind Med 38:609–618.11071683
Parker GA, Bogo V, Young RW. 1981. Acute toxicity of conventional versus shale-derived JP-5 jet fuel: Light microscopic, hematologic, and serum chemistry studies. Toxicol Appl Pharmacol 57(3):302–317.7222045
Pearson CD. 1988. Determination of phenolic antioxidants in JP-5 jet fuels by gas chromatography-mass selective detection. J Chromatogr 449:440–447.
Peden-Adams MM, Eudaly J, Eudaly E, 2001. Evaluation of immunotoxicity induced by single or concurrent exposure to N,N-diethyl-m-toluamide (DEET), pyridostigmine bromide (PYR), and JP-8 jet fuel. Toxicol Ind Health 17(5–10):192–209.12539864
Pfaff J, Parton K, Lantz RC, 1995. Inhalation exposure to JP-8 jet fuel alters pulmonary function and substance P levels in Fischer 344 rats. J Appl Toxicol 15(4):249–256.7594192
Pfaff JK, Tollinger BJ, Lantz RC, 1996. Neutral endopeptidase (NEP) and its role in pathological pulmonary change with inhalation exposure to JP-8 jet fuel. Toxicol Ind Health 12(1):93–103.8713717
Pharr D, McKenzie J, Hickman A. 1992. Fingerprinting petroleum contamination using synchronous scanning fluorescence spectroscopy. Ground Water 30(4):484–489.
Pleil JD, Smith LB, Zelnick SD. 2000. Personal exposure to JP-8 jet fuel vapors and exhaust at air force bases. Environ Health Perspect 108(3):183–192.10706522
Porter HO. 1990. Aviators intoxicated by inhalation of JP-5 fuel vapors. Aviat Space Environ Med 61(7):654–656.2386453
Potter TL, Simmons KE. 1998. Composition of petroleum mixtures. Volume 2. Amherst, MA: Amherst Scientific Publishers, 37–41, 46–51.
Proctor SP, Heaton KJ, Smith KW, 2011. The Occupational JP8 Exposure Neuroepidemiology Study (OJENES): Repeated workday exposure and central nervous system functioning among US Air Force personnel. Neurotoxicology 32(6):799–808.21824494
Puhala E, Lemasters G, Smith L, 1997. Jet fuel exposure in the United States Air Force. Appl Occup Environ Hyg 12(9):606–610.
*Rai UC, Singh TSK. 1980. Cardio-pulmonary changes in mongrel dogs after exposure to kerosene smoke. Indian J Exp Biol 18(11):1263–1266.7216284
Ramos G, Kazimi N, Nghiem DX, 2004. Platelet activating factor receptor binding plays a critical role in jet fuel-induced immune suppression. Toxicol Appl Pharmacol 195(3):331–338.15020195
Ramos G, Limon-Flores AY, Ullrich SE. 2007. Dermal exposure to jet fuel suppresses delayed-type hypersensitivity: A critical role for aromatic hydrocarbons. Toxicol Sci 100(2):415–422.17890764
Ramos G, Limon-Flores AY, Ullrich SE. 2009. JP-8 induces immune suppression via a reactive oxygen species NF-κβ-dependent mechanism. Toxicol Sci 108(1):100–109.19095747
Ramos G, Nghiem DX, Walterscheid JP, 2002. Dermal application of jet fuel suppresses secondary immune reactions. Toxicol Appl Pharmacol 180(2):136–144.11969381
*Rao GS, Pandya KP. 1980. Hepatic metabolism of heme in rats after exposure to benzene, gasoline, and kerosene. Arch Toxicol 46(3–4):313–317.6894534
Reed DA, Sterner TR. 2002. Total petroleum hydrocarbon criteria working group (TPHCWG) Field Demonstration Report: Air Force Plant Number 6 Fuel Farm Dobbins AFB, Georgia. Wright-Patterson AFB, OH: Air Force Research Laboratory. AFRL-HE-WP-TR-2002–0158.
RePORTER. 2014. Jet fuels. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. January 8, 2014.
Reutman SR, LeMasters GK, Knecht EA, 2002. Evidence of reproductive endocrine effects in women with occupational fuel and solvent exposures. Environ Health Perspect 110:805–811.12153763
Rhodes AG, LeMasters GK, Lockey JE, 2003. The effects of jet fuel on immune cells of fuel system maintenance workers. J Occup Environ Med 45(1):79–86.12553182
Ritchie GD, Rossi J, Nordholm AF, 2001. Effects of repeated exposure to JP-8 jet fuel vapor on learning of simple and difficult operant tasks by rats. J Toxicol Environ Health A 64(5):385–415.11700005
Ritchie G, Still K, Rossi J, 2003. Biological and health effects of exposure to kerosene-based jet fuels and performance additives. J Toxicol Environ Health B Crit Rev 6(4):357–451. ADA560252. http://www.dtic.mil/get-tr-doc/pdf?AD=ADA560252. January 19, 2014.12775519
Riviere JE, Brooks JD, Monteiro-Riviere NA, 1999. Dermal absorption and distribution of topically dosed jet fuels jet-A, JP-8, and JP-8(100). Toxicol Appl Pharmacol 160(1):60–75.10502503
Robb TM, Rogers MJ, Woodward SS, 2010. In vitro time- and dose-effect response of JP-8 and S-8 jet fuel on alveolar type II epithelial cells of rats. Toxicol Ind Health 26(6):367–374.20504826
Robledo RF, Witten ML. 1998. Acute pulmonary response to inhaled JP-8 jet fuel aerosol in mice. Inhal Toxicol 10:531–553.
Robledo RF, Witten ML. 1999. NK1-receptor activation prevents hydrocarbon-induced lung injury in mice. Am J Physiol 276(2 Pt 1):L229–L238.9950884
Robledo RF, Young RS, Lantz RC, 2000. Short-term pulmonary response to inhaled JP-8 jet fuel aerosol in mice. Toxicol Pathol 28(5):656–663.11026600
Rossi J, Nordholm AF, Carpenter RL, 2001. Effects of repeated exposure of rats to JP-5 or JP-8 jet fuel vapor on neurobehavioral capacity and neurotransmitter levels. J Toxicol Environ Health A 63(6):397–428.11482797
*Roudabush RL, Terhaar CJ, Fassett DW, 1965. Comparative acute effects of some chemicals on the skin of rabbits and guinea pigs. Toxicol Appl Pharmacol 7(4):559–565.5839391
Rowe LD, Dollahite JW, Camp BJ. 1973. Toxicity of two crude oils and of kerosine to cattle. J Am Vet Med Assoc 162(1):61–66.4683544
RTECS. 1998. Registry of Toxic Effects of Chemical Substances. Washington, DC: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
Runion HE. 1988. Occupational exposures to potentially hazardous agents in the petroleum industry. Occupational Medicine: State of the Art Reviews 3(3):431–444.
Saksena PN. 1969. Kerosene oil poisoning in children. J Indian Med Assoc 52(4):169–171.5771208
Salthouse R. 1992. Making clean gasoline: The effect on jet fuels. Bethesda, MD: Logistics Management Inst.
Santhanakrishnan BR, Chithra S. 1978. Accidental kerosene poisoning in infants and children. Indian J Pediatr 45(367):265–273.730290
*Sarker AK, Ghosh S, Barik K. 1990. A study of accidental poisoning (in children) in a rural medical college hospital of West Bengal. Indian J Public Health 34(3):159–162.2103925
Saunders NR, Ek CJ, Habgood MD, 2008. Barriers in the brain: A renaissance? Trends Neurosci 31(6):279–286.18471905
Saunders NR, Liddelow SA, Dziegielewska KM. 2012. Barrier mechanisms in the developing brain. Front Pharmacol 3(10.3389/fphar.2012.00046):Article 46.
*Scharf SM, Prinsloo I. 1982. Pulmonary mechanics in dogs given different doses of kerosene intratracheally. Am Rev Respir Dis 126(4):695–700.7125363
*Scharf SM, Heimer D, Goldstein J. 1981. Pathologic and physiologic effects of aspiration of hydrocarbons in the rat. Am Rev Respir Dis 124(5):625–629.7305118
Scherr P, Hutchinson G, Neiman R. 1992. Non-Hodgkin’s lymphoma and occupational exposure. Cancer Res 52(19):5503–5509.
Scheuplein R, Charnley G, Dourson M. 2002. Differential sensitivity of children and adults to chemical toxicity. I. Biological basis. Regul Toxicol Pharmacol 35(3):429–447.12202057
Schultz TW, Epler JL, Witschi H, 1981. Health effects research in oil shale development. Oak Ridge National Laboratory report no. ORNL/TM-8034. Oak Ridge, TN: Oak Ridge National Laboratory.
Seldén A, Ahlborg G Jr. 1991. Mortality and cancer morbidity after exposure to military aircraft fuel. Aviat Space Environ Med 62:789–794.1930063
Sengupta R, Fondekar S, Alagarsamy R. 1993. State of oil pollution in the Northern Arabian Sea after the 1991 Gulf oil spill. Marine Pollut Bull 27:85–91.
Serdar B, Egeghy PP, Gibson R, 2004. Dose-dependent production of urinary naphthols among workers exposed to jet fuel (JP-8). Am J Ind Med 46(3):234–244.15307122
Serdar B, Egeghy PP, Waidyanatha S, 2003. Urinary biomarkers of exposure to jet fuel (JP-8). Environ Health Perspect 111(14):1760–1764.14594628
Shannon MW, Borron SW, Burns MJ, eds. 2007. Haddad and Winchester’s clinical management of poisoning and drug overdose. 4^th^ ed. Philadelphia, PA: WB Saunders Company, 1343–1346.
Shotar AM. 2005. Kerosene poisoning in childhood: A 6-year prospective study at the Princess Rahmat Teaching Hospital. Neuro Endocrinol Lett 26(6):835–838.16380681
Siemiatycki J, Dewar R, Nadon L, 1987. Associations between several sites of cancer and twelve petroleum-derived liquids. Scand J Work Environ Health 13:493–504.3433051
Simmank K, Wagstaff L, Sullivan K, 1998. Prediction of illness severity and outcome of children symptomatic following kerosene ingestion. Ann Trop Paediatr 18(4):309–314.9924587
Singh S, Singh J. 2001. Dermal toxicity: Effect of jet propellant-8 fuel exposure on the biophysical, macroscopic and microscopic properties of porcine skin. Environ Toxicol Pharmacol 10(3):123–131.21782567
Singh S, Singh J. 2004. Dermal toxicity and microscopic alterations by JP-8 jet fuel components in vivo in rabbit. Environ Toxicol Pharmacol 16(3):153–161.21782702
Singh S, Narang A, Walia BN, 1981. Accidental poisoning in children: Ten years experience. Indian Pediatr 18(3):163–166.7263018
Singh S, Zhao K, Singh J. 2003. In vivo percutaneous absorption, skin barrier perturbation, and irritation from JP-8 jet fuel components. Drug Chem Toxicol 26(2):135–146.12816398
Skisak C. 1991. The role of chronic acanthosis and subacute inflammation in tumor promotion in CD-l mice by petroleum middle distillates. Toxicol Appl Pharmacol 109(3):399–411.1906644
*Skyberg K, Ronneberg A, Kamoy JI, 1986. Pulmonary fibrosis in cable plant workers exposed to mist and vapor of petroleum distillates. Environ Res 40(2):261–273.3732201
Smith KW, Proctor SP, Ozonoff AL, 2012. Urinary biomarkers of occupational jet fuel exposure among Air Force personnel. J Expo Sci Environ Epidemiol 22(1):35–45.22044926
Smith LB, Bhattacharya A, Lemasters G, 1997. Effect of chronic low-level exposure to jet fuel on postural balance of US Air Force personnel. J Occup Environ Med 39(7): 623–632.9253723
Smith PB, Veley KE, Yarrington JT, 1999. 90-Day oral gavage toxicity study of C_9_-C_16_ aromatic fraction of Jet-A in female Sprague-Dawley CD rats and male C57BL/6 mice. Columbus, OH: Battelle. G003493B. ADA425287.
Soczo ER, Staps JJM. 1988. Review of biological soil treatment techniques in the Netherlands. In: Wolf K, van den Brink WJ, Colon FJ, eds. Contaminated soil ‘88: Second International Netherlands Organization for Applied Scientific Research/Federal Ministry of Research and Technology Conference, Hamburg, West Germany, April 11–15, 1988. Boston, MA: Kluwer Academic Publishers, 663–670.
John St MA. 1982. Kerosene poisoning in children in Barbados. Ann Trop Paediatr 2(1):37–40.6186189
Starek A, Vojtisek M. 1986. Effects of kerosene hydrocarbons on tissue metabolism in rats. Pol J Pharmacol Pharm 38(5–6):461–469.3575166
Steele RW, Conklin RH, Mark HM. 1972. Corticosteroids and antibiotics for the treatment of fulminant hydrocarbon aspiration. JAMA 219(11):1434–1437.5066898
Sterner TR, Hurley JM, Mattie DR. 2014. Acute dermal irritation study of ten jet fuels in New Zealand White rabbits: Comparison of synthetic and bio-based jet fuels with petroleum JP-8. Air Force Research Lab., Wright-Patterson AFB, OH. Human Performance Wing (711th)/Human Effectiveness Directorate. AFRL-RH-WP-TR-2014–0045.
Stoica BA, Boulares AH, Rosenthal DS, 2001. Mechanisms of JP-8 jet fuel toxicity. I. Induction of apoptosis in rat lung epithelial cells. Toxicol Appl Pharmacol 171(2):94–106.11222085
Struwe G, Knave B, Mindus P. 1983. Neuropsychiatric symptoms in workers occupationally exposed to jet fuel - a combined epidemiological and casuistic study. Acta Psychiatr Scand 67(Suppl 303):55–67.
Subcommittee on Accidental Poisoning. 1962. Co-operative kerosene poisoning study: Evaluation of gastric lavage and other factors in the treatment of accidental ingestion of petroleum distillate products. Pediatrics 648–674.
Sun NN, Wong SS, Nardi C, 2007. In vitro pro-inflammatory regulatory role of substance P in alveolar m acrophages and type II pneumocytes after JP-8 exposure. J Immunotoxicol 4(1):61–67.18958713
Sweeney LM, Prues SL, Reboulet JE. 2013. Subacute effects of inhaled Jet Fuel-A (Jet A) on airway and immune function in female rats. Inhal Toxicol 25(5):257–271.23614727
Swenberg JA. 1993. Cell proliferation and chemical carcinogenesis: Conference summary and future directions. Environ Health Perspect 101:153–158.
Tagami H, Ogino A. 1973. Kerosine dermatitis: Factors affecting skin irritability to kerosene. Dermatologica 146(2):123–131.4711878
Tal A, Aviram M, Bar-Ziv J, 1984. Residual small airways lesions after kerosene pneumonitis in early childhood. Eur J Pediatr 142(4):117–120.6468426
Texas Commission on Environmental Quality. 2004. JP-8 Jet fuel spill draft restoration plan. Austin, TX: Texas Commission on Environmental Quality, Texas Parks and Wildlife Department, Texas General Land Office. http://www.tceq.state.tx.us/assets/public/remediation/nrtp/teppcoplan.pdf. January 19, 2014.
Theobald N. 1988. Rapid preliminary separation of petroleum hydrocarbons by solid-phase extraction cartridges. Anal Chim Acta 204(1–2): 135144.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thomas DH, Delfino JJ. 1991. A gas-chromatographic/chemical indicator approach to assessing ground water contamination by petroleum products. Ground Water Monit Rev 11(4):90–100.
Tominaga S, Itoh K. 1985. Relationship between parental smoking and respiratory diseases of three year old children. Tokai J Exp Clin Med 10(4):395–399.3836522
Tsujino Y, Hieda Y, Kimura K, 2003. Dermal absorption of kerosene components in rats and the influence of its amount and area of exposure. Forensic Sci Int 133(1–2):141–145.12742702
Tu RH, Mitchell CS, Kay GG, 2004. Human exposure to the jet fuel, JP-8. Aviat Space Environ Med 75(1):49–59.14736133
Ullrich SE. 1999. Dermal application of JP-8 jet fuel induces immune suppression. Toxicol Sci 52(1):61–67.
Ullrich SE, Lyons HJ. 2000. Mechanisms involved in the immunotoxicity induced by dermal application of JP-8 jet fuel. Toxicol Sci 58(2):290–298.11099641
Upreti RK, Das M, Shanker R. 1989. Dermal exposure to kerosene. Vet Hum Toxicol 31(1):16–20.2523616
Vermulen EK, Merrill EA, Sterner TR. 1998. TPH criteria working group field demonstration: Misawa Air Base, Japan. Dayton, OH: United States Air Force Research Laboratory. AFRL-HE-WP-TR-1999–0029. www.dtic.mil/cgi-bin/GetTRDoc?AD=ADA453484. January 19, 2015.
Vernot EH, Drew RT, Kane ML. 1990a. Acute toxicological evaluation of straight run kerosene. J Am Coll Toxicol Part B 1(1):30–31.
Vernot EH, Drew RT, Kane ML. 1990b. Acute toxicological evaluation of jet fuel A. J Am Coll Toxicol Part B 1(2):29–30.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Vijayalaxmi Kligerman AD, Prihoda TJ, 2004. Cytogenetic studies in mice treated with the jet fuels, Jet-A and JP-8. Cytogenet Genome Res 104(1–4):371–375.15162067
Vijayalaxmi Kligerman AD, Prihoda TJ, 2006. Micronucleus studies in the peripheral blood and bone marrow of mice treated with jet fuels, JP-8 and Jet-A. Mutat Res 608(1):82–87.16815737
Wagner MJ, Stevens SC, Guilfoil AJ, 2009. Evaluation of barrier skin cream effectiveness against JP-8 jet fuel absorption and irritation. Wright-Patterson AFB, OH: U.S. Air Force, Air Force Material Command. AFRL-RH-WP-TR_2009–0086. http://www.dtic.mil/dtic/tr/fulltext/u2/a503802.pdf. January 20, 2014.
Walker JD, Petris L, Colwell RR. 1976. Comparison of the biodegradability of crude and jet fuels. Can J Microbiol 22(4):598–602.1260549
Wang RY. 2004. Hydrocarbon products. In: Dart RC, ed. Medical toxicology. 3rd ed. Philadelphia, PA: Lipincott Williams & Wilkins, 1328–1351.
Wang S, Young RS, Witten ML. 2001. Age-related differences in pulmonary inflammatory responses to JP-8 jet fuel aerosol inhalation. Toxicol Ind Health 17(1):23–29.12004922
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
White KL., Delorme MP, Beatty PW, 2013. Jet fuel kerosene is not immunosuppressive in mice or rats following inhalation for 28 days. J Toxicol Environ Health A 76(13):778–797.24028664
Whitman FT, Hinz JP. 2001. Sensory irritation study in mice: JP-4, JP-8, JP-8+100. Government Reports Announcements & Index (10):68.
Whitman FT, Hinz JP. 2004. Sensory irritation study in mice: JP-5, JP-TS, JP-7, DFM, JP-10. Brooks City-Base, TX: U.S. Air Force Institute for Operational Health. IOS-RS-BR-SR-2004–0001. 20050408025. www.dtic.mil/dtic/tr/fulltext/u2/a432128.pdf. January 19, 2014.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
WHO. 2011. Guidelines for drinking-water quality. 4th ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/publications/2011/dwq_guidelines/en/index.html. January 08, 2014.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
Witschi HP, Smith LH, Frome EL. 1987. Skin tumorigenic potential of crude and refined coal liquids and analogous petroleum products. Fundam Appl Toxicol 9:297–303.3653572
Witten M, Pfaff JK, Lantz RC, 1992a. Capsaicin pretreatment before JP-8 jet fuel exposure causes a large increase in airway sensitivity to histamine in rats [Abstract]. Regul Pept S 1:S176.
Witten ML, Pfaff JK, Parton K, 1992b. JP-8 jet fuel exposure alters lung chemical mediator and substance-p activity in rats [Abstract]. FASEB J 6(4):A1065.
Witzmann FA, Bauer MD, Fieno AM, 1999. Proteomic analysis of simulated occupational jet fuel exposure in the lung. Electrophoresis 20(18):3659–3669.10612293
Witzmann FA, Carpenter RL, Ritchie GD, 2000. Toxicity of chemical mixtures: Proteomic analysis of persisting liver and kidney protein alterations induced by repeated exposure of rats to JP-8 jet fuel vapor. Electrophoresis 21(11):2138–2147.10892725
Wolfe BM, Brodeur AE, Shields JB. 1970. The role of gastrointestinal absorption of kerosene in producing pneumonitis in dogs. J Pediatr 76(6):867–873.5444579
Wolfe RE, Kinead ER, Feldmann ML, 1996. Acute toxicity evaluation of JP-8 jet fuel and JP-8 jet fuel containing additives. Wright-Patterson AFB OH: U.S. Air Force, Armstrong Laboratory, Occupational and Environmental Health Directorate. 62. AL/OE-TR-1996–0136. ADA318722.
*Wolfsdorf J. 1976. Experimental kerosene pneumonitis in primates: Relevance to the therapeutic management of childhood poisoning. Clin Exp Pharmacol Physiol 3(6):539–544.827406
Wolfsdorf J, Kundig H. 1972. Kerosene poisoning in primates. S Afr Med J 46(20):619–621.4625017
Wolfsdorf J, Kundig H. 1974. Dexamethasone in the management of kerosene pneumonia. Pediatrics 53(1):86–90.4203313
*Wolfsdorf J, Paed D. 1976. Kerosene intoxication: An experimental approach to the etiology of the CNS manifestations in primates. J Pediatr 88(6):1037–1040.818358
Wong SS, Hyde J, Sun NN, 2004. Inflammatory responses in mice sequentially exposed to JP-8 jet fuel and influenza virus. Toxicology 197(2):139–147.15003324
Wong SS, Vargas J, Thomas A, 2008. In vivo comparison of epithelial responses for S-8 versus JP-8 jet fuels below permissible exposure limit. Toxicology 254(1–2):106–111.18930109
Yamaguchi S, Yamamoto H, Mizukoshi R, 1992. Rapid chemical diagnosis of kerosene ingestion by NMR. Clin Chem 38(4):593.
Yaron B, Sutherland P, Galin T, 1989. Soil pollution by petroleum products: II. Adsorption-desorption of “kerosene” vapors on soils. J Contam Hydrol 4:347–358.
Zheng W, Blot WJ, Shu X, 1992. Risk factors for oral and pharyngeal cancer in Shanghai, with emphasis on diet. Cancer Epidemiol Biomarkers Prev 1441–1448.
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372
Zucker AR, Berger S, Wood LD. 1986. Management of kerosene-induced pulmonary injury. Crit Care Med 14(4):303–304.3082595
*Zucker AR, Wood LD, Curet-Scott M, 1991. Partial lung bypass reduces pulmonary edema induced by kerosene aspiration in dogs. J Crit Care 6(1):29–35.