# 5 PRODUCTION, IMPORT/EXPORT, USE, AND DISPOSAL

## 5.1 PRODUCTION

No information is available in the TRI database on facilities that manufacture or process JP-5, JP-8, and Jet A fuels because these chemicals are not required to be reported under Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986) (EPA 2005).

As discussed in Chapter 4, most jet fuels are derived from petroleum. During the 1970s and 1980s, shale oil had been used to manufacture jet fuels, but this is no longer economically feasible (Chevron 2006). Figure 4-1 provides a general schematic for the straight-run production of jet fuels from crude oil. Heated crude oil is introduced into an atmospheric pressure distillation unit and the liquefied petroleum gasses (propane and butane) are boiled off from the top of the distillation column and eventually recondensed by a condenser unit. Middle distillates such as kerosene and diesel are drawn off the distillation column and treated by various processes that remove or reduce undesirable components before becoming jet fuels (API 2010b; Chevron 2006). The sweetening process removes corrosive mercaptans from the kerosene fraction by the mercapton oxidation (Merox) process in which mercaptans are converted to disulfides using a catalyst and an alkaline solution. The disulfides are noncorrosive and may be left in the final product or removed by additional treatment to lower the sulfur content of the resultant jet fuel. Hydroprocessing employs hydrogen and an appropriate catalyst to remove olefins, sulfur, and nitrogen-containing compounds from the distilled kerosene. Jet fuel manufactured by a particular refinery may be derived exclusively from straight-run processing or it may be a blend of straight-run, hydroprocessed, and/or hydrocracked product (as depicted in Figure 4-1); however, the finished product must meet all of the performance and regulatory requirements of the specific fuel as discussed in Chapter 4.

Concern that diminishing oil supplies could disrupt production of jet fuels from traditional petroleum sources has prompted research into alternative production methods. The Fischer-Tropsch process has been used to develop synthetic jet fuels from feedstocks other than petroleum (Chevron 2006; FAA 2009). In this process, Syngas (synthesis gas), a mixture of carbon monoxide and hydrogen, is reacted with catalysts to produce a variety of hydrocarbons. These hydrocarbons are then blended to produce a highly paraffinic synthetic jet fuel that contains virtually no sulfur, nitrogen, or aromatic compounds. The benefits and disadvantages of producing jet fuels using the Fischer-Tropsch process and other methods compared to traditional manufacturing methods using petroleum feedstock have been reviewed in a technical report produced by the Rand Corporation and the Massachusetts Institute of Technology (MIT) (FAA 2009).

Domestic production, import, and export data for kerosene is summarized in Tables 5-1 and 5-2. These data were derived from the EPA Inventory Update Reporting (IUR) system (EPA 2010) and the newly developed Chemical Data Reporting (CDR) database (EPA 2012a). According to the CDR website (http://www.epa.gov/oppt/cdr/), approximately 2.07×10^11^ pounds (93,725,241 tonnes) of kerosene was manufactured in 2012; however, several companies claimed this information as confidential business information (CBI) and therefore, the actual production volume is expected to be greater than what is indicated in Table 5-1 (EPA 2012a).

While the demand for kerosene has gradually declined over the previous 4 decades, demand for jet fuels has steadily increased. As a result, many refiners have chosen to produce Jet A-1 as their basic product and to simply divert a portion of the product for marketing as kerosene (IARC 1989). In the United States, production of jet fuels, including both kerosene-type (JP-5 and JP-8) and wide-cut fuels, increased from 37,636,000 tonnes (293,560,800 barrels) in 1970 to 56,939,000 tonnes (444,124,200 barrels) in 1985 (IARC 1989). In the countries of the Organisation for Economic Cooperation and Development (OECD), production increased from 57,659,000 tonnes (449,740,200 barrels) to 90,280,000 tonnes (704,184,000 barrels) during the same time period (IARC 1989). According to the Department of Energy, the consumption of jet fuels in the United States in 2010 and 2011 was 1.43 and 1.42 million barrels per day, respectively, for an annual consumption rate of 521,950,000 barrels consumed in 2010 and 518,300,000 barrels consumed in 2011 (EIA 2013c). The consumption rate is projected to increase to 1.52 million barrels per day (554,800,000 barrels annually) by 2020, 1.60 million barrels per day (584,000,000 barrels annually) by 2030, and 1.66 million barrels per day (605,900,000 barrels annually) by 2040 (EIA 2013c).

Data regarding the weekly production of jet fuels by U.S. refineries since 2010 are provided in Tables 5-3 (commercial jet fuels) and 5-4 (military jet fuels) from the U.S. Energy Information Administration (EIA 2014a).

## 5.2 IMPORT/EXPORT

Imports of distillate fuels have varied from year to year since the 1970s. Since 1975, imports of distillate jet fuels such as jet fuel no. 1 into the United States have been low compared to the amount of distillate jet fuels produced in the United States (API 1991). Imports of kerosene fluctuated between 1975 and 1984 and then showed a steady increase from 1985 to 1987, attaining an annual maximum of 6,935,000 barrels in 1987. Between 1988 and 1990, imports of kerosene decreased to a low of 1,825,000 barrels (API 1991). Table 5-1 shows that approximately 2,399,093 tonnes of kerosene (18,712,925 barrels) were imported into the United States in 2012; however, several companies claimed these data as CBI and did not report any import volumes publically. Table 5-5 shows the weekly import volume of kerosene-type jet fuels since 2000 as reported by the U.S. Energy Information Administration (EIA 2014b).

Table 5-1 Domestic Production, Import, and Export Volumes of Kerosene in 2012^a^

Domestic manufacturing (pounds) | Imported (pounds) | Volume used | Volume exported | Parent company name | Parent company city
2,400,000,000 | | 0 | 0 | Sunoco, Inc. | Philadelphia
109,000,000,000 | | 109,000,000,000 | 0 | Sunoco, Inc. | Philadelphia
2,530,000,000 | | 0 | 0 | ConocoPhillips Co. | Linden
3,739,372,000 | | 0 | 0 | Motiva Enterprises LLC | Houston
1,055,839,514 | | 1,055,839,514 | 0 | Equilon Enterprises LLC | Houston
2,946,370,260 | | 2,946,370,260 | 0 | Shell Deer Park Refining Limited Partnership | Deer Park
6,442,919,000 | | 0 | 0 | Motiva Enterprises LLC | Houston
| 2,945,948,325 | N/A | 0 | Shell Trading US Co. | Houston
1,185,666,446 | | 1,185,666,446 | 0 | Shell Chemical Company LP | Houston
5,537,432,425 | | 0 | 0 | Motiva Enterprise LLC | Houston
389,977,246 | | 389,977,246 | 0 | Hunt Consolidated, Inc. | Dallas
CBI | CBI | CBI | CBI | CBI | CBI
1,600,000,000 | | 400,000,000 | 0 | Western Refining Southwest, Inc. | El Paso
| 490,030,931 | N/A | 0 | Citgo Petroleum Corporation | Houston
| 141,484 | N/A | 0 | Equilon Enterprises LLC DBA Shell Oil | Houston
66,697,537 | | 0 | 0 | Calumet Specialty Products Partners LP | Princeton
405,477,132 | | 0 | 0 | Calumet Specialty Products Partners LP | Shreveport
25,920,768 | | 0 | 0 | Calumet Specialty Products Partners LP | Indianapolis
66,000,000 | | 62,000,000 | 0 | Citgo Petroleum Corporation | Lemont
2,691,000,000 | | 2,691,000,000 | 0 | Marathon Oil Corporation | Findlay
620,000,000 | | 0 | 0 | ConocoPhillips Co. | Houston
42,000,000 | | 42,000,000 | 0 | Calumet Specialty Products Partners LP | Indianapolis
857,000,000 | | 0 | 0 | Alon USA LP | Dallas
| 105,362 | 105,362 | 0 | United Refining Co. | Warren
CBI | CBI | CBI | CBI | Lyondell Chemical Co. | Houston
2,213,000,000 | | 1,223,000,000 | 0 | Marathon Oil Corporation | Findlay
126,000,000 | | 126,000,000 | 0 | Murphy Oil USA, Inc. | El Dorado
696,175,997 | | 696,175,997 | 0 | PPB Energy | Parsippany
1,511,255,360 | | 1,511,255,360 | 0 | Total Petrochemicals and Refining USA, Inc. | Houston
CBI | | CBI | CBI | Exxon Mobil Corporation | Irving
2,698,292 | | 2,698,292 | 0 | Solvchem, Inc. | Pearland
CBI | | CBI | CBI | BASF Corporation | Florham Park
2,830,000,000 | | 2,830,000,000 | 0 | Marathon Oil Corporation | Findlay
97,754,939 | | 97,754,939 | 0 | ConocoPhillips Co. | Anchorage
2,000,000,000 | | 2,000,000,000 | 0 | ConocoPhillips Co. | Ferndale
CBI | | CBI | CBI | Koch Industries, Inc. | Wichita
1,500,000,000 | | 0 | 0 | Tesoro Corporation | Kapolei
CBI | | CBI | CBI | Exxon Mobil Corporation | Irving
CBI | | CBI | CBI | Chalmette Refining LLC | Chalmette
| 200,000,000 | N/A | 0 | Chevron Corporation | Houston
CBI | | CBI | CBI | Exxon Mobil Corporation | Irving
2,400,000,000 | | 2,400,000,000 | 0 | Chevron Corporation | San Ramon
71,298,667 | | 0 | 0 | Nustar Energy LP | Brooks City- Base
1,359,000,000 | | 1,359,000,000 | 0 | Marathon Oil Corporation | Findlay
410,000,000 | | 77,000,000 | 0 | Tesoro Corporation | Mandan
1,500,000,000 | | 590,000,000 | 910,000,000 | Petrobras America, Inc. | Pasadena
1,313,155,341 | | 1,313,155,341 | 0 | Valero Services, Inc. | San Antonio
549,000,000 | | 549,000,000 | 0 | Marathon Oil Corporation | Findlay
CBI | CBI | CBI | CBI | Innospec, Inc. | Littleton
| 1 | N/A | 0 | ConocoPhillips Co. | Houston
| CBI | N/A | 0 | Ethyl Corporation | Richmond
940,000,000 | | 0 | 0 | Tesoro Corporation | Wilmington
| 330,000,000 | N/A | 0 | Tesoro Corporation | San Antonio
CBI | | CBI | 0 | Exxon Mobil Corporation | Irving
2,809,664,659 | | 2,809,664,659 | 0 | Citgo Petroleum Corporation | Corpus Christi
540,000,000 | | 540,000,000 | 0 | Hollyfrontier Corporation | Dallas
CBI | CBI | CBI | CBI | Valero Energy Corporation | San Antonio
1,600,000,000 | | 1,600,000,000 | 0 | Hollyfrontier Corporation | Dallas
CBI | CBI | CBI | CBI | Valero Energy Corporation | San Antonio
CBI | | CBI | 0 | Alon USA LP | Paramount
CBI | CBI | CBI | CBI | Valero Energy Corporation | Texas City
40,000,000 | | 0 | 0 | Marathon Oil Corporation | Findlay
1,300,000,000 | | 1,300,000,000 | 0 | ConocoPhillips Co. | Houston
CBI | CBI | CBI | CBI | BP Products North America, Inc. | Naperville
1,200,000,000 | | 1,200,000,000 | 0 | Tesoro Corporation | San Antonio
575,862,000 | | 0 | 72,413,000 | Astra West Coast Refining, Inc. | Huntington Beach
1,300,000,000 | | 129,930,445 | 0 | Tesoro Corporation | Kenai
870,000,000 | | 660,000,000 | 0 | Tesoro Corporation | San Antonio
CBI | | CBI | CBI | Koch Industries Inc. | Wichita
2,539,212,856 | | 2,539,212,856 | 0 | PBF Energy | Paulsboro
| CBI | N/A | CBI | Dorf Ketal Chemicals LLC | Stafford
1,700,000,000 | | 1,700,000,000 | 0 | ConocoPhillips Co. | Houston
720,000,000 | | 718,496,972 | 0 | Delek Us Holdings Inc. | Brentwood
1,356,000,000 | | 1,356,000,000 | 0 | Husky Energy, Inc. | Wilmington
CBI | CBI | CBI | 0 | Ocean Investments Corp. | Portsmouth
CBI | CBI | CBI | CBI | Premcor Refining Group | San Antonio
130,000,000 | | 130,000,000 | 0 | Hollyfrontier Corporation | Dallas
CBI | CBI | CBI | CBI | Valero Services, Inc. | San Antonio
998,799,401 | | 0 | 0 | Suncor Energy USA, Inc. | Commerce City
5,100,000,000 | | 0 | 0 | ConocoPhillips Co. | Houston
500,000,000 | | 500,000,000 | 0 | Countrymark | Indianapolis
220,000,000 | | 0 | 0 | Gary-Williams Energy Corporation | Wynnewood
CBI | CBI | CBI | CBI | Hovensa LLC | Christiansted
| CBI | N/A | 0 | 3M Co. | St. Paul
267,994,032 | | 267,994,032 | 0 | Alon USA LP | Dallas
1,100,000,000 | | 0 | 0 | Hollyfrontier Corporation | Dallas
320,000,000 | | 220,000,000 | 0 | Hollyfrontier Corporation | Dallas
CBI | CBI | CBI | CBI | Casey Co. | Long Beach
770,000,000 | | 9,500,000 | 0 | Tesoro Corporation | Salt Lake City
| 45,420,783 | N/A | 0 | Lukoil Pan Americas LLC | New York
CBI | CBI | CBI | CBI | The Premcor Refining Group, Inc. | Memphis
2,464,937,141 | | 2,464,937,141 | 0 | PBF Energy | Oregon
6,332,180,492 | 1,440,978 | 6,333,621,470 | 0 | Citgo Petroleum Corporation | Houston
1,925,000,000 | | 1,925,000,000 | 0 | Murphy Oil USA, Inc. | El Dorado
66,000,000 | | 36,000,000 | 0 | Hollyfrontier Corporation | Dallas
930,000,000 | | 930,000,000 | 0 | ConocoPhillips Co. | Houston
19,000,000 | | 18,000,000 | 0 | American Refining Group | Bradford
CBI | CBI | CBI | CBI | Valero Services, Inc. | Corpus Christi
CBI | CBI | CBI | CBI | Sinclair Oil Corporation | Salt Lake City
CBI | CBI | CBI | CBI | CBI | CBI
100,000,000 | | 100,000,000 | 0 | Montana Refining Co. | Great Falls
927,477,168 | | 0 | 0 | Transworld Oil | Lake Charles
CBI | CBI | CBI | CBI | CBI | CBI
3,082,443,279 | | 805,012,637 | 2,277,430,642 | ConocoPhillips Co. | Houston
145,475,223 | | 0 | 0 | CVR Refining, LLC | Coffeyville
390,000,000 | | 390,000,000 | 0 | Western Refining Southwest, Inc. | Gallup
120,000,000 | | 120,000,000 | 0 | WRB Refining LP | Houston
162,100,000 | | 0 | 162,100,000 | Black Elk Refining, LLC | Houston
CBI | CBI | CBI | CBI | Valero Ultramar Holdings, Inc. | Ardmore
841,000,000 | | 841,000,000 | 0 | Northern Tier Energy LLC | Ridgefield
CBI | CBI | CBI | CBI | Valero Energy Corporation | San Antonio
1,600,000,000 | | 1600,000,000 | 0 | National Cooperative Refinery Association | McPherson
CBI | | CBI | CBI | Exxon Mobil Corporation | Irving
CBI | CBI | CBI | CBI | CBI | CBI
CBI | CBI | CBI | CBI | Valero Energy Corporation | San Antonio
480,000,000 | | 240,000,000 | 0 | CHS, Inc. | Inver Grove Heights

a Data obtained from the EPA Chemical Data Reporting database (EPA 2012a).

CBI = confidential business information

Table 5-2 Non-confidential 2006 Inventory Update Reporting Records by Chemical, Including Manufacturing, Processing, and Use Information for Kerosene (Petroleum); CAS Registry No. 8008–20-6; Aggregated National Production Volume: ≥1 Billion Pounds

Company and site information
Company | Site | City | State^a^ | Manufacture | Import | Site limited
AGE Refining, Inc. | San Antonio | San Antonio | TX | Yes | No | Yes
Alon USA LP | Big Spring Refinery | Big Spring | TX | Yes | No | Yes
American Refining Group, Inc. | American Refining Group, Inc. | Bradford | PA | Yes | No | No
BP America, Inc. | BP, Prudhoe Bay Crude Oil Topping Plant | Prudhoe Bay | AK | Yes | No | No
BP America, Inc. | Los Angeles (Carson) Refinery | Carson | CA | Yes | No | No
BP America, Inc. | Texas City Refinery | Texas City | TX | Yes | No | No
BP America, Inc. | BP Products North America Inc., IST | Warrenville | IL | No | Yes | N/A
BP America, Inc. | Whiting Refinery | Whiting | IN | Yes | No | No
BP America, Inc. | Toledo Refinery | Oregon | OH | Yes | No | No
Big West Oil, LLC | North Salt Lake Refinery | North Salt Lake | UT
CHS, Inc. | Laurel Refinery | Laurel | MT | Yes | No | No
CITGO Petroleum Corporation | Corporate Office | Houston | TX | No | Yes | N/A
CITGO Petroleum Corporation | CITGO Refining and Chemicals Company East Plant | Corpus Christi | TX | Yes | No | No
CITGO Petroleum Corporation | PDV Midwest Refining, L.L.C., Lemont Refinery (operated by CITGO Petroleum Corporation) | Lemont | IL | Yes | No | No
CITGO Petroleum Corporation | Port Everglades Terminal | Fort Lauderdale | FL | No | Yes | N/A
CITGO Petroleum Corporation | Tampa Terminal | Tampa | FL | No | Yes | N/A
CITGO Petroleum Corporation | Lake Charles Manufacturing Complex | Lake Charles | LA | Yes | No | Yes
CITGO Petroleum Corporation | Linden Terminal | Linden | NJ | No | Yes | N/A
Calumet Lubricants Co., L.P. | Shreveport Refinery | Shreveport | LA | Yes | No | No
Calumet Lubricants Co., L.P. | Princeton Refinery | Princeton | LA | Yes | No | Yes
Calumet Lubricants Co., L.P. | Cotton Valley Refinery | Cotton Valley | LA | Yes | No | Yes
Chalmette Refining LLC | Chalmette Refining LLC | Chalmette | LA | Yes | No | No
Chevron U.S.A., Inc. | Global Supply and Trading | Houston | TX | No | Yes | N/A
Chevron U.S.A., Inc. | El Segundo | El Segundo | CA | Yes | No | Yes
Coffeyville Resources Refining and Marketing, LLC | Coffeyville Resources Refining and Marketing, LLC | Coffeyville | KS | Yes | No | No
ConocoPhillips Company | Ferndale Refinery | Ferndale | WA | Yes | No | Yes
ConocoPhillips Company | Kaparuk River Unit | Anchorage | AK | Yes | No | No
ConocoPhillips Company | Kaparuk River Unit | Anchorage | AK | Yes | No | Yes
ConocoPhillips Company | Los Angeles Refinery Carson Plant | Carson | CA | Yes | No | No
ConocoPhillips Company | Ponca City Refinery | Ponca City | OK | Yes | No | No
ConocoPhillips Company | Sweeny Refinery | Old Ocean | TX | Yes | No | No
ConocoPhillips Company | Lake Charles Refinery | Westlake | LA | Yes | No | No
ConocoPhillips Company | Ferndale Refinery | Ferndale | WA | Yes | No | No
ConocoPhillips Company | Borger Refinery | Borger | TX | Yes | No | No
ConocoPhillips Company | Bayway Refinery | Linden | NJ | Yes | No | No
ConocoPhillips Company | Alliance Refinery | Belle Chasse | LA | Yes | No | No
Countrymark Cooperative, LLP | Refinery | Mt. Vernon | IN | Yes | No | Yes
Diamond Shamrock Refining Co., L.P. | Valero Three Rivers Refinery | Three Rivers | TX | Yes | No | No
Ethyl Corporation | Houston Plant | Pasadena | TX
Exxon Mobil Corporation | Baton Rouge Refinery | Baton Rouge | LA | Yes | No | No
Exxon Mobil Corporation | Baytown Refinery | Baytown | TX | Yes | No | No
Exxon Mobil Corporation | Billings Refinery | Billings | MT | Yes | No | Yes
ExxonMobil Oil Corporation | Fairfax | Fairfax | VA | No | Yes | N/A
ExxonMobil Oil Corporation | Torrance Refinery | Torrance | CA | Yes | No | No
ExxonMobil Oil Corporation | Beaumont Refinery | Beaumont | TX | Yes | No | No
ExxonMobil Oil Corporation | Joliet Refinery | Channahon | IL | Yes | No | Yes
Flint Hills Resources, Alaska LLC | North Pole Refinery | North Pole | AK | Yes | No | No
Flint Hills Resources, LP | East Plant | Corpus Christi | TX | Yes | No | No
Flint Hills Resources, LP | West Plant | Corpus Christi | TX | Yes | No | No
Frontier El Dorado Refining Company | Frontier El Dorado Refining Company | El Dorado | KS | Yes | No | No
Giant Refining Company | Ciniza | Jamestown | NM | Yes | No | No
Giant Yorktown, Inc. | Refinery | Grafton | VA | Yes | No | No
Glencore Ltd. | Glencore Ltd. | Stamford | CT
Holly Refining & Marketing Company | Woods Cross Refinery | Woods Cross | UT | Yes | No | No
Hunt Refining Company | Tuscaloosa Refinery | Tuscaloosa | AL | Yes | No | Yes
Irving Oil, Inc. | Irving Oil Terminals Inc. - PADD 1 | Portsmouth | NH
Marathon Oil Corporation | Catlettsburg Refining, LLC | Catlettsburg | KY | Yes | No | No
Marathon Oil Corporation | Garyville | Garyville | LA | Yes | No | No
Marathon Petroleum Company LLC | Minnesota Refining Division | St. Paul Park | MN | Yes | No | No
Marathon Petroleum Company LLC | Michigan Refining Division | Detroit | MI | Yes | No | Yes
Marathon Petroleum Company LLC | Texas Refining Division | Texas City | TX | Yes | No | No
Midland Asphalt Materials Inc. | Tonawanda | Tonawanda | NY | Yes | No | No
Motiva Enterprises, LLC | Port Arthur Refinery | Port Arthur | TX | Yes | No | No
Motiva Enterprises, LLC | Convent Refinery | Convent | LA | Yes | No | No
Motiva Enterprises, LLC | Norco Refinery | Norco | LA | Yes | No | No
Murphy Oil Corporation | Meraux Refinery | Meraux | LA | Yes | No | No
Murphy Oil USA, Inc. | Superior Refinery | Superior | WI | Yes | No | No
Navajo Refining Company, L.P. | Lovington Refinery | Lovington | NM | Yes | No | No
Navajo Refining Company, L.P. | Artesia Refinery | Artesia | NM | Yes | No | No
Paramount Petroleum Corporation | Paramount | Paramount | CA | Yes | No | No
Paramount Petroleum Corporation | Wilibridge Asphalt Facility | Portland | OR | Yes | No | No
Penreco | Karns City | Karns City | PA | Yes | No | No
Premcor USA Inc. | The Premcor Refining Group Inc. DBA Valero Memphis Refinery | Memphis | TN | Yes | No | No
Premcor USA Inc. | Port Arthur Refinery | Port Arthur | TX | Yes | No | No
Safety-Kleen Systems, Inc. | Safety-Kleen Oil Recovery Co. | East Chicago | IN | Yes | No | No
San Juan Refining Company | Giant Refining, Bloomfield | Bloomfield | NM | Yes | No | No
Shell Chemical LP | Mobile Site | Saraland | AL | Yes | No | No
Shell Chemical LP | St. Rose Site | St. Rose | LA | Yes | No | No
Shell Chemical LP | Yabucoa, Inc. | Yabucoa | PR | Yes | No | No
Shell Deer Park Refining Company | Shell Deer Park Refining Company | Deer Park | TX | Yes | No | No
Shell Oil Products US | Los Angeles Refinery | Los Angeles | CA | Yes | No | No
Shell Oil Products US | Puget Sound Refinery | Anacortes | WA | Yes | No | No
Shell Trading (US) Company | Main office | Houston | TX | No | Yes | N/A
Sigmor Corporation | Diamond Shamrock Refining, L.P., Valero McKee Refinery | Sunray | TX | Yes | No | No
Sinclair Refining Company | Casper Refinery | Casper | WY | Yes | No | Yes
Sinclair Refining Company | Tulsa Refining Company | Tulsa | OK | Yes | No | No
Sinclair Wyoming Refining Company | Sinclair Wyoming Refining Company | Sinclair | WY | Yes | No | No
Suncor Energy (U.S.A.) Inc. | Commerce City Refinery | Commerce City | CO | Yes | No | No
Sunoco, Inc. | Tulsa Refinery | Tulsa | OK | Yes | No | No
Tesoro Corporation | Tesoro Alaska Company - Kenai Refinery | Kenai | AK | Yes | No | No
Tesoro Petroleum Corporation | Hawaii Refinery | Kapolei | HI | Yes | No | No
Tesoro Refining and Marketing Company | Anacortes | Anacortes | WA | Yes | No | No
Tesoro Refining and Marketing Company | Golden Eagle Refinery | Martinez | CA | Yes | No | Yes
Tesoro Refining and Marketing Company | Mandan Refinery | Mandan | ND | Yes | No | No
Tesoro Refining and Marketing Company | Salt Lake City Refinery | Salt Lake City | UT | Yes | No | No
Texaco Downstream LLC | Fuel and Marine Marketing LLC | San Ramon | CA | No | Yes | N/A
The Dow Chemical Company | Headquarters | Midland | MI | No | Yes | N/A
Tremco Incorporated | Beachwood | Beachwood | OH | No | Yes | N/A
U.S. Oil and Refining Co. | Tacoma | Tacoma | WA | Yes | No | No
Valero Energy Corporation | Premcor Refining Group Inc. | Delaware City | DE | Yes | No | Yes
Valero Refining Company | Valero Marketing and Supply Company | San Antonio | TX | No | Yes | N/A
Valero Refining Company | Paulsboro Refinery | Paulsboro | NJ | Yes | No | No
Valero Refining Company | Benicia Refinery and Asphalt Plant | Benicia | CA | Yes | No | Yes
Valero Refining Company | Wilmington | Wilmington | CA | Yes | No | Yes
Valero Refining Company | St. Charles Refinery | Norco | LA | Yes | No | No
Valero Unit Investments, LLC | Houston Refinery | Houston | TX | Yes | No | No
Valero Unit Investments, LLC | Texas City Refinery | Texas City | TX | Yes | No | No
Western Refining Company | Western Refining Company | El Paso | TX | Yes | No | No
Wynnewood Refining Company | Wynnewood Refining Company | Wynnewood | OK | Yes | No | No
Wyoming Refining Company | Newcastle Refinery | Newcastle | WY | Yes | No | Yes

a Post Office abbreviations used.

CAS = Chemical Abstracts Service; N/A = not applicable

Source: EPA 2010

Table 5-3 Weekly U.S. Production of Commercial Kerosene-Type Jet Fuel (Thousand Barrels per Day) Since 2010^a^

| Week 1 | | Week 2 | | Week 3 | | Week 4 | | Week 5
Year-month | End date | Value | End date | Value | End date | Value | End date | Value | End date | Value
2010-January | 01/01 | 1,335 | 01/08 | 1,354 | 01/15 | 1,334 | 01/22 | 1,264 | 01/29 | 1,215
2010-February | 02/05 | 1,157 | 02/12 | 1,134 | 02/19 | 1,159 | 02/26 | 1,141
2010-March | 03/05 | 1,160 | 03/12 | 1,171 | 03/19 | 1,147 | 03/26 | 1,170
2010-April | 04/02 | 1,190 | 04/09 | 1,209 | 04/16 | 1,244 | 04/23 | 1,289 | 04/30 | 1,319
2010-May | 05/07 | 1,328 | 05/14 | 1,342 | 05/21 | 1,323 | 05/28 | 1,296
2010-June | 06/04 | 1,290 | 06/11 | 1,280 | 06/18 | 1,279 | 06/25 | 1,291
2010-July | 07/02 | 1,329 | 07/09 | 1,353 | 07/16 | 1,381 | 07/23 | 1,399 | 07/30 | 1,382
2010-August | 08/06 | 1,357 | 08/13 | 1,339 | 08/20 | 1,308 | 08/27 | 1,287
2010-September | 09/03 | 1,285 | 09/10 | 1,281 | 09/17 | 1,299 | 09/24 | 1,282
2010-October | 10/01 | 1,269 | 10/08 | 1,251 | 10/15 | 1,223 | 10/22 | 1,219 | 10/29 | 1,216
2010-November | 11/05 | 1,199 | 11/12 | 1,217 | 11/19 | 1,249 | 11/26 | 1,248
2010-December | 12/03 | 1,280 | 12/10 | 1,270 | 12/17 | 1,266 | 12/24 | 1,278 | 12/31 | 1,287
2011-January | 01/07 | 1,313 | 01/14 | 1,297 | 01/21 | 1,288 | 01/28 | 1,270
2011-February | 02/04 | 1,243 | 02/11 | 1,215 | 02/18 | 1,225 | 02/25 | 1,217
2011-March | 03/04 | 1,223 | 03/11 | 1,255 | 03/18 | 1,243 | 03/25 | 1,262
2011-April | 04/01 | 1,272 | 04/08 | 1,277 | 04/15 | 1,293 | 04/22 | 1,270 | 04/29 | 1,272
2011-May | 05/06 | 1,253 | 05/13 | 1,250 | 05/20 | 1,278 | 05/27 | 1,288
2011-June | 06/03 | 1,331 | 06/10 | 1,347 | 06/17 | 1,363 | 06/24 | 1,396
2011-July | 07/01 | 1,381 | 07/08 | 1,400 | 07/15 | 1,415 | 07/22 | 1,394 | 07/29 | 1,413
2011-August | 08/05 | 1,389 | 08/12 | 1,363 | 08/19 | 1,346 | 08/26 | 1,362
2011-September | 09/02 | 1,381 | 09/09 | 1,389 | 09/16 | 1,415 | 09/23 | 1,401 | 09/30 | 1,419
2011-October | 10/07 | 1,417 | 10/14 | 1,372 | 10/21 | 1,342 | 10/28 | 1,282
2011-November | 11/04 | 1,238 | 11/11 | 1,228 | 11/18 | 1,223 | 11/25 | 1,217
2011-December | 12/02 | 1,250 | 12/09 | 1,276 | 12/16 | 1,290 | 12/23 | 1,309 | 12/30 | 1,293
2012-January | 01/06 | 1,310 | 01/13 | 1,311 | 01/20 | 1,324 | 01/27 | 1,319
2012-February | 02/03 | 1,302 | 02/10 | 1,292 | 02/17 | 1,296 | 02/24 | 1,307
2012-March | 03/02 | 1,293 | 03/09 | 1,279 | 03/16 | 1,265 | 03/23 | 1,247 | 03/30 | 1,257
2012-April | 04/06 | 1,271 | 04/13 | 1,263 | 04/20 | 1,292 | 04/27 | 1,291
2012-May | 05/04 | 1,280 | 05/11 | 1,280 | 05/18 | 1,270 | 05/25 | 1,280
2012-June | 06/01 | 1,339 | 06/08 | 1,378 | 06/15 | 1,425 | 06/22 | 1,456 | 06/29 | 1,456
2012-July | 07/06 | 1,485 | 07/13 | 1,460 | 07/20 | 1,447 | 07/27 | 1,471
2012-August | 08/03 | 1,486 | 08/10 | 1,502 | 08/17 | 1,528 | 08/24 | 1,504 | 08/31 | 1,448
2012-September | 09/07 | 1,404 | 09/14 | 1,367 | 09/21 | 1,339 | 09/28 | 1,357
2012-October | 10/05 | 1,358 | 10/12 | 1,340 | 10/19 | 1,326 | 10/26 | 1,313
2012-November | 11/02 | 1,319 | 11/09 | 1,302 | 11/16 | 1,297 | 11/23 | 1,260 | 11/30 | 1,244
2012-December | 12/07 | 1,290 | 12/14 | 1,308 | 12/21 | 1,339 | 12/28 | 1,378
2013-January | 01/04 | 1,374 | 01/11 | 1,381 | 01/18 | 1,357 | 01/25 | 1,318
2013-February | 02/01 | 1,299 | 02/08 | 1,290 | 02/15 | 1,302 | 02/22 | 1,305
2013-March | 03/01 | 1,312 | 03/08 | 1,293 | 03/15 | 1,300 | 03/22 | 1,347 | 03/29 | 1,387
2013-April | 04/05 | 1,423 | 04/12 | 1,443 | 04/19 | 1,429 | 04/26 | 1,389
2013-May | 05/03 | 1,405 | 05/10 | 1,408 | 05/17 | 1,373 | 05/24 | 1,370 | 05/31 | 1,350
2013-June | 06/07 | 1,344 | 06/14 | 1,385 | 06/21 | 1,416 | 06/28 | 1,437
2013-July | 07/05 | 1,461 | 07/12 | 1,460 | 07/19 | 1,470 | 07/26 | 1,479
2013-August | 08/02 | 1,482 | 08/09 | 1,475 | 08/16 | 1,478 | 08/23 | 1,475 | 08/30 | 1,483
2013-September | 09/06 | 1,516 | 09/13 | 1,512 | 09/20 | 1,489 | 09/27 | 1,451
2013-October | 10/04 | 1,405 | 10/11 | 1,371 | 10/18 | 1,364 | 10/25 | 1,362
2013-November | 11/01 | 1,368 | 11/08 | 1,380 | 11/15 | 1,374 | 11/22 | 1,385 | 11/29 | 1,401
2013-December | 12/06 | 1,436 | 12/13 | 1,475 | 12/20 | 1,501 | 12/27 | 1,527
2014-January | 01/03 | 1,543 | 01/10 | 1,527 | 01/17 | 1,495 | 01/24 | 1,444 | 01/31 | 1,384
2014-February | 02/07 | 1,375 | 02/14 | 1,360 | 02/21 | 1,369 | 02/28 | 1,384
2014-March | 03/07 | 1,375 | 03/14 | 1,365 | 03/21 | 1,362 | 03/28 | 1,361
2014-April | 04/04 | 1,378 | 04/11 | 1,395 | 04/18 | 1,404 | 04/25 | 1,418
2014-May | 05/02 | 1,416 | 05/09 | 1,430 | 05/16 | 1,429 | 05/23 | 1,413 | 05/30 | 1,419
2014-June | 06/06 | 1,417 | 06/13 | 1,440 | 06/20 | 1,433 | 06/27 | 1,419
2014-July | 07/04 | 1,440 | 07/11 | 1,457 | 07/18 | 1,510 | | 1,548

a Data obtained from EIA (2014a).

Table 5-4 Weekly U.S. Production of Military Kerosene-Type Jet Fuel (Thousand Barrels per Day) Since 2010^a^

| Week 1 | | Week 2 | | Week 3 | | Week 4 | | Week 5
Year-month | End date | Value | End date | Value | End date | Value | End date | Value | End date | Value
2010-January | 01/01 | 128 | 01/08 | 105 | 01/15 | 109 | 01/22 | 134 | 01/29 | 148
2010-February | 02/05 | 154 | 02/12 | 153 | 02/19 | 128 | 02/26 | 137
2010-March | 03/05 | 127 | 03/12 | 139 | 03/19 | 161 | 03/26 | 157
2010-April | 04/02 | 175 | 04/09 | 162 | 04/16 | 152 | 04/23 | 148 | 04/30 | 142
2010-May | 05/07 | 144 | 05/14 | 136 | 05/21 | 143 | 05/28 | 147
2010-June | 06/04 | 142 | 06/11 | 147 | 06/18 | 143 | 06/25 | 142
2010-July | 07/02 | 149 | 07/09 | 143 | 07/16 | 151 | 07/23 | 153 | 07/30 | 153
2010-August | 08/06 | 153 | 08/13 | 138 | 08/20 | 140 | 08/27 | 141
2010-September | 09/03 | 147 | 09/10 | 161 | 09/17 | 144 | 09/24 | 132
2010-October | 10/01 | 124 | 10/08 | 108 | 10/15 | 105 | 10/22 | 118 | 10/29 | 109
2010-November | 11/05 | 123 | 11/12 | 125 | 11/19 | 111 | 11/26 | 116
2010-December | 12/03 | 100 | 12/10 | 112 | 12/17 | 116 | 12/24 | 126 | 12/31 | 121
2011-January | 01/07 | 117 | 01/14 | 107 | 01/21 | 102 | 01/28 | 114
2011-February | 02/04 | 113 | 02/11 | 122 | 02/18 | 116 | 02/25 | 110
2011-March | 03/04 | 118 | 03/11 | 121 | 03/18 | 139 | 03/25 | 154
2011-April | 04/01 | 147 | 04/08 | 159 | 04/15 | 147 | 04/22 | 135 | 04/29 | 146
2011-May | 05/06 | 144 | 05/13 | 140 | 05/20 | 138 | 05/27 | 131
2011-June | 06/03 | 126 | 06/10 | 137 | 06/17 | 142 | 06/24 | 135
2011-July | 07/01 | 148 | 07/08 | 143 | 07/15 | 149 | 07/22 | 160 | 07/29 | 137
2011-August | 08/05 | 147 | 08/12 | 149 | 08/19 | 163 | 08/26 | 165
2011-September | 09/02 | 165 | 09/09 | 151 | 09/16 | 135 | 09/23 | 139 | 09/30 | 134
2011-October | 10/07 | 136 | 10/14 | 132 | 10/21 | 134 | 10/28 | 136
2011-November | 11/04 | 136 | 11/11 | 135 | 11/18 | 132 | 11/25 | 133
2011-December | 12/02 | 129 | 12/09 | 128 | 12/16 | 127 | 12/23 | 122 | 12/30 | 134
2012-January | 01/06 | 130 | 01/13 | 129 | 01/20 | 125 | 01/27 | 118
2012-February | 02/03 | 110 | 02/10 | 110 | 02/17 | 103 | 02/24 | 98
2012-March | 03/02 | 103 | 03/09 | 106 | 03/16 | 102 | 03/23 | 118 | 03/30 | 129
2012-April | 04/06 | 125 | 04/13 | 139 | 04/20 | 122 | 04/27 | 123
2012-May | 05/04 | 133 | 05/11 | 119 | 05/18 | 128 | 05/25 | 128
2012-June | 06/01 | 128 | 06/08 | 149 | 06/15 | 141 | 06/22 | 137 | 06/29 | 124
2012-July | 07/06 | 121 | 07/13 | 139 | 07/20 | 132 | 07/27 | 140
2012-August | 08/03 | 127 | 08/10 | 126 | 08/17 | 126 | 08/24 | 115 | 08/31 | 113
2012-September | 09/07 | 110 | 09/14 | 120 | 09/21 | 130 | 09/28 | 131
2012-October | 10/05 | 131 | 10/12 | 132 | 10/19 | 142 | 10/26 | 142
2012-November | 11/02 | 134 | 11/09 | 135 | 11/16 | 117 | 11/23 | 117 | 11/30 | 134
2012-December | 12/07 | 123 | 12/14 | 134 | 12/21 | 134 | 12/28 | 117
2013-January | 01/04 | 125 | 01/11 | 125 | 01/18 | 130 | 01/25 | 134
2013-February | 02/01 | 123 | 02/08 | 112 | 02/15 | 115 | 02/22 | 112
2013-March | 03/01 | 108 | 03/08 | 110 | 03/15 | 92 | 03/22 | 81 | 03/29 | 82
2013-April | 04/05 | 86 | 04/12 | 87 | 04/19 | 93 | 04/26 | 112
2013-May | 05/03 | 113 | 05/10 | 118 | 05/17 | 139 | 05/24 | 136 | 05/31 | 134
2013-June | 06/07 | 138 | 06/14 | 117 | 06/21 | 103 | 06/28 | 105
2013-July | 07/05 | 108 | 07/12 | 109 | 07/19 | 109 | 07/26 | 98
2013-August | 08/02 | 89 | 08/09 | 99 | 08/16 | 101 | 08/23 | 104 | 08/30 | 116
2013-September | 09/06 | 104 | 09/13 | 105 | 09/20 | 108 | 09/27 | 103
2013-October | 10/04 | 106 | 10/11 | 102 | 10/18 | 93 | 10/25 | 81
2013-November | 11/01 | 81 | 11/08 | 89 | 11/15 | 94 | 11/22 | 98 | 11/29 | 102
2013-December | 12/06 | 98 | 12/13 | 96 | 12/20 | 98 | 12/27 | 93
2014-January | 01/03 | 89 | 01/10 | 89 | 01/17 | 91 | 01/24 | 99 | 01/31 | 97
2014-February | 02/07 | 96 | 02/14 | 92 | 02/21 | 85 | 02/28 | 89
2014-March | 03/07 | 97 | 03/14 | 100 | 03/21 | 98 | 03/28 | 95
2014-April | 04/04 | 89 | 04/11 | 90 | 04/18 | 88 | 04/25 | 86
2014-May | 05/02 | 87 | 05/09 | 88 | 05/16 | 90 | 05/23 | 98 | 05/30 | 94
2014-June | 06/06 | 82 | 06/13 | 82 | 06/20 | 81 | 06/27 | 91
2014-July | 07/04 | 100 | 07/11 | 99 | 07/18 | 94 | | 99

a Data obtained from EIA (2014b).

Kerosene exportation between 1987 and 1989 remained relatively constant with a yearly export average of approximately 547,500 barrels. However, by 1990, the annual export of kerosene was 2,190,000 barrels (API 1991), an increase of approximately 400%. Table 5-1 shows that approximately 1,609,977 tonnes (12,557,821 barrels) of kerosene were exported from the United States in 2012; however, several companies claimed these data as CBI and did not report any export volumes publically. Table 5-6 provides the U.S. exports of kerosene-type jet fuels since 1981 as reported by EIA (2014c).

## 5.3 USE

Aviation turbine fuels were not used until the 1930s when the first turbojet engine was developed. Jet-powered aircraft had only limited use in World War II, but further military and commercial developments allowed jet engines to dominate as power sources for aircraft by the 1960s. JP-1 was the first U.S. specification for jet fuel (AN-F-32A, 1944). JP-1 was a kerosene fuel with a maximum freeze point of −60°C and a minimum flash point of 43°C established for operability and safety (Air Force 1987). The flash and freeze points establish boundaries on the minimum and maximum size, respectively, of the hydrocarbon molecules in jet fuel. As fuel specifications evolved, trading off producibility and cost versus performance and safety, the U.S. Air Force settled on JP-4 (MIL-F-5624A, a gasoline-kerosene mix) in the 1950s–1970s, the Navy has used JP-5 (a minimum 60°C flash point kerosene also listed in MIL-F-5624) shipboard since the 1950s, and commercial aviation has used Jet A/Jet A-1 (ASTM D1655, minimum 38°C flash point) since its rapid growth in the 1960s (Air Force 1987b; Dukek and Winans 1969; Edwards 2003). Heavier losses in JP-4 fueled aircraft in Vietnam (versus JP-5) caused the U.S. Air Force to convert to JP-8 in 1980s. As discussed in Chapter 4, JP-8 is the military equivalent to Jet A-1, but contains additive packages that may not be required for commercial jet fuels. Recent studies in the United States have indicated that use of Jet A with its −40°C maximum freeze point was an acceptable and cost-effective alternative to JP-8, so the Air Force is scheduled to complete the conversion to F-24 (Jet A + the additive package) in 2014 for use in the continental United States (Air Force 2013). Thus, setting aside the military additive package, jet fuels world-wide consist almost entirely of the very similar Jet A and Jet A-1, which essentially only differ in freeze point. The composition of these two fuels is very similar, as can be seen in fuel property collections such as the World Fuel Sampling Program (Hadaller and Johnson 2006) and the annual Petroleum Quality Information Service (PQIS) reports by DLA-Energy. For example, in 2012, the PQIS database reported on thousands of samples of Jet A, JP-8, and Jet A-1. The weighted mean freeze points of Jet A/JP-8/Jet A-1 were −49.8, −51.3, and −52.7°C, respectively—much smaller variations than those present within each class of itself. The weighted mean aromatic content of the three fuels were 17.3, 17.1, and 17.6 vol%, respectively—again, much smaller variations than seen within each fuel. Thus, for all intents and purposes, Jet A, JP-8, F-24, and Jet A-1 can be treated as the same fuel in terms of composition and fuel properties, aside from the presence of the military additive package in JP-8 and F-24.

Table 5-5 Weekly U.S. Imports of Kerosene-Type Jet Fuel (Thousand Barrels per Day) Since 2000

| Week 1 | | Week 2 | | Week 3 | | Week 4 | | Week 5
Year-month | End date | Value | End date | Value | End date | Value | End date | Value | End date | Value
2000-January | 01/07 | 53 | 01/14 | 68 | 01/21 | 95 | 01/28 | 189
2000-February | 02/04 | 120 | 02/11 | 162 | 02/18 | 109 | 02/25 | 100
2000-March | 03/03 | 165 | 03/10 | 127 | 03/17 | 126 | 03/24 | 90 | 03/31 | 79
2000-April | 04/07 | 77 | 04/14 | 113 | 04/21 | 109 | 04/28 | 106
2000-May | 05/05 | 149 | 05/12 | 76 | 05/19 | 103 | 05/26 | 163
2000-June | 06/02 | 134 | 06/09 | 141 | 06/16 | 131 | 06/23 | 104 | 06/30 | 142
2000-July | 07/07 | 118 | 07/14 | 115 | 07/21 | 152 | 07/28 | 76
2000-August | 08/04 | 177 | 08/11 | 121 | 08/18 | 174 | 08/25 | 52
2000-September | 09/01 | 125 | 09/08 | 122 | 09/15 | 76 | 09/22 | 140 | 09/29 | 190
2000-October | 10/06 | 128 | 10/13 | 177 | 10/20 | 183 | 10/27 | 173
2000-November | 11/03 | 145 | 11/10 | 205 | 11/17 | 89 | 11/24 | 125
2000-December | 12/01 | 100 | 12/08 | 162 | 12/15 | 82 | 12/22 | 225 | 12/29 | 181
2001-January | 01/05 | 250 | 01/12 | 133 | 01/19 | 250 | 01/26 | 220
2001-February | 02/02 | 238 | 02/09 | 192 | 02/16 | 231 | 02/23 | 221
2001-March | 03/02 | 116 | 03/09 | 237 | 03/16 | 188 | 03/23 | 155 | 03/30 | 91
2001-April | 04/06 | 148 | 04/13 | 156 | 04/20 | 148 | 04/27 | 165
2001-May | 05/04 | 175 | 05/11 | 318 | 05/18 | 97 | 05/25 | 167
2001-June | 06/01 | 144 | 06/08 | 151 | 06/15 | 137 | 06/22 | 94 | 06/29 | 147
2001-July | 07/06 | 168 | 07/13 | 50 | 07/20 | 240 | 07/27 | 241
2001-August | 08/03 | 133 | 08/10 | 176 | 08/17 | 111 | 08/24 | 168 | 08/31 | 120
2001-September | 09/07 | 117 | 09/14 | 212 | 09/21 | 69 | 09/28 | 120
2001-October | 10/05 | 42 | 10/12 | 155 | 10/19 | 130 | 10/26 | 49
2001-November | 11/02 | 36 | 11/09 | 174 | 11/16 | 88 | 11/23 | 71 | 11/30 | 57
2001-December | 12/07 | 85 | 12/14 | 104 | 12/21 | 131 | 12/28 | 68
2002-January | 01/04 | 88 | 01/11 | 105 | 01/18 | 39 | 01/25 | 193
2002-February | 02/01 | 113 | 02/08 | 77 | 02/15 | 146 | 02/22 | 76
2002-March | 03/01 | 105 | 03/08 | 28 | 03/15 | 48 | 03/22 | 135 | 03/29 | 116
2002-April | 04/05 | 106 | 04/12 | 192 | 04/19 | 105 | 04/26 | 87
2002-May | 05/03 | 144 | 05/10 | 78 | 05/17 | 99 | 05/24 | 89 | 05/31 | 59
2002-June | 06/07 | 153 | 06/14 | 127 | 06/21 | 105 | 06/28 | 104
2002-July | 07/05 | 73 | 07/12 | 89 | 07/19 | 53 | 07/26 | 104
2002-August | 08/02 | 69 | 08/09 | 124 | 08/16 | 29 | 08/23 | 166 | 08/30 | 59
2002-September | 09/06 | 145 | 09/13 | 93 | 09/20 | 166 | 09/27 | 86
2002-October | 10/04 | 156 | 10/11 | 143 | 10/18 | 160 | 10/25 | 243
2002-November | 11/01 | 192 | 11/08 | 86 | 11/15 | 123 | 11/22 | 101 | 11/29 | 218
2002-December | 12/06 | 188 | 12/13 | 108 | 12/20 | 68 | 12/27 | 84
2003-January | 01/03 | 192 | 01/10 | 115 | 01/17 | 224 | 01/24 | 75 | 01/31 | 111
2003-February | 02/07 | 82 | 02/14 | 48 | 02/21 | 110 | 02/28 | 107
2003-March | 03/07 | 67 | 03/14 | 164 | 03/21 | 118 | 03/28 | 35
2003-April | 04/04 | 100 | 04/11 | 70 | 04/18 | 97 | 04/25 | 105
2003-May | 05/02 | 143 | 05/09 | 118 | 05/16 | 154 | 05/23 | 99 | 05/30 | 128
2003-June | 06/06 | 165 | 06/13 | 53 | 06/20 | 128 | 06/27 | 216
2003-July | 07/04 | 174 | 07/11 | 168 | 07/18 | 175 | 07/25 | 187
2003-August | 08/01 | 156 | 08/08 | 216 | 08/15 | 118 | 08/22 | 68 | 08/29 | 153
2003-September | 09/05 | 122 | 09/12 | 122 | 09/19 | 149 | 09/26 | 48
2003-October | 10/03 | 108 | 10/10 | 298 | 10/17 | 49 | 10/24 | 90 | 10/31 | 91
2003-November | 11/07 | 86 | 11/14 | 54 | 11/21 | 57 | 11/28 | 69
2003-December | 12/05 | 82 | 12/12 | 128 | 12/19 | 53 | 12/26 | 146
2004-January | 01/02 | 139 | 01/09 | 100 | 01/16 | 108 | 01/23 | 86 | 01/30 | 77
2004-February | 02/06 | 65 | 02/13 | 136 | 02/20 | 86 | 02/27 | 57
2004-March | 03/05 | 101 | 03/12 | 131 | 03/19 | 37 | 03/26 | 68
2004-April | 04/02 | 30 | 04/09 | 59 | 04/16 | 81 | 04/23 | 121 | 04/30 | 59
2004-May | 05/07 | 102 | 05/14 | 173 | 05/21 | 159 | 05/28 | 166
2004-June | 06/04 | 172 | 06/11 | 211 | 06/18 | 80 | 06/25 | 234
2004-July | 07/02 | 160 | 07/09 | 86 | 07/16 | 81 | 07/23 | 67 | 07/30 | 136
2004-August | 08/06 | 179 | 08/13 | 98 | 08/20 | 257 | 08/27 | 103
2004-September | 09/03 | 76 | 09/10 | 95 | 09/17 | 60 | 09/24 | 77
2004-October | 10/01 | 56 | 10/08 | 157 | 10/15 | 153 | 10/22 | 94 | 10/29 | 164
2004-November | 11/05 | 51 | 11/12 | 235 | 11/19 | 163 | 11/26 | 105
2004-December | 12/03 | 110 | 12/10 | 121 | 12/17 | 119 | 12/24 | 85 | 12/31 | 198
2005-January | 01/07 | 30 | 01/14 | 107 | 01/21 | 134 | 01/28 | 76
2005-February | 02/04 | 57 | 02/11 | 143 | 02/18 | 66 | 02/25 | 127
2005-March | 03/04 | 63 | 03/11 | 77 | 03/18 | 88 | 03/25 | 145
2005-April | 04/01 | 200 | 04/08 | 51 | 04/15 | 111 | 04/22 | 49 | 04/29 | 75
2005-May | 05/06 | 170 | 05/13 | 100 | 05/20 | 116 | 05/27 | 39
2005-June | 06/03 | 48 | 06/10 | 75 | 06/17 | 86 | 06/24 | 107
2005-July | 07/01 | 56 | 07/08 | 22 | 07/15 | 165 | 07/22 | 81 | 07/29 | 68
2005-August | 08/05 | 80 | 08/12 | 39 | 08/19 | 31 | 08/26 | 165
2005-September | 09/02 | 105 | 09/09 | 143 | 09/16 | 185 | 09/23 | 191 | 09/30 | 159
2005-October | 10/07 | 179 | 10/14 | 221 | 10/21 | 319 | 10/28 | 301
2005-November | 11/04 | 444 | 11/11 | 249 | 11/18 | 139 | 11/25 | 183
2005-December | 12/02 | 183 | 12/09 | 400 | 12/16 | 138 | 12/23 | 258 | 12/30 | 167
2006-January | 01/06 | 122 | 01/13 | 154 | 01/20 | 182 | 01/27 | 42
2006-February | 02/03 | 174 | 02/10 | 66 | 02/17 | 143 | 02/24 | 87
2006-March | 03/03 | 104 | 03/10 | 106 | 03/17 | 102 | 03/24 | 161 | 03/31 | 123
2006-April | 04/07 | 70 | 04/14 | 254 | 04/21 | 190 | 04/28 | 262
2006-May | 05/05 | 209 | 05/12 | 112 | 05/19 | 256 | 05/26 | 345
2006-June | 06/02 | 221 | 06/09 | 100 | 06/16 | 183 | 06/23 | 188 | 06/30 | 263
2006-July | 07/07 | 225 | 07/14 | 172 | 07/21 | 167 | 07/28 | 224
2006-August | 08/04 | 205 | 08/11 | 300 | 08/18 | 399 | 08/25 | 266
2006-September | 09/01 | 119 | 09/08 | 124 | 09/15 | 292 | 09/22 | 158 | 09/29 | 200
2006-October | 10/06 | 215 | 10/13 | 399 | 10/20 | 182 | 10/27 | 201
2006-November | 11/03 | 186 | 11/10 | 78 | 11/17 | 127 | 11/24 | 96
2006-December | 12/01 | 141 | 12/08 | 247 | 12/15 | 107 | 12/22 | 163 | 12/29 | 249
2007-January | 01/05 | 270 | 01/12 | 137 | 01/19 | 196 | 01/26 | 261
2007-February | 02/02 | 203 | 02/09 | 232 | 02/16 | 221 | 02/23 | 286
2007-March | 03/02 | 188 | 03/09 | 372 | 03/16 | 238 | 03/23 | 263 | 03/30 | 165
2007-April | 04/06 | 294 | 04/13 | 336 | 04/20 | 297 | 04/27 | 233
2007-May | 05/04 | 324 | 05/11 | 264 | 05/18 | 162 | 05/25 | 294
2007-June | 06/01 | 237 | 06/08 | 312 | 06/15 | 191 | 06/22 | 230 | 06/29 | 293
2007-July | 07/06 | 305 | 07/13 | 194 | 07/20 | 189 | 07/27 | 265
2007-August | 08/03 | 247 | 08/10 | 231 | 08/17 | 283 | 08/24 | 203 | 08/31 | 224
2007-September | 09/07 | 194 | 09/14 | 200 | 09/21 | 268 | 09/28 | 112
2007-October | 10/05 | 246 | 10/12 | 191 | 10/19 | 235 | 10/26 | 174
2007-November | 11/02 | 191 | 11/09 | 152 | 11/16 | 196 | 11/23 | 220 | 11/30 | 240
2007-December | 12/07 | 146 | 12/14 | 190 | 12/21 | 153 | 12/28 | 135
2008-January | 01/04 | 166 | 01/11 | 85 | 01/18 | 56 | 01/25 | 182
2008-February | 02/01 | 209 | 02/08 | 157 | 02/15 | 71 | 02/22 | 132 | 02/29 | 87
2008-March | 03/07 | 258 | 03/14 | 298 | 03/21 | 41 | 03/28 | 111
2008-April | 04/04 | 203 | 04/11 | 318 | 04/18 | 178 | 04/25 | 114
2008-May | 05/02 | 131 | 05/09 | 300 | 05/16 | 161 | 05/23 | 116 | 05/30 | 162
2008-June | 06/06 | 109 | 06/13 | 86 | 06/20 | 114 | 06/27 | 66
2008-July | 07/04 | 34 | 07/11 | 98 | 07/18 | 63 | 07/25 | 119
2008-August | 08/01 | 59 | 08/08 | 74 | 08/15 | 95 | 08/22 | 67 | 08/29 | 50
2008-September | 09/05 | 26 | 09/12 | 79 | 09/19 | 68 | 09/26 | 145
2008-October | 10/03 | 151 | 10/10 | 73 | 10/17 | 85 | 10/24 | 38 | 10/31 | 136
2008-November | 11/07 | 36 | 11/14 | 88 | 11/21 | 77 | 11/28 | 45
2008-December | 12/05 | 26 | 12/12 | 45 | 12/19 | 111 | 12/26 | 54
2009-January | 01/02 | 56 | 01/09 | 10 | 01/16 | 69 | 01/23 | 101 | 01/30 | 16
2009-February | 02/06 | 111 | 02/13 | 23 | 02/20 | 60 | 02/27 | 59
2009-March | 03/06 | 47 | 03/13 | 155 | 03/20 | 56 | 03/27 | 150
2009-April | 04/03 | 29 | 04/10 | 76 | 04/17 | 115 | 04/24 | 56
2009-May | 05/01 | 123 | 05/08 | 58 | 05/15 | 170 | 05/22 | 73 | 05/29 | 102
2009-June | 06/05 | 67 | 06/12 | 51 | 06/19 | 98 | 06/26 | 61
2009-July | 07/03 | 99 | 07/10 | 76 | 07/17 | 93 | 07/24 | 68 | 07/31 | 161
2009-August | 08/07 | 76 | 08/14 | 67 | 08/21 | 98 | 08/28 | 112
2009-September | 09/04 | 93 | 09/11 | 85 | 09/18 | 123 | 09/25 | 115
2009-October | 10/02 | 93 | 10/09 | 89 | 10/16 | 74 | 10/23 | 107 | 10/30 | 86
2009-November | 11/06 | 35 | 11/13 | 82 | 11/20 | 102 | 11/27 | 63
2009-December | 12/04 | 96 | 12/11 | 57 | 12/18 | 77 | 12/25 | 65
2010-January | 01/01 | 102 | 01/08 | 87 | 01/15 | 108 | 01/22 | 140 | 01/29 | 116
2010-February | 02/05 | 109 | 02/12 | 64 | 02/19 | 102 | 02/26 | 61
2010-March | 03/05 | 99 | 03/12 | 20 | 03/19 | 77 | 03/26 | 92
2010-April | 04/02 | 55 | 04/09 | 86 | 04/16 | 99 | 04/23 | 91 | 04/30 | 128
2010-May | 05/07 | 67 | 05/14 | 36 | 05/21 | 67 | 05/28 | 86
2010-June | 06/04 | 64 | 06/11 | 62 | 06/18 | 51 | 06/25 | 54
2010-July | 07/02 | 118 | 07/09 | 59 | 07/16 | 78 | 07/23 | 86 | 07/30 | 65
2010-August | 08/06 | 70 | 08/13 | 77 | 08/20 | 93 | 08/27 | 69
2010-September | 09/03 | 94 | 09/10 | 136 | 09/17 | 98 | 09/24 | 120
2010-October | 10/01 | 28 | 10/08 | 64 | 10/15 | 80 | 10/22 | 37 | 10/29 | 74
2010-November | 11/05 | 53 | 11/12 | 31 | 11/19 | 113 | 11/26 | 35
2010-December | 12/03 | 130 | 12/10 | 29 | 12/17 | 60 | 12/24 | 41 | 12/31 | 81
2011-January | 01/07 | 79 | 01/14 | 63 | 01/21 | 16 | 01/28 | 127
2011-February | 02/04 | 61 | 02/11 | 61 | 02/18 | 24 | 02/25 | 51
2011-March | 03/04 | 16 | 03/11 | 14 | 03/18 | 27 | 03/25 | 101
2011-April | 04/01 | 64 | 04/08 | 68 | 04/15 | 79 | 04/22 | 128 | 04/29 | 54
2011-May | 05/06 | 72 | 05/13 | 102 | 05/20 | 73 | 05/27 | 63
2011-June | 06/03 | 98 | 06/10 | 86 | 06/17 | 72 | 06/24 | 53
2011-July | 07/01 | 53 | 07/08 | 73 | 07/15 | 114 | 07/22 | 80 | 07/29 | 108
2011-August | 08/05 | 75 | 08/12 | 18 | 08/19 | 18 | 08/26 | 39
2011-September | 09/02 | 15 | 09/09 | 4 | 09/16 | 14 | 09/23 | 55 | 09/30 | 7
2011-October | 10/07 | 86 | 10/14 | 48 | 10/21 | 45 | 10/28 | 32
2011-November | 11/04 | 116 | 11/11 | 58 | 11/18 | 49 | 11/25 | 79
2011-December | 12/02 | 29 | 12/09 | 10 | 12/16 | 9 | 12/23 | 39 | 12/30 | 36
2012-January | 01/06 | 7 | 01/13 | 1 | 01/20 | 4 | 01/27 | 7
2012-February | 02/03 | 5 | 02/10 | 87 | 02/17 | 28 | 02/24 | 52
2012-March | 03/02 | 34 | 03/09 | 4 | 03/16 | 3 | 03/23 | 7 | 03/30 | 55
2012-April | 04/06 | 11 | 04/13 | 98 | 04/20 | 11 | 04/27 | 10
2012-May | 05/04 | 5 | 05/11 | 36 | 05/18 | 93 | 05/25 | 56
2012-June | 06/01 | 3 | 06/08 | 57 | 06/15 | 4 | 06/22 | 4 | 06/29 | 0
2012-July | 07/06 | 3 | 07/13 | 2 | 07/20 | 52 | 07/27 | 59
2012-August | 08/03 | 33 | 08/10 | 57 | 08/17 | 33 | 08/24 | 105 | 08/31 | 95
2012-September | 09/07 | 73 | 09/14 | 142 | 09/21 | 35 | 09/28 | 113
2012-October | 10/05 | 16 | 10/12 | 111 | 10/19 | 153 | 10/26 | 136
2012-November | 11/02 | 16 | 11/09 | 51 | 11/16 | 5 | 11/23 | 25 | 11/30 | 26
2012-December | 12/07 | 53 | 12/14 | 25 | 12/21 | 0 | 12/28 | 0
2013-January | 01/04 | 63 | 01/11 | 0 | 01/18 | 2 | 01/25 | 96
2013-February | 02/01 | 54 | 02/08 | 47 | 02/15 | 45 | 02/22 | 77
2013-March | 03/01 | 23 | 03/08 | 34 | 03/15 | 44 | 03/22 | 4 | 03/29 | 0
2013-April | 04/05 | 0 | 04/12 | 83 | 04/19 | 37 | 04/26 | 0
2013-May | 05/03 | 21 | 05/10 | 35 | 05/17 | 35 | 05/24 | 46 | 05/31 | 136
2013-June | 06/07 | 76 | 06/14 | 70 | 06/21 | 108 | 06/28 | 73
2013-July | 07/05 | 47 | 07/12 | 99 | 07/19 | 46 | 07/26 | 6
2013-August | 08/02 | 63 | 08/09 | 193 | 08/16 | 55 | 08/23 | 117 | 08/30 | 148
2013-September | 09/06 | 85 | 09/13 | 67 | 09/20 | 96 | 09/27 | 73
2013-October | 10/04 | 45 | 10/11 | 50 | 10/18 | 52 | 10/25 | 80
2013-November | 11/01 | 53 | 11/08 | 55 | 11/15 | 77 | 11/22 | 123 | 11/29 | 18
2013-December | 12/06 | 25 | 12/13 | 63 | 12/20 | 46 | 12/27 | 31
2014-January | 01/03 | 61 | 01/10 | 48 | 01/17 | 59 | 01/24 | 77 | 01/31 | 16
2014-February | 02/07 | 98 | 02/14 | 94 | 02/21 | 58 | 02/28 | 10
2014-March | 03/07 | 84 | 03/14 | 8 | 03/21 | 96 | 03/28 | 107
2014-April | 04/04 | 129 | 04/11 | 218 | 04/18 | 130 | 04/25 | 15
2014-May | 05/02 | 124 | 05/09 | 73 | 05/16 | 78 | 05/23 | 137 | 05/30 | 34
2014-June | 06/06 | 92 | 06/13 | 28 | 06/20 | 196 | 06/27 | 154
2014-July | 07/04 | 103 | 07/11 | 71 | 07/18 | 122

a Data obtained from EIA (2014b).

Table 5-6 Monthly U.S. Exports of Kerosene-Type Jet Fuel (Thousand Barrels per Month) Since 1981^a^

Year | January | February | March | April | May | June | July | August | September | October | November | December
1981 | 28 | 21 | 10 | 18 | 16 | 12 | 19 | 22 | 20 | 14 | 23 | 222
1982 | 255 | 245 | 80 | 44 | 27 | 38 | 32 | 32 | 41 | 35 | 269 | 692
1983 | 272 | 223 | 27 | 17 | 40 | 21 | 37 | 193 | 270 | 24 | 373 | 458
1984 | 318 | 68 | 21 | 148 | 22 | 191 | 306 | 52 | 27 | 158 | 329 | 738
1985 | 79 | 624 | 182 | 149 | 147 | 102 | 106 | 660 | 133 | 773 | 848 | 559
1986 | 1,188 | 429 | 333 | 371 | 428 | 184 | 300 | 138 | 420 | 778 | 668 | 626
1987 | 1,404 | 565 | 214 | 121 | 117 | 146 | 139 | 74 | 1,029 | 1,086 | 1,336 | 2,287
1988 | 2,524 | 974 | 1,624 | 392 | 119 | 463 | 107 | 440 | 265 | 54 | 271 | 2,470
1989 | 2,297 | 566 | 19 | 477 | 36 | 35 | 287 | 467 | 1,018 | 849 | 1,183 | 1,309
1990 | 668 | 1,393 | 515 | 331 | 238 | 207 | 302 | 927 | 1,349 | 2,246 | 4,218 | 1,854
1991 | 2,265 | 4,393 | 1,197 | 758 | 1,047 | 391 | 840 | 326 | 295 | 1,342 | 137 | 1,273
1992 | 1,375 | 1,168 | 194 | 368 | 202 | 583 | 1,623 | 500 | 333 | 1,266 | 1,125 | 3,439
1993 | 2,976 | 451 | 2,575 | 1,833 | 1,460 | 1,035 | 1,799 | 1,017 | 414 | 396 | 765 | 1,063
1994 | 561 | 722 | 445 | 71 | 282 | 305 | 340 | 311 | 784 | 541 | 524 | 1,002
1995 | 766 | 545 | 528 | 138 | 221 | 311 | 572 | 535 | 587 | 1,774 | 387 | 1,940
1996 | 3,443 | 1,929 | 1,543 | 333 | 414 | 325 | 837 | 1,040 | 1,525 | 821 | 1,340 | 3,418
1997 | 2,407 | 635 | 342 | 621 | 275 | 1,146 | 1,004 | 819 | 471 | 1,214 | 1,325 | 2,429
1998 | 1,137 | 710 | 899 | 957 | 702 | 737 | 796 | 225 | 751 | 663 | 722 | 506
1999 | 785 | 225 | 697 | 736 | 997 | 792 | 1,073 | 246 | 995 | 800 | 1,825 | 1,585
2000 | 408 | 503 | 1,030 | 1,111 | 1,095 | 798 | 641 | 583 | 1,008 | 1,289 | 1,902 | 1,221
2001 | 839 | 437 | 1,262 | 506 | 513 | 544 | 722 | 743 | 620 | 966 | 1,917 | 1,426
2002 | 264 | 1,130 | 62 | 38 | 94 | 29 | 67 | 50 | 424 | 39 | 351 | 447
2003 | 1,125 | 519 | 1,067 | 1,018 | 603 | 200 | 373 | 214 | 588 | 883 | 295 | 549
2004 | 678 | 556 | 1,211 | 571 | 916 | 850 | 318 | 1,600 | 2,314 | 1,566 | 1,641 | 2,579
2005 | 878 | 1,875 | 2,235 | 2,927 | 3,575 | 2,040 | 1,428 | 1,706 | 469 | 351 | 1,068 | 651
2006 | 742 | 712 | 1,105 | 1,263 | 1,005 | 1,005 | 1,050 | 1,518 | 1,789 | 1,724 | 1,481 | 1,477
2007 | 1,213 | 870 | 1,631 | 1,024 | 602 | 754 | 1,641 | 826 | 1,257 | 1,017 | 2,750 | 1,427
2008 | 1,836 | 1,956 | 1,984 | 959 | 2,346 | 2,590 | 2,899 | 1,910 | 860 | 1,876 | 1,547 | 1,627
2009 | 2,379 | 1,171 | 1,899 | 1,981 | 2,656 | 1,270 | 1,505 | 1,688 | 1,901 | 2,949 | 2,226 | 3,605
2010 | 3,514 | 1,852 | 2,173 | 2,281 | 2,441 | 1,701 | 2,539 | 2,630 | 2,426 | 1,973 | 3,082 | 4,141
2011 | 3,906 | 2,786 | 2,715 | 3,059 | 1,733 | 2,221 | 3,390 | 2,806 | 3,089 | 2,419 | 3,173 | 4,027
2012 | 3,562 | 3,650 | 3,090 | 2,697 | 3,864 | 4,562 | 4,390 | 3,410 | 3,920 | 4,637 | 4,801 | 5,874
2013 | 5,014 | 3,188 | 4,093 | 4,129 | 4,150 | 5,407 | 4,938 | 6,020 | 4,217 | 4,304 | 6,419 | 6,262
2014 | 4,268 | 4,058 | 4,322 | 3,414

a Data obtained from EIA (2014c).

## 5.4 DISPOSAL

Vapors generated in tank truck loading of jet fuels can be disposed of by the installation of a vapor recovery system (NIOSH 1989). Runoff of jet fuels from loading and unloading aircraft operations can be separated by an on-site oil/water separation system.

Several methods have been investigated for the disposal of jet fuels spilled onto soil from normal aircraft operations or from accidental spills. One method, in situ soil venting, involves using vacuum blowers to pull large amounts of air through soil contaminated with jet fuels (Elliot and DePaoli 1990). The vacuum pulls out the soil gas, and the jet fuel contaminants volatilize as a result of disrupted equilibrium. Incineration of free-product extracted from contaminated media is another method of disposal proposed for soils and water contaminated with jet fuels (OHM/TADS 1985). Incineration of soils contaminated with jet fuels has also been investigated (OHM/TADS 1985). Other methods include absorption (straw, polyurethane foam, activated carbon, and peat have been used as absorbents), gelling agents, combustion promoters, dispersants, and mechanical systems (OHM/TADS 1985). Biodegradation has also been suggested as a means of disposal for spills onto soil (OHM/TADS 1985). Hydrocarbon-degrading bacteria have been shown to degrade petroleum products into smaller units and eventually into nonseparable particles (Butt et al. 1988). Soil contaminated with jet fuel no. 1 was found to have a growth response of 10^6^ colony-forming units per mL in 7 out of 21 types of bacteria isolated for sample study (Butt et al. 1988). For more information on biodegradation, refer to Chapter 5.

Wastes containing Jet A, JP-5, and JP-8 are considered hazardous if they meet certain criteria specified by law. Hazardous wastes are subject to the handling, transport, treatment, storage, and disposal regulations as promulgated under the Resource Conservation and Recovery Act (IRPTC 1985). Regulations governing the treatment and disposal of wastes containing JP-5, JP-8, and Jet A fuels are detailed in Chapter 7.