# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## JP-5 vapor Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | JP-5 vapor
CAS Number: | 8008-20-6
Date: | March 2017
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 23
Species: | Mouse

[underlined: Minimal Risk Level]: 2 [ ] mg/kg/day [X] mg/m^3^

[underlined: Reference]: Gaworski CL, MacEwen JD, Vernot EH, et al. 1984. Comparison of the subchronic inhalation toxicity of petroleum and oil shale JP-5 jet fuels. In: MacFarland HN, Holdsworth CE, MacGregor JA, et al., eds. Advances in modern environmental toxicology. Volume VI: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, 33–47.

[underlined: Experimental design]: Groups of approximately 35 female C57BL/6 mice were exposed by inhalation to petroleum-based JP-5 vapor at 0, 150, or 750 mg/m^3^ continuously for 90 days. End points evaluated included: clinical signs, body weight (measured monthly), and histopathological examination of major tissues (adrenals, anus, bladder, brain, colon, duodenum, esophagus, gall bladder, heart, ileum, kidneys, larynx, liver, lungs and bronchi, mammary gland, mandibular lymph node, nasal cavity, ovaries, pancreas, parathyroids, pituitary, prostate, salivary gland, sciatic nerve, seminal vesicles, skin, spleen, bone-sternebrae, vertebrae or femur plus marrow, stomach, testes, thigh muscle, thymus, thyroid, trachea, and uterus).

[underlined: Effect noted in study and corresponding doses]: No effect on body weight gain was noted. The only remarkable finding in mice was hepatocellular fatty changes and vacuolization at 150 and 750 mg/m^3^. The incidences were 8/37 (22%), 29/33 (88%), and 23/34 (68%) in the 0, 150, and 750 mg/m^3^ groups, respectively.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] minimal LOAEL

150 mg/m^3^; hepatocellular fatty changes and vacuolization.

[underlined: Uncertainty Factors used in MRL derivation]:

- [x] 3 for use of a minimal LOAEL
- [x] 3 for extrapolation from animals to humans with dosimetric adjustments
- [x] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: A human equivalent concentration (HEC) of 150 mg/m^3^ was calculated by multiplying the mouse LOAEL by the ratio of the blood:gas partition coefficients in humans and animals. Because blood:gas partition coefficients are not measurable for a complex mixture such as JP-5, the default ratio of 1 was used (EPA 1994).

150 mg / m^3^ × 1 = 150 mg / m^3^

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The intermediate-duration toxicity of inhaled JP-5 has been investigated in rats, mice, and dogs. In male rats, the most sensitive effect is an increase in the occurrence of hyaline droplets in the proximal renal tubules, which was observed in rats continuously exposed to ≥150 mg/m^3^ JP-5 vapor (Gaworski et al. 1984). This effect, which is only observed in male rats, is due to an accumulation of alpha_2u_-globulin in hyaline droplets and is not considered relevant to humans (EPA 1991a; Flamm and Lehman-McKeeman 1991; Hard et al. 1993; Swenberg 1993). No adverse effects were observed in female rats exposed to ≤750 mg/m^3^ JP-5 vapor (Gaworski et al. 1984). Similar to mice, the liver appears to be the most sensitive target of toxicity in dogs; diffuse hepatocellular swelling was observed in male and female dogs continuously exposed to ≥150 mg/m^3^ JP-5 vapor (Gaworski et al. 1984). The nervous system was the only other target examined in intermediate JP-5 studies. An evaluation of neurobehavioral performance in rats found increased forelimb grip strength in rats similarly exposed to 1,200 mg/m^3^ JP-5 vapor (Rossi et al. 2001); no alterations in other neurobehavioral tests were found.

Studies with JP-8 have also identified the immune system as a sensitive target of toxicity; based on the similarity between JP-5 and JP-8, it is likely that the immune system will also be a relevant target of JP-5. The lowest reliable LOAEL for immunotoxicity following acute-duration inhalation exposure to JP-8 was 1,000 mg/m^3^ identified in rats exposed to JP-8 vapor and aerosol 1 hour/day for 7 days (Hilgaertner et al. 2011).

[underlined: Agency Contacts (Chemical Managers)]: John Risher and Obaid Faroon

## JP-8 vapor Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | JP-8 vapor
CAS Number: | 8008-20-6
Date: | March 2017
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 31
Species: | Rat

[underlined: Minimal Risk Level]: 3 [ ] mg/kg/day [X] mg/m^3^

[underlined: Reference]: Ritchie GD, Rossi J, Nordholm AF, et al. 2001. Effects of repeated exposure to JP-8 jet fuel vapor on learning of simple and difficult operant tasks by rats. J Toxicol Environ Health, Part A 64: 385–415.

[underlined: Experimental design]: Groups of male Sprague-Dawley rats (16/group) were exposed whole-body to 0, 500, or 1,000 mg/m^3^ JP-8 fuel vapors 6 hours/day, 5 days/week for 6 weeks. Sixty-five days after exposure termination, the rats underwent simple and difficult operant tasks (lever acquisition, fixed ratio, lever spatial reversal, stimulus reversal, and incremental repeated acquisition in order of increasing difficulty). After the neurobehavioral testing, 4 rats/group were killed and the brains were dissected and processed for determination of neurotransmitters and their metabolites.

[underlined: Effect noted in study and corresponding doses]: Exposure to 1,000 mg/m^3^ JP-8 fuel vapors induced significant deficits in acquisition or performance of the two most difficult tasks, but not in the simple learning tasks compared to rats in the low-exposure group. Learning/performance of complex tasks in the low-exposure group generally exceeded performance of control rats, while learning by high-exposure rats was almost always inferior to control rats, suggesting possible neurobehavioral hormesis. Neurochemical analyses showed significantly increased levels of dopamine in the cerebral cortex and DOPAC (major dopamine metabolite) in the brainstem for as long as 180 days post-exposure in both exposed groups relative to controls. This could have resulted from solvent-induced reductions in cyclic guanosine monophosphate (GMP) that is involved in signal transduction in specific brain regions.

[underlined: Dose and end point used for MRL derivation]:

[X] NOAEL [ ] LOAEL

The MRL is based on a NOAEL of 500 mg/m^3^ and LOAEL of 1,000 mg/m^3^ for neurotoxicity.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans with dosimetric adjustments
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

If an inhalation study in animals, list conversion factors used in determining human equivalent dose: A NOAEL_HEC_ of 89 mg/m^3^ was calculated by multiplying the NOAEL_ADJ_ by the ratio of the blood:gas partition coefficients in humans and animals. Because blood:gas partition coefficients are not measurable for a complex mixture such as JP-8, the default ratio of 1 was used (EPA 1994).

89 mg / m^3^ × 1 = 89 mg / m^3^

[underlined: Was a conversion used from intermittent to continuous exposure]? The NOAEL of 500 mg/m^3^ was adjusted for intermittent exposure:

NOAEL_ADJ_ = 500 mg / m^3^ × 6 hours / 24 hours × 5 days / 7 days = 89 mg / m^3^

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Two studies have examined the systemic toxicity of JP-8 following intermediate-duration inhalation exposure. Mattie et al. (1991) reported an increase in hyaline nephropathy in male rats continuously exposed to ≥500 mg/m^3^ JP-8 vapor for 90 days. No other effects were observed in the male rats and no effects were observed in the female rats; the highest concentration tested was 1,000 mg/m^3^. In contrast, Hanas et al. (2010) reported a number of adverse effects in male rats exposed to JP-8 vapor 6 hours/day for 91 days. At 250 mg/m^3^ proximal tubular damage was observed in the kidneys; enlarged alveolar capillaries, myocardial scarring, reduction in fat cells/globules in bone marrow, and dilated sinusoids and fatty hepatocytes were observed at 500 mg/m^3^. Interpretation of the results of the Hanas et al. (2010) study is limited by the small number of animals tested (3/group). The renal effects observed in the Mattie et al. (1991) and Hanas et al. (2010) studies are characteristic of alpha_2u_-globulin nephropathy, which is not considered a relevant effect in humans (EPA 1991a; Flamm and Lehman-McKeeman 1991; Hard et al. 1993; Swenberg 1993).

A 6-week study conducted by Rossi et al. (2001) also evaluated the neurotoxicity of JP-8 in rats exposed for 6 weeks. An alteration in a novel appetitive stimulus test was observed in rats exposed to 1,000 mg/m^3^ JP-8 vapor; the investigators suggested that this test quantified dopamine system sensitization in the rat. No other alterations in neurobehavioral tests were found. Studies by Fechter et al. (2012) and Guthrie et al. (2014, 2015) evaluated the potential of JP-8 to damage the auditory system. No significant alterations in auditory function was observed in rats exposed to 1,500 mg/m^3^ JP-8 vapor for 4 weeks (Fechter et al. 2012); however, if the rats were also exposed to non-damaging noise, there was damage to the auditory function. Central auditory processing dysfunction was observed in rats exposed to 1,000 mg/m^3^ JP-8 vapor for 4 weeks; however, no damage to peripheral auditory function, including damage to cochlear hair cells, was observed (Guthrie et al. 2014, 2015).

In addition to these studies, three University of Arizona studies have reported edema and inflammation of the terminal bronchioles in rats exposed 1 hour/day for 28 or 56 days to JP-8 aerosols and vapors (Hays et al. 1995; Pfaff et al. 1995, 1996). Hays et al. (1995) also found increased lung epithelial permeability and alveolar permeability. None of the three studies measured the vapor component of the test atmosphere (see Section 3.2.1 for a discussion of these studies).

[underlined: Agency Contacts (Chemical Managers)]: John Risher and Obaid Faroon

## JP-8 Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | JP-8
CAS Number: | 8008-20-6
Date: | March 2017
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 11
Species: | Mouse

[underlined: Minimal Risk Level]: 3 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: Keil D, Dudley A, EuDaly JG, et al. 2004. Immunological and hematological effects observed in B6C3F1 mice exposed to JP-8 jet fuel for 14 days. J Toxicol Environ Health Part A 67:1109–1129.

[underlined: Experimental design]: The study examined the effects of JP-8 fuel on humoral and cell-mediated and hematological parameters in female B6C3F1 mice. Groups of mice (4–6/group) were administered doses of JP-8 fuel ranging from 250 to 2,000 mg/kg/day by gavage in olive oil for 14 days. End points monitored included body weight; weight of the liver, kidneys, spleen, and thymus; spleen and thymus cellularity; lymphocyte proliferation; natural killer (NK) cell activity; antibody plaque-forming cells assay; splenic and thymic CD4/CD8 subpopulations; and bone marrow cellularity and colony-forming units.

[underlined: Effect noted in study and corresponding doses]: There were no clinical signs during the study. There was a trend for increase in body weight gain, but there was no statistical significance. Relative kidney weight was not affected, but liver weight was significantly increased at ≥1,000 mg/kg/day (23%). Significant hematological alterations included decreases in hemoglobin levels, hematocrit levels, and red blood cell counts and increases in mean corpuscular volume at 2,500 mg/kg/day; mean corpuscular volume was also increased at 1,500 and 2,000 mg/kg/day. All of these changes were ≤7% relative to controls and probably of no toxicological significance. There were no significant changes in peripheral blood differential count. An increase in colony forming units was observed in the bone marrow of mice administered 2,000 mg/kg/day, but there were no alterations in bone marrow cellularity. A significant decrease in cellularity was observed in the thymus at 2,000 mg/kg/day; no alterations were observed in the spleen. No significant alterations in mitogen-induced T or B cell proliferation or alterations in NK activity were observed. In response to sheep red blood cells (SRBCs), there were significant suppression of IgM antibody production (when assessed using antibody plague-forming cell response) at doses ≥500 mg/kg/day. However, there were no significant alterations in serum levels of anti-SRBC IgM when measured by ELISA or hemagglutination. In the spleen, there were no alterations in the percentage of individual T-cell phenotypes or the ratio of CD4+ to CD8+ cells; however, decreases in CD4^−^/CD8^−^ cells were observed at 1,000 and 2,000 mg/kg/day. In contrast, there were significant decreases in the absolute values of CD8^+^, CD4^+^, and CD4^+^/CD8^+^ T-cell subpopulations in the thymus in mice administered 2,000 mg/kg/day.

[underlined: Dose and end point used for MRL derivation]:

[X] NOAEL [ ] LOAEL

The MRL is based on a NOAEL of 250 mg/kg/day and LOAEL of 500 mg/kg/day for an impaired response to SRBCs.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The available data on the acute-toxicity of JP-8 primarily focused on immunotoxicity. Altered immune function (response to SRBCs) was observed in mice administered 1,000 mg/kg/day JP-8 for 7 days (Dudley et al. 2001) or 500 mg/kg/day for 14 days (Keil et al. 2004; Peden-Adams et al. 2001). At higher doses, decreases in thymus weight and cellularity were observed (Dudley et al. 2001). Impaired immune response was also observed in the offspring of mice administered 1,000 mg/kg/day on GDs 6–15 (Keil et al. 2003). In another developmental toxicity study (Cooper and Mattie 1996), a decrease in fetal body weight was observed at a dose (1,000 mg/kg/day) that also resulted in decreased maternal weight gain and mortality.

Although the acute-duration studies did not examine the potential for systemic toxicity, intermediate-duration JP-8 oral studies suggest that systemic effects such as liver toxicity would occur at higher doses than the LOAEL for immunotoxicity (Mattie et al. 1995, 2000).

[underlined: Agency Contacts (Chemical Managers)]: John Risher and Obaid Faroon

## JP-8 Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | JP-8
CAS Number: | 8008-20-6
Date: | March 2017
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 28
Species: | Rat

[underlined: Minimal Risk Level]: 0.3 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: Mattie DR, Cooper JR, Sterner TR, et al. 2001. Developmental neurobehavioral effects on JP-8 jet fuel on pups from female Sprague-Dawley rats exposed by oral gavage. Wright-Patterson, AFB: OH: Air Force Research Laboratory. 22. ARFL-HE-WP-TR-2001–0186. ADA428272.

[underlined: Experimental design]: The study examined neurobehavioral parameters in pups from rats exposed to JP-8 fuel for a total of 21 weeks (90 days followed by cohabitation, gestation, delivery, and lactation). Groups of rats (35/groups) were administered 0, 325, 750, or 1,500 mg/kg neat JP-8 fuel by gavage. Litters were standardized to four male and four female pups on PND 4. Pup weights were recorded on PNDs 1, 4, 14, 21, and 90. Male pups were checked for descent of testes on PND 21 or 22. Female pups were checked for vaginal opening on PND 30. The following neurobehavioral tests were conducted: surface righting (beginning PND 4), negative geotaxis (beginning PND 5), swimming development (PNDs 6–20), and water maze (PNDs 70 and 77)

[underlined: Effect noted in study and corresponding doses]: The results showed a significant alteration in the total score for the swimming development test at ≥325 mg/kg/day on PND 8 and at 750 and 1,500 mg/kg/day on PND 14; however, no significant alterations in total score were observed on PNDs 10, 12, 16, 18, or 20. The alterations in the total scores were primarily due to swimming direction scores; significant decreases in direction scores were observed on PND 6 (750 and 1,500 mg/kg/day), PND 8 (≥325 mg/kg/day), and PND 14 (750 and 1,500 mg/kg/day); no alterations in angle of head or limb usage scores were observed at any time point. No significant alterations in surface righting (tested on PND 4), negative geotaxis (tested on PND 5), or water maze performance (tested on PNDs 70 and 77) were observed. The investigators suggested that the results in the swimming development test were indicative of a possible developmental delay in motor coordination; however, the delay did not affect motor ability at later ages.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] LOAEL

The MRL is based on a LOAEL of 325 mg/kg/day for neurodevelopmental effects.

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Two studies have evaluated the intermediate-duration oral toxicity of JP-8 (Mattie et al. 1995, 2000). Administration of 750 mg/kg/day resulted in increases in serum ALT and AST activities in male rats, stomach hyperplasia in male and female rats, hypoglycemia in male rats, perianal dermatitis in male rats, and hyaline droplet formation in the kidneys of male rats; perianal dermatitis was also observed in female rats at 1,500 mg/kg/day. The third study in the intermediate-duration database was the Mattie et al. (2001) developmental study, which was the basis of the MRL.

Acute-duration oral studies suggest that the immune system is also a sensitive target of JP-8 toxicity; however, this end po int has not been investigated following intermediate-duration exposure. The lowest LOAEL for immune effects identified in oral exposure studies was 500 mg/kg/day for an impaired response to SRBCs (Keil et al. 2004). Since the LOAEL for neurodevelopmental is similar to this LOAEL, the intermediate MRL should be protective for potential immune effects.

[underlined: Agency Contacts (Chemical Managers)]: John Risher and Obaid Faroon