# CHAPTER 8 REFERENCES

*Cited in text

*ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. Fifth ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 1988. TLVs Threshold Limit Values and biological exposure indices for 1988–1989. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 2001. Isophorone. ACGIH Documentation of the threshold limit values and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*Alden CL. 1986. A review of unique male rat hydrocarbon nephropathy. Toxicol Pathol 14(1):109–111.2424069
*Altshuller AP, Bufalini JJ. 1971. Photochemical aspects of air pollution: A review. Environ Sci Technol 5:39–64.
*AME Inc. 1972a. 90-Day subchronic toxicity of isophorone in the rat (final report). Submitted by Affiliated Medical Enterprises, Inc. to the U.S. Environmental Protection Agency under TSCA 8D. OTS0205975.
*AME Inc. 1972b. 90-day subchronic toxicity of isophorone in the dog (final report). Submitted by Affiliated Medical Enterprises, Inc. to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0205975.
*Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
*Anjou K, von Sydow E. 1967. The aroma of cranberries. II. Vaccinium macrocarpon. Acta Chem Scand 21(8):2076–2082.6083071
*Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 8:69–201.
*Atkinson R. 1987. A structure-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. Int J Chem Kinet 19:799–828.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
*ATSDR. 2017. Isophorone. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
*Barnes D, Bellin J, DeRosa C, 1987. Reference dose (RfD): Description and use in health risk assessments. Volume I, Appendix A: Integrated risk information system supportive documentation. Washington, DC: US Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600886032a.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
*Barrows ME, Petrocelli SR, Macek KJ, 1978. Bioconcentration and elimination of selected water pollutants by bluegill sunfish. Am Chem Soc Div Environ Chem 18:345–346.
*Barrows ME, Petrocelli SR, Macek KJ, 1980. Bioconcentration and elimination of selected water pollutants by bluegill sunfish (Lepomis macrochirus). In: Dynamics exposure and hazard assessment of toxic chemicals. Ann Arbor, MI: Ann Arbor Science, 379–392.
*Bierbaum PJ, Parnes WD. 1974. Survey of Electrical, Division of Bristol Brass Corporation, South Winsor, Connecticut. Cincinnati, OH: U. S. Department of Health and Human Service, Public Health Service, Centers for Disease Control, National Institute of Occupational Safety and Health, 1–29.
*Bio/dynamics. 1984a. Inhalation teratology probe study in rats and mice. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0507219.
*Bio/dynamics. 1984b. Inhalation teratology study in rats and mice. Final report. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0507224.
*Brondeau MT, Bonnet P, Guenier JP, 1990. Adrenal-dependent leukopenia after short-term exposure to various airborne irritants in rats. J Appl Toxicol 10(2):83–86.2362083
Browning E. 1959. Toxic Solvents: A Review. Br J Ind Med 16:23–39.13618517
Browning E. 1965. Toxicity and metabolism of industrial solvents. Ketones (8). Elsevier Publishing Co., 412–462.
*Bucher JR. 1988. Written communication (September 14) regarding the review of the toxicological profile for isophorone to James Selkirk, Chief CTEB, NIH, NIEHS, EHS, DHHS, Research Triangle Park, NC.
*Bursey JT, Pellizzari ED. 1982. Analysis of industrial wastewater for organic pollutants in consent decree survey. Athens, GA: U.S. Environmental Protection Agency, Environmental Research Laboratory, Office of Research and Development.
*Camanzo J, Rice CP, Jude DJ, 1987. Organic priority pollutants in nearshore fish from 14 Lake Michigan tributaries and embayments. J Great Lakes Res 13:296–309.
*Carpenter CP, Smyth HF. 1946. Chemical burns of the rabbit cornea. Am J Ophthalmol 29:1363–1372.20276971
*CAS. 1988. Chemical Abstracts Service Online Registry File. 8–3-88.
Charbonneau M, Swenberg JA. 1988. Studies on the biochemical mechanism of α2µ-globulin nephropathy in rats. CIIT Activities 8(6):1–5.
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*CLSDB. 1987. Contract Laboratory Statistical Data Base. Printout of database provided by Viar Corp. April 13, 1987.
*CMA. 1981. Report of the Chemical Manufacturers Association ketones program panel. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0512076.
*CMA. 1984a. L5178Y TK +/− mouse lymphoma mutagenesis assay on isophorone. Submission of test data volume III. Isophorone mutagenicity studies with cover letter. Chemical Manufacturers’ Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4D. OTS0507222.
*CMA. 1984b. Activity of isophorone in the micronucleus cytogenetic assay in mice. Submission of test data volume III. Isophorone mutagenicity studies with cover letter. Chemical Manufacturers’ Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4D. OTS0507222.
*CMA. 1984c. Unscheduled DNA synthesis in rat primary hepatocytes with isophorone. Submission of test data volume III. Isophorone mutagenicity studies with cover letter. Chemical Manufacturers’ Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4D. OTS0507222.
*Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56:898–908.
*Dean J. (ed) 1985. Lange’s handbook of chemistry. 13th ed. New York: McGraw-Hill Book Company, 7–468.
*DeCeaurriz JC, Micillino JC, Bonnet P, 1981a. Sensory irritation caused by various industrial airborne chemicals. Toxicol Lett 9(2):137–143.7302985
*DeCeaurriz J, Bonnet P, Certin C, 1981b. [Chemicals as central nervous system depressants. Benefits of an animal model.] Cah Notes Doc 104(3):351–355. (French)
*DeCeaurriz J, Micillino JC, Marignac B, 1984. Quantitative evaluation of sensory-irritating and neurobehavioral properties of aliphatic ketones in mice. Food Chem Toxicol 22(7):545–549.6540229
*DeVault DS. 1985. Contaminants in fish from Great Lakes harbors and tributary mouths. Arch Environ Contam Toxicol 14(5):587–594.
*Dietrich DR, Swenberg JA. 1991. NCI-Black-Reiter (NBR) male rats fail to develop renal disease following exposure to agents that induce α-2u-globulin (α_2u_) nephropathy. Fundam Appl Toxicol 16(4):749–762.1715830
*DOE. 2016a. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. May 2016. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/teel/Revision_29_Table3.pdf. February 28, 2017.
*DOE. 2016b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for Chemicals of Concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. https://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. March 2, 2017.
Dow Chemical Company. 1962. Results of range finding toxicological tests on isophorone. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206147.
*Dutertre-Catella H. 1976. Thèse. Contribution a l’etude analytique toxicologique et biochimique de l’isophorone. Universite Rene Descartes de Paris. Serie E - No 318.
*Dutertre-Catella CH, Nguyen PL, Dang Q Quoc, 1978. Metabolic transformations of the 3,5,5–2-cyclohexene-1-one trimethyl (isophorone). Toxicol Eur Res 1(4):209–216.741480
*Eastman Kodak. 1967. Toxicity and health hazard summary. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206524.
*EPA. 1974. Draft analytical report New Orleans area water supply study. U.S. Environmental Protection Agency. EPA9061074002. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101WZ63.txt. June 6, 2018.
*EPA. 1975. Preliminary assessment of suspected carcinogens in drinking water. Interim report to Congress, June, 1975. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1980a. Guidelines and methodology used in the preparation of health effect assessment chapters of the consent decree water criteria documents. U.S. Environmental Protection Agency. Fed Regist 45:79347–79357.
*EPA. 1980b. Ambient water quality criteria for isophorone. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. EPA440580056. PB81117673.
EPA. 1980c. Water quality criteria documents: Availability. Fed Regist 45:79318–79379b (11/28/88).
*EPA. 1982. Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH. U.S. Environmental Protection Agency.
*EPA. 1985a. Exposure Analysis Modeling System: Reference manual for EXAMS II. Athens, GA: U.S. Environmental Protection Agency, Environmental Research Laboratory, Office of Research and Development. EPA600385038.
*EPA. 1985b. 40 CFR Parts 117 and 302. Notification requirements; Reportable quantity adjustments; Final rule and proposed rule. Fed Regist 50(65):13456–13522 (4/4/85).
*EPA. 1986. Health and environmental effects profile for isophorone. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office.
*EPA. 1987a. U.S. EPA contract laboratory program. Statement of work for organic analysis. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1987b. Health effects assessment for isophorone. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office, Emergency and Remedial Response.
*EPA. 1988a. Analysis of clean water act effluent guidelines pollutants. Summary of the chemicals regulated by industrial point source category. Code of Federal Regulations. 40 CFR Parts 400–475. Washington, DC: U.S. Environmental Protection Agency, Office of Water.
*EPA. 1988b. Integrated Risk Information System (IRIS). Reference dose (RfD) for oral exposure for isophorone. Online. (Revised; verification date 5/15/86). Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office.
*EPA. 1991. Alpha_2u_-globulin: Association with chemically induced renal toxicity and neoplasia in the male rat. U.S. Environmental Protection Agency. EPA625391019F.
*EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
*EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking water. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
*EPA. 2012. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. https://www.epa.gov/sites/production/files/2015-09/documents/dwstandards2012.pdf. April 25, 2013.
*EPA. 2016. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-03/documents/compiled_aegl_update_.pdf. September 8, 2017.
*Farley FF. 1977. Photochemical reactivity classification of hydrocarbons and other organic compounds. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600377001B.
*FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. January 8, 2014.
*Foureman P, Mason JM, Valencia R, 1994. Chemical mutagenesis testing in Drosophila: X. Results of 70 coded chemicals tested for the National Toxicology Program. Environ Mol Mutagen 23(3):208–227.8162896
FSTRAC. 1988. Summary of state and federal drinking water standards and guidelines. Prepared by chemical communication subcommittee Federal-State Toxicology and Regulatory Alliance Committee (FSTRAC).
*Gandy J, Millner GC, Bates HK, 1990. Effects of selected chemicals on the glutathione status in the male reproductive system of rats. J Toxicol Environ Health 29(1):45–57. 10.1080/15287399009531370. 2299686
*Ghassemi M, Quinlivan S, Bachmaier J. 1984. Characteristics of leachates from hazardous waste landfills. J Environ Sci Health A A 19(5):579–620.
*Gulati DK, Witt K, Anderson B, 1989. Chromosome aberration and sister chromatid exchange tests in Chinese hamster ovary cells in-vitro III. Results with 27 chemicals. Environ Mol Mutagen 13(2):133–193 2917552
*Hall LW Jr, Hall WS, Bushong SJ, 1987. In situ striped bass (Morone saxatilis) contaminant and water quality studies in the Potomac River. Aquat Toxicol 10(2–3):73–99.
*Hannah SA, Austern BM, Eralp AE, 1986. Comparative removal of toxic pollutants by six wastewaters treatment processes. J Water Pollut Control Fed 58:27–34.
*Harrison FL, Bishop DJ, Mallon BJ. 1985. Comparison of organic combustion products in fly ash collected by a Venturi wet scrubber and an electrostatic precipitator at a coal-fired power station. Environ Sci Technol 19(2):186–193.
*Haruta H, Yagi H, Iwata T, Tamura S. 1974. Syntheses and plant growth retardant activities of quaternary ammonium compounds derived from α-ionone and isophorone. Agric Biol Chem 38:417–422.
*Hauser TR, Bromberg SM. 1982. EPAs monitoring program at Love Canal 1980. Environ Monit Assess 2:249–271.24264296
*Hawley GG. 1981. The condensed chemical dictionary. 10th ed., 581.
*Hawthorne SB, Sievers RE. 1984. Emission of organic air pollutants from shale oil wastewaters. Environ Sci Technol 18(6):483–490.22247953
*Hawthorne SB, Sievers RE, Barkley RM. 1985. Organic emissions from shale oil wastewaters and their implications for air quality. Environ Sci Technol 19(10):992–997.
*Hazleton Labs. 1964. Acute toxicity studies, mice, rats, rabbits, guinea pigs. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206267.
*Hazleton Labs. 1965a. LC50 determination, acute inhalation exposure rats. Final Report. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206267.
*Hazleton Labs. 1965b. Human sensory irritation thresholds. Five ketones - final report. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206267.
*Hazleton Labs. 1968. Assessment and comparison of subacute inhalation toxicities of three ketones. Final Report. Submitted to the U. S Environmental Protection Agency under TSCA Section 8D. OTS0206267.
*Hites RA. 1979. Sources and fates of industrial organic chemicals. Proc Natl Conf Munic Sludge Manage 8:107–119.
*Honma M, Hayashi M, Shimada H, 1999a. Evaluation of the mouse lymphoma tk assay (microwell method) as an alternative to the in vitro chromosomal aberration test. Mutagenesis 14(1):5–22.10474816
*Honma M, Zhang LS, Sakamoto H, 1999b. The need for long-term treatment in the mouse lymphoma assay. Mutagenesis 14(1):23–29.10474817
*HSDB. 1988. Hazardous Substances Data Bank. Online: 7/27/88.
*IARC. 2017. Agents classified by the IARC Monographs, Volumes 1–117. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf. September 11, 2017.
*Imbriani M, Ghittori S, Pezzagno G, 1985. Urine/air partition coefficients for some industrially important substances. G Ital Med Lav 7(4):133–140.3836917
*IRIS. 2003. Isophorone. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0063_summary.pdf. September 10, 2017.
*Johansson E, Ryhage R. 1976. Gas chromatographic mass spectrometric identification and determination residual by-products in clofibrate preparations. J Pharm Pharmacol 28(12):927–929.12274
*Jungclaus GA, Games LM, Hites RA. 1976. Identification of trace organic compounds in tire manufacturing plant wastewaters. Anal Chem 48:1894–1896.970644
*Kawasaki M. 1980. Experiences with the test scheme under the chemical control law of Japan: An approach to structure-activity correlations. Ecotoxic Environ Saf 4:444–454.
*Keith IH, Garrison AW, Allen FR, 1976. Identification of organic compounds in drinking water from thirteen United States cities. In: Keith LH, ed. Advances in the identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Press, 329–373.
*Kinzer G, Riggin R, Bishop T, 1984. EPA Method Study 19, Method 609 (nitroaromatics and isophorone). Govt Reports Announcements & Index, Issue 16.
*Kominsky JR. 1981. Health hazard evaluation determination report no. HE 78–107-563, Pittsburgh, PA: Swinston Company.
*Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Lee SA, Frederick L. 1981. Health hazard evaluation report no. HHE80–103-827. Ridgefield, NJ: Joel and Aronoff.
*Lehmann R, Hatt H, van Thriel C. 2016a. Alternative in vitro assays to assess the potency of sensory irritants – Is one TRP channel enough? Neurotoxicology 60:178–186. 10.1016/j.neuro.2016.08.010. 27545873
*Lehmann R, Schobel N, Hatt H, 2016b. The involvement of TRP channels in sensory irritation: A mechanistic approach toward a better understanding of the biological effects of local irritants. Arch Toxicol 90(6):1399–1413. 10.1007/s00204–016-1703–1. 27037703
*Levy A. 1973. The photochemical smog reactivity of organic solvents. Solvent theory and practices. American Chemical Society, Washington, DC: Adv Chem Ser 124:70–94.
*Matsuoka A, Yamakage K, Kusakabe H, 1996. Re-evaluation of chromosomal aberration induction on nine mouse lymphoma assay "unique positive’ NTP carcinogens. Mutat Res 369(3–4):243–252.8792842
*Matthews EJ, Spalding JW, Tennant RW. 1993. Transformation of balb-c-3t3 cells: V. Transformation responses of 168 chemicals compared with mutagenicity in salmonella and carcinogenicity in rodent bioassays. Environ Health Perspect 101(Suppl 2):347–482.8243403
*McFall JA, Antoine SR, DeLeon IR. 1985. Base-neutral extractable organic pollutants in biota and sediments from Lake Pontchartrain. Chemosphere 14(10):1561–1569.
*McGregor DB, Brown A, Cattanach P, 1988. Responses of the L5178Y tk+/tk- mouse lymphoma cell forward mutation assay: III. 72 coded chemicals. Environ Mol Mutagen 12(1):85–154.3383842
*McKee RH, Phillips RD, Lerman SA, 1987. The genotoxic potential of isophorone [Abstract]. Environ Mutagen 9(8):71.
*McShane SF, Pollock TE, Lebel A, 1987. Biophysical treatment of landfill leachate containing organic compounds. Proc Ind Waste Conf 41:167–177.
*Mortelmans K, Haworth S, Lawlor T, 1986. Salmonella mutagenicity tests: II. Results from the testing of 270 chemicals. Environ Mutagen 8(Suppl 7):1–119. http://www.ncbi.nlm.nih.gov/pubmed/3516675.
*NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
NATICH. 1987. NATICH data base report on state, local and EPA air toxics activities. National air toxics information clearinghouse. Prepared by the Office of Air Quality Planning and Standards, Research Triangle Park, NC, State and Territorial Air Pollution Program Administrators, and Association of Local Air Pollution Control Officials.
*Nielsen GD. 1991. Mechanisms of activation of the sensory irritant receptor by airborne chemicals. Crit Rev Toxicol 21(3):183–208.2039594
*NIOSH. 1978a. Health hazard evaluation determination report no. 77–78-466. Prefinish Metals, Inc., Elk Grove Village, Illinois.
*NIOSH. 1978b. Criteria for a recommended standard: Occupational exposure to ketones. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. DHHS (NIOSH) publication no. 78–173.
*NIOSH. 1984. NIOSH manual of analytical methods. 3rd ed. Cincinnati, OH: U.S. Department of Health and Human Service, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 2508–1 to 2508–3.
*NIOSH. 2016. Isophorone. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0355.html. October 12, 2017.
*NTP. 1986. Technical report series no. 291. Toxicology and carcinogenesis studies of isophorone (CAS No. 78–59-1) in F344/N rats and B6C3Fl mice (gavage studies). National Toxicology Program. Research Triangle Park, NC: U.S. Department of Health and Human Services. Public Health Service, National Institutes of Health, NIH publication no. 86–2547.
*NTP. 2016. Report on carcinogens, Fourteenth edition. CASRN Index in MS Excel. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. March 1, 2017.
*O’Donoghue JL, Haworth SR, Curren RD, 1988. Mutagenicity studies on ketone solvents: Methyl ethyl ketone, methyl isobutyl ketone, and isophorone. Mutat Res 206(2):149–161.3050497
*OHM-TADS. 1988. Oil and Hazardous Materials Technical Assistance Data System Online: 8/4/88, 4–5.
*OSHA. 1989. Air contaminants. Final Rule. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910. Fed Regist 54(12):2941.
*OSHA. 2016a. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Code of Federal Regulations. Occupational Safety and Health Standards. 29 CFR 1926.55. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol8/pdf/CFR-2016-title29-vol8-sec1926–55.pdf. March 6, 2017.
*OSHA. 2016b. Subpart Z - Toxic and hazardous substances. Air contaminants. Code of Federal Regulations. Occupational Safety and Health Standards. 29 CFR 1910.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1000.pdf. March 6, 2017.
*OSHA. 2017. Subpart Z - Toxic and hazardous substances. Air contaminants. Code of Federal Regulations. Occupational Safety and Health Standards. 29 CFR 1915.1000. https://www.gpo.gov/fdsys/pkg/CFR-2017-title29-vol7/pdf/CFR-2017-title29-vol7-sec1915-1000.pdf. September 7, 2017.
*Ozretich RJ, Schroeder WP. 1986. Determination of selected neutral priority pollutants in marine sediment, tissue, and reference materials utilizing bonded-phase sorbents. Anal Chem 58:2041–2048.
*Papa AJ, Sherman PD. 1981. Ketones. In: Encyclopedia of chemical technology, 3rd ed. 13:898, 899, 918–922.
*Perry DL, Chuang CC, Jungclaus GA, 1979. Identification of organic compounds in industrial effluent discharges. U.S. Environmental Protection Agency. Environmental Research Laboratory. EPA600479016. PB294794.
*Potokar M, Grundler OJ, Heusener A, 1985. Studies on the design of animal tests for the corrosiveness of industrial chemicals. Food Chem Toxicol 23(6):615–617.4040107
*Price KS, Waggy GT, Conway RA. 1974. Brine shrimp bioassay and seawater BOD of petrochemicals. J Water Pollut Contr Fed 46:63–77.
Proctor NH, Hughes JP. 1978. Chemical hazards of the workplace. Philadelphia, PA: JB Lippincott Co, 300–301.
*Rowe VK, Wolf MA. 1963. Ketones. In: Patty FA, ed. Industrial hygiene and toxicology, 2nd ed. Vol II. New York, NY: Interscience, 1722–1724; 1763–1765.
RTECS. 1988. Registry of Toxic Effects of Chemical Substances Online 8/4/88.
*Sadtler Index. 1966. Ultraviolet spectrum j/44.
*Salisbury S. 1983. Health hazard evaluation report no. HETA 82–207-1278, Garden City Engraving, Augusta, GA.
*Samimi B. 1982. Exposure to isophorone and other organic solvents in a screen printing plant. Am Ind Hyg Assoc J 43(1):43–48.7055084
*SANSS. 1988. Online: 7/31/88.
*Selden JR, Dolbeare F, Clair JH, 1994. Validation of a flow cytometric in vitro DNA repair (UDS) assay in rat hepatocytes. Mutat Res 315(2):147–167.7520997
*Shafer KH. 1982. Determination of nitroaromatic compounds and isophorone in industrial and municipal waste waters. U.S. Environmental Protection Agency, Office of Research and Development, 1–71.
*Sheldon LS, Hites RA. 1978. Organic compounds in the Delaware River. Environ Sci Technol 12:1188–1194.
Short BG, Swenberg JA. 1988. Pathologic investigations of the mechanism of unleaded gasoline-induced renal tumors in rats. CIIT Activities 8(7):1–6.
*Silverman L, Schulte HF, First MW. 1946. Further studies on sensory response to certain industrial solvent vapors. J Ind Hyg Toxicol 28(6):262–266.21002364
*Smyth HF Jr., Seaton J. 1940. Acute response of guinea pigs and rats to inhalation of the vapors of isophorone. J Ind Hyg Toxicol 22(10):477–483.
*Smyth HF Jr., Seaton J, Fischer L. 1942. Response of guinea pigs and rats to repeated inhalation of vapors of mesityl oxide and isophorone. J Ind Hyg Toxicol 24:46–50.
*Smyth HF Jr, Weil CS, West JS, 1969. An exploration of joint toxic action: Twenty-seven industrial chemicals intubated in rats in all possible pairs. Toxicol Appl Pharmacol 14:340–347.5772858
*Smyth HF Jr., Weil CS, West JS, 1970. An exploration of joint toxic action. II. Equitoxic versus equivolume mixtures. Toxicol Appl Pharmacol 17:498–503.5471565
*State of Kentucky. 1986. New or modified sources emitting toxic air pollution. 401 KAR 63:022.
*Stonebraker RD, Smith AJ Jr. 1980. Containment and treatment of a mixed chemical discharge from "The Valley of the Drums" near Louisville, Kentucky. In: Proceedings on the Control of Hazardous Material Spills National Conference, Nashville, TN, 1–10.
*Strasser J Jr. 1988. Written communication to Sharon Wilbur, Syracuse Research Corporation, Syracuse, NY and Poster Presentation from J. Strasser, CIIT, Research Triangle Park, NC. August 23.
*Strasser J Jr., Charbonneau M, Borghoff SJ, 1988. Renal protein droplet formation in male Fischer 344 rats after isophorone (IPH) treatment. Toxicologist 8:136.
*Suffet IH, Brenner L, Cairo PR. 1980. Gas chromatography-mass spectrometry identification of trace organics in Philadelphia, Pennsylvania, USA drinking waters during a two-year period. Water Res 14:853–867.
*Swenberg JA. 1993. α_2u_-Globulin neuropathy: Review of the cellular and molecular mechanisms involved and their implications for human risk assessment. Environ Health Perspect 101(Suppl 6):30–44.8513761
*Swenberg JA, Short B, Borghoff S, 1989. The comparative pathobiology of alpha 2µ-globulin nephropathy. Toxicol Appl Pharmacol 97:35–46.2464861
*Tabak HH, Quave SA, Mashni CI, 1981a. Biodegradability studies for predicting the environmental fate of organic priority pollutants. In: Test protocols for environmental fate and movement of toxicants. Proc of a Symposium of the Association of Official Analytical Chemists 94th Annual Meeting, Washington, DC, 267–327.
*Tabak HH, Quave SA, Mashni CI, 1981b. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Contr Fed 53:1503–1518.
*Tennant RW, Margolin BH, Shelby MD, 1987. Prediction of chemical carcinogenicity in rodents from in-vitro genetic toxicity assays. Science (Wash D C) 236(4804):933–941.
*Thier R, Xu DG. 1990. Urinary excretion of isophorone metabolites by male rats. 31st Spring Meeting of the Deutsche Gesellschaft Fuer Pharmakologie Und Toxikologie (German Society for Pharmacology and Toxicology), Mainz, West Germany, March 13–16, 1990. Naunyn-Schmiedeberg’s Arch Pharmacol 341(Suppl):R11.
*Thier R, Peter H, Wiegand HJ, 1990. DNA binding study of isophorone in rats and mice. Arch Toxicol 64(8):684–685 2090039
*Truhaut R, Dutertre-Catella H, Phu-Lich MN. 1970. [First results of studying the metabolism of an industrial solvent on the rabbit: isophorone.] CR Acad SC Paris Seril D 271:1333–1336. (French)
*Truhaut R, Dutertre-Catella H, Phu-Lich N, 1972. [Toxicity of an industrial solvent, isophorone: irritating effect on the skin and mucous membranes.] Eur J Toxicol 5(1):31–37. (French)4647420
*Union Carbide. 1968. Ketones booklet F-419771. Isophorone data indicating relative degree of hazard to animals. Submitted to the U.S. Environmental Protection agency under TSCA Section 8D. OTS0205868.
*USITC. 1986. Synthetic organic chemicals. U.S. Production and Sales, 1985. Washington, DC: U.S. Government Printing Office.
*USITC. 1987. Synthetic organic chemicals. U.S. Production and Sales, 1986. Washington, DC: U.S. Government Printing Office.
*Veith GD, Macek KJ, Petrocelli SR, 1980. An evaluation of using partition coefficients and water solubility to estimate bioconcentration factors for organic chemicals in fish. ASTM STP 707. Aquatic Toxicology. In: Easton JG, ed. Am Soc Test Mater 116–129.
VIEW database. 1988. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch. October 1988.
VIEW database. 1989. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch. June 1989.
*Ware GD. 1973. Written communication (June 26) to Herbert Stokinger. Chairman, Committee on Threshold Limits, American Conference of Governmental Industrial Hygienists to Western Electric Co., Kearny, PA.
*Weast RC. 1985. CRC handbook of chemistry and physics. Boca Raton, FL: CRC Press, Inc., C328.
*WHO. 1995. Isophorone. Environmental Health Criteria 174. Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc174.htm. March 2018.
*WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
*WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
*Wiedmer C, Velasco-Schon C, Buettner A. 2017. Characterization of odorants in inflatable aquatic toys and swimming learning devices- which substances are causative for the characteristic odor and potentially harmful? Anal Bioanal Chem 409:3905–3916.28401289
*Yoshioka Y, Nagase H, Ose Y, 1986. Evaluation of the test method "activated sludge, respiration inhibition test" proposed by the OECD. Ecotox Environ Saf 12(3):206–212.
*Zissu D. 1995. Histopathological changes in the respiratory tract of mice exposed to ten families of airborne chemicals. J Appl Toxicol 15(3):207–213.7560741