# VERSION HISTORY

Date | Description
July 2018 | Update of data in Chapters 2, 3, and 7
December 1989 | Final toxicological profile released