# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding isophorone in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for isophorone.

Table 7-1 Regulations and Guidelines Applicable to Isophorone

Agency | Description | Information | Reference
Air
EPA | RfC | No data | IRIS 2003
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2012
EPA | | | EPA 2012
EPA | 1-Day health advisory for a 10-kg child | 15 mg/L | EPA 2012
EPA | | | EPA 2012
EPA | 10-Day health advisory for a 10-kg child | 15 mg/L | EPA 2012
EPA | | | EPA 2012
EPA | DWEL | 7 mg/L | EPA 2012
EPA | | | EPA 2012
EPA | Lifetime health advisory | 0.1 mg/L | EPA 2012
EPA | | | EPA 2012
EPA | 10^−4^ Cancer risk | 4 mg/L | EPA 2012
EPA
EPA | National primary drinking water regulations | No data | EPA 2009
EPA
EPA | RfD | 2×10^−1^ mg/kg/day | IRIS 2003
WHO | Drinking water quality guidelines | No data | WHO 2017
FDA | EAFUS | Yes^a,b^ | FDA 2013
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | Group C^d^ | IRIS 2003
EPA | | | IRIS 2003
EPA | Oral slope factor | 9.5×10^−4^ per (mg/kg)/day | IRIS 2003
IARC | Carcinogenicity classification | No data | IARC 2017
Occupational
OSHA | PEL (8-hour TWA) for general industry, construction, and shipyards | 25 ppm^e^; 140 mg/m^3f^ | OSHA 2016a, 2016b, 2017
NIOSH | REL (up to 10-hour TWA) | 4 ppm (23 mg/m^3^) | NIOSH 2016
NIOSH | | | NIOSH 2016
NIOSH | IDLH | 200 ppm | NIOSH 2016
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2016
DOE | PACs-air | | DOE 2016a
| PAC-1^g^ | 12 ppm
| PAC-2^g^ | 33 ppm
| PAC-3^g^ | 200 ppm

a The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

b Status: fully up-to-date toxicology information has been sought.

c A3: confirmed animal carcinogen with unknown relevance to humans.

d C: possible human carcinogen.

e Parts of vapor or gas per million parts of contaminated air by volume at 25°C and 760 torr.

f Approximate milligrams of substance per cubic meter of air.

g Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2016a).

AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization