# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists common synonyms, trade names and other pertinent identification information for isophorone.

Table 4-1 Chemical Identity of Isophorone

Characteristic | Information | Reference
Chemical name | 2-Cyclohexen-1-one,3,5,5-trimethyl- | CAS 1988
Synonym(s) and registered trade name(s) | Isophorone; Isoacetophorone; 1,5,5-Trimethyl-3-oxocyclohexene | CAS 1988; SANSS 1988
Chemical formula | C_9_H_14_O | CAS 1988
Chemical structure | [image] | SANSS 1988
CAS Registry Number | 78-59-1 | CAS 1988

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 4-2 lists important physical and chemical properties of isophorone.

Table 4-2 Physical and Chemical Properties of Isophorone

Property | Information | Reference
Molecular weight | 138.1 | Union Carbide 1968
Color | Water-white | Hawley 1981
Physical state | Liquid | Hawley 1981
Freezing point | −8.1°C | Union Carbide 1968
Boiling point | 215.3°C | Union Carbide 1968
Density at 20°C | 0.9229 g/m^3^ | Union Carbide 1968
Odor | Mild | Union Carbide 1968
Odor threshold:
Water | 5.4 ppm (w/v) | Amoore and Hautala 1983
Air | 0.20 ppm (v/v) | Amoore and Hautala 1983
Solubility:
Water at 20°C | 12,000 mg/L | Union Carbide 1968
Organic solvents | Soluble in ether, acetone, alcohol | Weast 1985
Partition coefficients:
Log K_ow_ | 1.67 (20°C, experimental) | Veith et al. 1980
Log K_oc_ | No data
Vapor pressure at 20°C | 0.3 mmHg | Extrapolated using data from Union Carbide 1968
Henry’s law constant at 20°C | 4.55×10^−6^ atm-m^3^/mol | Calculated from vapor pressure and water solubility data
Autoignition temperature | 864°F (462°C) | Hawley 1981
Flashpoint | 184°F (84°C) (open cup) | Dean 1985
Flammability limits | 0.8–3.5 vol% | HSDB 1988
Conversion factors (in air, 20°C) | ppm (v/v)×5.75=mg/m^3^
| mg/m^3^×0.174=ppm (v/v)