# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Isophorone Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Isophorone
CAS Numbers: | 78-59-1
Date: | December 1989 March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: The acute-duration inhalation database was not considered suitable for derivation of an MRL. Although acute inhalation studies in human subjects identify NOAEL and LOAEL values of 10 and 25 ppm, respectively, for irritation of the nose and 35 and 65 ppm, respectively, for irritation of the eyes, study exposures were very short (≤15 minutes) (Hazleton Labs 1965b; Silverman et al. 1946). An acute-duration inhalation MRL based on data from these short exposure durations may not be considered protective for continuous exposure for up to 2 weeks. Studies in animals also identified respiratory tract irritation as the most sensitive effect of isophorone in air. Respiratory effects have been observed over a wide range of exposures, from 27.8 ppm for 5 minutes in mice for an RD_50_ value (indicative of respiratory irritation) to 619 ppm for 6 hours in mice for respiratory tract congestion (DeCeaurriz et al. 1981a; Hazelton Labs 1964). Other effects observed in animals exposed acutely to inhaled isophorone include decreased leukocyte count at 67 ppm (Brondeau et al. 1990) and neurological effects at ≥89 ppm (Bio/dynamics 1984a; DeCeaurriz et al. 1981b, 1984). Developmental effects of inhalation exposure to isophorone in animals have been evaluated in a few studies; however, examinations of comprehensive developmental endpoints were not conducted, and/or interpretation of study results is complicated by inadequate exploration of exposure-response relationships (Bio/dynamics 1984a, 1984b; Dutertre-Catella 1976).

Because comprehensive toxicological endpoints were not examined in acute inhalation studies in animals, available data do not allow for identification of the most sensitive effect of exposure. Therefore, data are not suitable for derivation of an acute-duration inhalation MRL for isophorone.

Agency Contact (Chemical Manager): Melanie Buser

## Isophorone Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Isophorone
CAS Numbers: | 78-59-1
Date: | December 1989 March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: The intermediate-duration database for inhalation exposure consists of 2 studies in rats: a 4-week study with exposures to 0 or 37 ppm for 6 hours/day, 5 days/week (Hazleton Labs 1968) and a 4–6-month study with exposures to 0 or 500 ppm for 6 hours/day, 5 days/week (Dutertre-Catella 1976). The Hazleton Labs (1968) study reported decreased terminal body weights in male rats (10% lower than controls), but no hematological or renal effects were observed in male or female rats. The Dutertre-Catella (1976) study observed irritation of the nasal mucosa and hepatic microvacuolization; no hematological or renal effects were observed. Comprehensive toxicological endpoints were not examined in either study and both studies only evaluated a single exposure level of isophorone. Therefore, data are not sufficient for derivation of an intermediate-duration inhalation MRL.

Agency Contact (Chemical Manager): Melanie Buser

## Isophorone Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Isophorone
CAS Numbers: | 78-59-1
Date: | December 1989 March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: One study evaluated the effects of chronic inhalation of isophorone (Dutertre-Catella 1976). Rats and rabbits were exposed to 0 or 250 ppm isophorone for 6 hours/day, 5 days/week for 18 months. In both rats and rabbits, irritation of the nasal mucosa and hepatic microvacuolization was observed. No hematological or renal effects were found in either species. However, because comprehensive toxicological endpoints were not examined and only a single exposure level of isophorone was evaluated, data are not sufficient for derivation of a chronic-duration inhalation MRL.

Agency Contact (Chemical Manager): Melanie Buser

## Isophorone Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Isophorone
CAS Numbers: | 78-59-1
Date: | December 1989 March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: The acute oral exposure database consists of studies designed to assess lethality in rats and mice following single doses of isophorone (Dutertre-Catella 1976; Hazleton Labs 1964; Smyth et al. 1969, 1970). These studies report LD_50_ values in rats ranging from 2,104 to 3,450 mg/kg in rats (Hazleton Labs 1964; Smyth et al. 1969, 1970) and an LD_50_ value of 2,200 mg/kg in mice (Dutertre-Catella 1976). At a sublethal dose in rats (1,450 mg/kg), neurotoxicity (depression) was observed (Hazleton Labs 1964). No other effects occurring at sublethal or lethal doses were reported in acute oral studies, and studies did not assess comprehensive toxicological endpoints. Therefore, data are not adequate to derive an acute-duration oral MRL.

Agency Contact (Chemical Manager): Melanie Buser

## Isophorone Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Isophorone
CAS Numbers: | 78-59-1
Date: | December 1989 March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 3 mg/kg/day
Critical Effect: | NOAEL
Reference: | AME Inc. 1972a
Point of Departure: | NOAEL of 311.8 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 4R
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 3 mg/kg/day was derived for isophorone. The MRL is based on a NOAEL of 311.8 mg/kg/day reported in a dietary study in rats (AME Inc. 1972a). The NOAEL was divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: The AME Inc. (1972a) study examined comprehensive toxicological endpoints, including histopathological assessments of tissues. No adverse effects of isophorone were observed.

Other intermediate-duration oral studies examining comprehensive toxicological endpoints did not identify any adverse effects of isophorone (AME Inc. 1972b; NTP 1986). AME Inc. (1972b) reported a NOAEL of 150 mg/kg/day for exposure of dogs administered isophorone by capsule for 90 days, 5 days/week. NTP (1986) also evaluated exposure of rats and mice by gavage for 16 days or 13 weeks. The following values were identified as NOAELs for adverse effects or doses at which no lethality occurred: 1,000 mg/kg/day for decreased body weight in rats exposed for 16 days; 500 mg/kg/day for staggering observed in mice exposed for 16 days; 500 mg/kg/day for lethargy and for no lethality in rats exposed for 13 weeks; and 500 mg/kg/day for stagger in mice exposed for 13 weeks.

Selection of the Principal Study: The AME Inc. (1972b) and NTP (1986) 13-week studies identified similar NOAEL values: 311.8 mg/kg/day for no adverse effects in rats exposed to isophorone in the diet (AME Inc. 1972b) and 500 mg/kg/day for lethargy and death in rats and stagger in mice exposed by gavage (NTP 1986). The AME Inc. (1972b) study was selected as the principal study because dietary exposure is considered more relevant to humans than gavage exposure.

Summary of the Principal Study:

AME Inc. 1972a. 90-Day subchronic toxicity of isophorone in the rat (final report). Submitted by Affiliated Medical Enterprises, Inc. to the U.S. Environmental Protection Agency under TSCA 8D. OTS0205975.

Groups of 20 female rats were exposed to dietary isophorone for 90 days. Based on food consumption and body weight, daily doses were 0, 78.9, 163.8, 311.8 mg/kg/day. The following parameters were assessed: body weight, food intake, clinical signs, organ weight, serum (blood) chemistry, urinalysis, gross necropsy, and histopathology. Relative to controls, no adverse effects of isophorone were observed in any dose group. Thus, a NOAEL of 311.8 mg/kg/day was identified for this study.

Selection of the Point of Departure for the MRL: The NOAEL of 311.8 mg/kg/day was selected as the basis of the MRL.

Uncertainty Factor: The NOAEL was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

Other Additional Studies or Pertinent Information that Lend Support to this MRL: As noted previously, intermediate-duration oral studies have also identified several NOAEL values for isophorone.

Agency Contact (Chemical Manager): Melanie Buser

## Isophorone Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Isophorone
CAS Numbers: | 78-59-1
Date: | December 1989 March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.2 mg/kg/day
Critical Effect: | Hepatic, renal and gastrointestinal lesions
Reference: | NTP 1986
Point of Departure: | LOAEL of 179 mg/kg/day
Uncertainty Factor: | 1,000
LSE Graph Key: | 11M
Species: | Mouse

MRL Summary: A chronic-duration oral MRL of 0.2 mg/kg/day was derived for isophorone. The MRL is based on a LOAEL of 179 mg/kg/day (adjusted for intermittent exposure from 250 mg/kg/day) for lesions of the liver, kidney, and gastrointestinal tract reported in a gavage study in mice (NTP 1986). The LOAEL was divided by a total uncertainty factor of 100 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: The NTP (1986) study examined comprehensive toxicological endpoints, including histopathological assessments of tissues. At the lowest dose tested (250 mg/kg/day administered by gavage 5 days/week for 103 weeks), non-neoplastic lesions were observed in male mice in the gastrointestinal tract (hyperkeratosis of the forestomach), liver (hepatocytomegaly), and kidney (chronic focal inflammation). It is not possible to determine which of these findings were the most sensitive, as lower doses were not evaluated

The NTP (1986) study also evaluated effects of chronic-duration oral exposure to isophorone in rats at the same doses as in mice. At a dose of 250 mg/kg/day, alpha-2µ-globulin-induced nephropathy was observed in male rats. At the 500 mg/kg/day dose, renal tumors subsequent to alpha-2µ-globulin-induced nephropathy were observed. As discussed in the profile, this effect is unique to male rats and is not toxicologically relevant to human health (EPA 1991; Swenberg 1993). No other effects were observed in rats. Thus, the most sensitive effects of chronic-oral exposure to isophorone were selected as the critical effect for derivation of the MRL.

Selection of the Principal Study: One study evaluated the effects of chronic-duration oral exposure to isophorone in rats and mice (NTP 1986). The study was well-conduced with appropriate controls and examined comprehensive toxicological endpoints.

Summary of the Principal Study:

NTP. 1986. Technical report series no. 291. Toxicology and carcinogenesis studies of isophorone (CAS No. 78-59-1) in F344/N rats and B6C3Fl mice (gavage studies). National Toxicology Program. Research Triangle Park, NC: U.S. Department of Health and Human Services. Public Health Service, National Institutes of Health, NIH publication no. 86-2547.

Groups of 50 male and female mice were exposed to 0 (vehicle control), 250, or 500 mg/kg/day isophorone administered by gavage 5 days/week for 103 weeks. The following parameters were assessed: body weight, clinical signs, and gross and microscopic evaluation of comprehensive tissues. In the 250 and 500 mg/kg/day groups, non-neoplastic lesions were observed in male mice in the gastrointestinal tract (hyperkeratosis of the forestomach), liver (hepatocytomegaly), and kidney (chronic focal inflammation). Incidence data for these lesions are shown in Table A-1. In the 500 mg/kg/day group, lymphoma and tumors of the liver and skin were observed. In female mice, hyperkeratosis of the forestomach was observed in 10% of mice, compared to 2% in controls. However, the incidences of hepatocytomegaly and chronic focal inflammation of the kidney in female mice in both isophorone treatment groups were similar to controls.

Table A-1 Non-neoplastic Lesions in Mice exposed to Isophorone for 103 Weeks

| Dose (mg/kg/day)^a^
Lesion type | Vehicle control | 250 | 500
Gastrointestinal (hyperkeratosis of forestomach) | 0/47 | 5/49 (10%) | 4/49 (8%)
Liver (hepatocytomegaly) | 23/48 (48%) | 39/50 (78%) | 37/50 (74%)
Kidney (chronic focal inflammation) | 7/48 (15%) | 18/50 (36%) | 21/50 (42%)

a Administered by gavage 5 days/week.

Source: NTP 1986

Selection of the Point of Departure for the MRL: The LOAEL of 179 mg/kg/day (adjusted for intermittent exposure from 250 mg/kg/day) for non-neoplastic lesions of the gastrointestinal tract, liver, and kidney was selected as the basis of the MRL. Note that benchmark dose analysis to determine the point of departure was not considered valid because the incidence of all lesions reached an apparent maximum at the lowest dose tested.

Adjustment for Intermittent Exposure: The LOAEL was adjusted for intermittent exposure (5 days/week).

Uncertainty Factor: The LOAEL was divided by a total uncertainty factor of 1,000:

- 10 for use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The NTP (1986) study is the only study that evaluated chronic-duration oral exposure to isophorone (see discussion above).

Agency Contact (Chemical Manager): Melanie Buser