# 10 REFERENCES

*Cited in text

*AAPM. 1999. American Association of Physicists in Medicine. Home page. http://www.aapm.org
*Aarkrog. 1971. Environmental behavior of plutonium accidentally released at Thule, Greenland. Health Phys 32:271–284.
*Abraham SK, Sarma L, Kesavan PC. 1993. Protective effects of chlorogenic acid, curcumin and beta-carotene against gamma-radiation-induced in vivo chromosomal damage. Mutat Res 303(3):109–112.7694126
*ACGIH. 1998. 1998 TLVs and BEIs. Threshold limit values for chemical substances and physical agents. Biological exposure indices. American Conference of Governmental Industrial Hygienists. March 1, 1998.
*ACHRE. 1995. The Marshallese. Final report. Advisory Committee on Human Radiation Experiments. Chapter 12. U.S. Govt. Printing Office Document #064-000-00-848-9. http://nattie.eh.doe.gov/systems/hrad/chap12_3.html
*ACHRE. 1995. The uranium miners. Final report. Advisory Committee on Human Radiation Experiments. Chapter 12, section 2. http://nattie.eh.doe.gov/systems/hrad/chap12_2.html
*Adams GE, Wilson A. 1993. Radiation toxicology. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology, Vol 2, 1397–1415.
*AFRRI. 1998. Armed Forces Radiobiology Research Institute. Home page. http://www.afrri.usuhs.mil/www/index.html
*Aghamohammadi SZ, Goodhead DT, Savage JRK. 1988. Induction of sister chromatid exchanges (SCE) in G0 lyphocytes by plutonium-238 a-particles. Int J Radiat Biol 53(6):909–915.
*Albert RE, Shore RE. 1986. Carcinogenic effects of radiation on the human skin. In: Radiation carcinogenesis. New York, NY: Elsevier, 335–345.
*Albert RE, Shore RE, Harley NH, . 1986. Followup studies of patients treated by epilation for tinea capitis. In: Burns F, Upton AC, Silini G, eds. Radiation, carcinogenesis and DNA alterations. New York, NY: Plenum Press, 1–25.
*Amaral EC, Vianna ME, Godoy JM, . 1991. Distribution of Cs-137 soils due to the Goiania accident and decisions for remedial action during the recovery phase. Health Phys 60(1):91–98.1983991
*American Airpower Heritage Museum. 1996. The “special” bomb. http://www.avdigest.com/aahm/trspcbmb.html.
*Amundson SA, Chen DJ. 1994. Ionizing radiation-induced mutation of human cells with different DNA repair capacities. Los Alamos National Lab, NM.
*Andersen ME, MacNaughton MG, Clewell HJ, . 1987. Adjusting exposure limits for long and short exposure periods using a physiological pharmacokinetic model. Am Ind Hyg Assoc J 48(4):335–343.3591649
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. In: H. Salem, ed. Animal test alternatives. U.S. Army Chemical Research Development and Engineering Center, Aberdeen Proving Ground, Maryland.
*Andrews LS, Ahmedna M, Grodner RM, . 1998. Food preservation using ionizing radiation. Rev Environ Contam Toxicol 154:1–53.9414630
*Angelo DL, Rittiger CL, Scott RP, . 1999. Exposure rates associated with high level fluoroscopic equipment and data recording modes. Health Phys 76(supplement 2):578–582.
*Anonymous. 1995. Advisory committee on human radiation experiments. Supplemental volume 2. Sources and documentation. Final report. Department of Energy, Washington, DC. Advisory Committee on Human Radiation Experiments.
*Anonymous. 1997a. Report on search for human radiation experiment records, 1944-1994 (volume 1). Assistant to the Secretary of Defense for Nuclear and Chemical and Biological Defense Programs, Washington, DC.
*Anonymous. 1997b. Report on search for human radiation experiment records, 1944-1994 (volume 2). Assistant to the Secretary of Defense for Nuclear and Chemical and Biological Defense Programs, Washington, DC.
*ANSI. 1978. American National Standards Institute. Radiation Protection Instrumentation Test and Calibration, ANSI N323, New York, NY. The Institute of Electrical and Electronics Engineer, Inc.
*ANSI. 1993. American National Standards Institute. Personnel Dosimetry Performance Criteria for Testing, ANSI N13.11.
*Artemova AM, Peterkove V. 1994. Thyroid status in children and adolescents living in areas contaminated with radioactive materials after the Chernobyl accidents. In: Nagataki S, ed. International Congress Series, No. 1074, 0(0):233–235.
*Atomic Energy Insights. 1996. Chernobyl Health Effects: Best Available Data. Adams Atomic Engines, Tarpon Springs, vol. 2, No. 1. http://ans.neep.wisc.edu/~ans/point_source/AE/apr96/effects.html.
*ATSDR. 1990a. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*ATSDR. 1990b. Toxicological profile for thorium. U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry. Atlanta, GA.
*ATSDR. 1990c. Toxicological profile for plutonium. U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry. Atlanta, GA.
*ATSDR. 1990d. Toxicological profile for radium. U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry. Atlanta, GA.
*ATSDR. 1990e. Toxicological profile for radon. U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry. Atlanta, GA.
*ATSDR. 1999a. Toxicological profile for aluminum. U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry. Atlanta, GA.
*ATSDR. 1999b. Toxicological profile for uranium. U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry. Atlanta, GA.
*Aub JC, Evans RD, Hempelmann LH, . 1952. The late effects of internally-deposited radioactive materials in man. Medicine: Analytical Reviews of General Neurology and Pediatrics 31:221–329.
*Ayene SI, Srivastava PN. 1985. Radioprotective effect of 2-mercaptopropionylglycine on radiation-induced microsomal lipid peroxidation. Int J Radiat Biol Relat Stud Phys Chem Med 48(2):197–205.3926681
*Badhwar GD, Cucinotta FA, O’Neill PM. 1994. An analysis of interplanetary space radiation exposure for various solar cycles. Radiat Res 138(2):201–208.8183990
*Balsalobre B. 1991. Complement, circulating immunocomplexes and autoantibodies after ionizing radiation exposure. Rev Esp Fisiol 47(3):147–50.1798858
*Baranov AE, Guskova AK, Nadejina NM, . 1995. Chernobyl experience: Biological indicators of exposure to ionizing radiation. Stem Cells 13(Suppl 1):69–77.7488970
*Barnes JE, McClellan RO, Hobbs CH. 1972. Toxicity in the dog of inhaled ^90^Y in fused clay particles: Distribution, retention kinetics, and dosimetry. Radiat Res 49:416–429.4621653
*Barnthouse LW. 1995. Effects of ionizing radiation on terrestrial plants and animals: A workshop report. Oak Ridge National Lab.
*Bassant MH, Court L. 1978. Effects of whole-body irradiation on the activity of rabbit hippocampal neurons. Radiat Res 75:593–606.724988
*Bayrakova A, Filev G, Baev I, . 1987. Reciprocal translocations in germ cells of male mice receiving external gamma-irradiation. Mutat Res 176(1):53–58.3796659
Baylor College. 1999. Radiation effects. Baylor College of Medicine. http://radefx.bcm.tmc.edu/
*Bazyltchik SV, Astakhova LN. 1995. Mental development of children exposed to ionizing radiation in utero and in infancy. In: Nagataki S, Yamashita S, ed. International Congress Series, No. 1103. Nagasaki Symposium: Radiation and Human Health: Proposal from Nagasaki; Nagasaki Symposium ’95, 50th Anniversary Meeting of the Atomic Bombing in Nagasaki, Nagasaki, Japan, September 19, 1995. Elsevier Science Publishers B.V.: Amsterdam, Netherlands; New York, New York, USA. 97–102.
*Bebeshko VG. 1995. Health effects of the Chernobyl accident abstract. 1995 Uranium Institute Symposium Abstract. http://www.uilondon.org/uiabs95/bebast/html.
*Bebeshko VG. 1996. Health effects of the Chernobyl accident. Uranium Inst Uranium and Nucl Energy 1995 20th Int Symp, London, UK, 67–73.
*Becker PHB, Matta LESC, Moreira AJC. 1991. Guidance for selecting nuclear instrumentation derived from experience in the Goiania accident. Health Phys 60(1):77–80.1983988
*Beechey CV, Green D, Humphreys ER, . 1975. Cytogenic effects of plutonium-239 in male mice. Nature 256(5518):577–578.1165773
*BEIR III. 1980. The effects on populations of exposure to low levels of ionizing radiation. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC: National Academy Press.
*BEIR IV. 1988. Health risks of radon and other internally deposited alpha-emitters. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC: National Academy Press.
*BEIR V. 1990. Health effects of exposure to low levels of ionizing radiation. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC: National Academy Press.
Bellona. 1998. Reprocessing plants in Siberia: Seversk. http://www.bellona.no/e/russia/sibir/sibir2.htm.
*Belot Y, Gauthier D, Camus H, . 1979. Prediction of the flux of tritiated water from air to plant leaves. Health Phys 37:575–583.536219
*Benjamin SA, Boecker BB, Cuddihy RG . 1979. Nasal carcinomas in Beagles after inhalation of relatively soluble forms of beta-emitting radionuclides. J Natl Cancer Inst 63:133–139.286823
*Benjamin SA, Hahn FF, Boecker BB. 1978. Effects of chronic pulmonary irradiation on periheral lymphocytes and their function in the dog. Radiat Res 75:121–137.684163
*Benjamin SA, Hahn FF, Chiffelle TL, . 1975. Occurence of hemangiosarcomas in Beagles with internally deposited radionuclides. Cancer Res 35:1745–1755.1169116
*Benjamin SA, Jones RK, Snipes MB, . 1976. Comparative effects of inhaled relatively insoluble forms of ^90^Y, ^144^Ce, and ^90^Sr on canine peripheral lymphocyte function. In: J. E. Ballou, ed. Radiation and the lympathic system. CONF-740930. 90–99.
*Benjamin SA, Lee AC, Angleton GM, . 1986. Neoplasms in young dogs after perinatal irradiation. J Natl Cancer Inst 77(2):563–571.3461215
*Bentur Y, Horlatsch N, Koren G. 1991. Exposure to ionizing radiation during pregnancy: Perception of teratogenic risk and outcome. Teratology 43(2):109–112.2014476
*Berger ME, Hurtao R, Dunlap J, . 1997. Accidental radiation injury to the hand: Anatomical and physiological considerations. Health Phys 72(3):343–348.9030835
*Bhatia AL, Gupta ML, Singh RP. 1978. Response of mice liver to continuous beta-irradiation from tritiated water. J Radiat Res (Tokyo) 19(3):197–204.739440
*Biedermann KA, Sun J, Giaccia AJ, . 1991. Acid mutation in mice confers hypersensitivity to ionizing radiation and deficiency DNA double-strand break repair. Proc Natl Acad Sci USA 88:1394–1397.1996340
*Bigatti P, Lamberti L, Ardito G, . 1988. Cytogenetic monitoring of hospital workers exposed to low-level ionizing radiation. Mutat Res 204(2):343–347.3343984
*Birioukov A, Meurer M, Peter RU, . 1993. Male reproductive system in patients exposed to ionizing irradiation in the Chernobyl accident. Arch Androl 30(2):99–104.8470947
*Blocher D. 1988. DNA double-strand break repair determines the RBE of α-particles. Int J Radiat Biol 54(5):761–771.2902170
*Bocian E, Ziemba-zak B, Roseik O, . 1977. Chromosome aberrations in human lymphocytes exposed to tritiated water in vitro. Current Topics in Radiation Research Quartley 12:168–181.
*Boecker BB. 1972. Toxicity of 137 CsCl in the Beagle: Metabolism and dosimetry. Radiat Res 50:556–573.4624034
*Boecker BB, Hahn FF, Muggenburg BA. 1988. The relative effectiveness of inhaled alpha- and beta-emitting radionuclides in producing cancer. Radiation Protection Practice 2:1059–1062.
*Bogo V, Jacobs AJ, Weiss JF. 1985. Behavioral toxicity and efficacy of WR-2721 as a radioprotectant. Radiat Res 104(2 Pt 1):182–190.3001816
*Booth GF. 1977. The need for radiation controls in phosphate and related Iidustries. Health Phys 32:285–290.881315
*Borek C, Abraham SK, Sarma L. 1993. Molecular mechanisms in cancer induction and prevention protective effects of chlorogenic acid, curcumin and beta-carotene against gamma-radiation-induced in vivo chromosomal damage. Environ Health Perspect 101:237–245.
*BRAMA. 1996. Gateway Ukraine. http://www.brama.com/ukraine/cbyl.html
*Brandao-Mello CE, Oliveira AR, Valverde NJ, . 1991. Clinical and hematological aspects of Cs-137: The Goiania radiation accident. Health Phys 60(1):31–39.1983978
*Brandvold LL, Brandvold DK, Popp CJ. 1981. Effects of uranium mining and milling on surface water in New Mexico. In: 7th National Conference: Energy Environ, 467–476.
*Brent . 1980. Radiation teratogenesis. Teratology 21:281–298.7006137
*Brodsky A. 1996. Review of radiation risks and uranium toxicity with application to decisions associated with decommissioning clean-up criteria. RSA Publications.
*Brooks AL, Carsten AL, Mead DK, . 1976. The effect of continuous intake of tritiated water (HTO) on the liver chromosomes of mice. Radiat Res 68:480–489.1005664
*Brooks AL, Guilmette RA, Hahn FF, . 1992. Distribution and biological effects of inhaled ^239^Pu(NO_3_)_4_ in Cynomolgus monkeys. Radiat Res 130:79–87.1561321
*Brooks AL, Mead DK, Peters RF. 1971b. Effect of chronic exposure to ^60^Co on the frequency of metaphase chromosome aberrations in the liver cells of the Chinese hamster (in vivo). Int J Radiat Biol 20:599–604.
*Brooks AL, Peters RF, Rollag MD. 1971a. Metaphase chromosome aberrations in Chinese hamster liver cells in vivo after single acute ^60^Co exposure. Radiat Res 45:191–201.5539705
*Bruni JE, Persaud TVN, Froese G, . 1994. Effects of in-utero exposure to low-dose ionizing radiation on development in the rat. Histology and Histopathology 9(1):27–33.8003817
*Buc-Calderon P, Roberfroid M. 1990. Increase in the survival time of mice exposed to ionizing radiation by a new class of free radical scavengers. Experientia 46(7):708–710.2164953
*Buell MG, Harding RK. 1989. Proinflammatory effects of local abdominal irradiation on rat gastrointestinal tract. Dig Dis Sci 34(3):390–399.2920645
*Burt C. 1966. The genetic determination of differences in intelligence: A study of monozygotic twins reared together and apart. Brit J Psychol 57(1–2):137–153.5949392
*Caldwell GG, Kelly DB, Heath CW. 1980. Leukemia among participants in military maneuvers at a nuclear bomb test: A preliminary report. JAMA 244:1575–1578.6932516
*Caltech. 1998. Gamma-ray and X-ray spectroscopy with scintillation and semiconductor detectors. http://tweedledee.wonderland.caltech.edu/~derose/labs/exp12.html
*Canfi A, Chayoth R, Weill S, . 1990. The reproductive system of male rats exposed to very low doses of ionizing radiation, 1: Hormonal profile of animals exposed after sexual maturity. Andrologia 22(2):129–136.2124782
*Cardis E, Anspaugh L, Ivanov VK, . 1996. Estimated long term health effects of the Chernobyl accident. Lawrence Livermore National Lab., CA.
*Cardis SE, Gilbert ES, Carpenter L, . 1994. Direct estimates of cancer mortality due to low-doses of ionizing radiation - an international study. Lancet 344(8929):1039–1043.7934443
*Cassoni AM, McMillan TJ, Peacock JH, . 1992. Differences in the level of DNA double-strand breaks in human tumour cell lines following low dose-rate irradiation. Eur J Cancer 28A(10):1610–1614.1389473
*CDC. 1995. Centers for Disease Control and Prevention and National Institute for Occupational Safety and Health: Research plan for occupational energy-related analytical epidemiology, 2–12.
*Cember H. 1996. Introduction to health physics, 3rd ed. New York, NY: McGraw Hill.
*Cenajek D, Chodera A, Wojciak Z, . 1980. Cystamine effect on the pharmacokinetics of imipramine in radiation sickness. Acta Physiol Pol 31(2):123–129.7395537
*Chang J. 1999. Table of the nuclides. Korea Atomic Energy Research Institute. http://www.dne.bnl.gov/CoN/index.html
*Charles MW, Williams JP, Coggle JE. 1988. Skin carcinogenesis following uniform and nonuniform beta irradiation. Health Phys 55(2):399–406.3410711
Chase. 1985. Medical applications of radioisotopes. In: Remington’s pharmaceutical sciences, Chapter.29. Easton, PA: Mack Publishers.
*Checkoway H, Pearce N, Crawford-Brown J, . 1988. Radiation doses and cause-specific mortality among workers at a nuclear materials fabrication plant. American Journal of Epidemiology 127(2):255–266.3337081
*Chernousenko VM. 1991. Chernobyl: Insight from the inside. Springer-Verlag. http://www.halcyon.com/blackbox/hw/accounts.html
*Childs JD. 1981. The effect of a change in mutation rate on the incidence of dominant and x-linked recessive disorders in man. Mutat Res 83:145–158.7196989
*Chmelevsky D, Kellerer AM, Spiess H, . 1986. A proportional hazard analysis of bone sarcoma rates in German 244 radium patients. In: Gassner and Gerber, eds. The radiobiology of radium and thorotrast, 32–37.
*CIA. 1959. Accident at the Kasli Atomic Plant, Central Intelligence Agency. Report #CS3/389,785 Washington, D.C. March 4, 1959.
*Civil Defense Technology Workshop. 1995. Partnership for peace emergency perparedness program civil defense technology workshop. http://www.dtic.mil/fefenselink/emerg/reports/techwkshp.index.html.
*Clark LS, Albertini RJ, Nicklas JA. 1997. The aminothiol wr-1065 protects t lymphocytes from ionizing radiation-induced deletions of the HPRT gene. Cancer Epidemiol Biomarkers Prev 6(12):1033–7.9419399
*Cleaver JE. 1977. Induction of thioguanine- and ouabain-resistant mutants and single-strand breakes in the DNA of Chinese hamster ovary cells by ^3^H-thymidine. Genetics 87:129–138.914028
*Clewell HJ, III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
*Cobb JC, Eversole BC, Archer PG, . 1982. Plutonium burdens in people living around the Rocky Flats Plant. EPA-600/4-82-069. Springfield, VA: National Technical Information Service.
*Cockerham LG, Cerveny TJ, Hampton JD. 1986. Postradiation regional cerebral blood flow in primates. Aviat Space Environ Med 57(6):578–582.2424423
*Coggle JE, Lambert BE, Moores SR. 1986. Radiation effects in the lung. Environ Health Prospect 70:261–291.
*Coquerelle TM, Weibezahn KF, Lucke-Huhle C. 1987. Rejoining of double stand breaks in normal human and ataxia-telangeictasia fibroblasts after exposure to ^60^Co γ-rays, ^24^1Am α-particles or bleomycin. Int J Radiat Biol 51(2):209–218.
*Court-Brown WM, Doll R. 1957. Leukemia and aplastic anemia in patients treated for ankylosing spondylitis. London: HMSO.
*Court-Brown WM, Doll R. 1959. Adult leukemia. Trends in mortality in relation to aetiology. Br Med J 1:1063.13638632
*Court-Brown WM, Doll R. 1965. Mortality from cancer and other causes after radiotherapy for ankylosing spondylitis. Br Med J 2:1327.5848660
*Crossen PE, Morgan WF. 1979. The effects of β-radiation on sister-chromatid exchanges in cultured human lymphocytes. Mutat Res 62:125–129.492193
*Crump KS, Ng T-H, Cuddihy RG. 1987. Cancer incidence patterns in the Denver metropolitan area in relation to the Rocky Flats plant. American Journal of Epidemiology 126(1):127–135.3591777
*Cuddihy RG. 1978. Deposition and retention of inhaled niobium in Beagle dogs. Health Phys 34:167–176.632096
*Cuddihy RG. 1981. Modeling the metabolism of actnide elements. In: M. E. Wrenn, ed. Actinides in man and animals. Salt Lake City, UT: R. D. Press, 617–628.
*Cuddihy RG. 1984. Mathematical models for predicting clearance of inhaled radioactive materials. Lung modeling for inhalation of radioactive materials, EUR-9382-EN 167-180.
*Cuddihy RG, Boecker BB, 1970. Kinetics of lanthanum retention and tissue distribution in the Beagle dog following administration of ^140^LaCl _3_ by inhalation, gavage and injection. Health Phys 19:419–426.5512924
*Cuddihy RG, Boecker BB, McClellan RO, 1976. ^144^Ce in tissues of Beagle dogs after inhalation of CeCl_3_ with special emphasis on endoctrine glands and reproductive organs. Health Phys 30:53–59.1244338
*Cuddihy RG, Ozog JA. 1973. Nasal absorption of CsCl, SrCl_2_ BaCl_2_ and CeCl_3_ in Syrian hamsters. Health Phys 25:219–224.4785408
*Czeizel A, Sankaranarayanan K. 1984. The load of genetic and partially genetic disorders in man. I. Congential anomalies: Estimates of detriment in terms of years of life lost and years of impaired life. Mutat Res 128:73–103.6472308
*da Silva CJ, Delgado JU, Luiz MTB, . 1991. Considerations related to the decontamination of houses in Goiania: Limitations and implications. Health Phys 60(1):87–90.1983990
*Darby SC, Nakashima E, Kato H. 1985. A parallel analysis of cancer mortality among atomic bomb survivors and patients with ankylosing spondylitis given X-ray therapy. J Natl Cancer Inst 72:1.
*Das UN, Ramadevi G, Rao KP, . 1989. Prostaglandins can modify gamma-radiation and chemical induced cytotoxicity and genetic damage in vitro and in vivo. Prostaglandins D 38(6):689–716.
*Dasgupta P. 1970. Beta-ray induced chromosome breakage phenomena in plants. Cytologia 35:1–35.5448835
*Davila DR, Guilmette RA, Bice DE. 1992. Long-term consequences of ^239^PuO_2_. I. Exposure in dogs: Persistent t lymphocyte dysfunction. Int J Radiat Biol 61:123–133.1345923
*De Luca JC, Dulout FN, Andrieu JM. 1988. The induction of reciprocal translocations in mouse germ cells by chemicals and ionizing radiations. I. Dose-response relationships and combined effects of bleomycin with thio-tepa and gamma-rays. Mutat Res 202(1):65–70.2460767
*De-Chang W, Gong Y-F. 1994. Current status of studies on the biological effects of low-level internal irradiation. Int J Occup Med Toxicol 3(2):219–227.
*Dehos A, Beaufort F, Erzberger A, . 1986. Changes in subpopulations of lymphocytes after exposure to ionizing radiation in vitro and in vivo. First Conference of the European Society for Analytical Cellular Pathology 8940386 Schlo 18N03.
*Demidchik EP, Kazakov VS, Astakhova LN, . 1994. Thyroid cancer in children after the Chernobyl accident: Clinical and epidemiological evaluation of 251 cases in the Republic of Belarus. In: Nagataki, S. ed. Nagasaki Symposium on Chernobyl: Update and Future, International Congress Series, No. 1074, 21–30.
*Devi PU, Baskar R, Hande MP. 1994. Effect of exposure to low-dose gamma radiation during late organogenesis in the mouse fetus. Radiat Res 138(1):133–138.8146293
*Diel JH, Mewhinney JA. 1980. Toxicity of inhaled ^238^PuO_2_. I. Metabolism. In: Book of Papers, 5th International Congress of the International Radiation Protection Association, Israel Health Physics Soc. 107–110.
*DOE. 1970. Staff report on Bikini Atoll environmental levels of plutonium. U.S. Department of Engery Coordination and Information Center, Las Vegas, NV, Accession Number NV0042828, April 11, 1970.
*DOE. 1975. Eneu island ground water and Bikini island cistern water. U.S. Department of Energy Coordination and Information Center, Las Vegas, NV, Accession Number NV0071181.
*DOE. 1978. Preliminary Results: Wholebody counting of Bikini Island residents. U.S. Department of Energy Coordination and Information Center, Las Vegas, NV, Accession Number NV0062367, April, 1978.
*DOE. 1988. Health physics manual of good practices for uranium facilities. U.S. Department of Energy, Idaho National Engineering Laboratory, EGG-2530 UC-41.
*DOE. 1991. Health effects of low-level radiation in shipyard workers. U.S. Department of Energy. DOE Contract No. DE-AC02-79EV10095.
*DOE. 1992. Integrated data base for 1993. U. S. spent fuel and radioactive waste inventories projects, and characteristics. U. S. Department of Energy. Oak Ridge National Laboratory. (ORNL). DOE/RW-0006, Rev 9. Oak Ridge, TN.
*DOE. 1993. Occupational radiation protection. U.S. Department of Energy. Code of Federal Regulations. 10 CFR 835.
*DOE. 1994a. Radiological control manual, U. S. Department of Energy. DOE/EH-0256T, Rev I, Springfield VA. National Technical Information Service.
*DOE. 1994b. External gamma radiation: “gamma dose rates 3 feet above ground on island of Rongelap”. Department of Energy, Nevada Coordination and Information Center, Las Vegas. NV0050785.
*DOE. 1995. Hyuman radiation experiments associated with the U.S. Department of Energy and its predecessors. U.S. Department of Energy, Assistant Secretary for Environment, Safety, and Health, Washington, DC, Document #DOE/EH-0491
*DOE. 1996a. Waste isolation pilot plant (WIPP) fact sheet: About radiation. U.S. Department of Energy. http://www.wipp.carlsbad.nm.us/wippfact/radiatn.html
DOE. 1996b. Yucca Mountain project. U.S. Department of Energy http://yucca_web.ymp.gov/timeline/eis/fact/index.htm
*DOE. 1996c. Environmental Management. U.S. Department of Energy http://www.em.doe.gov/rainplum/fig16.html
*DOE. 1996d. Environmental Management Index. U.S. Department of Energy http://www.em.doe.gov/cgi-bin/tc/tindex.html
*DOE. 1997a. EML procedures manual, HASL-300, 28^th^ edition. Environmental Measurements Laboratory, U. S. Department of Energy, New York.
*DOE. 1997b. Occupational radiation protection. U.S. Department of Energy, Washington, D.C. 10 CFR 835.
*DOE. 1997c. Nuclear power generation and fuel cycle report 1997. Energy Information Administration, U. S. Department of Energy. Washington, DC DOE/EIA-0436(97).
*DOE. 1998. Occupational radiation protection; final rule. U.S. Department of Energy. Federal Register. 63 FR 59662. November 4, 1998.
*DOE. 1999a. DOE openness: Human radiation Experiments. http://www.ohre.doe.gov/
*DOE. 1999b. Comprehensive Epidemiological Data Resource. http://cedr.lbl.gov
*Doggett NA, McKenizie WH. 1983. An analysis of the distribution and dose response of chromosome aberrations in human lymphocytes after in vitro exposure to ^137^cesium gamma radiation. Radiat Environ Biophys 23:33–51.
*DOT. 1995. Carriage by public highway. Class 7 (radioactive) material. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 177.842.
*DOT. 1996. Radiation protection program. U.S. Department of Transportation, Washington, D.C. 49 CFR 172.803.Subpart I.
*DOT. 1997. General requirements for shipments and packaging. Class 7 (radioactive) materials. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 173, Subpart I.
*DOT. 1998. Hazardous materials; withdrawal of radiation protection program requirement; final rule. U.S. Department of Transportation. Federal Register. 63 FR 48566. September 10, 1998.
*Dreicer M, Hakonson TE, White GC, . 1984. Rainsplash as a mechanism for soil contamination of plant surfaces. Health Phys 46(1):177–187.6693237
*Dreyer NA, Loughlin JE, Fahey FH, . 1982. The feasiblity of epdemiologic studies of cancer in residents near the Rocky Flats plant. Health Phys 42(1):65–68.7056649
*Dubrova YE, Jeffreys AJ, Malashenko AM. 1993. Mouse minisatellite mutations induced by ionizing radiation. Nat Genet 5(1):92–94.8220434
*Dufrain RJ, Littlefield LG, Joiner EE, . 1979. Human cytogenetic dosimetry: A dose-response relationship from alpha particle radiation from 241Am. Health Phys 37:279–289.511556
*Durakovic A. 1986a. Heart function studies in dogs after acute gamma irradiation of the precordium. Mil Med 151(5):275–277.3086774
*Durakovic A. 1986b. Hepatobiliary kinetics after whole body irradiation. Mil Med 15(19):487–489.
*Eadie GG, Kaufmann RF. 1977. Radiological evaluation of the effects of uranium mining and milling operations on selected ground water supplies in the Grants Mineral Belt, New Mexico. Health Phys 32:231–241.881310
Earth and Environmental Sciences Directorate. 1996. http://www-ep.es.llnl.gov/www-ep/atm/ras/chernob.html
*Eastern Turkestan Information Bulletin. 1996. The consequences of nuclear tests in eastern Turkestan. http://www.geocities.com/CapitolHill/1730/cnt.html
*Eichholz G. 1982. Environmental aspects of nuclear power. Ann Arbor, MI: Ann Arbor Science.
*Eisenbud M. 1987. Environmental radioactivity from natural, industrial and military sources. Third edition. Academic Press, 84–104.
*EPA. 1976a. Maximum contaminant levels for radium-226, radium-228, and gross alpha particle radioactivity in community water systems. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.15.
*EPA. 1976b. Maximum contaminant levels for beta particle and photon-radioactivity from man-made radionuclides in community water systems. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.16.
*EPA. 1976c. Monitoring frequency for radioactivity in community water systems. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.26.
*EPA. 1977. Environmental radiation protection standards for nuclear power operations. Environmental standards for the uranium fuel cycle. Standards for normal operations. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 190, Subpart B.
*EPA. 1979. Radiological impact caused by emissions of radionuclides into air in the United States. U.S. Environmental Protection Agency. Report No. 520/7-79-006, Washington, D.C. Quoted by Eisenbud 1987.
*EPA. 1980. Prescribed procedures for measurement of radioactivity in drinking water. U. S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory, Cincinnati, OH. EPA-600-4-0-032. 96-111.
*EPA. 1984. Radionuclides: Background information document for final rules. Vol 1. U.S. Environmental Protection Agency, Office of Radiation Program, Washington, DC. EPA 520/1- 84-022-1. NTIS PB85-165751.
*EPA. 1988. Limiting values of radionuclide intake and air concentration and dose conversion factors for inhalation, submersion, and ingestion; Federal Guidance Report No. 11. Oak Ridge National Laboratory and Office of Radiation Programs, Environmental Protection Agency. EPA-520/01-88-020.
*EPA. 1989a. National emission standards for radon emissions from underground mines. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Subpart B.
*EPA. 1989b. Compliance procedures methods for determining compliance with subpart I [40 CFR 61]. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Appendix E.
*EPA. 1989c. Methods for estimating radionuclide emissions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Appendix D.
*EPA. 1989d. National emission standards for emissions of radionuclides other than radon from Department of Energy facilities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Subpart H.
*EPA. 1990. Interim methods for development of inhalation reference doses. U. S. Environmental Protection Agency. EPA-600/8-90/066A.
*EPA. 1991. National emission standards for radionuclide emissions from elemental phosphorus plants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Subpart K.
*EPA. 1992. National emission standards for radon emissions from phosphogypsum stacks. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Subpart R.
*EPA. 1993a. Environmental radiation protection standards for management and disposal of spent nuclear fuel, high-level and transuranic radioactive wastes. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 191.
*EPA. 1993b. Standards for management of uranium byproduct material pursuant to section 84 of the Atomic Energy act of 1954, as amended. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Subpart D.
*EPA. 1993c. Standards for management of thorium byproduct materials pursuant to section 84 of the atomic energy act of 1954, as amended. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Subpart E.
*EPA. 1994a. National emission standards for radon emissions from disposal of uranium mill tailings. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Subpart T.
*EPA. 1994b. Environmental radiation data report 74, April-June 1993. U. S. Environmental Protection Agency. Office of Indoor Air and Radiation. EPA 402-R-93-093.
*EPA 1995a. Standards for the control of residual radioactive materials from inactive uranium processing sites. Standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Subpart A.
*EPA. 1995b. Standards for cleanup of land and buildings contaminated with residual radioactive materials from inactive uranium processing sites. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Subpart B.
*EPA. 1995c. Implementation. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Subpart C.
EPA. 1995d. Environmental radiation data report 82. U. S. Environmental Protection Agency. Office of Indoor Air and Radiation. EPA-402-R-97-005 February 1997.
*EPA. 1996a. National emission standards for radionuclide emissions from federal facilities other than nuclear regulatory commission licensees and not covered by subpart H. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Subpart I.
*EPA. 1996b. Test methods. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Appendix B.
*EPA. 1996c. Health and environmental protection standards for uranium and thorium mills. U.S. Environmental Protection Agency, Washington, D.C. 40 CFR 192.
*EPA. 1996d. Radiation exposure and risk assessment manual. U.S. Environmental Protection Agency. EPA-402-R-96-016.
*EPA. 1996e. Sources of information on indoor air quality. http://www.epa.gov/iedweb00/radon/graphics/zonemap.jpg
*EPA 1997a. National primary drinking water regulations: Analytical methods for radionuclides; final rule and proposed rule. U.S. Environmental Protection Agency. Federal Register. 62 FR 10168. March 5, 1997.
*EPA. 1997b. Radiation standards/guidance/criteria. U.S. Environmental Protection Agency, Office of Radiation and Indoor Air, Internet version. http://www.epa.gov/radiation/
*EPA. 1998a. Land disposal restrictions phase IV: final rule promulgating treatment standards for metal wastes and mineral processing wastes; mineral processing secondary materials and bevill exclusion issues; treatment standards for hazardous soils, and exclusion of recycled wood preserving wastewaters. U.S. Environmental Protection Agency. Federal Register. 63 FR 28566. May 26, 1998.
*EPA. 1998b. Class V injection wells underground injection control regulations, revisions; proposed rule. U.S. Environmental Protection Agency. Federal Register. 63 FR 40586. July 29, 1998.
*EPA. 1998c. Current drinking water standards. National primary and secondary drinking water regulations. U.S. Environmental Protection Agency. Office of Water. Office of Ground Water and Drinking Water. http://www.epa.gov/OGWDW/wot/appa.html.
*EPA. 1999a. National Air and Environmental Radiation Laboratory (NAREL). Home page. U.S. Environmental Protection Agency. http://www.epa.gov/narel/index.html
*EPA. 1999b. EPA’s Indoor Air Quality (IAQ) Home Page. Office of Radiation and Indoor Air. http://www.epa.gov/iedweb00/radon/graphics/zonemap.jpg
*Etoh H, Taguchi YH, Tabachnick J. 1977. Cytokinetics of regeneration in beta-irradiated guinea-pig epidermis. Radiat Res 71(1):109–118.877235
*Evans RD. 1966. The effect of skeletally deposited alpha-ray emitters in man. Br J Radiol 39:881–895.5225013
*Evans RD, Keane AT, Kolenkow RJ. 1969. Radiogenic tumor in the radium cases studied at MIT. In: Mays CW, . eds. Delayed effects of bone seeking radionuclides. Salt Lake City, UT: University of Utah Press, 157–194.
*Fahim FA, Roshdy HM, Yousri RM, . 1993. Some biochemical aspects of the protective effect of strontium chloride on gamma-irradiated rats. Biometals 6(3):163–170.8400762
*Fajgelj A, Lakoski A, Horvat D, . 1991. Chromosome aberrations induced in human lymphocytes by U-234 fission neutrons: I. Irradiation of human blood samples in the “dry cell” of the TRIGA Mark II nuclear reactor. Strahlenther Onkol 167:661–666.1962281
*Farooqi Z, Kesavan PC. 1992. Radioprotection by caffeine pre- and post-treatment in the bone marrow chromosomes of mice given whole-body gamma-irradiation. Mutat Res 269(2):225–230.1383705
*Farooqi Z, Kesavan PC. 1993. Low-dose radiation-induced adaptive response in bone marrow cells of mice. Mutat Res 302 (2):83–89.7684509
*Faustman EM, Omenn GS. 1996. Risk assessment. In: Klaassen CD ed. Casarett & Doull’s toxicology: The basic science of poisons, 5th edition. New York, NY: McGraw Hill, 75–88.
*Faw RD, Shultis JK. 1993. Radiological assessment: Sources and exposures. Englewood Cliffs, NJ: Prentice-Hall.
*FDA. 1973a. Performance standards for ionizing radiation emitting products. Television receivers. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 1020.10.
*FDA. 1973b. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 1020.20.
*FDA. 1974. Performance standards for ionizing radiation emitting products. Cabinet X-ray systems. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 1020.40.
*FDA. 1977a. Radio frequency radiation for the heating of food including microwave frequencies. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 179.30.
*FDA. 1977b. Ultraviolet radiation for the processing and treatment of food. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 179.39.
*FDA. 1986. General provisions for food irradiation. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 179.25.
*FDA. 1991. Performance standards for ionizing radiation emitting products. Computed tomography (CT) equipment. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 1020.33.
*FDA. 1993a. Irradiation in the production, processing, and handling of animal feed and pet food. Ionizing radiation for treatment of laboratory animal diets. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 579.22.
*FDA. 1993b. Performance standards for ionizing radiation emitting products. Radiographic equipment. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 1020.31.
*FDA. 1994a. Performance standards for ionizing radiation emitting products. Diagnostic X-ray systems and their major components. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 1020.30
*FDA. 1994b. Performance standards for ionizing radiation emitting products. Fluroscopic equipment. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 1020.32.
*FDA. 1995. Irradiation in the production, processing and handling of animal feed and pet food. Ionizing radiation for the treatment of poultry feed and poultry feed ingredients. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 579.40.
*FDA. 1996a. Sources of radiation used for inspection of food, for inspection of packaged food, and for controlling food processing. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 179.21.
*FDA. 1996b. Pulsed light for the treatment of food. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 179.41.
*FDA. 1996c. Packaging materials for use during the irradiation of prepackaged foods. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 179.45.
*FDA. 1996d. Performance standards for ionizing radation emitting products. U.S. Department of Health and Human Services. Food and Drug Administration. U.S. Department of Agriculture. 21 CFR 1020.
*FDA. 1997. Ionizing radiation for the treatment of food. U.S. Department of Health and Human Services. Food and Drug Administration. Code of Federal Regulations. 21 CFR 179.26.
*FDA. 1998. Accidental radioactive contamination of human food and animal feeds: Recommendations for state and local agencies. U.S. Department of Health and Human Services. Food and Drug Administration. Center for Devices and Radiological Health. Rockville, MD 20850. August 13, 1998.
*FEMA. 1996. Radiological Emergency Planning and Preparedness. U.S. Federal Emergency Management Agency, Washington, D.C. 44 CFR 351.
*FEMA. 1997. U.S. Federal Emergency Management Agency. http://fema.gov/home/fema/radiolo.htm
*Ferrer I, Olive M, Ribera J, . 1996. Naturally occurring (programmed) and radiation-induced apoptosis are associated with selective c-jun expression in the developing rat brain. European Journal of Neuroscience 8(6):1286–1298.8752598
*Fischbein A, Zabludovsky N, Eltes F, . 1997. Ultramorphological sperm characteristics in the risk assessment of health effects after radiation exposure among salvage workers in Chernobyl. Environ Health Perspect 105(suppl. 6):1445–1449.9467060
*Floersheim GL. 1992. Calcium antagonists protect mice against lethal doses of ionizing radiation. Br J Radiol 65(77):1025–1029.1450817
*Floersheim GL, Chiodetti N, Bieri A. 1988. Differential radioprotection of bone marrow and tumour cells by zinc aspartate. Br J Radiol 61(726):501–508.3370431
*Fomenko LA, Kozhanowskaja Ja K, Gaziev AI. 1995. The adaptive repair response in tissues of chronically irradiated mice. Radiation Protection Dosimetry 62(1–2):31–34.
*Forsberg J, Harms-Ringdahl M, Ehrenberg L, 1978. Interaction of ascorbate with the radioprotective effect of mercaptoethylamin. An exploratory study in mice, whole animals and cell cultures. Int J Radiat Biol Relat Stud Phys Chem Med 34(3):245–252.309452
*Fossett NG, Byrne BJ, Kelley SJ, . 1994. The influence of large deletions on the mutation frequency induced by tritiated water and X-radiation in male Drosophila melanogaster post-meiotic germ cells. Mutation Research 307:213–222.7513799
*Fujiki H, Mori M, Tanooka H. 1982. Delayed induction of ornithine decarboxylase in mouse skin after irradiation with beta-rays. Cancer Lett 15(1):15–17.7059960
*Fujiwara SRL, Carter M, Akiyama M, . 1994. Autoantibodies and immunoglobulins among atomic bomb survivors. Radiat Res 137(1):89–95.8265792
*Fukui M. 1978. Evaluation of a combined sorption model for describing cesium transport in a soil. Health Phys 35(4):555–562.748260
*Galvin JB, Bice DE, Gilmette RA. 1989. Pulmonary immune response of dogs after exposure to 239PuO2. Int J Radiat Biol 55:285–296.2563400
*GAO. 1995. Letter Report. Nuclear safety: Concerns with nuclear facilities and other sources of radiation in the former Soviet Union. U.S. General Accounting Office. Report No. GAO/RCED-96-4, November 07, 1995. http://www.emanifesto.org/OTAEnergyEast/OTAEEEch4.htm
*Garcia H, Shubik P. 1971. Epilation and hair greying in hamsters following one single application of beta rays. J Invest Dermatol 572:94–99.
*Gearhart JM, Diel JH, McClellan RO. 1980. Intrahepatic distribution of plutonium in Beagles. Radiat Res 84:343–352.7443987
*Generoso WM, Cain KT, Cacheiro NL, . 1985. ^239^Plutonium-induced heritable translocations in male mice. Mutat Res 152(1):49–52.4047084
*Geraci JP, Mariano MS, Jackson KL. 1991. Hepatic radiation injury in the rat. Radiat Res 125(1):65–72.1824725
*Geraci JP, Mariano MS, Jackson KL, . 1992. Effects of dexamethasone on late radiation injury following partial-body and local organ exposures. Radiat Res 129(1):61–70.1530802
*Giambarresi LI, Walker RI. 1989. Prospects for radioprotection. In: Textbook of military medicine: Part 1: Warfare, weaponry and the casualty. Medical Consequences of Nuclear Warfare 2:246–273.
*Gidali J, Istvan E, Feher I. 1985. Long-term perturbation of hemopoiesis after moderate damage to stem cells. Exp Hematol 13(7):647–651.4029292
*Gilbert ES. 1983. An evaluation of several methods for assessing the effects of occupational exposure to radiation. Biometrics 39:161–171.6871345
*Gilbert ES, Omohundro E, Buchanan JA, . 1993. Mortality of workers at the Hanford site: 1945-1986. Health Phys 64(6):577–590.8491612
*Gilbert ES, Petersen GR, Buchanan JA. 1989. Mortality of workers at the Hanford site: 1945-1981. Health Phys 56(10):11–25.2909496
*Gillett NA, Hahn FF, Mewhinney JA, . 1985. Osteosarcoma development following single inhalation exposure to americium-241 in Beagle dogs. Radiat Res 104:83–93.3863193
*Gillett NA, Muggenburg BB, Boecker FF . 1987a. Single inhalation exposure to ^90^SrCl_2_ in the Beagle dog: Hematological effects. Radiat Res 110:267–288.3575656
*Gillett NA, Muggenburg BB, Boecker WC, . 1987. Single inhalation exposure to ^90^SrCl_2_ in the Beagle dog: Late biological effects. J Natl Cancer Inst 79(2):359–376.3110478
*Gillett NA, Muggenburg BB, Mewhinney . 1988. Primary liver tumors in Beagle dogs exposed by inhalation to aerosols of plutonium-238 dioxide. Am J Pathol 133:265–276.3142267
*Gillett NA, Stegelmeier BL, Kelly G. 1992. Expression of epidermal growth factor receptor in plutonium-239 induced lung neoplasms in dogs. Vet Pathol 29:425–449.
*Gilot-Delhalle J, Moutschen J, Garsou J. 1988. Induction of translocations in mouse spermatogonia after fractionated exposure to ^60^Co gamma-rays. Mutat Res 207(1):29–31.3336376
*Glasstone S, Dolan PJ. 1977. The effects of nuclear weapons. U.S. Govt. Printing Office, Washington, DC.
*Goans RE. 1995. Project sapphire. Health Phys 68:296–298.7860299
*Godoy JM, Guimaraes RJ. Pereira JC, . 1991. Cesium-137 in the Goiania waterways during and after the radiological accident. Health Phys 60(1):99–103.1983992
*Gonzalez AJ. 1994. Biological effects of low doses of ionizing radiation: A fuller picture. IAEA Bull 36(4):37–45.
*Gore DJ, Patrick G. 1978. The distribution and clearance of inhaled uranium dioxide particles on the first bifurcation and trachea of rats. Phys Med Biol 23:730–737.704675
*Gracheva LM, Korolev VG. 1972. The role of β radiation, accompanying the decay of phosphorus-32 incorporated into the cells of diploid yeasts in the induction of recombination. Genetika 8(9):84–91.
*Grahn D, Carnes BA. 1988. Genetic injury in hybrid male mice exposed to low doses of ^60^Co gamma-rays or fission neutrons. III. Frequencies of abnormal sperm and reciprocal translocations measured during and following long-term weekly exposures. Mutat Res 2:285–294.
*Grahn D, Lee CH, Farrington BF. 1983. Interpretation of cytogenetic damage induced in the germ line of male mice exposed for over 1 year to ^239^Pu alpha particles, fission neutrons, or ^60^Co gamma rays. Radiat Res 95(3):566–583.6611862
*Griffith WC, Guilmette RA. 1991. Multiparameter analysis of fall-out plutonium burdens in human hair. Radiation Protection Dosimetry 38(1/3):113–119.
*Griffith WC, Mewhinney JA, Muggenburg BA, . 1983. Bioassay model for estimating body burdens of ^241^Am from excretion analyses. Health Phys. 44:545–554.6862929
*Guilmette RA, Eidson AF. 1992. Using animal dosimetry models to interpret human bioassay data for actinide exposures. Int J Radioanalytical Nucl Chem Articles 1561:449–525.
*Guilmette RA, Mewhinney JA. 1989. A biokinetic model of inhaled curium compounds in dogs: Application to human exposure data. Health Phys 187–198.
*Hahn FF, Barnes JE, Hobbs CH, 1975. Effect of ^90^Y Inhaled in fused clay particles on the gastrointestinal tract of Beagles. Radiation Research 61:444–456.1114264
*Hahn FF, Benjamin SA, Boecker BB. 1977. Comparative pulmonary carcinogenicity of inhaled beta-emitting radionuclides in Beagle dogs. In: Walton WH, ed. Inhaled particles, IV. New York, NY: Pergamon Press, (Part 1):221–234.
*Hahn FF, Boecher CH, Hobbs CH . 1976. Effect of ^144^Ce inhaled in fused clayed particles on the tracheobronchial lymph nodes. In: Ballou JE, ed. Radiation and the lympatic system, Doc. CONF-740930 218–224.
*Hahn FF, Boecker BB, McClellan RG. 1988. Organs and cells at risk after inhalation of insoluble beta-emitting radionuclides: Lessons from experimental studies. Ann Occup Hyg 32:1123–1128.
*Hahn FF, Lundgren DL. 1992. Pulmonary neoplasms in rats that inhaled cerium-144 dioxide Toxicol Pathol 20:169–178.
*Hahn FF, Mewhinney JA, Merickel BS, . 1981. Primary bone neoplasms in Beagle dogs exposed by inhalation to aerosols of plutonium-238 dioxide. J Natl Cancer Inst 67:917–927.6944558
*Hall EJ. 1988. Radiobiology for the radionuclides by workers, Part 1. New York, NY: Pergamon Press, 23–55.
*Hall EJ (ed). 1994. Cell-survival curves. In: Radiobiology for the radiologist (third edition), Philadelphia, PA: Lippincott, 18–38.
*Hall EJ. 1998. Radiation and life. Uranium Information Center. http://www.uic.com.au/ral.htm
*Ham WT. 1953. Radiation cataracts. Arch Opthalmol 50:618.
*Hamlet R, Heryet JC, Hopewell JW, . 1986. Late changes in pig skin after irradiation from beta-emitting sources of different energy. Br J Radiol Suppl 19:51–54.
*Handler J. 1992. U.S. Military activity in the Arctic in the 1990s: Is it needed? Greenpeace Nuclear Campaign Report. http://www.greenpeace.org/~usa/reports/nuclear/arctconf.html.
*Harapanhalli RS, Narra VR, Yaghmai V, . 1994. Vitamins as radioprotectors in vivo. II. Protection by vitamin A and soybean oil against radiation damage caused by internal radionuclides. Radiat Res 139(1):115–122.8016300
*Harley NH. 1991. Toxic effects of radiation and radioactive material. In: Amdur MO, Doull, JD, Klaassen CD, ed. Casarett and Doull’s toxicology: The basic science of poisons, 4th ed. New York, NY: Pergamon Press, 723–752.
*Harley NH, Kolber AB, Shore RE, . 1983. The skin dose and response for the head and neck in patients irradiated with X-rays for tinea capitis: Implications for environmental radioactivity. In: Proceedings in Health Physics Society Mid-Year Symposium, Albuquerque, NM; Health Physics Society, 125–142.
*Hart DR, McKee PM, Burt AJ, . 1986. Benthic community and sediment quality assessment of Port Hope Harbour, Lake Ontario. J Great Lakes Res 12:206–220.
*Hart PM, Archer DB, Chakravarthy U. 1995. Asymmetry of disciform scarring in bilateral disease when one eye is treated with radiotherapy. British Journal of Ophthalmology 79(6):562–568.7542916
*Harvard Medical School, Beth Israel Hospital. 1996. Safety concerns. http://www.bih.harvard.edu/radiology/headings/risks.html
*Harvey RS. 1970. Temperature effects on the sorption of radionuclides by freshwater algae. Health Phys 19(2):293–297.4998199
*Hatch M, Susser M. 1990. Background gamma radiation and childhood cancers within ten miles of a USA nuclear plant. Int J Epidemiol 19(3):546–552.2262246
*Hatch MC, Beyea J, Nieves JW, . 1990. Cancer near the Three Mile Island nuclear plant (Pennsylvania, USA): Radiation emissions. Am J Epidemiol 132(3):397–412.2389745
*Havenaar JM, Rumyantzeva GM, van den Brink W, . 1997. Long-term mental health effects of the Chernobyl disaster: An epidemiologic survey in two former Soviet regions. Am J Psychiatry 154(11):1605–7.9356574
*Hendee W. 1973. Radioactive isotopes in biological research. New York, NY: John Wiley and Sons.
*Hobb CH, Barnes JE, McCleelan RO, . 1972. Toxicity in the dog of inhaled ^90^Y in fused clay particles: Early biological effects. Radiat Res 49:430–460.5058081
*Hobbs C, McClellan R. 1986. Radiation and radioactive materials. In: Doull J, ., eds. Cassarett and Doull’s toxicology: The basic science of poison, 3rd ed. New York, NY: Macmillan Publishing Co., Inc., 497–530.
*Hoffmann W, Kranefeld A, Schmitz-Feuerhake I. 1993. Radium-226-contaminated drinking water: Hypothesis on an exposure pathway in a population with elevated childhood leukemia. Environ Health Perspect 101(Suppl 3):113–115.8143601
*Holm LE, Eklund G, Lundell G. 1980. Incidence of malignant thyroid tumors in humans after exposure to diagnostic doses of iodine-131. II. Estimation of thyroid gland size, thyroid radiation dose, and predicted versus observed number of malignant thyroid tumors. J Natl Cancer Inst 65:1221–1224.6933269
*Hopewell JW, Coggle JE, Wells J, . 1986. The acute effects of different energy beta-emitters on pig and mouse skin. Br J Radiol Suppl 19:47–51.
*HPS. 1996. Health Physics Society (HPS) Standard no. N13.30-1996. Performance Criteria for Radiobioassay published by the Health Physics Society in 1996.
*HPS. 1999. Health Physics Society. Home page. http://www.hps.org
*HSDB. 1995. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Program (via TOXNET), Bethesda, MD. January 1995.
*Hulse EV. 1966. Incidence and pathogenesis of skin tumours in mice irradiated with single external doses of low energy beta particles. Br J Cancer 21(3):531–547.
*Humphreys ER, Humm JL, Monte-Carlo A. 1988. Approach to the microdosimetry of ^224^Ra in murine compact and cancellous bone. Health Phys 54(6):607–615.3163989
*Husen T. 1959. Psychological twin research: A methological study. Uppsala, Sweden: Almqvist & Wiksells.
*ICRP. 1977. Recommendations of the ICRP. Publication #26. International Commission on Radiological Protection, Stockholm, Sweden.
*ICRP. 1984. International Commission for Radiation Protection. A compilation of the major concepts and quantities in use by ICRP. ICRP Publication 42. Oxford: Pergamon Press.
*ICRP. 1986. International Commission for Radiation Protection. Developmental effects of irradiation on the brain of the embryo and the fetus. ICRP Publication 49.
*ICRP. 1991. 1990 Recommendations of the International Commission on Radiological Protection, ICRP Publication 60. Oxford: Pergamon Press.
*ICRP. 1995. Limits for intakes of radionuclides by workers. 5. Dosimetric model for the respiratory system. In: Sowby FD (ed). Radiation Protection, ICRP Publication 30 (Part I) - limits for intakes of radionuclides by workers. A report of committee 2 of the International Commission on Radiological Protection. International Commission on Radiological Protection. Oxford, New York, Frankfurt: Pergamon Press, 23–55.
*ICRP. 1997. Work of the International Commission on Radiological Protection, Internet version, http://www.irpa.at/irpa/icrp.htm.
*Iijima K, Morimoto K. 1991. Quantitative analyses of the induction of chromosome aberrations and sister-chromatid exchanges in human lymphocytes exposed to γ rays and mitomycin-C in combination. Mutat Res 263:263–268.1907353
*Ijiri K. 1989. Cell death (apoptosis) in mouse intestine after continuous irradiation with gamma rays and with beta rays from tritiated water. Radiat Res 118(1):180–191.2704788
*Inano H, Suzuki K, Ishii-Ohba H, 1989. Steroid hormone production in testis, ovary, and adrenal gland of immature rats irradiated in utero with ^60^Co. Radiat Res 117(2):293–303.2922474
*Indran M, Carr KE, Gilmore RS, . 1991. Mucosal changes in mouse duodenum after gamma-irradiation or reserpine treatment. J Submicrosc Cytol Pathol 23(2):267–278.2070352
*Iranzo E, Rivas P, Mingarro E. 1991. Distribution and migration of plutonium in soils of an accidentally contaminated environment. Radiochim Acta 52/53:249–256.
*Iranzo E, Salvador S, Iranzo CE. 1987. Air concentrations of plutonium-239 and plutonium-240 and potential radiation doses to persons living near plutonium contaminated areas in Palomares, Spain. Health Phys 52(4):453–462.3570788
IRIS. 1999. Integrated risk information system (IRIS). Online. U.S. Environmental Protection Agency. National Center for Environmental Assessment, Cincinnati, OH. http://www.epa.gov/iris/subst/index.html
*ITRI. 1991-1993. Biennial report on long-term dose-resposes studies of inhaled or injected radionuclides (Report 139). Inhalation Toxicology Research Institute, Lovelace Biomedical and Environmental Research Institute, Albuquerque, NM, 1–99.
*Jablon S, Hrubec Z, Boice Z, . 1990. Cancer in populations near nuclear facilities. NIH Publication No. 90-874. Washington, DC: U.S. Government Printing Office.
*Jacoby R, Glauberman N (eds). 1995. The bell curve debate. History, documents, opinions. New York, NY: Times Books.
*Jagetia GC, Ganapathi NG. 1991. Treatment of mice with a herbal preparation (Liv. 52) reduces the frequency of radiation-induced chromosome damage in bone marrow. Mutat Res 253(2):123–126.1922138
*James A, Roy M. 1987. Dosimetric lung models. In: Gerber G, ., eds. Age-related factors in radionuclide metabolism and dosimetry. Boston, MA: Martinus Nijhoff Publishers, 95–108.
*James AC, Birchall A, Cross FT. 1989. The current approach of the ICRP Task Group for modeling doses to respiratory tract tissues. Health Phys 57:281–282.2759868
*Janeczko K, Pawlinski R, Setkowicz Z, . 1997. Long-term postnatal effect of prenatal irradiation on the astrocyte proliferative response to brain injury. Brain Research 770(1–2):237–241.9372224
*Jenner TJ, deLara CM, O’Neill P, . 1993. Induction and rejoining of DNA double-strand breaks in V79-4 mammalian cells following γ- and α-irradiation. Int J Radiat Biol 64(3):265–273.8105005
*Jeter EK, Gadsden RH, Cate JC IV. 1991. Irradiation effect on aging red blood cells. Ann Clin Lab Sci 21(6):420–425.1781666
*Jiang TN, Lord BI, Hendry JH. 1994. Alpha particles are extremely damaging to developing hemopoiesis compared to gamma irradiation. Radiat Res 137(3):380–384.8146282
*Johnson CJ. 1981. Cancer incidence in an area contaminated with radionuclides near a nuclear installation. Ambio 10(4):176–182.
*Johnson NF. 1995. Radiobiology of lung target cells. Radiation Protection Dosimetry 60(4):327–330.
*Josephson ES, Brynjolfsson A, Wierbicki E. 1974. The use of ionizing radiation for preservation of food and feed products. Radiat Res 96–117.
*Kadhim MA, Macdonald DA, Goodhead DT, . 1992. Transmission of chromosomal instability after plutonium α-particle irradiation. Nature 355(6362):738–740.1741061
*Kamiguchi Y, Tateno H, Mikamo K. 1990. Dose-response relationship for the induction of structural chromosome aberrations in human spermatozoa after in vitro exposure ito tritium β-rays. Mutat Res 228:125–131.2300065
*Kamiguchi Y, Tateno H, Mikamo K. 1991. Micronucleus test in 2-cell embryos as a simple assay system for human sperm chromosome aberrations. Mutat Res 252:297–303.2052009
*Kanwar KC, Verma a. 1992. Alterations in the hematological profile in rat following whole body gamma radiation with and without venoruton and pretreatment. J Environ Pathol Toxicol Oncol 11(4):235–239.1507075
*Kathren RL. 1984. Radioactivity in the environment. Distribution and surveillance. New York, NY: Harwood Academic Publishers, 93–115.
*Kaufman AS. 1996. IQ, lead level, and inferences from research studies - comments addressing the underlying science forming the basis of HUD’s regulatory impact analysis. Psychological Assessment Resources, Inc. (PAR): i–ii; 1–56.
*Kazakov VS, Demidchik EP, Astakhova LN. 1992. Thyroid cancer after Chernobyl. Scientific correspondence. Nature 359(3).
*Kelsey KT, Wiencke JK, Liber HL. 1995. Biomarkers to detect radiation exposures. In: Biomarkers and occupational health: Progress and perspectives, 215–225.
*Kempf SR, Port RE, Ivankovic S. 1994. Anticarcinogenic effect of tetrachlorodecaoxide after total-body gamma irradiation in rats. Radiat Res 139(2):226–231.8052699
*Kim TH, Kim SH, Lee YS, . 1994. Protective effects of potato extracts and 16,16-dimethyl prostaglandin E2 on the induction of hepatic foci by cotreatment of gamma radiation and diethylnitrosamine. Anticancer Res 14(5A):1979–1982.7847837
*Klener V, Tuscany R, Vejlupkova J, . 1986. Long-term follow-up after accidental gamma irradiation from a ^60^Co source. Health Phys 51(5):601–607.3771221
*Kneale GW, Mancuso TF, Stewart AM. 1981. Hanford radiation study III: A cohort study of the cancer risks from radiation to workers at Hanford (1944-77) by the method of regression models in life-tables. British Journal of Industrial Medicine 38:156–166.7236541
*Kneale GW, Stewart AM. 1986. Prenatal x rays and cancers: Futher tests of data from the Oxford survey of childhood cancers. Health Phys 51(3):369–376.3744839
*Knoll GF. 1989. Radiation detection and measurement. Second edition. New York, NY: John Wiley & Sons.
*Kohn WG, Grossman E, Fox PC, . 1992. Effect of ionizing radiation on sympathetic nerve function in rat parotid glands. J Oral Pathol Med 21(3):134–137.1583597
*Kondo S. 1993. Health effects of low-level radiation. Osaka, Japan: Kinki University Press and Madison, WI: Medical Physics Publishing.
*Koshimoto C, Takahashi S, Kubota Y, . 1994. Evaluation of the effect of gamma-irradiation on fetal erythropoiesis in rats using blood cell volume as the index. J Radiat Res (Tokyo) 35(2):74–82.7965992
*Kossenko MM, Izhevsky PV, Degteva MO. 1994. Pregnancy outcome and early health status of children born to the Techa River population. Sci Total Environ 142(1,2):91–100.8178140
*Kovacs CJ, Gooya JM, Harrell JP. 1991. Altered radioprotective properties of interleukin I alpha (IL-1) in non-hematologic tumor-bearing animals. Int J Radiat Oncol Biol Phys 20(2):307–310.1991693
*Kovacs CJ, Harrell JP, Evans MJ. 1992. Absence of interleukin I alpha radioprotection in tumor-bearing animals: Elevated plasma levels of prostaglandin E versus a preexisting primed marrow. J Leukoc Biol 51(1):53–58.1740644
*Krieger HL, Whittaker EL. 1980. Prescribed procedure for measurment of radioactivity in drinking water. U. S. Environmental Protection Agency, Office of Research and Development. EPA 600/4-80-032.
*Krisch RE, Krasin F, Sauri CJ. 1976. DNA breakage, repair and lethality after ^125^I decay in rec+ and recA strains of Escherichia coli. Int J Radiat Biol 29(1):37–50.
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Wallace Hayes, ed. Principles and methods of toxicology, 3rd edition. New York, NY: Raven Press, Ltd.
*Krishnan K, Andersen ME, Clewell HJ,III, . 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Yang, RSA, ed., Toxicology of chemical mixtures. New York, NY: Academic Press.
*Kuglik P, Slotova J. 1991. Different effects of pretreatment with triated thymidine (^3^H-dTh) on radiation-induced sister chromatid exchanges (SCEs) and micronuclei in Vicia faba root tip cells. Biologia Plantarum 33(4):291–297.
*Kumar S, Kumar A, Goyal PK, . 1983. Population kinetic studies in mouse jejunum under continuous beta-exposure from tritiated water. Radiobiol Radiother (Berl) 24(2):239–242.6867305
*Kusama T, Hasegawa Y. 1993. Stage differences in developmental disorders in ICR mouse embryos irradiated with gamma-rays. Senten Ijo 33:115–23.
*LaBauve RJ, Brooks AL, Mauderly JL, . 1980. Cytogenetic and other biological effects of ^239^PuO_2_ inhaled by the Rhesus monkey. Radiat Res 82:310–335.6769136
*Laissue JA, Altermatt HJ, Bally E, . 1987. Protection of mice from whole body gamma irradiation by deuteration of drinking water: Hematologic findings. Exp Hematol 15(2):177–180.3545878
*Lazanyi A. 1965. The effect of sulphoguanidine and p-nitrobenzoic acid on the chromosome breakage-reunion process by γ-, X-and β-irradiation in Vicia faba. Int J Rad Biol 10(4):329–342.
*Le XC, Xing JZ, Lee J, . 1998. Inducible repair of thymine glycol detected by an ultrasensitive assay for DNA damage. Science 280(5366):1066–1069.9582118
*Leadon SA. 1996. Repair of DNA damage produced by ionizing radiation: A minireview. Seminars in Radiation Oncology 6(4):295–305.10717187
*Lee AC, Angleton GM, Benjamin SA. 1989. Hypodontia in the Beagle after perinatal whole-body ^60^Co gamma irradiation. Radiat Res 118(3):467–475.2657843
*Leemhorst JG. 1993. Potentials of ionizing-radiation in reducing hazards to man and environment. Radiat Phys Chem 42(3:)19–21.
*Lefaix JL, Martin M, Tricaud Y, . 1993. Muscular fibrosis induced after pig skin irradiation with single doses of ^192^Ir gamma-rays. Br J Radiol 66(786):537–544.8330139
*Leung H. 1993. Physiologically-based pharmacokinetic modeling. In: Ballantine B, Marro T, Turner T, eds., General and applied toxicology, Vol. I. New York, NY: Stockton Press, 153–164.
*Lide DR. 1994. In: CRC handbook of chemistry and physics, 74th ed. 50–51, 54, 73, 83–84, 90102, 106, 122.
*Lieberman R. 1984. Facility radiochemistry procedures manual. Eastern Environmental Radiation Facility. U. S. Environmental Protection Agency. EPA 520/5-84-006.
*Lin I-H, Hau D-M, Chen W-C, . 1996. Effects of low-dose gamma-ray irradiation on peripheral leukocyte counts and spleen of mice. Chinese Medical Journal (English edition) 109(3):210–214.
*Lipman RM, Tripathi BJ, Tripathi RC. 1988. Cataracts induced by microwave and ionizing radiation. Surv Ophthalmol 33(3):200–210.3068822
*Lippmann M, Schlesinger RB. 1984. Interspecies comparisons of particle deposition and mucociliary clearance in tracheobronchial airways. J Tox Environ Health 13:441[261]–469[289].
*Liu VF, Boubnov NV, Weaver DT. 1995. Cell cycle checkpoints and repair of ionizing radiation damage. Stem Cells 13(Suppl 1):117–28.7488937
*Lloyd DC, Edwards AS, Fitzsimons EJ. 1994. Death of a classified worker probably caused by overexposure to gamma radiation. Occupational and Environmental Medicine 51(10):713–718.8000499
*Lognonne JL, Ducousso R, Rocquet G, . 1985. Influence of whole-body gamma irradiation upon arachidonic acid metabolism in rat platelets. Biochimie 67(9):1015–1021.3936548
*Loucas BD, Geard CR. 1994. Initial damage in human interphase chromosomes from alpha particles with linear energy transfers relevant to radon exposure. Radiat Res 13:9–14.
*Lowry JD, Lowry SB. 1988. Radiaonuclides in drinking water. American Water Works Association Journal 80:51–64.
*Lubin JH, Boice JD, Edling C, . 1995. Lung cancer in randon-exposed miners and estimation of risk from indoor exposure. J Natl Canc Instit. 87:817–826. http://cancer.med.upenn.edu/cancer_news/lung_radon.html
*Lucas JN. 1998. Cytogenetic signature for ionizing radiation. Int J Radiat Biol 73(1):15–20.9464473
*Luckey TD. 1994. Radiation hormesis in cancer mortality. Int J Occup Med Toxicol 3(2):175–193.
*Luckey TD. 1997. Radiation hormesis: Biopositive effect of radiations. In: Bastide M, ed. Signals and images (7th and 8th Groupe), 31–39.
*Lumniczky K, Antal S, Unger E, . 1997. Oncogenic changes in murine lymphoid tumors induced by in utero exposure to ionizing radiation. Radiat Oncol Investig 5(3):158–62.
*Lundell M, Hakulinen T, Holm L-E. 1994. Thyroid cancer after radiotherapy for skin hemangioma in infancy. Radiat Res 140(3):334–339.7972685
*Lundgren DL, Hahn FF, McClellan RO. 1980a. Influence of age at the time of inhalation exposure to aerosols of ^144^CeO_2_ on ^144^Ce retention, dosimetry and toxicity in mice. Health Phys 38:643–655.7410082
*Lundgren DL, Hahn FF, McClellan RO. 1981. Toxicity of ^90^Y inhaled in relatively insoluble fused aluminosilicate particles when inhaled by mice. Radiat Res 88:510–523.7313078
*Lundgren DL, Hahn FF, Rebar AH. 1983. Effects of the single or repeated inhalation exposure of Syrian hamsters to aerosols of ^239^PuO_2_. Int J Radiat Biol Relat Stud Phys Chem Med 43(1):1–18.6601068
*Lundgren DL, Hahn FF, Sanchez A . 1976. Effect of inhaled yttrium-90 in fused clay particles on the pulmonary clearance of inhaled staphyloccoccus aureus in mice. Radiat Res 66:231–246.1265218
*Lundgren DL, Mauderly JL, Carlton WW. 1990. Biological effects of inhaled ^239^PuO_2_ in rats with pre-existing pulmonary emphysema. Hum ExpToxicol 9(5):295–308.
*Lundgren DL, Mauderly JL, Rebar AH. 1991. Modifying effects of preexisting pulmonary fibrosis on biological responses of rats to inhaled ^239^PuO_2_. Health Phys 60(3):353–363.1704874
*Lundgren DL, McClellan RO, Hahn FF. 1980b. Repeated inhalation exposure of mice to ^144^CeO_2_ I. Retention and dosimetry. Radiat Res 82:106–122.6768099
*Lundgren DL, McClellan RO, Thomas RL, . 1974. Toxicity of inhaled ^144^CeO_2_ in mice. Radiat Res 58:448–461.10876635
*Lushbaugh C, Eisele G, Burr W Jr, . 1991. Current status of biological indicators to detect and quantify previous exposures to radiation. Biological Indicators Working Group. Health Phys 60:103–109.2004917
*Lynch L, Bowen M, Malone L. 1994. Patient exposure to ionizing radiation in the intensive care unit due to protable chest radiography. Irish Journal of Medical Science 163:136–137.8200778
*Macintyre WJ, Saha GB. 1995. Sources of ionizing radiation and their effects on humans. In: Cordasco EM, Sr., Demeter SL, Zenz C, eds. Environmental respiratory diseases. Van Nostrand Reinhold Co. Inc.: New York, New York, USA; Van Nostrand Reinhold Co. Ltd.: Wokingham, England, UK, 337–348.
*Maes AA, Hilali ED, Leonard A, . 1993. Stable chromosome aberrations 25 years after severe accidental radiation exposure. Radiation and Environmental Biophysics 32(4):319–324.8310126
*Maisin JR. 1988. Protection against ionizing radiation by combinations of radioprotectors. Pharmacol Ther 39(1–3):189–193.3059367
*Malhotra N, Rani N, Rana K, . 1990. Radiation induced blood pathology in chick-erythrocytes and related parameters. Exp Pathol 38(4):241–248.2201560
*Mancuso TF, Stewart A, Kneale G. 1977. Radiation exposures of Hanford workers dying from cancer and other causes. Health Phys 33:369–385.591314
*Martland HS. 1931. The occurrence of malignancy in radioactive persons: A general review of data gathered in the study of the radium dial painters, with special reference to the occurrence of osteogenic sarcoma and the inter-relationship of certain blood diseases. The American Journal of Cancer 15(4):2435–2516.
*Maruyama H, Yamamoto I. 1992. Suppression of ^125^I-uptake in mouse thyroid by seaweed feeding: Possible preventative effect of dietary seaweed on internal radiation injury of the thyroid by radioactive iodine. Kitasato Arch Exp Med 65(4):209–216.1344008
*Masse F. 1996. Personal communication (via http://www.fi.uib.no/~ladi/ADNAN/radiationprimer.txt).
*Masse R, Cross FT. 1989. Risk considerations related to lung modeling. Health Phys 57:283–289.2691450
*Matanoski GM. 1991. Health effects of low-level radiation in shipyard workers, Report by Johns Hopkins University.
*Mathur S, Nandchahal K, Bhartiya HC. 1991. Radioprotection by MPG of mice ovaries exposed to sublethal gamma radiation doses at different postnatal ages. Acta Oncol 30(8):981–983.1777248
*Matsushita S, Ando K, Koike S, . 1994. Radioprotection by WR-151327 against the late normal tissue damage in mouse hind legs from gamma ray radiation. Int J Radiat Oncol Biol Phys 30(4):867–872.7960989
*Mays CW. 1988. Alpha-particle-induced cancer in humans. Health Phys 55(4):637–652.2844697
*Mays CW, Aamodt RL, Inn KGW, . 1992. External gamma ray counting of selected tissue from a throatrast patient. Health Phys 63:33–40.1522008
*Mazur L, Manowska J, Bobik R. 1991. Effects of ^60^Co gamma-irradiation of mice on the temporal changes of acid phosphatase activity in spleen and liver. Acta Physiol Hung 78(2):135–141.1808979
*McClellan RO, Barnes JE, Boecker BB, . 1970. Toxicity of beta-emitting radionuclides inhaled in fused clay particles—An experimental approach. In: Nettesheim P, Hanna MB, Deatherage JW, eds. Morphology of experimental respiratory carcinogenesis. CONF-700501. 395–415.
*McClellan RO, Benjamin SA, Boecker TL, . 1973. Neoplasms in dogs that inhaled ^90^SrCl_2_. In: Sanders CL, . eds. Radionuclide carcinogenesis. CONF-720505. 215–232.
*McClellan RO, Boecker BB, Cuddihy RG, . 1982. Health effects from internally deposited radionuclides released in nuclear disasters. In: The control of exposure of the public to ionizing radiation in the event of accident or attack. National Council on Radiation Protection and Measurements, Bethesda, MD, 28–39.
*McCurdy D, Tai LQ, Frias S, . 1997. Delayed repair of DNA damage by ionizing radiation in cells from patients with juvenile systemic lupus erythematosus and rheumatoid arthritis. Radiat Res 147(1):48–54.8989369
McGuire SA, Peabody CA. 1982. Working safely in gamma radiology. National Research Council.
*Merck. 1989. Merck index: An encyclopedia of chemicals, drugs, and biologicals. 11th ed. Budavari S, ed. Rahway NJ: Merck & Co., Inc.
*Mettler F, Moseley R. 1985. Medical effects of ionizing radiation. New York, NY: Grune and Stratton.
*Mewhinney JA, Griffith WC. 1982. Model of am metabolism in Beagles and humans. Health Phys 42:629–644.7085303
*Mewhinney JA, Griffith WC. 1983. Tissue distribution model for assessment of human inhalation exposures to ^241^AmO_2_. Health Phys 44:537–544.6862928
*Mikamo K, Kamiguchi Y, Tateno H. 1990. Spontaneous and in vitro radiation-induced chromosome aberrations in human spermatozoa: Applications of a new method. Mutation and the Environment: Part B: Metabolism, testing methods, and chromosomes 340B:447–456.
*Mikamo K, Kamiguchi Y, Tateno H. 1991. The interspecific in vitro fertilization system to measure human sperm chromosomal damage. New Horizons in Biological Dosimetry 372:531–542.
*Milkovic-Kraus S, Kubelka D, Vekic B. 1992. Biological monitoring of three cobalt-60 radiation incident victims. Am J Ind Med 22(2):243–247.1415289
*Miller RC, Randers-Pehrson G, Geard CR, . 1999. The oncogenic transformation potential of the passage of single α particles through mammalian cell nuclei. Proc Natl Acad Sci, USA. 96:19–22.9874764
*Milner SM, Nguyen TT, Herndon DN, . 1996. Radiation injuries and mass casualties. In: Herndon DN, ed. Total burn care. W. B. Saunders, 425–431.
*Minamisawa T, Hirokaga K, Sasaki S. 1990. Gross morphological changes of the mouse brain exposed prenatally to ionizing radiation. J Radiat Res (Tokyo) 31(2):214–218.2213692
*Minamisawa T, Hirokaga K, Sasaki S, . 1992. Effects of fetal exposure to gamma rays on aggressive behavior in adult male mice. J Radiat Res (Tokyo) 33(3):243–249.1464856
*Misurova E, Kropacova K. 1992. Synthesis of nucleic acids in blood cells in mice after irradiation with gamma rays. Neoplasma 39(1):29–33.1382233
*Mitchel REJ, Trivedi A. 1992. Chronic exposure to ionizing radiation as a tumor promoter in mouse skin. Radiat Res 129(2):192–201.1734450
*Mlekodaj RL. 1995. Basic units and concepts in radiation exposures. In: Young JP, Yalow RS, ed. Advances in chemistry series, 23–37.
*Moisoi N, Petcu I. 1995. A bone marrow peroxidation study on low-dose irradiated rats. Nutrition 11(5Suppl):585–587.8748228
*Moreira MCF. 1991. Radiological survey of Goiania by a mobile monitoring unit. Health Phys 60(1):81–85.1983989
*Morgan KZ, Turner JE. 1973. Principles of radiation protection. New York, NY: John Wiley and Sons.
*Morrissey P, Charrier K, Bressler L, . 1988. The influence of IL-1 treatment on the reconstitution of the hemopoietic and immune systems after sublethal radiation. J Immunol 140(12):4204–4210.3286769
*Mossman KL. 1992. Ionizing radiation at low doses: The question of cancer. J NIH Research 4:51–53.
*MSHA. 1997. MSHA’s Mission Statement. Mine Safety and Health Administration, Department of Labor. Internet version. http://www.msha.gov/MISSION.HTM
*Muggenburg BA, Boecker BB, Hahn FF, . 1990. Lung lavage therapy to lessen the biological effects of inhaled cerium-144 in dogs. Radiat Res 124(2):147–155.2247595
*Muggenburg BA, Guilmette RA, Griffith WC, . 1994. The toxicity of inhaled particles of ^238^PuO_2_ in dogs. Ann Occup Hyg 38:269–274.
*Muggenburg BA, Wolff RK, Mauderly JL, . 1988. Cardiopulmonary function of dogs with plutonium-induced chronic lung injury. Radiat Res 115(2):314–324.3406370
*Munson LH. 1988. Health physics manual of good practices for reducing radiation exposure to levels that are as low as reasonably achievable. U.S. Department of Energy, Pacific Northwest Laboratory. DE89 000406, PNL-7\6577, UC-610.
*Murphy CE, Jr. 1993. Tritium transport and cycling in the environment. Health Phys 65(6):683–697.8244714
*Murray RL. 1994. Understanding radioactive waste, 4th edition. Columbus, OH and Richland WA: Batelle Press.
*Myrden JA, Hiltz JE. 1969. Breast cancer following multiple fluoroscopies during artificial pneumothorax treatment of pulmonary tuberculosis. Can Med Assoc J (22):1032–1034.5784909
*Nagasawa H, Little JB, Inkret WC, . 1990b. Cytogenic effects of extremely low doses of plutonium-238 alpha-particle irridation in CHO K-1 cells. Mutation Research 244:233–238.2366817
*Nagasawa H, Robertson J, Little JB. 1990a. Induction of chromosal aberrations and sister chromatid exchanges by alpha particles in density-inhibited cultures of mouse 10T1/2 and 3T3 cells. Int J Radiat Biol 57(1):35–44.1967292
*Najarian T, Colton T. 1978. Mortality from leukemia and cancer in shipyard nuclear workers. Lancet 1:1018–1020.76937
*Nakashima E. 1994. Relationship of five anthropometric measurements at age 18 to radiation dose among atomic bomb survivors exposed in utero. Radiat Res 138(1):121–126.8146291
*Narra VR, Harapanhalli RS, Goddu SM. 1995. Radioprotection against biological effects of internal radionuclides in vivo by S-(2-aminoethyl)isothiouronium bromide hydrobromide (AET). J Nucl Med 36(2):259–266.7830127
*NAS. 1994. Specific measures needed to reduce radiation exposure to resettlers of Marshall Islands atoll. In: National Research Council News, National Academy of Sciences. July 21, 1994.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Reserach Council. Washington, DC: National Academy Press, 15–35.
*NASA. 1995. Radiation safety aspects of commercial high-speed flight transportation. National Aeronautics and Space Administration, Hampton, VA. http://heasarc.gsfc.nasa.gov/docs/asca/new_results.html#sn1006.
*Natarajan AT, Vyas RC, Wiegant J. 1991. A cytogenetic follow-up study of the victims of a radiation accident in Goiania (Brazil). Mutat Res 247(1):103–112.2002796
National Academies. 1994. http://www2.nas.edu/whatsnew/22f2.html
*NCI. 1990. Cancer in populations living near nuclear facilities. National Cancer Institute. NIH publication NO. 90-874.
NCI. 1996. NCI fact sheet: Questions and answers about radon and cancer - updated 06/96. National Cancer Institute. http://oncolink.upenn.edu/pdq_html/6/engl/600352.html.
*NCRP. 1976. Environmental radiation measurements. National Council on Radiation Protection and Measurements. Report No. 50. Washington, DC.
*NCRP. 1978. Instrumentation and monitoring methods for radiation protection. National Council on Radiation Protection and Measurements. Report No. 57. Washington, DC.
*NCRP. 1979. Tritium in the environment. National Council on Radiation Protection and Measurements. Report No.62. Bethesda, MD.
*NCRP. 1983. Environmental radioactivity. Proceedings of the Nineteenth Annual Meeting. National Council on Radiation Protection and Measurements. Proceedings No.5. Bethesda, MD.
*NCRP. 1984a. Neutron contamination from medical electron accelerators. National Council on Radiation Protection and Measurements. Report No.79. Bethesda, MD.
*NCRP. 1984b. Exposures from the uranium series with emphasis on radon and its daughters. National Council on Radiation Protection and Measurements. Report No. 77. Bethesda, MD.
*NCRP. 1984c. Radiological assessment predicting the transport, bioaccumulation, and uptake by man of radionuclides released to the environment. National Council on Radiation Protection and Measurements. Report No. 76. Bethesda, MD.
NCRP. 1984d. Evaluation of occupational and environmental exposures to radon and radon daughters in the United States. National Council for Radiation Protection and Measurements. Report No. 78. Bethesda, MD.
*NCRP. 1985. A handbook of radioactivity measurements procedures. 2nd ed. National Council on Radiation Protection and Measurements. NCRP Report No. 58. Bethesda, MD.
*NCRP. 1987a. Ionizing radiation exposure of the population of the United States. National Council on Radiation Protection and Measurements. NCRP Report No. 93. 1–69.
*NCRP. 1987b. Exposure of the population in the United States and Canada from natural background radiation. National Council on Radiation Protection and Measurements. Report No. 94. Bethesda, MD.
*NCRP. 1987c. Public radiation exposure from nuclear power generation in the United States. National Council on Radiation Protection and Measurements. Report No. 92. Bethesda, MD.
*NCRP. 1987d. Use of bioassay proceedures for assessent of internal radionuclide deposition. National Council on Radiation Protection and Measurements. Report No. 87. Washington, DC.
*NCRP. 1989a. Exposure of the U.S. population from diagnostic medical radiation. National Council on Radiation Protection and Measurements. Report No. 100. Bethesda, MD.
*NCRP. 1989b. Radiation protection for medical and allied health personnel. National Council on Radiation Protection and Measurements. Report No. 105. Bethesda, MD.
*NCRP. 1989c. Exposure of the U. S. population from occupational radiation. National Council on Radiation Protection and Measurements. Report No. 101. Bethesda, MD.
*NCRP. 1991. Calibration of survey instruments used in radiation protection for the asessment of ionizing radiation fields and radioactive surface contamination. National Council on Radiation Protection and Measurements. Report No. 112. Washington, DC.
*NCRP. 1993. Limitation of exposure to ionizing radiation. National Council on Radiation Protection and Measurements. Report No. 116. National Council on Remediation Protection and Measurement.
*NCRP. 1996. Sources and magnitude of occupational and public exposures from nuclear medicine procedures. Report No. 124. Bethesda, MD.
*NCRP. 1997. Mission and goals and background information. National Council on Radiation Protection and Measurements. Internet version, http://www.ncrp.com.
*Needleman HL, Gatsonis CA. 1990. Low-level lead exposure and the IQ of children: A meta-analysis of modern studies. JAMA 263(5):673–678.2136923
*Needleman HL, Rabinowitz M, Leviton A, . 1984. The relationship between prenatal exposure to lead and congenital anomalies. JAMA 251(22):2956–2959.6716624
*Needleman HL, Schell A, Bellinger D, . 1990. The long-term effects of exposure to low doses of lead in childhood - an 11-year follow-up report. New Engl J Med 322(2):83–88.2294437
*Neel JV. 1992. The genetic effects of human exposures to ionizing radiation. In: Young JP, Yalow RS, ed. Advances in Chemistry Series, 243. Radiation and Public Perception: Benefits and Risks; 203rd National Meeting of the American Chemical Society, San Francisco, California, USA, April 5-10, 1992. American Chemical Society: Washington, DC, USA, 115–131.
*Neel JV, Schull WJ, Awa AA. 1990. The children of parents exposed to atomic bombs: Estimates of the genetic doubling dose of radiation for humans. Am J Hum Genet 46:1053–1072.2339701
*Nelson JM, Stevens RG. 1996. Body iron stores may modify sensitivity to occupational radiation exposure. Applied Occupational and Environmental Hygiene 11(4):421–424.
*Neta RS, Steve M, Finkelman FH, . 1994. IL-12 protects bone marrow from and sensitizes intestinal tract to ionizing radiation. J Immunol 153(9):4230–4237.7930625
*NFPA. 1992. National Fire Protection Association. Fire protection handbook. 3–144.
NIE. 1995. Soviet-designed nuclear power plants. NIE Source Book. Nuclear Energy Institute. Washington, D.C. Third Edition.
*NIH. 1994. Radon and lung cancer risk: A joint analysis of 11 underground miner studies. U.S. Department of Health and Human Services, National Institutes of Health, NIH publication 94-3644, Bethesda, MD.
*NIH. 1999. Fact Sheet. What we know about radiation. U.S. Department of Health and Human Services, National Institutes of Health. http://www.nih.gov/health/chip/od/radiation
*NIST. 1991. Calibration services users guide. National Institute of Standards and Technology, Special Publication 250. Washington, DC.
*NIST. 1995. Standard reference materials catalog. National Institute of Standards and Technology, Special Publication 260. Washington, DC.
*Nogam MJT, Huang SJ, James JM, . 1993. Mice chronically exposed to low dose ionizing radiation possess splenocytes with elevated levels of HSP70 mRNA, HSC70 and HSP72 and with an increased capacity to proliferate. Int J Radiat Biol 63(6):775–783, 27.8100265
*Nogami M, Huang JT, Nakamura LT, . 1994. T cells are the cellular target of the proliferation-augmenting effect of chronic low-dose ionizing radiation in mice. Radiat Res 139(1):47–52.8016307
*Norman A, McBride WH, Bennett LR, . 1988. Postirradiation protection of chromosomes by linoleate. Int J Radiat Biol 54(4):521–524.2902149
*Norton S, Kimler BF. 1987. Correlation of behavior with brain damage after in utero exposure to toxic agents. Neurotoxicol Teratol 9(2):145–150.3657750
*Norton S, Kimler BF. 1988. Comparison of functional and morphological deficits in the rat after gestational exposure to ionizing radiation. Neurotoxicol Teratol 10(4):363–371.3226380
*Norton S, Kimler BF. 1990. Early effects of low doses of ionizing radiation on the fetal cerebral cortex in rats. Radiat Res 124(2):235–241.2247604
*Nothdurft W, Fliedner TM, Fritz TE, . 1995. Response of hemopoiesis in dogs to continuous low dose rate total body irradiation. Stem Cells 13(suppl 1):261–267.7488955
Nussbaum RH, Wolfgang K. 1996. Health consequences of exposures to ionizing radiation from external and internal sources: Challenges to radiation protection standards and biomedical research. http://www.healthnet.org/MGS/Article1.html
*O’Hare NJ, Gilligan P, Murphy D, . 1997. Estimation of foetal brain dose from I-131 in the foetal thyroid. Physics in Medicine and Biology 42(9):1717–1726.9308078
*Ohba M, Benson J. 1998. A-bomb www museum. http://www.csi.ad.jp/ABOMB/
*Oliveira AR, Brandao-Mello CE, Valverde NJL, . 1991a. Localized lesions induced by Cs-137 during the Goiania accident. Health Phys 60(1):25–29.1983976
*Oliveira AR, Hunt JG, Valverde NJL, . 1991b. Medical and related aspects of the Goiania accident: An overview. Health Phys 60(1):17–24.1983975
*Ootsuyama A, Tanooka H. 1986. Unscheduled DNA synthesis after beta-irradiation of mouse skin in situ. Mutat Res 166(2):183–185.3762564
*Ootsuyama A, Tanooka H. 1989. Induction of osteosarcomas in mouse lumbar vertebrae by repeated external β-irradiation. Cancer Research 49:1562–1564.2924307
*Orfanos SE, Chen XL, Burch SE, . 1994. Radiation-induced early pulmonary endothelial ectoenzyme dysfunction in vivo: Effect of indomethacin. Toxicol Appl Pharmacol 124(1):112–122.8291052
*OSHA. 1996a. Toxic and hazardous substances. Ionizing radiation. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1096.
*OSHA. 1996b. Safety and health regulations for construction. Ionizing radiation. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.53.
*OSHA. 1997. OSHA Regulations, Ionizing Radiation. Occupational Safety and Health Administration, Department of Labor. Code of Federal Regulations. Washington, D.C. 29 CFR 1910.1096.
*Ossenkopp KP, Giugno L. 1985. Taste aversions conditioned with multiple exposures to gamma radiation abolition by area postrema lesions in rats. Brain Res 346(1):1–7.3902148
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*OTA. 1994. Fueling reform: Energy technologies for the former East Bloc, Chapter 4: Non-fossil fuel technologies, August 9, 1994. Office of Technology Assessment. http://www.emanifesto.org/OTAEnergyEast/OTAEEEch4.htm
*Otake M, Schull W. 1984. Mental retardation in children exposed in utero to the atomic bombs: A reassessment. Technical Report RERF TR 1-83, Radiation Effects Research Foundation, Japan.
*Padovani L, Mauro F, Caporossi D, . 1993. Cytogenetic study in lymphocytes from children exposed to ionizing radiation after Chernobyl accident. GRAI9423; ERA9444.
*Panizzon RG, Hanson WR, Schwartz DE, . 1988. Ionizing radiation induces early, sustained increases in collagen biosynthesis: A 48-week study in mouse skin and skin fibroblast cultures. Radiat Res 116(1):145–156.3186926
*Paretzke HG. 1997. Late somatic health effects. Ciba Found Symp 203:167–177.9339317
*Pastorova B, Ahlersova E, Ahlers I, . 1997. The effect of a single whole-body irradiation with a lethal dose on catecholamine levels in the pineal glands of rats. Journal of Physiology and Pharmacology 48(1):73–79.9098827
*PBS. 1999. Race for the superbomb; nuclear weapons test map. Public Broadcast System. http://www.pbs.org/wgbh/pages/amex/bomb/maps.
*Peter RU, Braun-Falco O, Birioukov A, . 1994. Chronic cutaneous damage after accidental exposure to ionizing radiation: The Chernobyl experience. J Am Acad Dermatol 30(5 Pt 1):719–723.8176010
*Peterson VM, Adamovicz JJ, Elliott TB, . 1994. Gene expression of hematoregulatory cytokines is elevated endogenously after sublethal gamma irradiation and is differentially enhanced by therapeutic administration of biologic response modifiers. J Immunol 153(5):2321–2330.8051428
*Petridou E, Proukakis C, Tong D, . 1994. Trends and geographical distribution of childhood leukemia in Greece in relation to the Chernobyl accident. Scandinavian Journal of Social Medicine 22(2):127–131.8091154
*Petrova A, Gnedko T, Maistrova I, . 1997. Morbidity in a large cohort study of children born to mothers exposed to radiation from Chernobyl. Stem Cells 15(suppl. 2):141–150.
*Pierce BA, Yukyko S, Preston BL, . 1996. Studies of the mortality of atomic bomb survivors. Rep Rad Res 146:1–27.
*Pinon-Lataillade G, Viguier-Martinez MC, Touzalin AM, . 1991. Effect of an acute exposure of rat testes to gamma rays on germ cells and on Sertoli and Leydig cell functions. Reprod Nutr Dev 31(6):617–629.1777054
*Pitot III HC, Dragan YP. 1996. Chemical carcinogenesis. In: Klassen CD, ed. Casarett & Doull’s toxicology: The basic science of poisons, 5th edition. New York, NY: McGraw Hill, 201–267.
*Pohl-Ruling J, Fischer P. 1979. The dose-effect relationship of chromosome aberrations to alpha and gamma irradiation in a population subjected to an increased burden of natural radioactivity. Radiat Res 80(1):61–81.504574
*Polednak AP. 1979. Long-term effects of radium exposure in female dial workers: Liver function and liver disease. Environ Res 18(2):454–465.510260
*Polednak AP. 1980. Fertility of women after exposure to internal and external radiation. J Environ Pathol Toxicol 4(1):457–470.7441129
*Polednak AP, Farnham JE. 1980. Osteometry and autoradiography of the long bones of skeletons of women exposed to internal radiation at 13-19 years of age. Am J Phys Anthropol 52(3):335–340.7386603
*Pomerantseva MD, Ramaya LK, Shevchenko VA. 1989. Evaluation of the genetic effects of ^238^Pu incorporated into mice. Mutat Res 226(2):93–98.2733722
*Poretti G. 1989. Radiation exposure of a population through X-ray and nuclear medicine. Radiat Phys Chem 342:317–326.
*Pospisil M, Hofer M, Pipalova I, . 1992. Enhancement of hematopoietic recovery in gamma-irradiated mice by the joint use of diclofenac, an inhibitor of prostaglandin production, and glucan, a macrophage activator. Exp Hematol 20(7):891–895.1628707
*Potten CS. 1985. Radiation and skin. London: Taylor & Francis.
*Potter GD, Mcintyre Dr, Pomeroy D. 1969. Transport of fallout radionuclides in the grass-to-milk food chain studied with a germanium lithium-drifted detector. Health Phys 16:197–300.5772183
*PSU. 1999. Earth and Mineral Sciences, Penn State University. http://www.ems.psu.edu/~radovic/TMI.html
*Pukkala E, Auvinen A, Wahlberg G. 1995. Incidence of cancer among Finnish airline cabin attendants, 1967-92. British Medical Journal 311(7006):649–652.7549630
*Purrott RJ, Edwards AA, Lloyd DC, . 1980. The induction of chromosome aberrations in human lymphocytes by in vitro irradiation with a-particles from plutonium-239. Int J Radiat Biol 38(3):277–284.
*Raabe O. 1993. Cancer and injury risks from internally deposited radionuclides. In: Actualités sur le césium, Journée organisée par le comité de radioprotection d’électricité de France, Paris, March 25, 1993, 39–48.
*Raabe OG. 1994. Three dimensional models of risk from internally deposited radionuclides. In: Internal radiation dosimetery. Madison, WI: Medical Physics Publishing.
*Raabe O. 1996. Oh, wunder. The inverse dose-rate effect is quelled by the effective threshold. 1996 International Congress on Radiation Protection, 9^th^ International Congress, Vienna, Austria. 2:378–380.
*Raabe OG, Book SA, Parks NJ, . 1981. Lifetime studies of ^226^Ra and ^90^Sr toxicity in Beagles—a status report. Radiat Res 86(3):515–28.7244126
*Raabe OG, Bushberg JT. 1996. Ionizing radiation and the lungs. Occupational and Environmental Respiratory Disease 535–560.
*Radford EP, Renard KGS. 1984. Lung cancer in Swedish iron miners exposed to low doses of radon daughters. New Engl J Med 310:1485–1494.6325913
*RADNET. 1996. Information about source points of anthropogenic radioactivity. A freedom of nuclear information resource 1–15. http://home.acdia.net/cbm/Rad5.html
*RADRES. 1999. Radiation Research Society. Home page. http://www.radres.org/intro.htm
*Raicevic JJ, Merkle M, Ehrhardt J, . 1997. Loss of lifetime due to radiation exposure: Averaging problems. Health Phys 72(4):550–557.9119679
*Ralcewicz TA, Persaud TV. 1995. Effects of prenatal exposure to low dose ionizing radiation on the development of the cerebellar cortex in the rat. Histol Histopathol 10(2):371–83.7599434
*Ramaiya LK, Pomerantseva MD, Chekhovich AV, . 1994. Genetic effects of testicular incorporation of ^137^Cs in mice. Mutat Res 324(4):139–145.7519738
*Rao DV, Narra VR, Howell RW, . 1990. Biological consequence of nuclear versus cytoplasmic decays of ^125^I: Cysteamine as a radioprotector against Auger cascades in vivo. Radiat Res 124(2):188–193.2247599
*Rasey JS, Magee S, Nelson N, . 1990. Response of mouse tissues to neutron and gamma radiation protection by WR-3689 and WR-77913. Radiother Oncol 17(2):167–173.2157242
*Reitz G, Horneck G, Facius R, . 1995. Results of space experiments. Radiation and Environmental Biophysics 34(3):139–144.7480627
*Remington JP. 1985. Remington’s pharmaceutical sciences. 17^th^ edition. Easton, PA: Mack Publishers.
*Remington JP, Gennaro AR. 1995. Remington, the science and practice of pharmacy. 19^th^ edition. Easton, PA: Mack Publishers.
*RERF. 1998. Radiation Effects Research Foundation. Home page. http://www.rerf.or.jp/
*Revsin BK, Watson JE Jr. 1993. Long-term environmental trends. Selection of sampling locations in a reactor-aquatic cooling system. Health Phys 64:178–182.8449712
*Reyners H, Gianfelici E, De Reyners, . 1992. Brain atrophy after foetal exposure to very low doses of ionizing radiation. Int J Radiat Biol 62(5):619–626.1361519
*Rezvani M, Heryet JC, Hopewell JW. 1989. Effects of single doses of gamma-radiation on pig lung. Radiother Oncol 14(2):133–142.2652198
*Ribas G, Carbonell E, Xamena N, . 1994. Genotoxicity of tritiated water in human lymphocytes. Toxicology Letters 70:63–69.8310458
*Richardson RB, Eatough JP, Henshaw DL. 1991. Dose to red bone marrow from natural radon and thoron exposure. Br J Radiol 64(763):608–624.1651797
*Ricoul M, Dutrillaux B. 1991. Variations of chromosome radiation sensitivity in fetal and adult mice during gestation. Mutat Res 250(1–2):331–335.1944349
*Rinsky RA, Waxweiler RJ, Murray WE Jr., . 1981. Cancer mortality at a naval nuclear shipyard. Lancet 231–235.
*Roberts DHJ, White GRM, Ockey CH. 1987. Sister chromatid induction by β-irradiation from incorporated ^3^H-thymidine: A paradox explained. Chromosoma 96:72–76.3436226
*Roesch WC, ed. 1987. U.S.-Japan joint reassessment of atomic bomb radiation dosimetery in Hiroshima and Nagasaki. Radiation Effects Research Foundation, Minami-ku, Japan 732:1–36.
*Ron E, Modan B. 1984. Thyroid and other neoplasms following childhood scalp irradiations. In: Boice JD, Fraumeni JF, eds. Radiation carcinogenesis: Epidemiology and biological significance, New York, NY: Raven Press, 139–151.
*Roux C, Elefant E, Gaboriaud G. 1986. Association of microwaves and ionizing radiation: Potentiation of teratogenic effects in the rat. Radiat Res 108(3):317–326.3797637
*Rosenthal JJ, de Almeida CE, Mendonca AH. 1991. The radiological accident in Goiania: The initial remedial action. Health Phys 60(1):7–15.
*Rowland RE, Stehney AF, Lucas HF. 1978. Dose-response relationships for female radium dial workers. Radiat Res 76:368–383.287126
*Rozhdestvensky LM, Fomicheva EI. 1995. The estimation of haematopoietic stem cell reaction to low level ionising radiation. Radiation Protection Dosimetry 62(1–2):49–51.
*Rozhdestvensky LM, Fomicheva EI. 1995. The estimation of hematopoietic stem cell reaction to low level ionizing radiation. Radiation Protection Dosimetry 62(1–2):49–51.
S. Cohen & Associates, Inc. 1994. Routine environmental sampling procedures manual for radionuclides. May 17, 1994.
*Saad AY, Abdelazim AA, el-Khashab MM, . 1991. Effects of gamma radiation on incisor development of the prenatal albino mouse. J Oral Pathol Med 20(8):385–388.1941655
*Saad AY, Abdelazim AA, el-Khashab MM, . 1994. Induction of cleft palate by gamma-irradiation of prenatal CD-1 mice. Cleft Palate Craniofac J 31(5):351–355.7986795
*Sabatier L, Martin M, Crechet F, . 1992. Chromosomal anomalies in radiation-induced fibrosis in the pig. Mutat Res 284:2257–2263.
*Saccomanno G, Archer VE, Auerbach MD, . 1971. Histologic types of lung cancer among uranium miners. Cancer 27:515–523.5549493
*Saccomanno G, Archer VE, Saunders RP, . 1976. Early indices of cancer risk among uranium miners with reference to modifying factors. Ann NY Acad Sciences 271:377–383.
*Saccomanno G, Yale C, Dixon W, . 1986. An epidemiological analysis of the relationship between exposure to radon progeny, smoking and bronchogenic carcinoma in the uranium-mining population of the Colorado Plateau (USA): 1960-1980. Health Phys 50:605–618.3700112
*Saku T, Hayashi Y, Takahara O, . 1997. Salivary gland tumors among atomic bomb survivors, 1950-1987. Cancer 79(8):1465–1475.9118025
*Salovsky PT, Shopova VI. 1992. Early biological effects of whole body irradiation on rat lungs. Radiat Environ Biophys 31(4):333–341.1332105
*Sanders CL, Kathren, RL. 1983. Ionizing radiation. Tumorigenic and tumoricidal effects. Columbus, OH: Battelle Press.
*Sanders CL, Kathren RL. 1997. Ionizing radiation tumorigenic and tumoricidal effects. New York, NY: Battelle Press, Springer-Verlag.
*Sandia Lab News. 1995. Palomares “bomb number four” - it crashed, it fell, it sank, but (whew!) it never blew up. http://www.sandia.gov/LabNews/LN01-19-96/palo.html
*Sasaki MS, Takatsuji T, Ejima Y, . 1987. Chromosome aberration frequency and radiation dose to lymphocytes by alpha-particles from internal deposit of Thorotrast. Radiat Environ Biophys 26(3):227–238.3659273
*Scheid W, Weber J, Petrenko S, . 1993a. Chromosome aberrations in human lymphocytes apparently induced by Chernobyl fallout. 64(5):531–534.
*Scheid W, Weber J, Traut H. 1993b. Chromosome abberations induced in the lymphycytes of pilots and stewardesses. Naturwissenschaften 80:528–530.8264808
*Schimmerling, W. 1995. Space and radiation protection: Scientific requirements for space research. Radiation and Environmental Biophysics 34(3):133–137.7480626
*Schultz MK. 1996. Irish Sea sediment IAEA-135, the Irish Sea, and the Sellafield reprocessing discharges. http://ocean.fsu.edu/oce/mschultz/Irish.html
*Schultz SC, Schultz V. 1994. Bikini and Enewetak Marshallese: Their atolls and nuclear weapons testing. Critical Reviews in Environmental Science and Technology 24(1):33–118.
*Schweitzer DJ, Benjamin SA, Lee AC. 1987. Retinal dysplasia and progressive atrophy in dogs irradiated during ocular development. Radiat Res 111(2):340–353.3628721
*Scott BR. 1990. A model for early death caused by radiation pneumonitis and pulmonary fibrosis after inhaling insoluble radioactive particles. Bull Math Biol 42(3):447–459.
*Scott BR, Dillehay LE. 1990. A model for hematopoeitic death in man from irradiation of bone marrow during radioimmunotherapy. Br J Radiol 63:862–870.2123723
*Scott BR, Hahn FF. 1980. A model that leads to the Weibull distribution function to characterize early radiation response probabilities. Health Phys. 39:521–530.7440163
*Searle AG, Beechey CV, Green D, . 1976. Cytogenetic effects of protracted exposures to alpha-particles from plutonium-239 and to gamma-rays from cobalt-60 compared in male mice. Mutat Res 41(2–3):297–310.1012301
*Searle AG, Beechey CV, Green D, . 1980. Comparative effects of protracted exposures to ^60^Co gamma-radiation and ^239^Pu alpha-radiation on breeding performance in female mice. Int J Radiat Biol Relat Stud Phys Chem Med 37(2):189–200.6966265
*Seed T, Carnes B, Tolle D, . 1993. Blood responses under chronic low daily dose gamma irradiation: II. Differential preclinical responses of irradiated female dogs in progression to either aplastic anemia or myeloproliferative disease. Leuk Res 17(5):411–420.8501968
*Seed TM, Carnes BA, Tolle DV, . 1989. Blood responses under chronic low daily dose gamma irradiation: I. Differential preclinical responses of irradiated male dogs in progression to either aplastic anemia or myeloproliferative disease. Leuk Res 13(12):1069–1084.2615465
*Selig C. 1995. The use of biological indicators to assess consequences of radiation exposure at the cell system level. Stem Cells 13(suppl. 1):323–325.7488964
*Sellins KS, Cohen JJ. 1987. Gene induction by gamma-irradiation leads to DNA fragmentation in lymphocytes. J Immunol 139(10):3199–3206.3680944
*Serio CS, Henning CB, Toohey RE, . 1983. Measurement of lymphoblastogenic activity from thorium workers. Int J Radiat Biol Relat Stud Phys Chem Med 44(3):251–256.6604709
*Sevan’kaev AV, Tsyb AF, Lloyd DC, . 1993. Rogue cells observed in children exposed to radiation from the Chernobyl accident. Int J Radiat Biol Mar 63(3):361–367.
*Sever LE, Gilbert ES, Hessol NA, . 1988. A case-control study of congentital malformations and occupational exposure to low-level ionizing radiation. Am J Epidemiol 127(2):226–242.3276166
*Shaheen AA, Hassan SH. 1994. Role of vitamin A in modulating the radiation-induced changes in intestinal disaccharidases of rats exposed to multifractionated gamma-radiations. Strahlenther Onkol 170(8):467–470.8085213
*Shapiro J. 1990a. Practical aspects of the use of radionuclides. In: Shapiro J, ed. Protection: A guide for scientists and physicians, 3rd edition. Cambridge MA: Harvard University Press, 264–333.
*Shapiro J. 1990b. Ionizing radiation and public health. In: Shapiro J, ed. Protection: A guide for scientists and physicians, 3rd edition. Cambridge MA: Harvard University Press, 334–429.
*Shapiro J. 1990c. Radiation protection, 3rd edition. Cambridge MA: Harvard University Press.
*Shcherbak YM. 1996. Ten years of the Chernobyl era. Sci Am 274(4):44–49.8907650
*Shearer SD, Jr., Sill CW. 1969. Evaluation of atmospheric radon in vicinity of uranium mill tailings. Health Phys 17:77–88.5798581
*Shevchenko VA, Pomerantseva MD, Ramaiya LK, . 1992. Genetic disorders in mice exposed to radiation in the vicinity of the Chernobyl nuclear power station. Sci Total Environ 112(1):45–56.1574704
*Shevchenko VA, Ramaya LK, Pomerantseva MD, . 1989. Genetic effects of ^131^I in reproductive cells of male mice. Mutat Res 226(2):87–91.2733721
*Shimizu Y, Kato H, Schull WJ. 1988. Life span study report 11 part 2. Cancer mortality in the years 1950-1985 based on the recently revised doses (DS86). Radiation Effects Research Foundation, Minami-ku, Japan 732:1–102.
*Shlein B. 1992. The health physics and radiological health handbook. Silver Spring, MD: Scinta, 264–265.
*Shyr LJ, Griffith WC, Boecker BB. 1991. An optimization strategy for a biokinetic model of inhaled radionuclides. Fundam Appl Toxicol 16:423–434.1855616
*Sigdestad CP, Grdina DJ, Connor AM, . 1986. A comparison of radioprotection from three neutron sources and ^60^Co by WR-2721 and WR-151327. Radiat Res 106(2):224–233.3010368
*Simon SL, Vetter, RJ (eds). 1997. Consequences of nuclear testing in the Marshall Islands. Health Phys 73(1).
*Smith JN, Ellis KM, Aarkrog A, . 1994. Sediment mixing and burial of the ^239, 240^Pu pulse from the 1968 Thule, Greenland, nuclear weapons accident. J Environ Radioactivity 25:135–1593.
*Smith PG. 1984. Radiation carcinogen: Epidemiology and biological signficance, In: Late effects of X-ray treatment of ankylosing spondylitis. Vol 1, 1AEA, Vienna, 107–118.
*Smith WN, Doll R. 1978. Age and time dependent changes in the rates of radiation-induced cancers in patients with ankylosing spondylitis following a single course of X-ray treatment. In: Late effects of ionizing radiation. Vol 1, 1AEA, Vienna, 205.
*Snipes MB, Spoo JW, Muggenburg BA, . 1996. Evaluation of the clearance of particles deposited on the conducting airways of Beagle dogs. J Aerosol Med 9(4):477–499.
*Song CW, Drescher JJ, Tabachnick J. 1968. Effect of anti-inflammatory compounds on beta-irradiation-induced increase in vascular peremeability. Radiat Res 34(3):616–625.5654012
*Sorahan T, Roberts PJ. 1993. Childhood cancer and paternal exposure to ionizing radiation: preliminary findings from the Oxford Survey of Childhood Cancers. Am J Ind Med 23 (2):343–354.8427262
*Spiess H, Mays CW. 1970. Bone cancers induced by ^224^Ra (Th X) in children and adults. Health Phys 19:713–729.4935546
*Spiess H, Mays CW. 1973. Protraction effect on bone-sarcoma induction of ^224^Ra in children and adults. In: Sanders CL, Busch RH, Ballow Je, Mahlum DD, eds. Radionuclides carciongensis. Springfield, VA: National Technical Information Service 437–450.
*Stahlhofen W, Gebhart J, Heyder J. 1980. Experimental determination of the regional deposition of aerosol particles in the human respiratory tract. J Amer Ind Hyg Assoc 41(6)385–398a.
*Stahlhofen W, Gebhart J, Heyder K, . 1981. Intercomparison of regional deposition of aerosol particles in the human respiratory tract and their long-term elimination. Experimental Lung Research 2:131–139.7274177
*Stavem P, Brogger A, Devik F, . 1985. Lethal acute gamma radiation accident at Kjeller, Norway. Report of a case. Acta Radiol Oncol 24(1):61–63.2984904
*Steinstrasser A. 1981. Biophysical investigations of the dose-effect relationship in chromosome aberrations of human lymphocytes caused by thorotrast deposits. I. Physical aspects. Radiat Environ Biophys 19(1):1–15.7220794
*Sternberg RJ, Kaufman JC. 1998. Human abilities. Annu Rev Psychol 49:479–502. http://biomedical.AnnualReviews.org/cgi/content/full/17/49/479.9496630
*Sternglass EJ, Gould JM. 1993. Breast cancer: Evidence for a relation to fission products in the diet. Int J Health Services 23(4):783–804.
*Stewart AM, Kneale GW. 1991. An overview of the Hanford controversy. Occup Med 6(4):641–63.1962251
*Stitt AW, Anderson HR, Gardiner TA, . 1994. The combined effects of diabetes and ionising radiation on the rat retina: An ultrastructural study. Curr Eye Res 13(1):79–86.8156828
*Stokinger HE. 1981. Uranium U. In: Clayton GD, Clayton FE, eds. Industrial hygiene and toxicology. Vol 2A, 3rd ed. New York, NY: John Wiley & Sons, 1995–2013.
*Stone WH, Saphire DG, Hackleman SM, . 1994. Effect of radiation and age on immunoglobulin levels in Rhesus monkeys (Macaca mulatta). Radiat Res 138(3):401–408.8184015
*Stram DO, Sposto R, Preston D, . 1993. Stable chromosome aberrations among A-bomb survivors: An update. Radiat Res 136(1):29–36.8210335
*Sublette C. 1995. Section 5.0 Effects of nuclear exposions. Nuclear weapons frequently asked questions, version 2.13. http://www.pal.xgw.fi/hew/NFAQ5.HTML.
*Sublette C. 1996. Section 8.0 The first nuclear weapons. Nuclear weapons frequently asked questions, version 2.15. http://www.pal.xgw.fi/hew/NFAQ8.HTML.
*Suzuki K, Takahashi M, Ishii-Ohba H, . 1990. Steroidogenesis in the testes and the adrenals of adult male rats after gamma-irradiation in utero at late pregnancy. J Steroid Biochem 35(2):301–305.2308342
*Swanson SM. 1985. Food chain transfer of U-series radionuclides in northern Saskatchewan aquatic system. Health Phys 49:747–770.4066338
*Sweet CW, Murphy CE Jr, Lorenz R. 1983. Environmental tritium transport from an atmospheric release of tritiated water. Health Phys 44(1):13–18.6826361
*Symons MCR. 1994. Direct and indirect damage to DNA by ionising radiation. Radiat Phys Chem 43(4):403–405.
*Takatsuji T, Saski MS. 1984. Dose-effect relationship of chromosome aberrations induced by 23 MeV alpha particles in human lymphocytes. Int J Radiat Biol 45(3):237–243.
*Takatsuji T, Saski MS, Takekoshi H. 1989. Effect of static magnetic field on the induction of chromosome aberrations by 4.9 MeV protons and 23 MeV alpha particles. J Radiat Res 30:238–246.2553938
*Tanaka K, Sawada S, Kamada N. 1994. Relative biological effectiveness and dose rate effect of tritiated water on chromosomes in human lymphocytes and bone marrow cells. Mut Res 323:53–61.7508567
*Thacker J. 1986. The nature of mutants induced by ionising radiation in cultured hamster cells: III. Molecular characterization of HPRT-deficient mutants induced by γ-ray or α-particles showing that the majority have deletions of all or part of the HPRT gene. Mutat Res 160:267–275.3007979
*Thun MJ, Baker DB, Steenland K, . 1985. Renal toxicity in uranium mill workers. Scand J Work Environ Health 11:83–90.
*Tobari I, Matsuda Y, Gu XH, . 1988. Dose-response relationship for translocation induction in spermatogonia of the crab-eating monkey (Macaca fascicularis) by chronic gamma-ray-irradiation. Mutat Res 201(1):81–87.3419451
*Tomonaga M, Matsuo T, Carter RL, . 1993. Differential effects of atomic bomb irradiation in inducing major leukemia types: Analyses of open-city cases including the life span study cohort based upon updated diagnositic systems and the dosimetry system 1986. (DS86). Radiation Effects Research Foundation, Minami-ku, Japan. 732:1–102.
*Trakhtenberg I, Ivanitskaya N, Talakin Y, . 1996. Follow-up consequences of ionizing irradiation low dose effects on the body immune system. Fresenius Environmental Bulletin 5(3/4):121–125.
*U of Michigan. 1999. Introduction to radiation. http://www.umich.edu/~radinfo/introduction
*U.S. Congress. 1990. Clean Air Act. Title III. Section 112. Hazardous air pollutants. One Hundred and First Congress of the United States. Public Law 101-549. 42 USC 7412. November 15, 1990.
*U.S. Congress. 1998. Mammography quality standards reauthorization act of 1998. House Reports: No. 105-713 Congressional Record Vol. 144.
*U.S. House of Representatives. 1999. Office of the Law Revision. Home page. http://uscode.house.gov/
*Umegaki K, Ichikawa T. 1994. Decrease in vitamin E levels in the bone marrow of mice receiving whole-body X-ray irradiation. Free Radical Biology and Medicine 17(5):439–444.7835750
*Umegaki K, Takeuchi N, Ikegami S, . 1994. Effect of beta-carotene on spontaneous and X-ray-induced chromosomal damage in bone marrow cells of mice. Nutr Cancer 22(3):277–284.7877897
*UNSCEAR. 1977. United Nations Scientific Committee on the Effects of Atomic Radiation. Sources and effects of ionizing radiation. New York, NY.
*UNSCEAR. 1982. United Nations Scientific Committee on the Effects of Atomic Radiation. Sources and effects of ionizing radiation. New York, NY.
*UNSCEAR. 1986. United Nations Scientific Committee on the Effects of Atomic Radiation. Sources and effects of ionizing radiation. New York, NY.
*UNSCEAR. 1988a. United Nations Scientific Committee on the Effects of Atomic Radiation. Sources and effects of ionizing radiation. New York, NY.
*UNSCEAR. 1988b. United Nations Scientific Committee on the Effects of Atomic Radiation. Sources and effects of ionizing radiation. New York, NY.
*UNSCEAR. 1993. United Nations Scientific Committee on the Effects of Atomic Radiation. Sources and effects of ionizing radiation. New York, NY.
*UPI. 1999. Japanese nuclear accident. Global Impact Net at http://www.upi.com. October 1, 1999.
*Upton AC. 1991. Risk estimates for carcinogenic effects of radiation. Annals of the ICRP 22(1):1–118.
*Uranium Information Center. 1995. Fifty years of nuclear threat and promise: Hiroshima and Nagasaki 1945, and subsequent weapons testing. Nuclear issues briefing paper No. 29. http://www.uic.com.au/nip29.html
*Urquhart JD, Black RJ, Muirhead MJ, . 1991. Case-control study of leukaemia and non-Hodgkin’s lymphoma in children in Caithness near the Dounreay nuclear installation. BMJ 302:692–696.1850635
*USDA. 1997. Animal and plant health inspection service, department of agriculture. Hawaiian fruits and vegetables. U.S. Department of Agriculture. Code of Federal Regulations. 7 CFR 318.
*USDOC. 1995. National Trade Data Bank. U.S. Department of Commerce. July 10, 1995.
*USERD. 1975. Preliminary external-dose estimates for future Bikini Atoll inhabitants. U.S. Energy Research and Development. Preliminary report No. UCRL-51879.
*USNRC. 1974. Regulatory guide 1.86. Termination of operating licenses for nuclear reactors. U.S. Nuclear Regulatory Commission. Washington, DC.
*USNRC. 1975. Regulatory guide 4.1. Programs for monitoring radioactivity in the environs of nuclear power plants. U.S. Nuclear Regulatory Commission. Washington, DC.
*USNRC. 1977a. Regulatory guide 1.109. Calculation of annual doses to man from routine releases of reactor effluents for the purpose of evaluating compliance with 10CFR part 50, appendix I Rev I, U.S. Nuclear Regulatory Commission. Washington DC.
*USNRC. 1977b. Regulatory guide 1.111. Methods for estimating atmospheric transport and dispersion of gaseous effluents in routine releases from light-water-colled reactors, Rev I. U.S. Nuclear Regulatory Commission. Washington DC.
*USNRC. 1977c. Regulatory guide 1.113. Estimating aquatic dispersion of effluents from accidental and routine reactor releases for the purposes of Implementing Appendix I Rev I, Washington DC.
*USNRC. 1979. Regulatory guide 4.15. Quality assurance for radiological monitoring programs: Effluent streams and environment. U.S. Nuclear Regulatory Commission. Washington, DC.
*USNRC. 1991. Occupational dose limits. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, Subpart C.
*USNRC. 1992. Nuclear regulatory commission digest. U.S. Nuclear Regulatory Commission. Washington, DC. NUREG-1350-V4.
*USNRC. 1993. Standards for protection against radiation. Annual limits on intake (ALIs) and derived air concentrations (DACs) of radionuclides for occupational exposure; effluent concentrations; concentrations for release to sewerage. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, Appendix B.
*USNRC. 1994. Standards for protection against radiation. Code of Federal Regulations. 10 CFR 20. U.S. Nuclear Regulatory Commission. Washington, DC.
*USNRC. 1995. Standards for protection against radiation. Quantities of licensed material requiring labeling. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, Appendix C.
*USNRC. 1996. Radiation dose limits for individual members of the public. U.S. Nuclear Regulatory Commission. Washington, D.C. Code of Federal Regulations. 10 CFR 20.1301, Subpart D.
*USNRC. 1997a. Standards for protection against radiation. U.S. Nuclear Regulatory Commission, Washington, D.C. Code of Federal Regulations. 10 CFR 20, Subpart A.
*USNRC. 1997b. Radiation dose limits for individual members of the public. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, Subpart D.
*USNRC. 1998. Physical protection for spent nuclear fuel and high-level radioactive waste; final rule. U.S. Nuclear Regulatory Commission. Federal Register. 63 FR 26955. May 15, 1998.
*USNRC. 1999. U.S. Nuclear Regulatory Commission. Home page. http://www.nrc.gov/
*van Wyngaarden KE, Pauwels EK. 1995. Hormesis: are low doses of ionizing radiation harmful or beneficial? Eur J Nucl Med 22(5):481–6.7641758
*Vicker MG, Bultmann H, Glade U, . 1991. Ionizing radiation at low doses induces inflammatory reactions in human blood. Radiat Res 128 (3):251–257.1961921
*Vigneulle RM, Herrera J, Gage T, . 1990. Nonuniform irradiation of the canine intestine. I. Effects. Radiat Res 121(1):46–53.2300668
*Vijayalaxmi, Reiter RJ, Meltz ML. 1995. Melatonin protects human blood lymphocytes from radiation-induced chromosome damage. Mutat Res 346(1):23–31.7530326
*Vulpis N. 1984. The induction of chromosome aberrations in human lymphocytes by in vitro irradiaton and B particles from tritiated water. Radiat Res 97:511–518.6729027
Vulpis N, Scarpa G. 1986. Induction of chromosome aberrations by ^90^Sr β particles in cultured human lymphocytes. Mutat Res 163(3):277–283.3785263
*Vyas DR, Dick RM, Crawford J. 1994. Management of radiation accidents and exposures. Pediatr Emerg Care 10(4):232–237.7937304
*Wang B, Takeda H, Gao W-M, Zhou X-Y . 1999. Induction of apoptosis by beta radiation from tritium compounds in mouse embryonic brain cells. Health Phys 77(I):16–23.10376537
*Wasserman H, . 1982. Killing our own: The disaster of America’s experience with atomic radiation. New York, NY: Delacorte Press.
*Wasserman J. 1986. Immunological indicators. In: Biological indicators for radiation dose assessment. Munchen: MMV Medizin Verlag. 85–105.
*Watanabe M, Suzuki M, Suzuki K, . 1990. Radioprotective effects of dimethyl sulfoxide in golden hamster embryo cells exposed to gamma rays at 77 K. II. Protection from lethal, chromosomal, and DNA damage. Radiat Res 124(1):73–78.2236498
*Wei L. 1992. Health effects on populations exposed to low-level radiation in China. In: Young JP, Yalow RS, eds. Advances in Chemistry Series, 243. Radiation and Public Perception: Benefits and Risks; 203rd National Meeting of the American Chemical Society, San Francisco, California, USA, April 5-10, 1992. American Chemical Society: Washington, DC USA, 219–238.
*Welleweerd J, Wilder Me, Carpenter SG, . 1984. Flow cytometroc determination of radiation-induced chromosome damage and its correlation with cell survival. Radiat Res 99:44–51.6739726
*Whittemore AS, McMillan A. 1983. Lung cancer mortality among U.S. uranium miners: A reappraisal. JNCI 71(3):489–499.6577225
*WHO 1995. Health consequences of the Chernobyl accident: Results of the IPHECA pilot projects and related national programmes-summary report. http://pllwww.who.ch/programmes/pll/dsa/newpub/env.htm#hea
*Whyte RK. 1992. First day neonatal mortality since 1935: Re-examination of the cross hypothesis. BMJ 304:343–346.1540730
*Wick RR, Chmelevsky D, Gossner W. 1986. 244Ra: Risk to bone and haematopoietic tissue in ankylosing spondylitis patients. In: Gossner and Gerber, eds. The radiobiology of radium and Thorotrast, 38–44.
*Wiley LM. 1994. Male mice receiving very low doses of ionizing radiation transmit an embryonic cell proliferation disadvantage to their progeny embryos. In: Olshan AF, Mattison DR, eds. Male-mediated developmental toxicity. New York, NY: Plenum Press, 81–91.
*Wiley LM, Baulch JE, Raabe OG, . 1997. Impaired cell proliferation in mice that persists across at least two generations after paternal irradiation. Radiat Res 148(2):145–151.9254733
*Wilkins RJ. 1971. Alpha-ray induced breakes in the DNA of Escherichia coli. Int J Radiat Biol 20(5):497–500.
*Wilkinson GS, Dreyer NA. 1991. Leukemia among nuclear workers with protracted exposure to low-dose ionizing radiation. Epidemiology 2(4):305–309.1832969
*Wing S, West CM, Wood JL, . 1994. Recording of external radiation exposures at Oak Ridge National Laboratory: Implications for epidemiological studies. Journal of Exposure Analysis and Environmental Epidemiology 4(1):83–93.7894270
*Wojcik A, Tuschl H. 1990. Indications of an adaptive response in C57BL mice pre-exposed in vivo to low doses of ionizing radiation. Mutat Res 243(1):67–73.2105467
*Wolff S, Jostes R, Cross FT, . 1991. Adaptive response of human lymphocytes for the repair of radon-induced chromosomal damage. Mutat Res 250:299–306.1944344
*Woodard HQ. 1980. Radiation carcinogenesis in man: A critical review. Environmental measurments laboratory report EML-380. U.S. Department of Energy, New York.
*Worgul BV, Medvedovsky C, Wu B. 1995. Use of non-subjective analysis of lens transparency in experimental radiation cataract research. Ophthalmic Research 27(suppl. 1):110–115.
*Wu L-J, Randers-Pehrson G, Xu A, . 1999. Targeted cytoplasmic irradiation with alpha particles induces mutations in mammalian cells. Proc Natl Acad Sci 96:4959–4964.10220401
*Xiao S, Jacobson-Kram D, Piantadosi S, . 1989. Increased chromosomal radiosensitivity in patients undergoing radioimmunoglobulin therapy. Mutat Res 227:39–45.2549411
*Yang IC, Edwards KW. 1984. Releases of radium and uranium into Ralston Creek and Reservoir, Colorado, USA, from uranium mining. In: Barney GS, Navratil JD, Schulz W, eds. 185th meeting: American Chemical Society Symposium Series 246. Geochemical behavior of disposed radioactive waste, Seattle WA. March 20-25, 1983. Washington, DC: American Chemical Society, 271–286.
*Yarilin AA, Sharova NI, Kuzmenok OI, . 1995. The role of the thymus in the appearance of immunologic effects of low dose irradiation. Radiat Protect Dosimetry 62(1–2):77–79.
*Yashimoto Y, Schull WJ, Kato H, . 1991. Mortality among the offspring (F1) of the atomic bomb survivors, 1946-1985 (REFR TR 1-91). Radiation Effects Research Foundation, Hiroshima, Japan.
*Zaman MS, Hipp EW, Lancaster FE. 1992. Brain myelination in rats treated with ionizing radiation in utero. J Environ Sci Health 27(5):621–639.
*Zaman MS, Hupp EW, Lancaster FE. 1993. Locomotion and physical development in rats treated with ionizing radiation in utero. J Environ Sci Health B 28(1):105–125.8426060
*Zhou XY, Dong JC, Geng XS, . 1986. Tritium beta-ray and cobalt-60 gamma-ray caused dominant lethal mutation in mice. Chin Med J 99(5):420–423.3100176
*Zucali JR, Moreb J, Gibbons W, . 1994. Radioprotection of hematopoietic stem cells by interleukin-1. Exp Hematol 22(2):130–135.8299734