# 7 REGULATIONS

Because of the potential for ionizing radiation to cause deterministic (acute radiation syndrome, cataracts) and nondeterministic (cancer) health effects in exposed individuals, safe dose guidelines and regulations have been established for both external radiation exposure and radionuclides in air and water by a number of international and national agencies. International and national regulations and guidelines pertinent to human exposure to ionizing radiation are summarized in Table 7-1. Those that protect against deterministic effects are based on identified acute thresholds doses for those effects, with a reduction to protect sensitive populations and provide safety margins that account for uncertainties. Those that protect against nondeterministic effects use the observed frequencies with which those effects occur at high doses, account for uncertainties that may exist, and assume a linear dose-effect relationship to calculate the doses at which the effects would be presumed to occur at some acceptable frequency, such as the range of 10^-4^ to 10^-6^ which EPA often considers. This proportionality assumes a linear no threshold (LNT) dose effect curve. During the last decade, there have been reductions in LNT-based public radiation dose limits and site cleanup levels that have increased the scope and cost of medical, occupational, and environmental radiation protection efforts. Some recent studies found a reduction in health effects when the dose was delivered at lower dose rates, indicating a potential application to future protection guidelines and regulations.

An MRL of 0.004 mSv (0.4 rem) has been derived for acute-duration external exposure (14 days or less), based on the developmental studies of Schull et al. (1988) and the IQ studies of Burt (1966).

An MRL of 0.001 Sv/yr (0.1 rem/yr) above background has been derived for chronic-duration external exposure (365 days or more) to radiation based on information that identified radiation doses that have not been reported to have detrimental effects on humans (BEIR V 1990).

The health effects of radiation have been recognized since early in the twentieth century, and by 1928 the International X-Ray and Radium Protection Committee (now the International Commission on Radiological Protection [ICRP]) was established. In the United States, a year later, the Advisory Committee on X Ray and Radiation Protection, now called the National Council on Radiation Protection and Measurements (NCRP), was formed. The NCRP was chartered in 1964 by the U.S. Congress to: (1) disseminate information of public interest and recommend radiation levels to protect the public, (2) support cooperation among organizations concerned with radiation protection, (3) develop basic concepts about radiation protection, and (4) cooperate with the ICRP and the International Commission on Radiation Units and Measurements. Even though the NCRP is a nongovernmental organization, it provides recommendations that guide the establishment of federal radiation policies, agency requirements, and statutory laws. Through the governmental agencies that rely on NCRP recommendations, the work of this organization has a significant impact on the many activities in the United States involving the use of radiation and radioactive materials.

In the United States, the Environmental Protection Agency (EPA) sets radiation safety policy and basic safety standard. The execution of this policy is assigned to the various regulatory agencies, including the EPA itself, for application to the specific activities that they regulate. The U.S. Nuclear Regulatory Commission (USNRC), an independent government agency, regulates commercial nuclear power reactors; research/test/training reactors; fuel cycle facilities; and the transport, storage and disposal of nuclear materials and waste (USNRC 1997b). The EPA is responsible for protecting the public and the environment and for clean up of radioactively contaminated sites (EPA 1997). The Mine Safety and Health Administration (Department of Labor) is responsible for protecting miners from exposure to radon and its daughters and gamma rays in underground or surface mines (MSHA 1997). The Food and Drug Administration (FDA) develops standards for equipment that emits ionizing radiation, such as radiographic and fluoroscopic equipment (FDA 1997), radioactive material concentrations in food (FDA 1998), and medical devices used in radiation therapy (FDA 1997).

A mammogram device, for example, uses low-dose x rays to produce a radiographic image of breast tissue. Unfortunately, mammograms are among the most difficult radiographic images to read. To reduce the chance of false negative and false positive diagnoses, the image must be of high quality (FDA 1997). Senate hearings on breast cancer held in 1992 found a wide range of problems with mammography practices in the United States. In response to these issues and to the growing incidence of breast cancer and its associated mortality rate, the U.S. Congress enacted the Mammography Quality Standards Act (MQSA). The enactment of the MQSA in 1992 was a statutory means of certifying and inspecting mammography facilities. Regulations established by the FDA to implement the MQSA ensured that only facilities accredited by an approved accreditation body and certified by the Secretary of Health and Human Services would lawfully continue to operate after October 1, 1994. In order to meet the October deadline, however, the MQSA needed to be amended and the process for issuing standards for facilities and the standards to be met by the accrediting bodies needed to be shortened. The amendments gave the FDA the authority to issue interim regulations, which were published on December 21, 1993 (FDA 1997, 1999a, 1999b). Final regulations for the MQSA, published on October 28, 1997, mandated that facilities would incorporate new requirements into their programs by April 28, 1999, the effective date for most of the regulations. Regulations concerning equipment will become effective on October 28, 2002 (FDA 1999b). Except for the Department of Veterans Affairs, all mammography facilities that produce, process, or interpret mammograms must meet the requirements of the MQSA. In order to keep the basic safeguards in place beyond the year 2000, the Mammography Quality Standards Reauthorization Act of 1998 was passed by Congress on October 9, 1998 (U.S. Congress 1998). The FDA recently announced the availability of its guidance document, Compliance Guidance: The Mammography Standards Act Final Regulations Document #1, which is intended to assist mammography facilities in meeting the MQSA final regulations (FDA 1999a).

The FDA recently updated its guidance document that presents recommended action levels for radionuclides in foods, both domestic and imported (FDA 1998). These derived intervention levels (DILs) are estimated levels in food that could lead to individuals receiving a radiation equivalent dose equal to the FDA protection action guide (PAG) that is set as the more limiting of either 0.5 rem (5 mSv) for committed effective dose or 5 rem (50 mSv) committed dose equivalent to any individual tissue or organ. Table 7-4 presents the most restrictive food DILs.

Transport of radioactive materials is regulated by the Department of Transportation (DOT) in conjunction with the USNRC. Coordinating government emergency response to accidents involving radioactive materials is the responsibility of the Federal Emergency Management Administration (FEMA).

National regulations governing the occupational exposure to ionizing radiation include USNRC regulations (10CFR20), EPA standards for uranium and thorium mills (40 CFR 192), Occupational Safety and Health Administration (OSHA) standards for ionizing radiation (29 CFR 1910.1096), the Department of Energy (DOE) standards for occupational radiation protection (10 CFR 835), and MSHA’s radon and gamma ray standards (60 FR 33719). National regulations concerning general population exposure to radiation have been developed by the EPA and USNRC based on the dose limit recommendations of the ICRP (ICRP 1997) and the NCRP (NCRP 1993).

Currently there are 29 “NRC Agreement States.” An agreement state is any state that has entered into an agreement with the USNRC under Section 274 of the Atomic Energy Act of 1954, as amended. The USNRC relinquishes to these states the majority of its regulatory authority over source, by-product, and special nuclear material in quantities not sufficient to form a critical mass. However, the regulation of nuclear reactors is under USNRC jurisdiction. In the remaining states, USNRC still handles all of the inspection, enforcement, and licensing responsibilities. States can regulate exposure to workers from electronic sources, as well as from naturally occurring and accelerator-produced radioactive materials. State regulations for ^226^Ra and strontium isotopes are listed in Tables 7-2 and 7-3, respectively.

The basic philosophy of radiation safety is to minimize unnecessary radiation exposure. The specific objectives of radiation safety guidance as stated by NCRP are (1) to prevent the occurrence of severe radiation-induced deterministic (nonstochastic) disease, and (2) to limit the risk of the nondeterministic (stochastic) effects (fatal cancer, and genetic effects) to a reasonable level compared with nonradiation risks and in relation to societal needs, benefits gained, and economic factors. In addition to regulations that set upper limits on radiation dose, the concept of ALARA (As Low As Reasonably Achievable) was introduced to ensure that work place endeavors resulting in exposures to radiation provide sufficient benefits which offset any potential detriment they cause (ACGIH 1998). The goal is not to eliminate all radiation exposure, which would not be possible, but instead to strive for an appropriate balance between protection of public health and reasonable costs (economic, social, etc.) while maintaining desirable dose limits. The American Conference of Governmental Industrial Hygienists (ACGIH) has adopted the occupational exposure guidance of the ICRP (ACGIH 1998). The values used by ACGIH as guidelines for exposure to radiation are given in Table 7-1.

The USNRC has set dose limits for individual members of the public of 0.1 rem/year, 5 rem/year for occupationally exposed workers, and 0.5 rem (0.005 Sv) during the gestation period to the fetus of a pregnant worker (USNRC 1996). More specific information on regulations pertaining to ionizing radiation exposure can be found in the references listed in Table 7-1 of this profile.

Table 7-1 Regulations and Guidelines Applicable to Ionizing Radiation

Agency | Description | Information | References
[underlined: INTERNATIONAL]
Guidelines:
a. Occupational
ICRP | Whole Body | 10 rem/5 years^a^ not to exceed 5 rem/year | ICRP 1991
ICRP | Eguivalent Dose to Lens of Eye | 15 rem/year | ICRP 1991
ICRP | Eguivalent Dose to Skin, Hands and Feet | 50 rem/year | ICRP 1991
ICRP | Annual Limits of Intake | (2 rem)/(E ( 50 ) Bq^− 1^) | ICRP 1991
b. General Population
ICRP | Effective dose limit and, if needed, higher values provided that the annual average over 5 years does not exceed this limit | 0.1 rem/year | ICRP 1991
ICRP | Equivalent dose limit | | ICRP 1991
ICRP | lens of eye | 1.5 rem/year | ICRP 1991
ICRP | skin, hands and feet | 5 rem/year | ICRP 1991
ICRP | woman’s abdomen | 0.2 rem | ICRP 1991
[underlined: NATIONAL]
Regulations:
a. Air
DOE | Derived Air Concentrations | Yes | 63 FR 59662 (10CFR 835.209); DOE 1998
EPA | Hazardous Air Pollutant; radionuclides (including radon) | Yes | CAA Amendments, Title III, Section 112 (b); U.S. Congress 1990
EPA | National Emissions Standards for Radon Emissions from Underground Uranium mines—effective dose equivalent for the public | 10 mrem/year | 40 CFR 61, Subpart B; EPA 1989a
EPA | National Emission Standards for Emissions of Radionuclides Other Than Radon from Department of Energy Facilities | Yes | 40 CFR 61, Subpart H; EPA 1989d
EPA | National Emissions Standards for radionuclide Emissions from Facilities Licensed by the Nuclear Regulatory commission and Federal Facility not Covered by Subpart H | Yes | 40 CFR 61, Subpart I; EPA 1996a
EPA | National Emission Standards for Radionuclide Emissions from Elemental Phosphorus Plants | 2 Ci/year^b^ | 40 CFR 61, Subpart K; EPA 1991
EPA | National Emissions Standards for Radon Emissions from Phosphogypsum Stacks—inactive stacks | 20 pCi/m^2^ | 40 CFR 61, Subpart R; EPA 1992
EPA | National Emission Standards for Radon Emissions from the Disposal of Uranium Mill Tailings—Radon-222 emissions to the ambient air from non-operational piles | 20 pCi/m^2^-s of radon | 40 CFR 61, Subpart T; EPA 1994
EPA | Test Methods | | 40 CFR 61, Appendix B; EPA 1996b
EPA | Test method for measuring radionuclide emissions from stationary sources | Method 114 | 40 CFR 61, Appendix B; EPA 1996b
EPA | Monitoring for radon-222 emissions | Method 115 | 40 CFR 61, Appendix B; EPA 1996b
EPA | Methods for Estimating Radionuclide Emissions | Yes | 40 CFR 61, Appendix D; EPA 1989c
EPA | Compliance Procedures Methods for Determining compliance with [40 CFR 61], Subpart I | Yes | 40 CFR 61, Appendix E; EPA 1989b
OSHA | Toxic and Hazardous Substances—ionizing radiation | Yes | 29 CFR 1910.1096; OSHA 1996a
OSHA | Safety and Health Regulations for Construction | Yes | 29 CFR 1926.53; OSHA 1996b
b. Water:
EPA | Maximum Contaminant Levels for Radium-266, Radium-228, and Gross Alpha Particle Radioactivity in Community Water Systems | | 40 CFR 141.15; EPA 1976a
EPA | Combined radium-266, and radium-228 | 5 pCi/L | 40 CFR 141.15; EPA 1976a
EPA | Gross alpha particle activity; including radium-226, but excluding radon and uranium | 15 pCi/L | 40 CFR 141.15; EPA 1976a
EPA | MCL for beta particles and photon activity | 0.004 rem/year | 40 CFR 141.16; EPA 1976b
EPA | Average Annual Concentrations Assumed to Produce Total Body or Organ Dose of 4 mrem/yr
EPA | Tritium (total body) | 20,000 pCi/L
EPA | Strontium-90 (bone marrow) | 8 pCi/L
EPA | Monitoring frequency for radioactivity in community water systems | Yes | 40 CFR 141.26; EPA 1976c
EPA | National Primary Drinking Water Regulations; Analytical Methods for Radionuclides (final rule and proposed rule) | Yes | 62 FR 10168 (40 CFR 141.25); EPA 1997
EPA | Class V Injection Wells Underground Injection Control Regulations, revisions; proposed rule | Yes | 63 FR 40586 (40 CFR 144,145, and 146); EPA 1998b
c. Other: Occupational
DOE | Exposure Limits for General Employees | | 63 FR 59662; DOE 1998 and; 10 CFR 835; DOE 1993
DOE | Total effective dose | 5 rem/year (0.05 Sv)^c^ | 63 FR 59662; DOE 1998 and; 10 CFR 835; DOE 1993
DOE | Deep dose equivalent plus Committed dose to any organ or tissue other than lens of the eye | 50 rem/year (0.5 Sv) | 63 FR 59662; DOE 1998 and; 10 CFR 835; DOE 1993
DOE | Eye lens dose equivalent | 15 rem/year (0.15 Sv) | 63 FR 59662; DOE 1998 and; 10 CFR 835; DOE 1993
DOE | Shallow dose equivalent to skin or other extremity | 50 rem/year | 63 FR 59662; DOE 1998 and; 10 CFR 835; DOE 1993
DOE | Planned Special Exposures | Yes | 63 FR 59662; DOE 1998 and; 10 CFR 835; DOE 1993
DOE | Limits for the embryo/fetus | 0.5 rem (conception to birth) | 63 FR 59662; DOE 1998 and; 10 CFR 835; DOE 1993
DOE | Limit for minors (total effective dose equivalent) | 0.1 rem (0.001 sievert) per year | 63 FR 59662; DOE 1998 and; 10 CFR 835; DOE 1993
DOE | Limit for members of the public in a controlled area (total effective dose equivalent) | 0.01 rem per year | 63 FR 59662; DOE 1998 and; 10 CFR 835; DOE 1993
DOE | Requirements for Individual Monitoring | Yes | 63 FR 59662; DOE 1998 and; 10 CFR 835; DOE 1993
DOT | General Requirements for Shipments and Packaging—Class 7 (Radioactive Material) | | 49 CFR 173, Subpart I; DOT 1997
DOT | Scope and definitions | Yes | 49 CFR 173, Subpart I; DOT 1997
DOT | Packaging design requirements | Yes | 49 CFR 173, Subpart I; DOT 1997
DOT | Table of activity limits | Yes | 49 CFR 173, Subpart I; DOT 1997
DOT | Requirements for determining A, and A_2_ values for radionuclides and for the listing of radionuclides on shipping papers and labels | Yes^d^ | 49 CFR 173, Subpart I; DOT 1997
DOT | Table of A, and A_2_ values | Yes | 49 CFR 173, Subpart I; DOT 1997
DOT | Radiation level limitations external surface radiation level not to be exceeded under conditions normally incident to transportation | 2 mSv/hour (200 mrem/hour) and the transport Index (Tl) is less than 10 | 49 CFR 173, Subpart I; DOT 1997
DOT | -packages exceeding the radiation level limit | | 49 CFR 173, Subpart I; DOT 1997
DOT | transport by exclusive use shipment | Yes | 49 CFR 173, Subpart I; DOT 1997
DOT | conditional maximum radiation level | 10 mSv/hour (1000 mrem/hour) | 49 CFR 173, Subpart I; DOT 1997
DOT | Outer surfaces of vehicle including top and underside | 2 mSv/hour (200 mrem/hour) | 49 CFR 173, Subpart I; DOT 1997
DOT | Any point 2 meters (6.6 feet) from the outer lateral surfaces, excluding top and underside | 0.1 mSv/hour (10 mrem/hour) | 49 CFR 173, Subpart I; DOT 1997
DOT | Any normally occupied space except carriers operating under the provisions of a state or federally regulated radiation protection program and wearing radiation dosimetry devices | 0.02 mSv/hour (2 mrem/hour) | 63 FR 48568 (49 CFR 173); DOT 1998
FDA | Radiation Protection Program Requirements | | 63 FR 48566 (49 CFR 172, etal.); DOT 1998
FDA | Hazardous materials table, special provisions, hazardous materials communications, emergency response information and training requirements (49 CFR 172, Subpart I) | Removed | 63 FR 48566 (49 CFR 172, etal.); DOT 1998
FDA | Carriage by rail (49 CFR 174.705) | Removed | 63 FR 48566 (49 CFR 172, etal.); DOT 1998
FDA | Carriage by aircraft (49 CFR 175.706) | Removed | 63 FR 48566 (49 CFR 172, etal.); DOT 1998
FDA | Carriage by vessel (49 CFR 176.703) | Removed | 63 FR 48566 (49 CFR 172, etal.); DOT 1998
FDA | Carriage by public highway (49 CFR 177.827) | Removed | 63 FR 48566 (49 CFR 172, etal.); DOT 1998
FDA | Carriage by Public Highway | | 49 CFR 177.842; DOT 1995
FDA | Requirements for class 7 (radioactive material) | Yes | 49 CFR 177.842; DOT 1995
FDA | Total transport index number | 50 | 49 CFR 177.842; DOT 1995
FDA | Irradiation in the Production, Processing and Handling of Animal Feed and Pet Food
FDA | Ionizing radiation for treatment of laboratory animal diets | | 21 CFR 579.22; FDA 1993a
FDA | -energy source | Gamma rays from sealed units of the radionuclides cobalt-60 or cesium-137 | 21 CFR 579.22; FDA 1993a
FDA | -limit for electrons generated | Not to exceed 10 million electron volts | 21 CFR 579.22; FDA 1993a
FDA | -single treatment for microbial disinfection of bagged complete diets for laboratory animals (mice, rats, hamsters, rabbits, and guinea pigs) | Absorbed dose not to exceed 50 kGy (5 Mrad) | 21 CFR 579.22; FDA 1993a
FDA | Ionizing radiation for the treatment of poultry feed and poultry feed ingredients | | 21 CFR 579.40; FDA 1995
FDA | -energy source | Gamma rays from sealed units of cobalt-60 | 21 CFR 579.40; FDA 1995
FDA | -single treatment poultry feed or feed ingredients that do not contain drugs for rendering them salmonella negative | 2.0 kGy (0.2 Mrad) minimum dose; 25 kGy (2.5 Mrad) maximum dose | 21 CFR 579.40; FDA 1995
FDA | Performance Standards For Ionizing Radiation Emitting Products
FDA | Cold-cathode gas discharge tubes | Yes | 21 CFR 1020.20; FDA 1973b
FDA | Diagnostic X-ray systems and their major components | Yes | 21 CFR 1020.30; FDA 1994a
FDA | Radiographic equipment | Yes | 21 CFR 1020.31; FDA 1993b
FDA | Fluoroscopic equipment | Yes | 21 CFR 1020.32; FDA 1994b
FDA | Computed tomography (CT) equipment | Yes | 21 CFR 1020.33 FDA 1991
FDA | Cabinet X-ray systems | Yes | 21 CFR 1020.40; FDA 1974
MSHA | Radon daughters, | | MSHA 1997
MSHA | Monitoring required 1/3 months | >0.1 WL | MSHA 1997
MSHA | Monitoring required 1/week | >0.3 WL | MSHA 1997
MSHA | Uranium Mines; monitoring monthly | 0.1 WL | MSHA 1997
MSHA | Gamma Radiation Dosimeters for All Employees and Records of Cumulative Individual Exposure | >0.002 roentgens/hr | MSHA 1997
NRC | Limits for Adults | | 10 CFR 20, Subpart C; USNRC 1991
NRC | Total effective dose | 5 rem/year | 10 CFR 20, Subpart C; USNRC 1991
NRC | Effective deep dose equivalent plus committed dose to any organ or tissue other than lens of the eye | 50 rem/year | 10 CFR 20, Subpart C; USNRC 1991
NRC | Eye lens dose equivalent | 15 rem/year | 10 CFR 20, Subpart C; USNRC 1991
NRC | Skin or other extremity; shallow dose | 50 rem/year | 10 CFR 20, Subpart C; USNRC 1991
NRC | Dose Limit for Minors | 10% of annual dose limit for adult workers
NRC | Dose Limit to an Embryo/fetus [of pregnant female] | 0.5 rem
NRC | Annual Limits On Intake (ALIs) and Derived Air Concentration (DACs) of Radionuclide for Occupational Exposure | Yes | 10 CFR 20, Appendix B; USNRC 1993
NRC | Quantities of Licensed Material Requiring Labeling | Yes | 10 CFR 20, Appendix C; USNRC 1995
NRC | Physical Protection for Spent Nuclear Fuel and High-level Radioactive Material | Yes | 63 FR 29655; USNRC 1998
d. Other: General Population
EPA | Hazardous Waste Injection Restrictions | Effective May 26, 2000 | 63 FR 28556 (40 CFR 148.18); EPA 1998a
EPA | Waste specific prohibitions, newly listed and identified waste | Effective May 26, 2000 | 63 FR 28556 (40 CFR 148.18); EPA 1998a
EPA | -radioactive wastes mixed with newly identified D004-D011 waste | | 63 FR 28556 (40 CFR 148.18); EPA 1998a
EPA | Environmental Standards for Uranium Fuel Cycle: Standards for Normal Operation | | 40 CFR 190, Subpart B; EPA 1977
EPA | Annual dose not to exceed: | | 40 CFR 190, Subpart B; EPA 1977
EPA | -whole body | ≤ 25 mrem | 40 CFR 190, Subpart B; EPA 1977
EPA | -thyroid | ≤ 75 mrem | 40 CFR 190, Subpart B; EPA 1977
EPA | -any other organ | ≤ 25 mrem | 40 CFR 190, Subpart B; EPA 1977
EPA | Total quantity of radioactive materials entering the general environment | | 40 CFR 190, Subpart B; EPA 1977
EPA | -krypton-85 | | 40 CFR 190, Subpart B; EPA 1977
EPA | -iodine-129 | 50,000 Ci | 40 CFR 190, Subpart B; EPA 1977
EPA | -plutonium-239 combined with other | 5 mCi | 40 CFR 190, Subpart B; EPA 1977
EPA | alpha-emitting transuranic radionuclides with half-lives greater than one year | 0.5 mCi | 40 CFR 190, Subpart B; EPA 1977
EPA | Environmental Radiation Protection Standards for Management and Disposal of Spent Nuclear Fuel, High-level and Transuranic Radioactive Wastes | | 40 CFR 191; EPA 1993a
EPA | Environmental standards for management and storage— applicability and definitions | Yes | 40 CFR 191; EPA 1993a
EPA | -whole body | 25 mrem | 40 CFR 191; EPA 1993a
EPA | -thyroid | 75 mrem | 40 CFR 191; EPA 1993a
EPA | -other critical organs | 25 mrem | 40 CFR 191; EPA 1993a
EPA | Environmental standards for disposal— applicability, definitions, containment and individual protection requirements | Yes | 40 CFR 191; EPA 1993a
EPA | -release limits for containment requirements | [underlined: Per 1000 MTHM^e^] | 40 CFR 191; EPA 1993a
EPA | Americium-241 or -243 | 100 | 40 CFR 191; EPA 1993a
EPA | Carbon-14 | 100 | 40 CFR 191; EPA 1993a
EPA | Cesium-135 or-137 | 1,000 | 40 CFR 191; EPA 1993a
EPA | Iodine-129 | 100 | 40 CFR 191; EPA 1993a
EPA | Neptunium-237 | 100 | 40 CFR 191; EPA 1993a
EPA | Plutonium-239, -240, or -242 | 100 | 40 CFR 191; EPA 1993a
EPA | Radium-226 | 100 | 40 CFR 191; EPA 1993a
EPA | Strontium-90 | 1,000 | 40 CFR 191; EPA 1993a
EPA | Technetium-99 | 10,000 | 40 CFR 191; EPA 1993a
EPA | Thorium-230 or -232 | 10 | 40 CFR 191; EPA 1993a
EPA | Tin-126 | 1,000 | 40 CFR 191; EPA 1993a
EPA | Uranium-233, -234, -235, -236, or -238 | 100 | 40 CFR 191; EPA 1993a
EPA | Any other alpha-emitting radionuclide with a half-life greater than 20 years | 100 | 40 CFR 191; EPA 1993a
EPA | Any other radionuclide with a half-life greater than 20 years that does not emit alpha particles | 1,000 | 40 CFR 191; EPA 1993a
EPA | Environmental Standards for Groundwater Protection | | 40 CFR 191; EPA 1993a
EPA | -applicability and definitions | Yes | 40 CFR 191; EPA 1993a
EPA | -disposal standards; levels of radioactivity in any underground drinking water source | Not to exceed limits specified in 40 CFR 141 | 40 CFR 191; EPA 1993a
EPA | Land Disposal Restrictions,
EPA | Effective dates of surface disposed wastes—mixed radioactive/newly identified waste codes D003-D011 | May 26, 2000 | 63 FR 28556 (40 CFR 268, App. VII); EPA 1998a
EPA | F035; mixed with radioactive waste | May 12,1999
EPA | Treatment Standards; radioactive high level wastes (nonwastewaters) generated during the reprocessing of fuel rods—Hazardous waste codes D002, D004-D011 | HLVIT^f^
EPA | Standards for Control of Residual Radioactive Material from Inactive Uranium Processing Sites | Yes | 40 CFR 192, Subpart A; EPA 1995a
EPA | Definitions | Yes | 40 CFR 192, Subpart A; EPA 1995a
EPA | Standards (for control of residual radioactive materials and their listed constituents) | Yes | 40 CFR 192, Subpart A; EPA 1995a
EPA | Maximum concentration of constituents for groundwater protection | 30 pCi/L | 40 CFR 192, Subpart A; EPA 1995a
EPA | Standards for Cleanup of Land and building Contaminated with Residual Radioactive Materials from Inactive Uranium Processing Sites | Yes | 40 CFR 192, Subpart B; EPA 1995b
EPA | Guidance for Implementation | Yes | 40 CFR 192, Subpart C; EPA 1995c
EPA | Additional Listed Constituents (replacement list of constituents for screening purposes) | Combined ^234^U and ^238^U | 40 CFR 192, Subpart C; EPA 1995c
EPA | Standards for Management of Uranium Byproduct Materials Pursuant to Section 84 of the Atomic Energy Act of 1954, as Amended | Yes | 40 CFR 192, Subpart D; EPA 1993b
EPA | Standards (for application during processing operations and prior to the endo of the closure period— concentration limits | 5 pCi/L | 40 CFR 192, Subpart D; EPA 1993b
EPA | Standards for Management of Thorium Byproduct Materials Pursuant to Section 84 of the Atomic Energy Act of 1954, as Amended | Yes | 40 CFR 192, Subpart E; EPA 1993c
FDA | Irradiation in the Production, Processing and Handling of Food
FDA | Sources of radiation used for inspection of food, inspection of packaged food and for controlling food processing | Yes | 21 CFR 179.21; FDA 1996a
FDA | General provisions for food irradiation | | 21 CFR 179.25; FDA 1986
FDA | Ionizing radiation for the treatment of food | | 21 CFR 179.26; FDA 1997
FDA | -energy source | gamma rays from seal units of radionuclides ^60^Co or ^137^Cs | 21 CFR 179.26; FDA 1997
FDA | -limit for electrons generated | 10 million electron volts | 21 CFR 179.26; FDA 1997
FDA | -limit for X-rays | 5 million electron volts | 21 CFR 179.26; FDA 1997
FDA | -control of Trichinella spiralis in pork carcasses of fresh | 0.3 kGy to 1 kGy (30 to 100 krad) | 21 CFR 179.26; FDA 1997
FDA | -growth and maturation inhibition of fresh food | Not to exceed 1 kGy (100 krad) | 21 CFR 179.26; FDA 1997
FDA | -disinfestation of arthropod pests in food | Not to exceed 1 kGy (100 krad) | 21 CFR 179.26; FDA 1997
FDA | -microbial disinfection of dry or dehydrated enzyme preparations (including immobilized enzymes) | Not to exceed 10 kGy (1 Mrad) | 21 CFR 179.26; FDA 1997
FDA | -microbial disinfection of selected dry or dehydrated aromatic vegetables substances when used as ingredients in small amounts solely for flavoring or aroma | Not to exceed 30 kGy (3 Mrad) | 21 CFR 179.26; FDA 1997
FDA | -control of food-borne pathogens in fresh or frozen, uncooked poultry products | Not to exceed 30 kGy (3 Mrad); packaging shall not exclude oxygen | 21 CFR 179.26; FDA 1997
FDA | -sterilization of frozen, packaged meats used solely in the National Aeronautics and Space Administration space flight program | Minimum dose 44 kGy (4.4 Mrad) | 21 CFR 179.26; FDA 1997
FDA | -control of food-borne pathogens in and for extension of shelf-life of refrigerated or frozen, uncooked meat, meat by-products or meat food products | Not to exceed 4.5 kGy (450 krad) maximum for refrigerated products; not to exceed 7.0 kGy (700 krad) maximum for frozen products | 21 CFR 179.26; FDA 1997
FDA | Radio-frequency radiation for the heating of food, including microwave frequencies | Yes | 21 CFR 179.30; FDA 1977a
FDA | Ultraviolet radiation for the processing and treatment of food | Yes | 21 CFR 179.39; FDA 1977b
FDA | Pulsed light for the treatment of food | | 21 CFR 179.41; FDA 1996b
FDA | -radiation sources | xenon flashlamps; emitting broad band radiation of 200 to 1,000 nanometers | 21 CFR 179.41; FDA 1996b
FDA | -pulse duration | 2 milliseconds | 21 CFR 179.41; FDA 1996b
FDA | -total cumulative treatment for control surface microorganisms | 12 Joules/cm^2^ | 21 CFR 179.41; FDA 1996b
FDA | Packaging materials for use during the irradiation of prepackaged foods | Yes | 21 CFR 179.45; FDA 1996c
FDA | Performance Standards for Ionizing Radiation Emitting Products | Yes | 21 CFR 1020.10; FDA 1973a
FDA | Television receivers | | 21 CFR 1020.10; FDA 1973a
FDA | Radiation Dose Limits For Individual
NRC | Members of the Public | | 10 CFR 20.1301; USNRC 1997b
NRC | Total effective dose equivalent to individual | 0.1 rem/year | 10 CFR 20.1301; USNRC 1997b
NRC | Dose from external sources | 0.002 rem/hour | 10 CFR 20.1301; USNRC 1997b
NRC | Effluent Concentrations and Concentrations for Releases to Sewerage | Yes | 10 CFR 20, Appendix B; USNRC 1993
USDA | Hawaiian Fruits and Vegetables | Yes | 7 CFR 318.13 to 13-4f; USDA 1997
Guidelines:
a, Water | MCLG for beta particles and photon activity | none | EPA 1998c
a, Water | MCLG for gross alpha particle activity | none | EPA 1998c
a, Water | MCLG for ^226^Rn and ^228^Rn combined | none | EPA 1998c
ACGIH | Effective Dose | | EPA 1998c
ACGIH | Any single year | 50 mSv (5 rem) | EPA 1998c
ACGIH | Averaged over 5 years; per year | 20 mSv (2 rem) | EPA 1998c
b. Other: Occupational | Annual Equivalent Dose | | ACGIH 1998
b. Other: Occupational | Lens of the eye | 150 mSv (15 rem) | ACGIH 1998
b. Other: Occupational | Skin | 500 mSv (50 rem | ACGIH 1998
b. Other: Occupational | Hands and feet | 500 mSv (50 rem) | ACGIH 1998
b. Other: Occupational | Embryo-Fetus exposures once pregnancy is known | | ACGIH 1998
b. Other: Occupational | Monthly equivalent dose^g^ | 0.5 mSv (0.05 rem) | ACGIH 1998
b. Other: Occupational | Dose to surface of women’s abdomen (lower trunk); for the remainder of the pregnancy | 2 mSv (0.2 rem) | ACGIH 1998
b. Other: Occupational | Intake of radionuclide | 1/20 of annual limit on intake (ALI) 4 working level months (WLM) | ACGIH 1998
b. Other: Occupational | Radon Daughters | 1/20 of annual limit on intake (ALI) 4 working level months (WLM) | ACGIH 1998
DOT | General public | 2 mrem/hr | DOT 1996
DOT | Cumulative dose, individual | 100 mrem/week; 500 mrem/year | DOT 1996
EPA^h^ | Effective dose equivalent | | EPA 1987; Fed Reg Part II
EPA^h^ | Adult | 5 rem/year | EPA 1987; Fed Reg Part II
EPA^h^ | Lens of the eye | 15 rem/year | EPA 1987; Fed Reg Part II
EPA^h^ | All other organs | 50 rem/year | EPA 1987; Fed Reg Part II
EPA^h^ | Juvenile workers(<18 years old) | 0.5 rem/year | EPA 1987; Fed Reg Part II
EPA^h^ | Pregnant workers | 0.5 rem/gestation period
EPA^h^ | Effective dose equivalent limit (stochastic limits) | 5 rem/year not to exceed 1 rem x age of individual | NCRP 1993
EPA^h^ | Equivalent dose limit (nonstochastic limits) | 5 rem/year
EPA^h^ | Skin, hands, and feet | 15 rem/year
EPA^h^ | Lens of the eyes | 50 rem/year
EPA^h^ | All other organs
EPA^h^ | Guidance: Cumulative exposure | 1 rem x age in years
EPA^h^ | Annual Reference Levels of Intake (ARLI) | 2 rem /yr (20 mSv/yr)^i^
c. Other: General Population
FDA | Accidental Radioactive Contamination of Human Food and Animal Feeds: Recommendations for State and Local Agencies | Yes | FDA 1998
FDA | Protective action guides for tissue or organ; ingestion pathway | | FDA 1998
FDA | Committed effective dose equivalent | 5 mSv (0.5 rem) | FDA 1998
FDA | Committed dose equivalent | 50 mSv (5 rem) | FDA 1998
NCRP^h^ | Effective dose equivalent limit | | NCRP 1993
NCRP^h^ | Continuous or frequent exposure | 0.1 rem/year | NCRP 1993
NCRP^h^ | Infrequent exposure | 0.5 rem/year | NCRP 1993
NCRP^h^ | Lens of the eye, skin, and extremities | 5 rem/year | NCRP 1993
NCRP^h^ | Embryo-fetus | 0.05 rem/month | NCRP 1993
NCRP^h^ | Remedial action recommended | | NCRP 1987
NCRP^h^ | Effective dose equivalent^j^ | >0.5 rem/year | NCRP 1987
NCRP^h^ | Exposure to radon and its decay products | >2 WLM/year | NCRP 1987
NCRP^h^ | Education and Training Exposures
NCRP^h^ | Effective dose equivalent limit | 0.1 rem/year
NCRP^h^ | Dose equivalent limit in a month | 0.05 rem
NCRP^h^ | Negligible Individual Risk Level
NCRP^h^ | Effective dose equivalent per source or practice | 0.01 rem/year
[underlined: STATE]
Regulations and Guidelines: Public Protection
a. Virginia | Acceptable ambient air concentrations Radionuclides | 8.00 pg/m^3^ (24 hours) | NATICH 1992

a Rem means the unit of dose equivalent from ionizing radiation to the total body or any internal organ or organ system. A “millirem (mrem)” is 1/1000 of a rem.

b Curie (CI) means the quantity of radioactive material producing 37 billion nuclear transformations per second; 1 millicurie [mCi] = 0.001 Ci, 1 picocurie [pCi] = 10^-12^ Ci).

c Unless otherwise specified, the radiological unit Sievert (Sv) is provided in the DOE regulations parenthetically and is not authorized for use in the documents required for record keeping. The quantities used in the records must be clearly indicated in special units of curie, rad, or rem, including multiples and subdivisions of these units. 10 mSv = 1 rem.

d A_1_ means the maximum activity of special form Class 7 (radioactive) material permitted in a Type A package. A^2^ means the maximum activity of class 7 material, other than special form, low specific activity material or surface contaminated objects permitted in a Type A package. See 49 CFR 173.403 for more detailed definitions.

e Values represent cumulative releases to the accessible environment for 10,000 years after disposal.

f HLVIT means vitrification of high level mixed radioactive wastes in units in compliance with all applicable radioactive protection.

g Sum of internal and external exposure but excluding doses from natural sources as recommended by the NCRP.

h Sum of external and internal exposures.

i The ARLI is the occupational, annual intake of radionuclides in Bq, averaged over 5 years, that equal a 50-year committed effective dose equivalent of 20 mSv.

j Including background but excluding internal exposures.

ACGIH = American Conference of Governmental Industrial Hygienists; CAA = Clean Air Act; DOE = Department of Energy; DOT = Department of Transportation; EPA = Environmental Protection Agency; ICRP = International Commission on Radiological Protection; kGy = KiloGray; krad = Kilorad; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; MSHA = Mine Safety Health Administration; Mrad = Megarad; mSv = Millisievert; MTHM = Metric Tons of Heavy Metal; NATICH = National Air Toxics Information Clearing House; NCRP = National Council on Radiation Protection; NRC = Nuclear Regulatory Commission (USNRC); OSHA = Occupational Safety and Health Administration; WL = working level; WLM = working level month

Table 7-2 Regulations and Guidelines Applicable to ^226^Ra

Agency | Description | Information | References
[underlined: STATE]
a. Regulations:
| Water Quality Criteria: Human Health | | CELDs 1994
AK | Drinking water | 5 pCi/L | CELDs 1994
AL | Drinking water | 5 pCi/L | CELDs 1994
AZ | Drinking water | 5 pCi/L | CELDs 1994
CA | Drinking water | 5 pCi/L | CELDs 1994
CO | Drinking water | 5 pCi/L combined | CELDs 1994
CT | Drinking water | 5 pCi/L | CELDs 1994
DE | Drinking water | 5 pCi/L | CELDs 1994
FL | Drinking water | 5 pCi/L combined | CELDs 1994
GA | Drinking water | 5 pCi/L | CELDs 1994
HI | Drinking water | 5 pCi/L | CELDs 1994
IA | Drinking water | 5 pCi/L | CELDs 1994
IN | Drinking water | 5 pCi/L | CELDs 1994
KY | Drinking water/waste management | 5 pCi/L | CELDs 1994
MD | Drinking water | 5 pCi/L | CELDs 1994
ME | Drinking water | 5 pCi/L | CELDs 1994
MT | Drinking water | 5 pCi/L | CELDs 1994
NC | Drinking water | 5 pCi/L | CELDs 1994
ND | Drinking water | 5 pCi/L | CELDs 1994
NE | Drinking water | 5 pCi/L | CELDs 1994
NH | Drinking water | 5 pCi/L combined | CELDs 1994
NM | Drinking water | 5 pCi/L | CELDs 1994
NY | Drinking water | 3 pCi/L | CELDs 1994
PR | Drinking water | 3 pCi/L | CELDs 1994
OH | Drinking water | 5 pCi/L | CELDs 1994
OK | Drinking water | 5 pCi/L | CELDs 1994
RI | Drinking water | 5 pCi/L | CELDs 1994
SC | Drinking water | 5 pCi/L | CELDs 1994
SD | Drinking water | 5 pCi/L | CELDs 1994
TN | Drinking water | 5 pCi/L | CELDs 1994
TX | Drinking water | 5 pCi/L | CELDs 1994
VA | Drinking water | 5 pCi/L | CELDs 1994
UT | Drinking water | 5 pCi/L | CELDs 1994
WA | Drinking water | 3 pCi/L | CELDs 1994
WV | Drinking water | 5 pCi/L | CELDs 1994
WY | Drinking water | 3 pCi/L combined | CELDs 1994
| Water Quality Criteria: Aquatic Life | | CELDs 1994
IA | Raw water sources for potable water | 5 pCi/L | CELDs 1994
MT | | None | CELDs 1994
NC | | 5 pCi/L | CELDs 1994
ND | | 5 pCi/L | CELDs 1994
NH | | 5 pCi/L | CELDs 1994
PR | | 3 pCi/L | CELDs 1994
WV | | 5 pCi/L | CELDs 1994
WY | | 5 pCi/L | CELDs 1994
| Water Quality Criteria: Agriculture | | CELDs 1994
AZ | Private Agriculture | 5 pCi/L | CELDs 1994
ND | Irrigation | 5 pCi/L | CELDs 1994
WY | Not specified | 5 pCi/L | CELDs 1994
| Water Quality Criteria: Recreational | | CELDs 1994
ND | Recreational (boating, fishing) | 5 pCi/L | CELDs 1994
NH | Recreational | 3 pCi/L | CELDs 1994
WY | Not specified | 5 pCi/L | CELDs 1994
| Water Quality - Monitoring | | CELDs 1994
CA | Drinking water | 5 pCi/L | CELDs 1994
FL | Drinking water | 5 pCi/L | CELDs 1994
IA | Drinking water | 1 pCi/L | CELDs 1994
ID | Drinking water | 5 pCi/L | CELDs 1994
IL | Drinking water | 5 pCi/L | CELDs 1994
IN | Drinking water | 3 pCi/L | CELDs 1994
MA | Drinking water | 5 pCi/L | CELDs 1994
MD | Drinking water | 1 pCi/L | CELDs 1994
MI | Drinking water | 3 pCi/L | CELDs 1994
MO | Drinking water | 5 pCi/L | CELDs 1994
MT | Drinking water | Yes | CELDs 1994
NC | Drinking water | 5 pCi/L | CELDs 1994
ND | Drinking water | 5 pCi/L | CELDs 1994
NM | Drinking water | 1 pCi/L | CELDs 1994
NY | Drinking water | 5 pCi/L | CELDs 1994
OH | Drinking water | 5 pCi/L | CELDs 1994
PR | Drinking water | 5 pCi/L | CELDs 1994
RI | Drinking water | 5 pCi/L | CELDs 1994
SC | Drinking water | 5 pCi/L | CELDs 1994
SD | Drinking water | 5 pCi/L | CELDs 1994
TN | Drinking water | 1 pCi/L | CELDs 1994
TX | Drinking water | 5 pCi/L | CELDs 1994
VA | Drinking water | 5 pCi/L | CELDs 1994
UT | Drinking water | 5 pCi/L | CELDs 1994
WA | Drinking water | 5 pCi/L | CELDs 1994
WI | Drinking water | 5 pCi/L | CELDs 1994
WV | Drinking water | 5 pCi/L | CELDs 1994
| Groundwater Quality Standards | | CELDs 1994
NE | Groundwater | 5 pCi/L | CELDs 1994
NC | Drinking, potable mineral water | 5 pCi/L | CELDs 1994
NY | Not specified | 3 pCi/L | CELDs 1994
PR | Not specified | 3 pCi/L | CELDs 1994
TN | Not specified | 5 pCi/L | CELDs 1994
VA | Not specified | 5 pCi/L | CELDs 1994
WY | Not specified | 5 pCi/L | CELDs 1994
| Groundwater Monitoring Parameters | | CELDs 1994
CA | Hazardous waste facilities | Yes | CELDs 1994
CO | Hazardous waste facilities | 5 pCi/L | CELDs 1994
IN | Public supply | 3 pCi/L | CELDs 1994
NC | Public supply | 5 pCi/L | CELDs 1994
NJ | Hazardous waste facilities | 5 pCi/L | CELDs 1994
NM | Public supply | 1 pCi/L | CELDs 1994
NY | Hazardous facility | 5 pCi/L | CELDs 1994
SC | Hazardous waste | 5 pCi/L | CELDs 1994
TN | Not specified | 5 pCi/L | CELDs 1994
WI | Hazardous waste | 5 pCi/L | CELDs 1994

CELDS = Comprehensive Environmental Legislative Database

Table 7-3 Regulations and Guidelines Applicable to Strontium Isotopes

Agency | Description | Information | References
[underlined: STATE]
a. Regulations:
| Water Quality Criteria - Human Health | | CELDs 1994
AZ | Agricultural, public, aquatic | 8 pCi/L | CELDs 1994
AL | Drinking water | 8 pCi/L | CELDs 1994
CA | Drinking water | 8 pCi/L | CELDs 1994
CO | Drinking water | 2 pCi/L | CELDs 1994
CT | Drinking water - standard | 8 pCi/L | CELDs 1994
DE | Drinking water - standard and monitoring | 8 pCi/L | CELDs 1994
FL | Drinking water | 8 pCi/L | CELDs 1994
GA | Drinking water | Yes | CELDs 1994
HI | Drinking water | 8 pCi/L | CELDs 1994
IA | Drinking water | 8 pCi/L | CELDs 1994
ID | Drinking water | 8 pCi/L | CELDs 1994
IL | Drinking water | 8 pCi/L | CELDs 1994
IN | Drinking water | 8 pCi/L | CELDs 1994
| Surface Water Quality Standards | | CELDs 1994
CO | | 8 pCi/L | CELDs 1994
| Water Quality Monitoring | | CELDs 1994
AL | Drinking water | Yes | CELDs 1994
AZ | Drinking water | Yes | CELDs 1994
CA | Drinking water | 8 pCi/L | CELDs 1994
CO | Drinking water | 2 pCi/L | CELDs 1994
DE | Drinking water | 8 pCi/L | CELDs 1994
GA | Drinking water | Yes | CELDs 1994
HI | Drinking water | Yes | CELDs 1994
IA | Drinking water | Yes | CELDs 1994
ID | Drinking water | Yes | CELDs 1994
IL | Drinking water | 8 pCi/L | CELDs 1994
IN | Drinking water | Yes | CELDs 1994
| Groundwater Quality Standards | | CELDs 1994
CO | Groundwater - Public | 8 pCi/L | CELDs 1994
IN | Groundwater - Drinking | 10 pCi/L | CELDs 1994

CELDS = Comprehensive Environmental Legislative Database

Table 7-4 FDA Derived Intervention Levels^a^ (Bq/kg)

Radionuclide | Age of individual at time of ingestion
Radionuclide | 3 months | 1 year | 5 years | 10 years | 15 years | Adult
^90^Sr | 308 | 362 | 616 | 389 | 160 | 465
^131^I | 196 | 167 | 722 | 1200 | 1690 | 2420
^134^Cs | 1600 | 2190 | 1940 | 1530 | 958 | 930
^137^Cs | 2000 | 2990 | 2810 | 2180 | 1370 | 1360
Cs group^b^ | 1800 | 2590 | 2380 | 1880 | 1160 | 1150
^103^Ru | 6770 | 8410 | 12200 | 16400 | 25000 | 28400
^106^Ru | 449 | 621 | 935 | 1340 | 2080 | 2360
^238^Pu | 2.5 | 21 | 17 | 14 | 12 | 10
^239^Pu | 2.2 | 18 | 14 | 13 | 10 | 9.8
^241^Am | 2.0 | 17 | 13 | 11 | 9.1 | 8.8
Pu+Am group^c^ | 2.2 | 19 | 15 | 13 | 9.6 | 9.3

a Derived Intervention Levels (DIL) presented are food concentrations whose consumption would deliver a committed effective dose equivalent equal to the most limiting of the protective action guides (PAGs) developed by FDA

b Computed as: (DIL for ^134^Cs + DIL for ^137^Cs)/2

c Computed as: (DIL for ^238^Pu + DIL for ^239^Pu + DIL for ^241^Am)/3

Source: FDA 1998