# APPENDIX C ACRONYMS, ABBREVIATIONS, AND SYMBOLS

AMAD: Activity Median Aerodynamic Diameter
ATSDR: Agency for Toxic Substances and Disease Registry
Bq: becquerel
C: Centigrade
CDC: Centers for Disease Control
CEL: Cancer Effect Level
CERCLA: Comprehensive Environmental Response, Compensation, and Liability Act
CFR: Code of Federal Regulations
Ci: curie
cm: centimeter
CNS: central nervous system
d: day
DHHS: Department of Health and Human Services
DOD: Department of Defense
DOE: Department of Energy
DOT: Department of Transportation
ECG: electrocardiogram
ED_50_: Effective Dose 50%
EEG: electroencephalogram
EPA: Environmental Protection Agency
EKG: see ECG
ERAMS: Environmental Radiation Ambient Monitoring System
ERD: Environmental Radiation Data
F: Fahrenheit
F_1_: first filial generation
ft: foot
g: gram
Gy: gray
HPS: Health Physics Society
hr: hour
IAEA: International Atomic Energy Agency
IARC: International Agency for Research on Cancer
ICRP: International Commission on Radiological Protection
ILB: Initial Lung Burden
IPB: Initial Pulmonary Burden
in: inch
J: joule
kg: kilogram
L: liter
LC_50_: lethal concentration, 50% kill
LD_Lo_: lethal dose, low
LD_50_: lethal dose, 50% kill
LD_50/30_: Lethal Dose 50%/30 days
LOAEL: lowest-observed-adverse-effect level
mg: milligram
min: minute
mL: milliliter
mm: millimeter
MRL: Minimal Risk Level
NAREL: National Air and Radiation Environmental Laboratory
NCRP: National Council on Radiation Protection and Measurements
NRC: Nuclear Regulatory Commission
ng: nanogram
nm: nanometer
NPL: National Priorities List
NRC: Nuclear Regulatory Commission
NTIS: National Technical Information Service
NTP: National Toxicology Program
OSHA: Occupational Safety and Health Administration
PHS: Public Health Service
ppm: parts per million
R: roentgen
sec: second
SCE: sister chromatid exchange
SMR: standard mortality ratio
STEL: short term exposure limit
STORET: STORAGE and RETRIEVAL
STP: standard temperature and pressure
Sv: sievert
TWA: time-weighted average
U.S.: United States
yr: year
wk: week

>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to
%: percent

Greek letters
α: alpha
β: beta
γ: gamma
µ: micro

Prefixes for radiological and physical units

a | atto | 10^-18^
c | centi | 10^-2^
d | deci | 10^-1^
E | exa | 10^18^
f | femto | 10^-15^
G | giga | 10^9^
k | kilo | 10^3^
p | pico | 10^-12^
m | milli | 10^-3^
M | mega | 10^6^
n | nano | 10^-9^
P | peta | 10^15^
T | tera | 10^12^
µ | micro | 10^-6^

Radiation units
Bq: becquerel
Ci: Curie
Gy: Gray
R: roengten
Sv: Seivert