# 9 REFERENCES

*Cited in text

Abbott A, Barker S. 1996. Chernobyl damage ‘underestimated’. Nature 380:658.
Abdel-Nabi H, Ortman JA. 1983. Radiobiological effects of ^131^I and ^125^I on the DNA of the rat thyroid: I. Comparative study with emphasis on the post radiation hypothyroidism occurrence. Radiat Res 93:525–533.6856755
*Abdullah ME, Said SA. 1981. Release and organ distribution of ^125^I from povidone-iodine under the influence of certain additives. Arzneim Forsch 31(1):59–61.7194095
Abel MS, Blume AJ, Garrett KM. 1989. Differential effects of iodide and chloride on allosteric interactions of the GABA_A_ receptor. J Neurochem 53:940–945.2547908
*Aboul-Khair SA, Buchanan TJ, Crooks J, . 1966. Structural and functional development of the human foetal thyroid. Clin Sci 31:415–424.5927693
Aboul-Khair SA, Crooks J, Turnbull AC, . 1964. The physiological changes in thyroid function during pregnancy. Clin Sci 27:195–207.14220900
Absil AC, Buxeraud J, Raby C. 1984. [Charge-transfer complexation of chlorpromazine in the presence of iodine; thyroid side effect of this molecule.] Can J Chem 62(9):1807–1811. (French)
ACGIH. 1992. Iodine. In: Documentation of the threshold limit values and biological exposure indices. Sixth Edition. Volume II. American Conference of Governmental Industrial Hygienists Inc. Cincinnati, OH.
*ACGIH. 2000. Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists Inc. Cincinnati, OH.
Adamson AS, Gardham JRC. 1991. Post ^131^I carcinoma of the thyroid. Postgrad Med J 67:289–290.2062779
*Ader AW, Paul TL, Reinhardt W, . 1988. Effect of mouth rinsing with two polyvinylpyrrolidone-iodine mixtures on iodine absorption and thyroid function. J Clin Endocrinol Metab 66(3):632–635.3350910
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Advani SH, Hege UP. 1992. Leukemia after ^131^I treatment of thyroid cancer-comments on the article second cancer following chemotherapy and radiotherapy-an epidemiological perspective by J. Kaldor. Acta Oncol 31(1):65.1586507
*AEC. 1966. I-129 as a geochemical and ecological tracer. U.S. Atomic Energy Commission. Pittsburgh, PA: Carnegie Institute of Technology. Report No. NYO-3624-1.
*AEC. 1968. Fission product inhalation program annual report 1967-1968. Lovelace Foundation for Medical Education and Research for U.S. Atomic Energy Commission. LF-39, UC-48.
AEC. 1970. Medical survey of the people of Rongelap and Utirik Islands thirteen, fourteen, and fifteen years after exposure to fallout radiation (March 1967, March 1968, and March 1969). Brookhaven National Laboratory for U.S. Atomic Energy Commission. BNL 50220 (T-562).
*AEC. 1974. U.S. Atomic Energy Commission. Environmental behavior and radiation doses from iodine-129. BNWL-SA-4879.
AECB. 1986. Transfer of radionuclides from the environment to human milk - A review. Ottawa, Canada: Atomic Energy Control Board. INFO-0192. NTIS DE 88705117.
AECB. 1994. Radioactive emission data from Canadian nuclear generating stations 1972 to 1992. Ottawa, Canada: Atomic Energy Control Board. INFO-0210(e) Rev-5. NTIS MIC-95-00188.
AECL. 1994. Atomic Energy of Canada, Ltd. Review and assessment of methods for the measurement and speciation of iodine in fresh water. NTIS PB95-160487.
Agbunag R. 2001. Preoperative vaginal preparation with povidone-iodine decreases the risk of post-cesarean endometritis. Am J Obstet Gynecol 184(1):S182.
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Federal Register 54(174):37618–37634.
*Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction, Atlanta, GA.
*Agency for Toxic Substances and Disease Registry. 1997. Toxicological Profile for Cyanide (Update). U.S. Department of Health and Human Services. Public Health Service.
*Agency for Toxic Substances and Disease Registry. 1999. Toxicological profile for ionizing radiation. Atlanta, GA.
*Agency for Toxic Substances and Disease Registry. 2000a. Hanford infant mortality and fetal death analysis 1940-1952. Atlanta, GA: U.S. Department of Health and Human Services. PB2000105892.
*Agency for Toxic Substances and Disease Registry. 2000b. Toxicological profile for polychlorinated biphenyls, Atlanta, GA.
Agerbaek H. 1974. Weight and iodine content of the thyroid gland in Jutland, Denmark [Letter]. Acta Med Scand 196:505.4456982
Aggett PJ. 1998. Neonatal trace element metabolism. In: Cowett RM, ed. Principles of perinatal-neonatal metabolism. New York, NY: Springer, 909–941.
*Aghini-Lombardi A, Antonangeli L, Martinon E, . 1999. The spectrum of thyroid disorders in an iodine-deficient community: The Pescopagano survey. J Clin Endocrinol Metab 84:561–566.10022416
Ahlgren L, Ivarsson S, Johansson L, . 1985. Excretion of radionuclides in human breast milk after the administration of radiopharmaceuticals. J Nucl Med 26:1085–1090.4032049
Ahmad AM, Ahmad M, Young ET. 2002. Objective estimates of the probability of developing hypothyroidism following radioactive iodine treatment of thyrotoxicosis. Eur J Endocrinol 146(6):767–775.12039696
*Ahmed M, Doe RP, Nuttall FQ. 1974. Triiodothyronine thyrotoxicosis following iodide ingestion: A case report. J Clin Endocrinol Metab 38:574–576.4820659
*Ahmed SR, Shalet SM. 1984. Radioactive iodine and testicular damage. N Engl J Med 311:1576.
*Ahmed SR, Shalet SM. 1985. Gonadal damage due to radioactive iodine (I^131^) treatment for thyroid carcinoma. Postgrad Med J 61:361–362.4022871
Ahn C-S, Rosenberg IN. 1968. Prompt stimulation of the organic binding of iodine in the thyroid by adenosine 3’,5’-phosphate in vivo. Proc Natl Acad Sci U S A 60(3):830–835.4299267
Ahn CS, Rosenberg IN. 1970. Iodine metabolism in thyroid slices: Effects of TSH, dibutyryl cyclic 3’,5’-AMP, NaF and prostaglandin E. Endocrinology 86:396–405.4311906
Ahnstrom G, Ehrenberg L, Hussain S, . 1970. On the killing and mutagenic action in e. coli associated with the Auger effect during ^125^I decay. Mutat Res 10:247–250.4250470
Ahren B, Rerup C. 1987. Kinetics of radioiodine released from prelabelled thyroid gland in vivo: Influence of propylthiouracil. Pharmacol Toxicol 61:69–71.3628185
Aiba M, Ninomiya J, Furuya K, . 1999. Induction of a critical elevation of povidone-iodine absorption in the treatment of a burn patient: Report of a case. Jpn J Surg 29:157–159.
Aii T, Kume A, Takahashi S, . 1990. The effect of the radionuclides from Chernobyl on iodine-131 and cesium-137 contents in milk and pastures in south-western Japan. Jpn J Zootech Sci 61(1):47–53.
Aizawa Y, Yoshida K, Kaise N, . 1997. The development of transient hypothyroidism after iodine-131 treatment in hyperthyroid patients with Graves’ disease: Prevalence, mechanism and prognosis. Clin Endocrinol 46:1–5.
*Akamizu T, Ikuyama S, Saji M, . 1990. Cloning, chromosomal assignment, and regulation of the rat thyrotropin receptor: Expression of the gene is regulated by thyrotropin, agents that increase cAMP levels, and thyroid autoantibodies. Proc Natl Acad Sci U S A 87:5677–5681.1696008
Akerib M. 1971. Iodine toxic to young animals. Worlds Poult Sci J 27(1):35–37.5547630
Akleyev AV. 1996. Experience with the studies of medical and biological effects of radiation incidents in the south Urals. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, the Netherlands: Elsevier, 117–126.
Aktay R, Rezai K, Seabold JE, . 1996. Four- to twenty-four hour uptake ratio: An index of rapid iodine-131 turnover in hyperthyroidism. J Nucl Med 37:1815–1819.8917181
Albinsson Y, Engkvist I. 1989. Diffusion of americium, plutonium, uranium, neptunium, cesium, iodine and technetium in compacted sand-bentonite mixture. Chalmers University of Technology, Department of Nuclear Chemistry, Goeteborg, Sweden. SKB Tech. Rep. 89-22.
Albinsson Y, Engkvist I. 1991. Diffusion of Am, Pu, U, Np, Cs, I and Tc in compacted sand-bentonite mixture. Radioact Waste Manage Nucl Fuel Cycle 15(4):221–239.
Albrecht HH, Creutzig H. 1976. [Salivary gland scintigraphy after radio-iodine therapy. Functional scintigraphy of the salivary gland after high dose radio-iodine therapy (author’s translation).] Fortschr Geb Rontgenstrahlen Nuklearmed Erganzungsbd 125(6):546–551. (German)
Alexander C, Bader JB, Schaefer A, . 1998. Intermediate and long-term side effects of high-dose radioiodine therapy for thyroid carcinoma. J Nucl Med 39:1551–1554.9744341
*Alexandrides T, Georgopoulos N, Yarmenitis S, . 2000. Increased sensitivity to the inhibitory effect of excess iodide on thyroid function in patients with beta-thalassemia major and iron overload and the subsequent development of hypothyroidism. Eur J Endocrinol 143(3):319–325.11022172
*Allegrini M, Pennington JAT, Tanner JT. 1983. Total diet study: Determination of iodine intake by neutron activation analysis. J Amer Diet Assoc 83:18–24.6863778
Allen EM. 1993. Acute iodine ingestion increases intrathyroidal glutathione. J Endocrinol Invest 16:265–270.7685786
*Allen EM, Braverman LE. 1990. The effect of iodine on lymphocytic thyroiditis in the thymectomized Buffalo rat. Endocrinology 127(4):1613–1616.2401228
*Allen EM, Appel MC, Braverman LE. 1986. The effect of iodide ingestion on the development of spontaneous lymphocytic thyroiditis in the diabetes-prone BB/W rat. Endocrinology 118(5):1977–1981.3754509
Allen EM, Appel MC, Braverman LE. 1987. Iodine-induced thyroiditis and hypothyroidism in the hemithyroidectomized BB/W rat. Endocrinology 121:481–485.3595527
*Allweiss P, Braunstein GD, Katz A, . 1984. Sialadenitis following I-131 therapy for thyroid carcinoma: Concise communication. J Nucl Med 25:755–758.6737074
Al-Rashood KA, Hagga MEM, Al-Khamees HA, . 1995. Differential pulse polarographic and spectrophotometric methods for the determination of trace amounts of iodide in Saudi waters. Saudi Pharm J 3(4):181–187.
Als C, Helbling A, Peter K, . 2000a Urinary iodine concentration follows a circadian rhythm: A study with 3023 spot urine samples in adults and children. J Clin Endocrinol Metab 85(4):1367–1369.10770167
Als C, Keller A, Minder C, . 2000b Age- and gender-dependent urinary iodine concentrations in an area-covering population sample from the Bernese region in Switzerland. Eur J Endocrinol 143(5):629–637.11078987
*Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Alvarez E. 1979. Neutropenia in a burned patient being treated topically with povidone-iodine foam. Plast Reconstr Surg 63(6):839–840.441200
Amdur MO. 1978. Respiratory response to iodine vapor alone and with sodium chloride aerosol. J Toxicol Environ Health 4:619–630.682211
Amiro BD, Sheppard SC, Johnston FL, . 1996. Burning radionuclide question: What happens to iodine, cesium and chlorine in biomass fires? Sci Total Environ 187:93–103.8766727
Ammerman CB, Miller SM, Fick KR, . 1977. Contaminating elements in mineral supplements and their potential toxicity: A review. J Anim Sci 44(3):485–538.321409
Amphoux-Fazekas T, Samih N, Hovsepian S, . 1998. DIDS (4,4’-diisothiocyanatostilbene-2,2’-disulfonic acid) increases iodide trapping, inhibits thyroperoxidase and antagonizes the TSH-induced apical iodide efflux in porcine thyroid cells. Mol Cell Endocrinol 141:129–140.9723894
Amvrosiev AP, Banetskaya NY. 1992. [Early and long-term effects of the combined action of iodine-131 and cesium-137 at low doses on ovaries of animals.] Dokl Akad Nauk Belarusi 36(9–10):855–858. (Russian)
Amvros’ev AP, Vereshchako GG, Redrov AG. 1991. [Analysis of the effect of iodine-131 on the cytochemical activity of peripheral blood lymphocyte hydroxyreductases in rats.] Gig Sanit 7:53–55. (Russian)
Anders E. 1962. Minimal dosage of iodide required to suppress uptake of iodine-131 by normal thyroid. Science 138:430–433.13986973
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Andersen S, Pedersen KM, Pedersen IB, . 2001. Variations in urinary iodine excretion and thyroid function. A 1-year study in health men. Eur J Endocrinol 144(5):461–465.11331211
Anderson DM, Marsh TL, Deonigi DA. 1996a. Developing historical food production and consumption data for ^131^I dose estimates: The Hanford experience. Health Phys 71(4):578–587.8830758
Anderson GS, Bird T. 1961. Congenital iodide goitre in twins. Lancet 2:742–743.13861227
*Anderson KA, Casey B, Diaz E, . 1996b. Speciation and determination of dissolved iodide and iodine in environmental aqueous samples by inductively coupled plasma atomic emission spectrometry. J AOAC Int 79(3):751–756.
Anderson LL, Lau CC, Gracely EJ, . 1997. Enhancement of ^131^I-mediated cytotoxicity by caffeine. Gynecol Oncol 65:253–257.9159334
*Anderson TJ. 1978. Methodology for the determination of environmental ^129^I and ^99^Tc. Savannah River Laboratory, Aiken, SC. NTIS: DP-MS-77-75 (Conf 780719-2).
*Andersson S, Forsman U. 1997. Determination of total iodine in biological material by alkaline ashing and column-switching ion-pair liquid chromatography. J Chromatogr B Biomed Appl 692:53–59.
Andreyeva LP, Shvedov VL. 1977. [Changes in the rat hemopoietic system when exposed to Strontium 89 and Iodine 131 simultaneously.] Radiobiologia 17(5):752–757. (Russian)
*Andros G, Wollman SH. 1991. Kinetics of equilibration of radionuclide in individual mouse thyroid follices in vivo. Am J Physiol 261(24):E529–E538.1928343
Anno Y, Sasaki T, Takeshita A, . 1975. Incidence of hypothyroidism after radioiodine treatment of hyperthyroidism: A report of the radioiodine therapy follow-up study. Nippon Igaku Hoshasen Gakkai Zasshi 35(7):545–555.1061051
Anokhin IN, Norets TA. 1986. [Disorders of immunologic homeostasis as affected by radioactive iodine preparation.] Med Radiol 31(11):55–58. (Russian)
Anonymous. 1980. Radioactive iodine and the risk of malignant thyroid tumour. N Z Med J 92:386–387.6937766
Anonymous. 1987. Studies evaluate medical responses to nuclear accidents, question use of potassium iodide. Am J Hosp Pharm 44:2651–2652.
Anonymous. 1991. Nuclear accident countermeasures: Iodine prophylaxsis. Rep Health Soc Subj (Lond) 39:1–63.1924993
Anonymous. 1994. Comparison of radionuclide levels in soil, sagebrush, plant litter, cryptogams, and small mammals. Westinghourse Hanford Co., Richland, WA. NTIS DE95001629.
Anonymous. 1997. Chemical mixture. Environ Health Perspect Suppl 105(1):371–372.
Ansell JE. 1996a. The blood in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 821–825.
Ansell JE. 1996b. The blood in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 637–644.
Antonangeli L, Maccherini D, Cavaliere R, . 2002. Comparison of two different doses of iodine in the prevention of gestational goiter in marginal iodine deficiency: A longitudinal study. Eur J Endocrinol 147(1):29–34.12088916
*AOAC. 1984. Official methods of analysis, 14^th^ ed. Association of Official Analytical Chemists. Arlington, VA.
APHS. 1998. Standard methods for the examination of water and waste water, 20^th^ ed. American Public Health Association. Washington, DC.
Appell R, Tsangaris N, Spiegel J. 1978. Radioiodine treated hyperthyroidism and thyroid carcinoma. Am Surg 44:537–540.707910
Ardawi MSM, Nasrat HA, Mustafa BE. 2002. Urinary iodine excretion and maternal thyroid function. Saudi Medicine 23(4):413–422.
*Ardito G, Lamberti L, Bigatti P, . 1987. Comparison of chromosome aberration frequency before and after administration of ^131^I in two groups of thyroid cancer patients. Tumori 73:257–262.3603721
Ardito G, Lamberti L, Bigatti MP. 1988. Chromosome studies on human lymphocytes following treatment with radioactive iodine in vitro. Boll Soc Ital Biol Sper 2(LXIV):131–138.
Ardito G, Lamberti L, Cottino F, . 1983. Analysis of cell kinetics, chromosome aberration frequency and sister chromatid exchanges in lymphocyte “in vitro” cultures of patients irradiated by ^131^I. Preliminary note. Boll Soc Ital Biol Sper 59(2):135–141.6860485
Arena Ansotegui J, Emparanza Knorr JI, San Millan Vege MJ, . 1989. [Iodine overload in newborn infants caused by the use of PVP-iodine for perineal preparation of the mother in vaginal delivery.] An Esp Pediatr 30(1):23–26. (Spanish)2648916
Arndt D, Mehnert WH, Franke W-G, . 1994. Radioiodine therapy during an unknown remained pregnancy and radiation exposure of the fetus. Strahlenther Onkol 170(7):408–414.8052940
Arrington LR, Taylor RN, Ammerman CB, . 1965. Effects of excess dietary iodine upon rabbits, hamsters, rats and swine. J Nutr 87:394–398.5841855
Arslan NC, Geard CR, Hall EJ. 1986. Low dose-rate effects of cesium-137 and iodine-125 on cell survival, cell progression, and chromosomal alterations. Am J Clin Oncol 9(2):114–115.
Artemova EP, Nikolaev AI. 1976. [Congenital disorders of the thyroid gland in experimental litters obtained from mothers subjected to immunization and the action of I-131.] Probl Endokrinol (Mosk) 22(2):66–70. (Russian)
Arthur JR. 1999. Functional indicators of iodine and selenium status. Proc Nutr Soc 58:507–512.10466196
*Arthur JR, Beckett GF. 1994. Roles of selenium in Type I iodothyronine 5’-deiodinase and in thyroid hormone and iodine metabolism. In: Burk RF, ed. Selenium in biology and human health. New York, NY: Springer-Verlag, 94–115.
Arthur JR, Nicol F, Beckett GJ. 1992a. The role of selenium in thyroid hormone metabolism and effects of selenium deficiency on thyroid hormone and iodine metabolism. Biol Trace Elem Res 34:321–325.1384621
Arthur JR, Nicol F, Beckett GJ. 1992b. The role of selenium in thyroid hormone metabolism and effects of selenium on thyroid hormone and iodine metabolism. Biol Trace Elem Res 33:37–42.1379458
Asmis LM, Gerber H, Kaempf J, . 1995. Epidermal growth factor stimulates cell proliferation and inhibits iodide uptake of FRTL-5 cells in vitro. J Endocrinol 145:513–520.7636435
Assimakopoulos PA, Ioannides KG, Pakou AA, . 1987. Transport of the radioisotopes iodine-131, cesium-134, and cesium-137 from the fallout following the accident at the Chernobyl nuclear reactor into cheese and other cheesemaking products. J Dairy Sci 70:1338–1343.3624589
Assimakopoulos PA, Ioannides KG, Pakou AA. 1988. The environmental behavior of ^131^I in northwestern Greece following the nuclear reactor accident at Chernobyl. Health Phys 55(5):783–791.3182283
Assimakopoulos PA, Ioannides KG, Pakou AA. 1989. The propagation of the Chernobyl ^131^I impulse through the air-grass-animal-milk pathway in northwestern Greece. Sci Total Environ 85:295–305.2814459
*Astakhova LN, Anspaugh LR, Beebe GW, . 1998. Chernobyl-related thyroid cancer in children in Belarus: A case-control study. Rad Res 150:349–356.
*Astakhova LN, Mityukova TA, Kobzev VF. 1996. Endemic goiter in Belarus following the accident at the Chernobyl nuclear power plant. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, the Netherlands: Elsevier, 67–95.
*ASTM. 1995. Annual book of ASTM Standards. Vol. 11.02. American Society for Testing of Materials. Philadelphia, PA.
*ASTM. 1998. American Society for Testing and Materials. Standard test methods for iodide and bromide ions in brackish water, seawater, and brines. NTIS ASTM-D 3869-95, 338–344.
ASTM. 1999. Annual book of ASTM standards, vol. 11.02. American Society for Testing of Materials. Philadelphia, PA: ASTM, 290–300.
*ATF. 2001a. Denaturants authorized for denatured spirits. U.S. Bureau of Alcohol, Tobacco, and Firearms. Code of Federal Regulations. 27 CFR 21.151. http://frwebgate.access.gpo.gov/cgi. May 16, 2001.
*ATF. 2001b. Uses of specially denatured alcohol and specially denatured rum. U.S. Bureau of Alcohol, Tobacco, and Firearms. Code of Federal Regulations. 27 CFR 21.141. http://frwebgate.access.gpo.gov/cgi-bin. May 16, 2001.
Aungst BJ, Vesell ES, Shapiro JR. 1979. Unusual characteristics of the dose-dependent uptake of propylthiouracil by thyroid gland in vivo: Effects of thyrotropin, iodide or phenobarbital pretreatment. Biochem Pharmacol 28:1479–1484.475856
Austin AR, Whitehead DC, Le Du YLP, . 1980. The influence of dietary iodine on iodine in the blood serum of cows and calves in the perinatal period. Res Vet Sci 28:128–130.7375723
Ayala C, Navarro E, Rodriguez JR, . 1998. Conception after iodine-131 therapy for differentiated thyroid cancer. Thyroid 8(11):1009–1011.9848714
Ayromlooi J. 1972. Congenital goiter due to maternal ingestion of iodides. Obstet Gynecol 39(6):818–822.5068335
Babu S, Shenolikar I. 1992. Thiocyanate ingestion through milk and its effects on serum triiodothyronine (T_3_) and thyroxine (T_4_) levels in monkeys fed low iodine diet. Indian J Dairy Sci 45(6):326–329.
*Bacher-Stier C, Riccabona G, Totsch M, . 1997. Incidence and clinical characteristics of thyroid carcinoma after iodine prophylaxis in an endemic goiter country. Thyroid 7(5):733–741.9349576
*Bachrach LK, Burrow GN, Gare DJ. 1984. Maternal-fetal absorption of povidone-iodine. J Pediatr 104(1):158–159.
Backer H, Hollowell J. 2000. Use of iodine for water disinfection: Iodine toxicity and maximum recommended dose. Environ Health Perspect 108(8):679–684.10964787
Bagchi N, Brown TR. 1986. Adaptation of male and female rats to iodine deficiency. Horm Metab Res 18:811–813.3817747
*Bagchi N, Fawcett DM. 1973. Role of sodium ion in active transport of iodide by cultured thyroid cells. Biochim Biophys Acta 318:235–251.4795651
*Bagchi N, Brown TR, Urdanivia E, . 1985a. Induction of autoimmune thyroiditis in chickens by dietary iodine. Science 230:325–327.4048936
Bagchi N, Shivers B, Brown TR. 1985b. Studies on the mechanism of acute inhibition of thyroglobulin hydrolysis by iodine. Acta Endocrinol 108:511–517.
*Bair WJ, Snyder MD, Walters RA, . 1963. Effect of I^127^ on thyroid uptake of inhaled I^131^. Health Phys 9:1399–1410.14090704
Bairakova A, Nikolova M, Kiradzhiev G. 1990. [Side-effects of iodine prophylaxis in pregnancy.] Rentgenol Radiol 29(2):46–50. (Russian)
Baker HJ, Lindsey JR. 1968. Equine goiter due to excess dietary iodide. J Am Vet Med Assoc 153(12):1618–1630.4177826
*Bakheet SMB, Hammami MM, Hemidan A, . 1998. Radioiodine secretion in tears. J Nucl Med 39(8):1452–1454.9708527
Bakheet SMB, Hammami MM, Powe J. 1996. False-positive radioiodine uptake in the abdomen and the pelvis: Radioiodine retention in the kidneys and review of the literature. Clin Nucl Med 21(12):932–937.8957606
*Bakiri F, Djemli FK, Mokrane LA, . 1998. The relative roles of endemic goiter and socioeconomic developmental status in the prognosis of thyroid carcinoma. Cancer 82:1146–1153.9506362
Bal CS, Padhy AK, Jana S, . 1994. Comparison of low and high dose I-131 ablation of remnant in differentiated thyroid cancer patients. In: Proceedings of the XVI International Cancer Congress: Free papers and posters: New Delhi (India), October 30-November 5, 1994. Bologna, Italy: Monduzzi Editore, 1059–1063.
Bal CS, Padhy AK, Jana S, . 1996. Prospective randomized clinical trial to evaluate the optimal dose of ^131^I for remnant ablation in patients with differentiated thyroid carcinoma. Cancer 77:2574–2580.8640708
Ball DW, Baylin SB, de Bustros AC. 1996. Medullary thyroid carcinoma. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 946–960.
*Ballad RV, Holman DW, Hennecke EW, . 1976. Iodine-129 in thyroids of grazing animals. Health Phys 30:345–350.1254491
*Ballad RV, Tan SH, Johnson JE, . 1978. Iodine-129 in man, cow and deer. Health Phys 34:691–696.730521
*Ballardin M, Gemignani F, Bodei L, . 2002. Formation of micronuclei and of clastogenic factor(s) in patients receiving therapeutic doses of iodine-131. Mutat Res 514(1–2):77–85.11815246
*Balonov MI, Krisyuk EM, Ramel C. 1999. Environmental radioactivity, population exposure and related health risks in the east Baltic region. Scand J Work Environ Health 25:17–32.
Balsam A, Sexton F, Borges M, . 1983. Formation of diiodotyrosine from thyroxine. J Clin Invest 72:1234–1245.6630509
Balter M. 1995. Chernobyl’s thyroid cancer toll. Science 270:1758–1759.8525362
*Baltisberger BL, Minder CE, Burgi H. 1995. Decrease of incidence of toxic nodular goitre in a region of Switzerland after full correction of mild iodine deficiency. Eur J Endocrinol 132:546–549.7749493
Baltrukiewicz Z, Derecki J, Pogorzelska-Lis M. 1973. Transfer of selected radionuclides from the organism of pregnant and feeding female rat to the offsprings. Acta Physiol Pol 24:437–444.4712411
Banerjee R, Gopinath G, Gopinath PG. 1988. Vascular changes in the brain following internally administered radioiosotope^131^-I in rats during postnatal period. Indian J Med Res 87:484–493.3169905
Banfield WG, Grimley PM, Hammond WG, . 1971. Electron probe analysis for iodine in human thyroid and parathyroid glands, normal and neoplastic. J Natl Cancer Inst 46:269–273.4940240
Bangming R, Jianguo L, Xianyu C, . 1996. [Study of thyroglobulin gene activity in thyroid disease.] Zhonghua Heyixue Zazhi 16(4):250–252. (Chinese)
*Barakat M, Carson D, Hetherton AM, . 1994. Hypothyroidism secondary to topical iodine treatment in infants with spina bifida. Acta Paediatr 83:741–743.7949805
Baran DT. 1996a. The skeletal system in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 853–857.
Baran DT. 1996b. The skeletal system in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 678–686.
*Baratta EJ, Esterly DG. 1989. Gamma-ray spectroscopic determination of iodine-131 and cesium-137 in foods: Two collaborative studies. J Assoc Off Anal Chem 72(4):667–669.2759997
*Barker SB. 1948. Determination of protein-bound iodine. J Biol Chem 173:715–724.18910726
*Barkley RA, Thompson TG. 1960. Determination of chemically combined iodine in sea water by amperometric and catalytic methods. Anal Chem 32:154–158l.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barnes ND, O’Connell EJ, Cloutier MD. 1975. Iodide-induced (SSKI) hypothyroidism in infancy. Ann Allergy 35:305–308.1242621
*Barrie LA, Hoff RM. 1985. Five years of air chemistry observations in the Canadian Arctic. Atmos Environ 19:1995–2010.
Barrington SF, Kettle AG, O’Doherty MJ, . 1996. Radiation dose rates from patients receiving iodine-131 therapy for carcinoma of the thyroid. Eur J Nucl Med 23(2):123–130.8925845
*Barrington SF, O’Doherty MJ, Kettle AG, . 1999. Radiation exposure of the families of outpatients treated with radioiodine (iodine-131) for hyperthyroidism. Eur J Nucl Med 26(7):686–692.10398815
Barsano CP. 1996. Other forms of hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 768–778.
Bartalena L, Bogazzi F, Martino E. 1996. Adverse effects of thyroid hormone preparations and antithyroid drugs. Drug Saf 15:53–63.8862963
Bartalena L, Marcocci C, Bogazzi F, . 1989. Use of corticosteroids to prevent progression of Graves’ ophthalmopathy after radioiodine therapy for hyperthyroidism. N Engl J Med 321(20):1349–1352.2811943
Bartalena L, Marcocci C, Bogazzi F, . 1998. Relation between therapy for hyperthyroidism and the course of Graves’ ophthalmopathy. N Engl J Med 338(2):73–78.9420337
*Bartolini P, Ribela MTCP, Araujo EA. 1988. Results of a thyroid monitoring survey carried out on workers exposed to ^125^I in Sao Paulo, Brazil. Health Phys 55(3):511–515.3170204
*Bašič M, Kasal B, Simonovic I, . 1988. ^131^I dose to the human fetal thyroid in the Zagreb district, Yugoslavia, from the Chernobyl accident. Int J Radiat Biol 54(2):167–177.2900274
Bastiani P, Papandreou J, Blanck O, . 1995. On the relationship between completion of N-acetyllactosamine oligosassharide units and iodine content of thyroglobulin: A reinvestigation. Endocrinology 136(10):4204–4209.7664637
*Baugnet-Mahieu L, Lemaire M, Leonard ED, . 1994. Chromosome aberrations after treatment with radioactive iodine for thyroid cancer. Radiat Res 140:429–431.7972697
*Baumgartner TG. 1976. Potassium iodide and iododerma. Am J Hosp Pharm 33:601–603.1274978
Bautista A, Barker PA, Dunn JT, . 1982. The effects of oral iodized oil on intelligence, thyroid status, and somatic growth in school-age children from an area of endemic goiter. Am J Clin Nutr 35:127–134.6278919
Baverstock KF. 1993. Thyroid cancer in children in Belarus after Chernobyl. World Health Stat Q 46:204–208.8017079
Bayliff CD, Sibbald WJ, Mills DG, . 1981. Electrolyte abnormalities following povidone-iodine topical therapy. Drug Intell Clin Pharm 15(10):801–802.7285801
Bazyltchik SV, Astakhova LN. 1996. Mental development of children exposed to ionizing radiation in utero and in infancy. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, the Netherlands: Elsevier, 97–102.
Beach SA, Dolphin GW. 1962. A study of the relationship between x-ray dose delivered to the thyroids of children and the subsequent development of malignant tumours. Phys Med Biol 6:583–598.
*Beals DM, Hayes DW. 1995. Technetium-99, iodine-129 and tritium in the waters of the Savannah river site. Sci Total Environ 173/174:101–115.8560219
*Beals DM, Chastagner P, Turner P. 1992. Analysis of iodine-129 in aqueous samples by inductively coupled plasma-mass spectrometry. Westinghouse Savannah River Company, Aiken, SC. NTIS DE93002694.
Beaugelin-Seiller K, Baudin JP, Brottet D. 1994. Use of aquatic mosses for monitoring artificial radionuclides downstream of the nuclear power plant of Bugey (River Rhone, France). J Environ Radioact 24:217–223.
Becciolini A, Porciani S, Lanini A, . 1994. Serum amylase and tissue polypeptide antigen as biochemical indicators of salivary gland injury during iodine-131 therapy. Eur J Nucl Med 21:1121–1125.7828622
Bech K. 1988. Importance of cytolytic activity and dietary iodine in the pathogenesis of postpartum thyroiditis. Allergy 43:161–166.
Becker BA. 1961. Iodide transport by the rabbit eye. Am J Physiol 200(4):804–806.13688429
Becker BA, Fenves AZ, Breslau NA. 1999. Membranous glomerulonephritis associated with Grave’s disease. Am J Kidney Dis 33(2):369–373.10023652
Becker DV. 1979. The role of radioiodine treatment in childhood hyperthyroidism. J Nucl Med 20(8):890–894.396368
Becker DV. 1983. Physiological basis for the use of potassium iodide as a thyroid blocking agent logistic issues in its distribution. Bull N Y Acad Med 59(10):1003–1008.6582961
Becker DV. 1987. Reactor accidents: Public health strategies and their medical implications. JAMA 258:649–654.3612987
Becker DV, Zanzonico P. 1997. Potassium iodide for thyroid blockade in a reactor accident: Administrative policies that govern its use. Thyroid 7(2):193–197.9133683
Becker DV, Braverman LE, Dunn JT, . 1984. The use of iodine as a thyroidal blocking agent in the event of a reactor accident: Report of the Environmental Hazards Committee of the American Thyroid Association. JAMA 252(5):659–661.6737670
Becker PC, Ibanez CA, Aguayo JB, . 1986. [Absence of foetal hypothyroidism despite treatment with ^131^I during gestation.] Rev Med Chil 114:343–345. (Spanish)3809807
Becker W, Borner W, Reiners C, . 1988. [Radioiodine therapy for immune hyperthyroidism depending on age. A tenable risk even for younger patients?]. Dtsch Med Wochenschr 113(23):954–961. (German)2454185
Beckham W, Ralson A. 1991. Letters to the editor. Australas Phys Eng Sci Med 14(3):173.1953505
Becks GP, Eggo MC, Burrow GN. 1987. Regulation of differentiated thyroid function by iodide: Preferential inhibitory effect of excess iodide on thyroid hormone secretion in sheep thyroid cell cultures. Endocrinology 120(6):2569–2575.3569143
Bednar J, Nemec J, Soutorova M, . 1980. Composition of circulating iodoproteins following therapeutic application of ^131^I for thyroid carcinoma. Radiochem Radioanal Lett 45(6):377–386.
Bednarczuk T, Kennerdell JS, Wall JR. 1997. Thyroid-associated ophthalmopathy: Etiology and pathogenesis. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 341–357.
Beekhuis H, Piers DA. 1983. Radiation risk of thyroid scintigraphy in newborns. Eur J Nucl Med 8:348–350.6311557
Beere HM, Bidey SP, Tomlinson S. 1989. Cytotoxicity of high iodide levels for porcine thyroid cells in primary culture is relieved by methimazole or stable cylic AMP analogues. J Endocrinol 121(Suppl):No pagination.
Beere HM, Cowin AJ, Soden J, . 1995. Iodide-dependent regulation of thyroid follicular cell proliferation: A mediating role of autocrine insulin-like growth factor-I. Growth Regul 5:203–209.8745146
Beere HM, Tomlinson S, Bidey SP. 1990. Iodide autoregulation of functional and morphological differentiation events in the FRTL-5 rat thyroid cell strain. J Endocrinol 124:19–25.2153747
Beeson KC, Forbes AL, Horvath DJ, . 1978. Plants and foods of plant origin. In: Geochemistry and the environment. Vol. III. Distribution of trace elements related to the occurrence of certain cancers, cardiovascular diseases and urolithiasis. Washington, DC: National Academy of Sciences, 59–78.
Beeson PB. 1994. Effects of iodides on inflammatory processes. Perspect Biol Med 37(2):173–181.8139884
Begishev A. 1975. [Data on the toxicity characteristics of iodine vapors under conditions of increased air temperature (experimental data).] Gig Tr Prof Zabol 6:38–41. (Russian)
*Behne D, Kyriakopoulos A. 1993. Effects of dietary selenium on the tissue concentrations of type I iodothyronine 5’-deiodinase and other selenoproteins. Am J Clin Nutr Suppl 57:310S–312S.8427210
*Beierwaltes WH. 1979. The history of the use of radioactive iodine. Semin Nucl Med IX(3):151–155.
Beierwaltes WH, Crane HR, Wegst A, . 1960. Radioactive iodine concentration in the fetal human thyroid gland from fall-out. JAMA 173(17):1895–1902.13798327
*Beierwaltes WH, Hilger MTJ, Wegst A. 1963. Radioiodine concentration in fetal human thyroid from fallout. Health Phys 9:1263–1266.14086672
BEIR V. 1990. Health effects of exposure to low levels of ionizing radiation. Biological Effects of Ionizing Radiations. Washington, DC: National Academy Press.
*Belfiore A, La Rosa GL, Padova G, . 1987. The frequency of cold thyroid nodules and thyroid malignancies in patients from an iodine-deficient area. Cancer 60:3096–3102.3677033
Bellisola G, Bratter P, Cinque G, . 1998. The TSH-dependent variation of the essential elements iodine, selenium and zinc within human thyroid tissues. J Trace Elem Med Biol 12:177–182.9857330
*Beno M, Hrabovcova A, Piknova D, . 1991. Human postmortem thyroid ^131^I content and risk estimates in Bratislava, Czechoslovakia following the Chernobyl accident. Health Phys 60(2):203–208.1989942
*Beno M, Mikulecky M, Hrabina J. 1992. Transfer factor of ^131^I from the fallout to human thyroid dose equivalent after the Chernobyl accident. Radiat Environ Biophys 31:133–139.1609058
*Benotti J, Benotti N. 1963. Protein-bound iodine, total iodine and butanol-extractable iodine by partial automation. Clin Chem 9:408–416.
*Benotti J, Benotti N, Pino S, . 1965. Determination of total iodine in urine, stool, diets and tissues. Clin Chem 11:932–936.5837839
Benson SG. 1969. Kinetics of I^131^ uptake and release in the rat thyroid gland. Ph.D. Dissertation, The University of Nebraska, 70.
Bercz JP. 1991. Endocrine toxicity of drinking water disinfectants. I. In vivo dehalogenation and clearance of iodinated nutrients. J Am Coll Toxicol 10(5):525–532.
Bercz JP, Jones LL, Harrington RM, . 1986. Mechanistic aspects of ingested chlorine dioxide on thyroid function: Impact of oxidants on iodide metabolism. Environ Health Perspect 69:249–255.3816729
Berenbaum MC. 1974. The production of pulmonary oedema in mice by cyclophosphamide and iodide. Agents Actions 4(1):7–14.
Beresford NA, Mayes RW, Barnett CL, . 1997. The effectiveness of oral administration of potassium iodide to lactating goats in reducing the transfer of radioiodine to milk. J Environ Radioact 35(2):115–128.
*Berg D, Kollmer WE, Kriegel H, . 1987. Radioactive iodine and cesium in Bavarian citizens after the nuclear reactor accident in Chernobyl. Trace Subst Environ Health 21:219–225.
Berg GEB, Michanek AMK, Holmberg ECV, . 1996. Iodine-131 treatment of hyperthyroidism: Significance of effective half-life measurements. J Nucl Med 37(2):229–232.
Berg GEB, Nystrom EH, Jacobsson L, . 1998. Radioiodine treatment of hyperthyroidism in a pregnant woman. J Nucl Med 39:357–361.9476950
Berg JN, Padgitt D. 1985. Iodine concentrations in milk from iodophor test dips. J Dairy Sci 68:457–461.3989086
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
*Berkovski V. 1999a. Radioiodine biokinetics. Part 1. Pregnant woman. In: Radiation and thyroid cancer. National Research Council, Canada, 319–325.
*Berkovski V. 1999b. Radiation biokinetics in the mother and fetus. Part 2. Fetus. In: Radiation and thyroid cancer. National Research Council, Canada, 327–332.
*Berkovski V. 2002. New iodine models family for simulation of short-term biokinetics processes, pregnancy and lactation. Food and Nutrition Bulletin 23(3):87–94.12362821
*Bermejo-Barrera P, Moreda-Pineiro A, Aboal-Somoza M, . 1994. Indirect determination of iodide, as an Hg_x_I_x_ complex, by electrothermal atomic absorption spectrometry. J Anal Atom Spectrom 9:483–487.
*Bernard JD, McDonald RA, Nesmith JA. 1970. New normal ranges for the radioiodine uptake study. J Nucl Med 11:449–451.4193901
Bernhard JD, Freedberg IM, Vogel LN. 1996a. The skin in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 792–795.
Bernhard JD, Freedberg IM, Vogel LN. 1996b. The skin in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 595–597.
*Bertelsen JB, Hegedus L. 1994. Cigarette smoking and the thyroid. Thyroid 4:327.7833671
Berthezene F, Greer MA. 1974. Studies on the composition of the thyroid psammoma bodies of chronically iodine-deficient rats. Endocrinology 95:651–659.4605169
Berthezene F, Mornex R. 1971. Variations chez le rat de la clearance thyroidienne de l’iode (CIT), du taux d’iodure plasmatique (PII) et de la captation absolue de l’iode stable (AUI) apres l’arret d’un traitement par le methylthiouracil (MTU). Pathol Biol 23–24:1075–1079.
Berthier C, Lemarchand-Beraud T. 1976. Thyroid cAMP and iodine, plasma and pituitary TSH during goiter development in rats. Excerpta Medica 378:485–489.
Berthier C, Lemarchand-Beraud T. 1978. Importance of thyroid iodine and cyclic AMP and TSH concentrations on goitre formation in rats. Acta Endocrinol 89:567–579.
Bertin M, Lallemand J, Hubert D. 1994. [Health consequences of a Chernobyl accident. An assessment eight years later.] Lyon Pharm 45(1):9–16. (French)
*Bertine KK, Goldberg ED. 1971. Fossil fuel combustion and the major sedimentary cycle. Science 173:233–235.17741418
Best JD, Chan V, Khoo R, . 1981. Incidence of hypothyroidism after radioactive iodine therapy for thyrotoxicosis in Hong Kong Chinese. Clin Radiol 32:57–61.7214823
Bestano M, Pagliaini R, Maira G, . 1993. Mediastinal uptake of 131-I in patients with thyroid cancer: May it be referred to normal thymus? Eur J Nucl Med 20:648.8267738
Bethell MF. 1970. Toxic psychosis caused by radioactive iodine [Letter]. Br J Psychiatry 117:473–479.5481210
*Better OS, Garty J, Brautbar N, . 1969. Diminished functional parathyroid reserver following I^131^ treatment for hyperthyroidism. Isr J Med Sci 5(3):419–422.5821829
*Beyer KH, Fehr DM, Gelarden RT, . 1981. Hydrochlorothiazide-induced ^131^I excretion facilitated by salt and water. J Clin Pharmacol 21(5–6):201–212.7263913
Beyssen ML, Lagorce JF, Cledat D, . 1999. Influence of dietary iodine on drug-induced hypothyroidism in the rat. J Pharm Pharmacol 51:745–750.10454054
Bhat IS, Kamath PR. 1969. Goat thyroids as indicators for routine environmental monitoring of radioiodine. Health Phys 16:65–67.5766059
*Bhat IS, Hedge AG, Chandramouli S, . 1973. Evaluation of internal exposure to radionuclides of I, Cs, and Co during maintenance operations on primary steam leak in a nuclear power station. Health Physics 25:135–139.4206136
Bhatt H. 1977. Effect of calcium intake on thyroid and renal clearance of iodine in goiter. J Physiol 269:64–65.
Bhatta KM, Evenstad KL. 1994. Use of potassium iodide for the treatment of symptomatic benign hyperplasia. (to Upsher-Smith Laboratories) Application: USA WO 94/25040, 10 Nov 1994. USA Patent WO 94/25040, issued 10 Nov 1994.
Bianco AC, Nunes MT, Martins EJ, . 1981. Possible mechanism of action of cholesterol enriched diet on the thyroid. Endocrinol Exp 15:277–285.6976263
*Bichsel Y, Vongunten U. 1999. Oxidation of iodine and hypoiodous acid in the disinfection of natural waters. Environ Sci Technol 33:4040–4045.
*Bidart JM, Lacroix L, Evain-Brion D, . 2000. Expression of Na^+^/I^−^ symporter and Pendred syndrome genes in trophoblast cells. J Clin Endocrinol Metab 85(11):4367–4372.11095481
Birnbaum DA. 1978. Febrile response to whirlpool bath treatments [Letter]. JAMA 239(12):1133.
Bishop ME, Garcia RL. 1978. Iododerma from wound irrigation with povidone-iodine. JAMA 240(3):249–250.351226
Bitton R, Sachmechi I, Benegalro Y, . 1993. Leukemia after a small dose of radioiodine for metastatic thyroid cancer. J Clin Endocrinol Metab 77(5):1423–1426.8077344
*Black A, Hounam RF. 1968. Penetration of iodine vapour through the nose and mouth and the clearance and metabolism of the deposited iodine. Ann Occup Hyg 11:209–225.
Black JA. 1963. Neonatal goitre and mental deficiency: The role of iodides taken during pregnancy. Arch Dis Child 38:526–529.14065998
*Black SC, Douglas RL, Barth DS. 1976. Gaseous radioiodine transport in the air-forage-cow-milk system. US Environmental Protection Agency, Las Vegas, NV. Report No. EMLS-LV-539-1, 1–25.
Blackwell N, Stevenson AC, Wiernik G. 1974. Chromosomal findings in patients treated with small doses of iodine-131. Mutat Res 25:397–402.4437576
Blahos J, Soumar J. 1973. [Increased frequency of hypothyroidism after iodine 131. Longitudinal study.] Probl Acutels Endocrinol Nutr 17:95–103. (French)
Blahos J, Soumar J. 1975. The role of age in the development of hypothyroidism after treatment with radioiodine. Endokrinologie 64(2):196–200.1149693
*Bleuer JP, Averkin YI, Abelin T. 1997. Chernobyl-related thyroid cancer: What evidence for role of short-lived iodines? Environ Health Perspect Suppl 105(6):1483–1486.9467068
Blincoe C, Bohman VR. 1991. Fallout ^131^I in western Nevada cattle thyroid glands: 1962-Early 1969. Bull Environ Contam Toxicol 47:485–490.1786430
Blomgren H, Wasserman J, Petrini B, . 1991. Blood lymphocyte population following ^131^I treatment for hyperthyroid. Acta Endocrinol 124:152–158.
Bloomer WD, Adelstein SJ. 1981. Iodine-125 cytotoxicity: Implications for therapy and estimation of radiation risk. Int J Nucl Med Biol 8:171–178.7033155
Bloomer WD, McLaughlin WH, Adelstein SJ. 1982. Therapeutic implications of iodine-125 cytotoxicity. Int J Radiat Oncol Biol Phys 8:1903–1908.7153101
*Blum M, Liuzzi A. 1967. Thyroid ^131^I burdens in medical and paramedical personnel. JAMA 200(11):184–186.12275413
Blumenthal RD, Alisauskas R, Lew W, . 1998. Myelosuppressive changes from single or repeated doses of radioantibody therapy: effect of bone marrow transplantation, cytokines, and hematopoietic suppression. Exp Hematol 26:859–868.9694507
Blumenthal RD, Sharkey RM, Quinn LM, . 1990. Use of hematopoietic growth factors to control myelosuppression caused by radioimmunotherapy. Cancer Res Suppl(50):1003s–1007s.2404578
*BNA. 2001a. Reports of individual monitoring. The Bureau of National Affairs, Inc. http://www.bna.com. February 22, 2001.
*BNA. 2001b. General license for use of byproduct material for certain in vitro clinical or laboratory testing. The Bureau of National Affairs, Inc. http://www.bna.com. February 22, 2001.
*BNA. 2001c. Quantities of radioactive materials requiring consideration of the need for an emergency plan for responding to a release. The Bureau of National Affairs, Inc. http://www.bna.com. February 22, 2001.
*BNA. 2001d. Quantities of licensed material requiring labeling. The Bureau of National Affairs, Inc. http://www.bna.com. February 22, 2001.
*BNA. 2001e. Release limits for containment requirements. The Bureau of National Affairs, Inc. http://www.bna.com. February 22, 2001.
*BNA. 2001f. Designation, reportable quantities, and notification. The Bureau of National Affairs, Inc. http://www.bna.com. February 22, 2001.
*BNA. 2001h. Environment and safety library: States and territories. The Bureau of National Affairs, Inc. http://www.bna.com. February 13, 2001.
Bo G, Guishan Y. 1997. [Effects of high-dose iodine on brain development in mice.] Chin J Prev Med 31(3):134–136. (Chinese)
Bobechko WP. 1989. Iodine in the diet. Can Med Assoc J 140:1431.
Bocanera LV, Krawiec L, Nocetti G, . 2001. The protein kinase C pathway inhibits iodide uptake by calf thyroid cells via sodium potassium-adenosine triphosphate. Thyroid 11(9):813–817.11575849
Bocanera LV, Krawiec L, Silberschmidt D, . 1997. Role of cyclic 3’5’guanosine monophosphate and nitric oxide in the regulation of iodide. J Endocrinol 155:451–457.9487990
Bockisch A, Jamitzky T, Derwanz R, . 1993. Optimized dose planning of radioiodine therapy of benign thyroidal diseases. J Nucl Med 34(10):1632–1638.8410273
Bodansky HJ. 1986. Thyroid cancer after ^131^I treatment. Lancet 2(8509):755–756.
*Bodigheimer K, Nowak F, Schoenborn W. 1979. Pharmacokinetics and thyrotoxicity of the sodium nitroprusside metabolite of thiocyanate. Dtsc Med Wochenschr 104:939–943.
Body JJ, Demeester-Mirkine N, Corvilain J. 1988. Calcitonin deficiency after radioactive iodine treatment. Ann Intern Med 109(7):590–591.3421566
Boeynaems J-M, Van Sande J, Dumont JE. 1995. Which iodolipids are involved in thyroid autoregulation: Iodolactones or iodoaldehydes? Eur J Endocrinol 132:733–734.7788014
Bogazzi F, Bartalena L, Brogioni S, . 1999. Comparison of radioiodine with radioiodine plus lithium in the treatment of Graves’ hyperthyroidism. J Clin Endocrinol Metab 84(2):499–503.10022407
*Bogazzi F, Bartalena L, Gasperi M, . 2001. The various effects of amiodarone on thyroid function. Thyroid 11(5):511–519.11396710
*Bogdanove EM, Strash AM. 1975. Radioiodine escape is an unexpected source of radioummunoassay error and chronic low level environmental contamination. Nature 257:426–427.1178046
*Bohuslavizki KH, Brenner W, Klutmann S, . 1998a. Radioprotection of salivary glands by amifostine in high-dose radioiodine therapy. J Nucl Med 39:1237–1242.9669401
*Bohuslavizki KH, Brenner W, Lassmann S, . 1996. Quantitative salivary gland scintigraphy in the diagnosis of parenchymal damage after treatment with radioiodine. Nucl Med Commun 17:681–686.8878127
*Bohuslavizki KH, Klutmann S, Bleckmann C, . 1999. Salivary gland protection by amifostine in high-dose radioiodine therapy by differentiated thyroid cancer. Strahlenther Onkol 175:57–61.
*Bohuslavizki KH, Klutmann S, Brenner W, . 1998b. Salivary gland protection by amifostine in high-dose radioiodine treatment: Results of a double-blind placebo-controlled study. J Clin Oncol 16(11):3542–3549.9817273
Boice JD, Engholm G, Kleinerman RA, . 1988. Radiation dose and second cancer risk in patients treated for cancer of the cervix. Radiat Res 116:3–55.3186929
Bolster AA, Hilditch TE. 1996. The radiation dose to the urinary bladder in radio-iodine therapy. Phys Med Biol 41:1993–2008.8912376
Bonnema SJ, Bertelsen H, Mortensen J, . 1999. The feasibility of high dose iodine 131 treatment as an alternative to surgery in patients with a very large goiter: Effect on thyroid function and size and pulmonary function. J Clin Endocrinol Metab 84(10):3636–3641.10523007
Book DA, McNeill DA, Parks NJ, . 1980. Comparative effects of iodine-132 and iodine-131 in rat thyroid glands. Radiat Res 81:246–253.6153809
Book SA. 1977a. ^131^I uptake and retention in fetal guinea pigs. Health Phys 32:149–154.863714
Book SA. 1977b. Iodine-129: Limits to radiologic dose. Health Phys 32(4):321–324.881328
Book SA. 1983. Iodine-129 uptake and effects of lifetime feeding in rats. Health Phys 45(1):61–66.6874352
*Book SA, Goldman M. 1975. Thyroidal radioiodine exposure of the fetus. Health Phys 29:874–877.811590
Book SA, McNeill DA, Spangler WL. 1980. Age and its influence on effects of iodine-131 in guinea pig thyroid glands. Radiat Res 81:254–261.7360882
Book SA, Wolf HG, Parker HR, . 1974. The exchange of radioiodine in pregnant and fetal sheep. Health Phys 26:533–539.4836699
Booz J, Smith T. 1977. Local distribution of energy deposition in and around the follicles of a ^125^I contaminated thyroid. Curr Top Radiat Res Q 12:12–32.
Bordell FL, Sayeg JA, Wald N, . 1972. In vivo measured effective half-life of ^125^I in human thyroids. Phys Med Biol 17(3):365–373.5070447
Bors J, Martens R, Kuhn W. 1984. [Effect of microorganisms on the adsorption and translocation of radioiodine in soil.] Atomkernerg Kerntech 44(1):87–88. (German)
Borys RD, Duce RA. 1979. Relationships among lead, iodine, trace metals and ice nuclei in a coastal urban atmosphere. J Appl Meteorol 18(11):1490–1494.
*Bostanci I, Sarioglu A, Ergin H, . 2001. Neonatal goiter caused by expectorant usage. Journal of Pediatric Endocrinology & Metabolism 14(8):1161–1162.11592576
Boudewyns A, Claes J. 2001. Acute cochleovestibular toxicity due to topical application of potassium iodide. Eur Arch Oto-rhino-laryngol 258(3):109–111.
*Boulos MS, Becker VJ, Manuel OK. 1973. Iodine-129 in thyroid glands. Health Phys 24:375–378.4698178
Bourdoux P, Ermans A, Mukalay A, . 1995. Recommendations concerning iodine prophylaxis. Eur J Endocrinol 133:764.8548065
*Bourdoux PP, Ermans AM, Mukalay A, . 1996. Iodine-induced thyrotoxicosis in Kivu, Zaire. Lancet 347:552–553.
Bourke JR, Murdoch S, Manley SW, . 1991. Epidermal growth factor (EGF) inhibits the secretomotor response of the thyroid: effects of EGF on radioiodine turnover and fluid transport in cultured porcine thyroid cells. J Endocrinol 128:213–218.2005412
Bourrinet P, Dencausse A, Cochet P, . 1997. Secretion in milk and transplacental transfer of two iodized oils, Lipiodol UF and Oriodol, in rabbits. Biol Neonate 71:395–402.9197342
Bouville A. 1977. [Estimation of the doses of iodine-129 effluents from nuclear installations-local and regional scales.] In: Iodine-129: Proceedings of an NEA specialist meeting. Paris, France: Organisation for Economic Co-Operation and Development, 53–68. (French)
Bouville A, Dreicer M, Beck HL, . 1990. Models of radioiodine transport to populations within the continental U.S. Health Phys 59(5):659–668.2145245
Bowlt C, Howe JR. 1992a. Measured human thyroid ^125^I activities deriving from waste discharges in the Thames Valley area, UK. J Radiol Prot 12(2):59–65.
Bowlt C, Howe JR. 1992b. The self-defining critical group and its application to a measured check of the derived limit for ^125^I in drinking water. Health Phys 63(6):686–691.1428890
Bowlt C, Tiplady P. 1989. Radioiodine in human thyroid glands and incidence of thyroid cancer in Cumbria. Br Med J 299:301–302.2504410
Bowman JC. 1975. Iodide mumps. J Tenn Dent Assoc 55(4):212–213.1069177
Bowman KO, Shenton LR, Bernard SR. 1985. Study of age dependent half-life of iodine in man: A reinforcement-depletion urn model. Bull Math Biol 47(2):205–213.4027435
*Boyages SC. 2000a. The neuromuscular system and brain in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 803–810.
*Boyages SC. 2000b. The neuromuscular system and brain in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 631–633.
*Boyages SC, Bloot AM, Maberly GF, . 1989. Thyroid autoimmunity in endemic goitre caused by excessive iodine intake. Clin Endocrinol 31:452–465.
*Boyd E, Ferguson-Smith MA, McDougall IR, . 1974. Chromosome breakage in human peripheral lymphocytes after radioactive iodine (^125^I) treatment. Radiat Res 57:482–487.10874962
Brabant G, Bergmann P, Kirsch CM, . 1992. Early adaptation of thyrotropin and thyroglobulin secretion to experimentally decreased iodine supply in man. Metabolism 41:1093–1096.1328820
Branemark PI, Albrektsson B, Lindstrom J, . 1966. Local tissue effects of wound disinfectants. Acta Chir Scand Suppl 357:166–176.
*Brätter P, Negretti de Bratter VEN. 1996. Influence of high dietary selenium intake on the thyroid hormone level in human serum. J Trace Elements Med Biol 10:163–166.
Braverman LE. 1990. Effects of iodine on thyroid function in man. Trans Am Clin Climatol Assoc 102:143–151.
Braverman LE. 1994a. Deiodination of thyroid hormones: A 30 year perspective. Exp Clin Endocrinol 102:355–363.7867697
Braverman LE. 1994b. Iodine and the thryoid: 33 years of study. Thyroid 4(3):351–356.7833675
*Braverman LE, Roti E. 1996a Effects of iodine on thyroid function. Acta Med Austriaca 23:4–9.8767509
Braverman LE, Utiger RD. 1996b Introduction to hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 736–737.
Braverman LE, Utiger RD. 1996c Introduction to thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 522–524.
*Braverman LE, Utiger RD, eds. 2000. Werner and Ingbar’s: The thyroid: A fundamental and cliical text. 8^th^ ed. New York, NY: Lippincott Williams and Wilkins.
*Braverman LE, Ingbar SH, Sterling K. 1970. Conversion of thyroxine (T4) to triiodothyronine (T3) in athyreotic human subjects. J Clin Invest 49:855–864.4986007
*Braverman LE, Ingbar SH, Vagenakis AG, . 1971a. Enhanced susceptibility to iodide myxedema in patients with Hashimoto’s disease. J Clin Endocrinol 32:515–521.
Braverman LE, Paul T, Reinhardt W, . 1987. Effect of iodine intake and methimazole on lymphocytic thyroiditis in the BB/W rat. Acta Endocrinol 281:70–76.
Braverman LE, Vagenakis AG, Wang C-A, . 1971b. Studies on the pathogenesis of iodide myxedema. Trans Assoc Am Physicians 84:130–138.4364605
Braverman LE, Woeber KA, Ingbar SH. 1969. Induction of myxedema by iodide in patients euthyroid after radioiodine or surgical treatment of diffuse toxic goiter. N Engl J Med 281(15):816–821.4980221
Bremner VF, Kennedy JS. 1978. Radiation effects of iodine-125 and iodine-131 on the overactive rat thyroid. Strahlentherapie 154:413–418.96552
*Brent GA, Larsen PR. 2000. Treatment of hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 851–858.
Briancon C, Halpern S, Jeusset J, . 1992. Acute effects of various doses of iodide on thyroid iodine autoregulation. Biol Trace Elem Res 32:267–273.1375064
Briancon C, Halpern S, Telenczak P, . 1990. Changes in ^127^I mice thyroid follicle studied by analytical ion microscopy: A key of the comprehension of amiodarone-induced thyroid diseases. Endocrinology 127(1):1502–1509.2387264
*Bricker NS, Hlad CJ. 1955. Observations on the mechanism of the renal clearance of I^131^. J Clin Invest 34:1057–1072.14392221
Brincker H, Hansen HS, Andersen AP. 1973. Induction of leukemia by ^131^I treatment of thyroid carcinoma. Br J Cancer 28:232.4517840
Brown AS, Susser ES, Butler PD, . 1996. Neurobiological plausibility of prenatal nutritional deprivation as a risk factor for schizophrenia. J Nerv Ment Dis 184(2):71–85.8596115
Brown J. 1956. Extra-thyroidal iodide metabolism in the rat. Endocrinology 58:68–78.13285449
*Brown RS, Bloomfield S, Bednarek FJ, . 1997. Routine skin cleansing with povidone-iodine is not a common cause of transient neonatal hypothyroidism in North America: A prospective controlled study. Thyroid 7(3):395–400.9226209
*Brown TR, Bagchi N. 1992. The role of iodine in the development of autoimmune thyroiditis. Int Rev Immunol 9:167–182.1283176
*Brown-Grant K. 1961. Extrathyroidal iodide concentrating mechanisms. Physiol Rev 41:189–213.
Brown-Grant K. 1967. A quantitative study of the effects of progesterone and related steroids on the uterus: Plasma concentration ratio for radioactive iodide in the rat. J Endocrinol 38:145–161.6026368
Brown-Grant K, Sherwood MR. 1971. Viability of the rat blastocyst following the oral administration of potassium perchlorate or potassium iodide to the mother. J Reprod Fertil 27:265–267.4331003
Brown-Grant K, John PN, Rogers AW. 1972. Analysis of the effects of progesterone on the synthesis of RNA and protein in the uterus of the ovariectomized rat and on the development of an iodide concentrating mechanism. J Endocrinol 53:363–374.5039218
*Bruhn JC, Franke AA, Bushnell RB, . 1983. Sources and content of iodine in California milk and dairy products. J Food Prot 46(1):41–46.30913706
*Bryant WP, Zimmerman D. 1995. Iodine-induced hyperthyroidism in a newborn. Pediatrics 95(3):434–436.7862489
Brzezinski J, Lewinski A, Karbownik M, . 1997. Effects of insulin-like growth factor I, epidermal growth factor and kalium iodide on thymidine kinase activity in homogenates of rat thyroid lobes incubated in vitro. Biomed Lett 55:153–167.
Bubenhofer R, Hedinger C. 1977. Schilddrusenmalignome vor und nach einfuhrung der jodsalzprophylaxe. Schweiz Med Wochenschr 107:733–741.867016
Bucher H, Torresani T, Sobradillo B, . 1983. [Does PVP-iodine disinfection of newborn infants cause transient hypothyroidism? Report on 6 cases and prospective study of 19 early operated infants using T4 and TSH determinations of dried blood samples.] Schweiz Med Wochenschr 113(18):671–679. (German)6867656
Buczek A. 1993. Influence of iodine compounds on embryogenesis of argas (A.) reflexus (Fabricius, 1794) (Acari, Ixodida, Argasidae). Acta Parasitol 38(1):41–43.
*Budavari S, O’Neil MJ, Smith A, ., eds. 1998. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. Whitehouse Station, NJ: Merck and Co., Inc.
Budyka AK, Ogorodnkiov BI. 1993a. [Calculation of gaseous fallout of Chernobyl accident by calculation of inhaled radiation dose.] Radiats Biol Radioecol 33(5):611–619. (Russian)8293085
Budyka AK, Ogorodnikov BI. 1993b. [Gaseous forms and aerosol particle sizes of iodine-131 products of Chernobyl accident during determination of inhaled dose radiaton.] Radiats Biol Radioecol 33(2):611–619. (Russian)8293085
Bundi RS, Scott JS, Halnan KE. 1977. Chronic myeloid leukemia following radioiodine therapy for carcinoma thyroid. Br J Radiol 50:61–64.264404
Bunzl K, Schimmack W. 1989. Associations between the fluctuations of the distribution coefficients of Cs, Zn, Sr, Co, Cd, Ce, Ru, Tc and I in the upper two horizons of a podzol forest soil. Chemosphere 18(11/12):2109–2120.
*Buraglio N, Aldahan A, Possnert G, . 2001. ^129^I from the nuclear reprocessing facilities traced in precipitation and runoff in Northern Europe. Environ Sci Technol 35:1579–1586.11329705
Burakov VS, Isaevich AV, Misakov PY, . 1993. Intracavity laser spectroscopic method for determining trace amounts of iodine and barium in water and biological samples. J Anal Atom Spectrom 0:307–309.
Burch HB, Gorman CA, Bahn RS, . 1996. Ophthalmopathy. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 536–553.
*Burch WM, Posillico JT. 1983. Hypoparathyroidism after I-131 therapy with subsequent return of parathyroid function. J Clin Endocrinol Metab 57(2):398–401.6863481
Burek CL, Talor M, Santana C, . 1998. Thyroiditis in NOD-H2^h4^ mice born and reared in conventional housing and ingesting different dose of iodine. FASEB J 12(5):A1097.
Burger AG, Engler D, Buergi U, . 1983. Ether link cleavage is the major pathway of iodothyronine metabolism in the phagocytosing human leukocyte and also occurs in vivo in the rat. J Clin Invest 71:935–949.6833495
Burgess JR, Dwyer T, McArdle K, . 2000. The changing incidence and spectrum of thyroid carcinoma in Tasmania (1978-1998) during a transition from iodine sufficiency in iodine deficiency. J Clin Endocrinol Metab 85(4):1513–1517.10770190
Bürgi H, Andersen MC, Schwander J, . 1973. Secretion of thyroxine and non-thyroxine iodine by the normal human thyroid gland. Influence of carbimazole and pharmacological doses of iodide. Eur J Clin Invest 3:142–150.4696510
Bürgi H, Baumbartner H, Steiger G. 1982. [Is there an upper limit of tolerance for dietary iodine administration?] Schweiz Med Wochenschr 112:2–7. (German)6895793
*Bürgi H, Kohler M, Morselli B. 1998. Thyrotoxicosis incidence in Switzerland and benefit of improved iodine supply. Lancet 352:1034.
Bürgi H, Radvila A, Kohler H, . 1974. Effects of pharmacological doses of iodide on the hyperplastic rat thyroid gland. Roles of intrathyroid iodide, thyrotropin and thyroglobulin in the Wolff-Chaikoff phenomenon. Endocrinology 95:388–396.4851767
Bürgi H, Schaffner T, Seiler JP. 2001. The toxicology of iodate: A review of the literature. Thyroid 11(5):449–456.11396703
Burke G, Kowalski K. 1971. Comparative effects of thyrotropin and long-acting thyroid stimulator on iodide trapping isolated thyroid cells. Acta Endocrinol 68:645–656.
Burke G, Silverstein GE. 1969. Hypothyroidism after treatment with sodium iodide I 131. JAMA 210(6):1051–1058.4900342
Burki HJ, Koch C, Wolff S. 1977. Molecular suicide studies of ^125^I and ^3^H disintegration in the DNA of Chinese hamster cells. Curr Top Radiat Res Q 12:408–425.
Burman KD, Smallridge RC, Burge JR, . 1987. Iodide administration enhances thyrotropin responsivenesss to thyrotrophin-releasing hormone during fasting: Evidence for normal pituitary feedback regulation. Clin Endocrinol 26:9–15.
Burmeister LA, Beatty RL, Wall JR. 1999. Malignant ophthalmopathy presenting one week after radioiodine treatment of hyperthyroidism. Thyroid 9(2):189–192.10090321
Burmeister LA, de Cret RP, Mariash CN. 1991. Local reactions to radioiodine in the treatment of thyroid cancer. Am J Med 90:217–222.1996591
Burnett JW. 1989. Iodides and bromides. Cutis 43(2):130.2702853
Burns PA, Peggie JR. 1979. Thyroid measurements of iodine-125 workers. Australian Radiation Laboratory, Yallambie, Victoria, Australia. NTIS ARLTR008.
Burrow GN. 1965. Neonatal goiter after maternal propylthiouracil therapy. J Clin Endocrinol Metab 25:403–408.14264264
*Burte PP, Nair AGC, Manohar SB, . 1991. Iodide and iodine uptake in plants. J Radioanal Nucl Chem 155(6):391–402.
Bushnell DL, Boles MA, Kaufman GE, . 1992. Complications, sequela and dosimetry of iodine-131 therapy for thyroid carcinoma. J Nucl Med 33(12):2214–2221.1460519
*Bustad LK. 1964. Biology of radioiodine. Oxford, England: Pergamon Press.
Buthieau A-M, Autissier N. 1977. [The effect of Mn2+ on thyroid iodine metabolism in rats.] C R Seances Soc Biol Fil 171(5):1024–1028. (French)146543
*Butler EC, Gershey RM. 1984. Application of ion-exchange chromatography with an ion-selective electrode detector to iodine determination in natural waters. Anal Chim Acta 164:154–161.
Buxeraud J, Absil AC, Raby C. 1984. Secondary antithyroid action of drugs in relation to structure. J Pharm Sci 73(12):1687–1690.6084710
Buxeraud J, Lagorce JF, Comby F, . 1992. Interaction between tetrahydro-3,5 dimethyl-2H-1,3,5 thiazidine-2-thione (MDTT or DAZOMET) and molecular iodine: Possible role in thyroid toxicity. Int J Environ Stud 42:177–186.
Cabanillas AM, Masini-Repiso AM, Coleoni AH. 1991. Rat thyroid monoamine oxidase (MAO) is regulated by thyrotropin: evidence that the main form of the enzyme (MAO-A) is not directly involved in iodide organification. J Endocrinol 131:25–31.1660515
Cailleux A-F, Schlumberger MJ. 1998. The role of iodine-131 scanning and serum thyroglobulin in follow-up of differentiated thyroid carcinoma after total ablation. Curr Opin Endocrinol Diabetes 5:307–313.
*Cann SA, van Netten JP, van Netten C. 2000. Hypothesis: Iodine, selenium and the development of breast cancer. Cancer Causes Control 11:121–127.10710195
Cann SAH, van Netten JP, van Netten C. 2001. Iodized salt and hypertension. Arch Intern Med 161(4):505–506.11252107
Canning JF, Stacey TE, Ward RHT, . 1986. Radioiodide transfer across sheep placenta. Am J Physiol 250(19):R112–R119.3942244
Cantin M. 1967a. Skeletal muscle lesions in iodide-treated rats. Arch Pathol 83:500–506.6024728
Cantin M. 1967b. Study of a generalized erythema induced by iodide. J Invest Dermatol 48(6):560–566.6028008
Cao X-Y, Jiang X-M, Dou Z-H, . 1994. Timing of vulnerability of the brain to iodine deficiency in endemic cretinism. N Engl J Med 331:1739–1744.7984194
*Capar SG, Cunningham WC. 2000. Element and radionuclide concentrations in food: FDA total diet study 1991-1996. J AOAC Int 83(1):157–177.10693017
Caplan RH, Kujak R. 1971. Thyroid uptake of radioactive iodine. JAMA 215(6):916–918.4099969
*Caplan RH, Kujak R, Murvich S, . 1976. Current status of the radioactive ^131^I uptake test. Minn. Med. 59:530–535.967128
Carey JE, Swanson DP. 1979. Thyroid contamination from airborne I-131. J Nucl Med 20:362.
*Carrasco N. 1993. Iodide transport in the thyroid gland. Biochim Biophys Acta 1154:65–82.8507647
Carroll KK. 1975. Experimental evidence of dietary factors and hormone-dependent cancers. Cancer Res 35:3374–3383.1104150
Carswell F, Kerr MM, Hutchinson JH. 1970. Congenital goitre and hypothyroidism produced by maternal ingestion of iodides. Lancet 1(7659):1241–1243.4192491
*Casara D, Rubello D, Saladini G, . 1993. Pregnancy after high therapeutic doses of iodine-131 in differentiated thyroid cancer: Potential risks and recommendations. Eur J Nucl Med 20:192–194.8462605
*Cassileth BR. 1999. Complementary and alternative cancer medicine. J Clin Oncol 17(11):44–52.10630262
Cassorla FG, Finegold DN, Parks JS, . 1983. Vasculitis, pulmonary cavitation, and anemia during antithyroid drug therapy. Am J Dis Child 137:118–122.6184983
Castaing H, Fournet JP, Leger FA, . 1979. [The thyroid gland of the newborn infant and postnatal iodine overload.] Arch Fr Pediatr 36(4):356–368. (French)496528
Castronovo FP. 1986. Iodine-131 thyroid burdens of European travelers returning to Boston after the Chernobyl accident. N Engl J Med 315:1679–1680.3785343
Castronovo FP. 1987. Iodine-131 thyroid uptake results in travelers returning from Europe after the Chernobyl accident. J Nucl Med 28:535–541.3572538
Castronovo FP. 1999. Teratogen update: Radiation and Chernobyl. Teratology 60(2):100–106.10440782
Catena C, Conti D, Trenta G, . 2000. Micronucleus yield and colorimetric test as indicators of damage in patients’ lymphocytes after 131I therapy. J Nucl Med 41(9):1522–1524.10994733
*Catena C, Villani P, Nastasi R, . 1994. Micronuclei and 3AB-index in patients receiving iodine-131 therapy. J Nucl Biol Med 38:586–593.7786922
Caturegli P, Hejazi M, Suzuki K, . 2000. Hypothyroidism in transgenic mice expressing IFN-gamma in the thyroid. Proc Natl Acad Sci USA 97(4):1719–1724.10677524
Caughey JE. 1970. Effects of iodation of bread. Lancet 1(7651):847.
Cavalieri RR. 1996. Nuclear imaging in the management of thyroid carcinoma. Thyroid 6(5):485–492.8936676
*Cavalieri RR. 1997. Iodine metabolism and thyroid physiology: Current concepts. Thyroid 7(2):177–181.9133680
CDC. 1993. Hanford thyroid disease study: Study protocol. Atlanta, GA: Centers for Disease Control. Prepared under CDC Contract Number 200-89-0716, 1–13, 68.
CDC. 1994. Radionuclide releases to the atmosphere from Hanford Operations, 1944-1972: Hanford environmental dose reconstruction project. Centers for Disease Control. PNWD-2222 HEDR UC-000. NTIS DE94 013 713.
*CDC. 1999. Hanford thyroid disease study. Centers for Disease Control, Atlanta, GA. http://www.fhcrc.org/science/phs/htds/.
*CDC. 2002. Hanford thyroid disease study. Final report. Centers for Disease Control. Fred Hutchinson Cancer Research Center.
Cebulska-Wasilewska A. 1989. Comparison of ambient air mutagenicity detected with tradescantia stamen hairs after Chernobyl accident and one year later. Environ Mol Mutagen 14(Suppl 15):35.2659329
Celani VJ, Gee W, Kaupp HA, . 1989. Unusual symmetric common carotid lesions and oral iodine 131 for hyperthyroidism. Vascular Surgery 9(6):833–834.
*Cember H. 1996. In: Introduction to Health Physics. 3^rd^ ed. New York, NY: McGraw-Hill, 66.
*Centanni M, Robbins J. 1987. Role of sodium in thyroid hormone uptake by rat skeletal muscle. J Clin Invest 80:1068–1972.2821072
Cevallos JL, Hagen GA, Maloof F, . 1974. Low-dosage ^131^I therapy of thyrotoxicosis (diffuse goiters). N Engl J Med 290:141–143.4859623
*Chabrolle JP, Rossier A. 1978a. Danger of iodine skin absorption in the neonate [Letter]. J Pediatr 93(1):158–159.650335
*Chabrolle JP, Rossier A. 1978b. Goitre and hypothyroidism in the newborn after cutaneous absorption of iodine. Arch Dis Child 53:495–498.686777
*Chadha RK, Lawrence JF. 1990. Determination of iodide in dairy products and table salt by ion chromatography with electrochemical detection. J Chromatogr 518:268–272.2258411
*Chambard M, Verrier B, Gabrion J, . 1983. Polarization of thyroid cells in culture: Evidence for the basolateral localization of the iodide “pump” and of the thyroid-stimulating hormone receptor-adenyl cyclase complex. J Cell Biol 96:1172–1177.6300145
*Chameides WL, Davis DD. 1980. Iodine, its possible role in tropospheric photochemistry. Journal of Geophysical Research 85:7383–7398.
Chan PC, Lisco E, Lisco H, . 1976. Radiotoxicity of intracellular ^3^H, ^125^I and ^131^I: A comparative study on cell survival and cytogenetic responses. Radiat Res 67:633.
Chan PC, Lisco E, Lisco H, . 1977. Cell survival and cytogenetic responses to ^125^I-UdR in cultured mammalians cells. Curr Top Radiat Res Q 12:426–435.
Chan T, Scheier NW, O’Connor PA. 1997. A numerical study of the effects of a discrete fracture and an excavation damage zone on ^129^I transport through the geosphere. At Energy Can Ltd, [Rep] AECL 11587:1–53.
Chang J-K, Chen Y-C, Liu C-H, . 1984. A case of chronic myelogenous leukemia following ^131^I therapy for metastatic thyroid carcinoma. J Formosan Med Assoc 83:730–735.
Chang T-C, Chang C-C, Chen F-W, . 1986. Long-term effect of radioiodine therapy on the thyroid antibodies in the patients of Graves’ disease with postirradiation hypothyroidism. J Formosan Med Assoc 85:1177–1182.
Chang Y-O. 1969. Effect of iodinated casein on production of vitamin B_12_ and folic acid deficiency in rats. Am J Physiol 216(1):11–15.5765571
Chang-Chien Y, Liaw K-Y, Wang D-J, . 1977. Thyroid cancer after irradiation. Int Surg 62(2):112–114.844967
Chanoine JP, Toppet V, Bourdoux P, . 1991. Smoking during pregnancy: A significant cause of neonatal thyroid enlargement. Br J Obstet Gynaecol 98:65–68.1998635
Chapman EM, Corner GW, Robinson D, . 1948. The collection of radioactive iodine by the human fetal thyroid. J Clin Endocrinol Metab 8:717–720.18880940
Chapman RS, Main RA. 1967. Diffuse thinning of hair in iodide-induced hypothyroidism. Br J Dermatol 79(2):103–105.4163704
Chapman WH. 1968. The changing frequency of thyroid carcinoma and Hashimoto’s thyroiditis as related to diagnostic criteria, iodized salt, and radiation. Lawrence Radiation Laboratory, University of California at Livermore, Bio-Medical Division. California. TID-4500, UC-48.
Chas J, Marciniak M, Baltrukiewicz Z. 1990. Retention of iodine upon intravenous or oral administration of Na^131^I and the absorbed doses of radiation derived from iodine radioisotopes incorporated into mature rats and sucklings. Nucleonika 35(7–9):195–211.
*Chazenbalk GD, Nagayama Y, Kaufman KD, . 1990. The functional expression of recombinant human thyrotropin receptors in nonthyroidal eukaryotic cells provides evidence that homologous desensitization to thyrotropin stimulation requires a cell-specific factor. Endocrinology 127(3):1240–1244.2167212
Chazenbalk GD, Valsecchi RM, Krawiec L, . 1988. Thyroid autoregulation, inhibitory effects of iodinated derivatives of arachidonic acid on iodine metabolism. Prostaglandins 36(2):163–172.3141976
Chegrinets G. 1992. [The iodine level of the environment and the risk of developing thyroid diseases.] Lik Sprava 4:16–19. (Russian)
*Chemfinder. 2001. Iodine. Chemfinder.com: Database and internet searching. http://www.chemfinder.com.
Chen J-Y, Huang H-S, Huang M-J, . 1990. Outcome following radioactive iodine therapy in Graves’ disease. Chang Keng I Hsueh Tsa Chih 13(4):258–267.2282562
Chen S-H, Wu S-M, Kou H-S, . 1994. Electron-capture gas chromatographic determination of cyanide, iodide, nitrite, sulfide, and thiocyanate anions by phase-transfer-catalyzed derivatization with pentafluorobenzyl bromide. J Anal Toxicol 18:81–85.8207938
*Chernyshov VP, Vykhovanets EV, Slukvin II, . 1998. Effect of iodine isotope on the pituitary-thyroid and immune systems of children living on the territories polluted by radionuclides. Bull Exp Biol Med 126(8):835–838.
*Cherstvoy ED, Nerovnya AM, Pozharskaya VP, . 1996. Thyroid carcinomas in children of the Republic of Belarus. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, The Netherlands: Elsevier, 43–48.
Chester HA, Pisarev MA, Juvenal GJ, . 1990. Further studies on iodide uptake autoregulation in calf thyroid slices. Acta Physiol Pharmacol Latinoam 40:149–154.
Chiacchierini RP. 1990. Iodine-131 exposures and neoplasia. Radiat Res 124(3):359–360.
Chin HS, Chin DKH, Morgenthaler NG, . 2000. Rarity of anti- Na^+^/I^−^- symporter (NIS) antibody with iodide uptake inhibiting activity in autoimmune thyroid diseases (AITD). J Clin Endocrinol Metab 85(10):3937–3940.11061560
Ching M. 1981. Dose-related effect of growth hormone on thyroidal radioiodine uptake. Horm Res 14:234–242.7308981
Chiovato L, Fiore E, Vitti P, . 1998. Outcome of thyroid function in Graves’ patients treated with radioiodine: Role of thyroid-stimulating and thyrotropin-blocking antibodies and of radioiodine-induced thyroid damage. J Clin Endocrinol Metab 83(1):40–46.9435414
Chiovato L, Santini F, Vitti P, . 1994. Appearance of thyroid stimulating antibody and Graves’ disease after radioiodine therapy for toxic nodular goitre. Clin Endocrinol 40:803–806.
Chisholm JC. 1981. Hypothyroidism: A rare cause of the bilateral carpal tunnel syndrome-a case report and a review of the literature. J Natl Med Assoc 73(11):1082–1085.7310927
Chiu AC, Sherman SI. 1997. Clinical manifestations and differential diagnosis of hypothyroidism. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 379–391.
*Cho JY, Leveille R, Kao R, . 2000. Hormonal regulation of radionuclide uptake activity and Na+/I− symporter expression in mammary glands. J Clin Endocrinol Metab 85(8):2936–2943.10946907
Choe SY, Yen-Chow YC, Woodbury DM. 1982. Effects of thyrotropin, acetazolamide, 4-acetamido-4’-isothiocyanostilbene-2,2’-disulfonic acid, perchlorate, and ouabin on the distribution of iodide ions in cells and luminal fluid of turtle thyroid. Endocrinology 110(1):121–125.6274614
Chopra IJ. 1996. Nature, source, and relative significance of circulating thyroid hormones. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 111–124.
*Chow CC, Phillips DIW, Lazarus JH, . 1991. Effect of low dose iodide supplementation on thyroid function in potentially susceptible subjects: Are dietary iodide levels in Britain acceptable? Clin Endocrinol 34:413–416.
Chow SY, Kemp JW, Woodbury DM. 1983. Effects of acetazolamide on iodide transport, electrolyte distribution and activities of carbonic anhydrase, Na^+^, K^+^-ATPase and HCO_3_^−^-ATPase in mouse, rat and turtle thyroid gland. J Endocrinol 97:167–174.6133903
Christensen VL, Ort JF. 1991. Iodine toxicity in large white turkey breeder hens. Poult Sci 70:2402–2410.1784560
Christiansen C, Pichler WJ, Skotland T. 2000. Delayed allergy-like reactions to X-ray contrast media: Mechanistic considerations. Eur Radiol 10(12):1965–1975.11305580
Christov K. 1978. Radiation-induced thyroid tumors in infant rats. Radiat Res 73:330–339.635111
Christov K, Raichev R. 1972. Thryoid carcinogenesis in hamsters after treatment with 131-iodine and methylthiouracil. Z Krebsforsch 77:171–179.
Christov K, Raichev R. 1973. Proliferative and neoplastic changes in the ovaries of hamsters treated with 131-iodine and methylthiouracil. Neoplasma 20(5):511–516.4796363
*Chu SYF, Ekstrom LP, Firestone RB. 1999. Isotope explorer: WWW table of radioactive isotopes. http://nucleardata.nuclear.lu.se/nucleardata/toi/listnuc.asp?
*Chun JT, Di Lauro R. 2001. Characterization of the upstream enhancer of the rat sodium/iodide symporter gene. Exp Clin Endocrinol Diabetes 109(1):23–26.11573134
Clairand I, Bouchet LG, Ricard M. 2000. Improvement of internal dose calculations using mathematical models of different adult heights. Phys Med Biol 45(10):2771–2785.11049171
Clark DE. 1955. Association of irradiation with cancer of the thyroid in children and adolescents. JAMA 159(10):1007–1009.
*Clark MN. 1981. A fatal case of iodine poisoning. Clin Toxicol 18(7):807–811.7307464
Clark WE, Thompson CT. 1977. Immobilization of iodine in concrete. (to The United States of America as represented by the United States Energy Research and Development Administration) Application: United States 4,017,417, 12 Apr 1977. United States Patent 4,017,417, issued 12 Apr 1977.
Clayson DB. 1975. Nutrition and experimental carcinogenesis: A review. Cancer Res 35:3292–3300.53097
Clayton CG. 1953. Irregularities of iodine assimilation by the follicles of the rat thyroid. Br J Radiol 26:99–101.13019073
Clemens PC, Neumann RSJ. 1989a. The Wolff-Chaikoff effect: Hypothyroidism due to iodine application [Letter]. Arch Dermatol 125(5):705.2712587
Clemens PC, Neumann S. 1989b. Transient primary hypothyroidism in the neonate. Clin Pediatr 28(7):335.
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Coakley FV, Panicek DM. 1997. Iodine allergy: An oyster without a pearl? Am J Roentgenol 169(4):951–952.9308442
Coakley FV, Panicek DM. 1998. Reply [Letter]. Am J Roentgenol 171(2):518–519.9694486
*Coakley JC, Francis I, Gold H, . 1989. Transient primary hypothyroidism in the newborn: Experience of the Victorian Neonatal Thyroid Screening Programme. Aust Paediatr J 25:25–30.2567157
Cobb LM, Harrison A, Dudley NE, . 1989. Relative concentration of astatine-211 and iodine-125 by human fetal thyroid and carcinoma of the thyroid in nude mice. Radiother Oncol 13:203–209.
Codaccioni J-L, Valery-Milhaud F, Ochi C. 1987. [Carbimazole administered alone can be effective in the treatment of hyperthyroidism induced by iodine.] Presse Med 16(6):312. (French)
Cody V. 1996. Thyroid hormone structure-function relationships. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 185–189.
*Cohen BI. 1985. The origin of I in soil and the ^129^I problem. Health Phys 49(2):279–285.4019198
Cohen J, Gierlowski TC, Schneider AB. 1990. A prospective study of hyperparathyroidism in individuals exposed to radiation in childhood. JAMA 264(5):581–584.2366296
Cohen JC, Roxe DM, Said R, . 1980. Iodide mumps after repeated exposure to iodinated contrast media. Lancet 1:762–763.
Cohen SB, Weetman AP. 1988. The effect of iodide depletion and supplementation in the Buffalo strain rat. J Endocrinol Invest 11:625–627.3243968
*Cohn BNE. 1932. Absorption of compound solution of iodine from the gastro-intestinal tract. Arch Intern Med 49:950–956.
*Cohn SH, Gusmano EA. 1963. Uptake and transfer of fallout i^131^ in pregnant women. Health Phys 9:1267–1269.14086673
Colin IM, Selvais PL, Rebai T, . 1994. Expression of the endothelin-1 gene in the rat thyroid gland and changes in its peptide and mRNA levels in goiter formation and iodide-induced involution. J Endocrinol 143:65–74.7964323
Collins SL. 1997. Thyroid cancer: Controversies and etiopathogenesis. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 495–564.
Collins WT, Capen CC. 1980a. Biliary excretion of ^125^I-thyroxine and fine structural alterations in the thyroid glands of Gunn rats fed polychlorinated biphenyls (PCB). Lab Invest 43:158–164.6772880
Collins WT, Capen CC. 1980b. Ultrastructural and functional alterations of the rat thyroid gland produced by polychlorinated biphenyls compared with iodide excess and deficiency, and thyrotropin and thyroxine administration. Virchows Arch B 33:213–231.6110270
*Comar CL, Wentworth RA, Georgi JR. 1963. Thyroidal deposition in man, rat and dog of radioiodine from milk and non-milk sources. Health Phys 9:1249–1252.14086670
*Conard RA. 1984. Late radiation effects in Marshall Islanders exposed to fallout 28 years ago. In: Boice KD, Fraument JF, eds. Radiation carcinogenesis: Epidemiology and biological significance. New York, NY: Raven Press, 57–71.
*Conard RA, Dobyns BM, Sutow WW. 1970. Thyroid neoplasia as late effect of exposure to radioactive iodine in fallout. JAMA 214(2):316–324.5469070
Connell JMC, Hilditch TE, McCruden DC, . 1983. Transient hypothyroidism following radioiodine therapy for thyrotoxicosis. Br J Radiol 56:309–313.6850213
Connolly KJ, Pharoah POD, Hetzel BS. 1979. Fetal iodine deficiency and motor performance during childhood. Lancet 2:1149–1151.91886
*Connolly RJ. 1971a. The changing iodine environment of Tasmania. Med J Aust 2:1191–1193.5171672
*Connolly RJ. 1971b. An increase in thyrotoxicosis in southern Tasmania after an increase in dietary iodine. Med J Aust 1(24):1268–1271.5565143
*Connolly RJ, Shepherd JJ. 1972. The effect of preoperative surgical scrubbing with providone iodine on urinary iodine levels. Aust N Z J Surg 42(1):94–95.4512556
*Connolly RJ, Vidor GI, Stewart JC. 1970. Increase in thyrotoxicosis in endemic goitre area after iodation of bread. Lancet 1(7645):500–502.4190182
Conrad LM, Hemken RW. 1978. Milk iodine as influenced by an iodophor teat dip. J Dairy Sci 61:776–780.690303
*Contempré B, Duale NL, Dumont JE, . 1992. Effect of selenium supplementation on thyroid hormone metabolism in an iodine and selenium deficient population. Clin Endocrinol 36:579–583.
*Contempré B, Dumont JE, Ngo B, . 1991. Effect of selenium supplementation in hypothyroid subjects of an iodine and selenium deficient area: The possible danger of indiscriminate supplementation of iodine-deficient subjects with selenium. J Clin Endocrinol Metab 73(1):213–215.2045471
Convey EM, Chapin L, Kesner JS, . 1979. Serum thyrotropin and thyroxine after thyrotropin releasing hormone in dairy cows fed varying amounts of iodine. J Dairy Sci 60(6):975–980.
Cooper DS. 1998. Radioiodine for hyperthyroidism: Where do we stand after 50 years? JAMA 280(4):375–376.9686558
*Cooper DS. 2000. Treatment of thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 691–715.
*Cooper LW, Hong GH, Beasley TM, . 2001. Iodine-129 concentrations in marginal seas of the North Pacific and Pacific-influenced waters of the Arctic Ocean. Mar Pollut Bull 42(12):1347–1356.11827122
Cooper RM. 1988. Potassium iodide for radiation exposure. Drug Intell Clin Pharm 22:33–34.
Coover LR. 1999. Vocal cord paralysis after ^131^I therapy for solitary toxic nodule. J Nucl Med 40:505.10086718
Coppa A, Mincione G, Mammarella S, . 1995. Epithelial rat thyroid cell clones, escaping from transforming growth factor beta negative growth control, are still inhibited by this factor in the ability to trap iodide. Cell Growth Differ 6:281–290.7794796
Coppola M, Vulpis N, Bertoncello G. 1984. Enhancement of chromosomal damage in human lymphocytes irradiated with x rays in the presence of iodine. Radiat Prot Dosim 9(2):99–104.
Corah LR, Ives S. 1991. The effect of essential trace minerals on reproduction in beef cattle. Vet Clin North Am 7(1):41–57.
Corda D, Kohn LD. 1986. Role of pertussis toxin sensitive G proteins in the alpha_1_ adrenergic receptor but not in the thyrotropin receptor mediated activation of membrane phospholipases and iodide fluxes in FRTL-5 thyroid cells. Biochem Biophys Res Commun 141(3):1000–1006.3028381
Corda D, Marcocci C, Kohn LD, . 1985. Association of the changes in cystolic Ca^2+^ and iodide efflux induced by thyrotropin and by the stimulation of alpha_1_-adrenerigic receptors in cultured rat thyroid cells. J Biol Chem 260(16):9230–9236.2862144
*Cornelis R, Speecke A, Hoste J. 1975. Neutron activation analysis for bulk and trace elements in urine. Anal Chim Acta 78:317–327.1166961
*Corvilain B, Dumont JE, Vassart G. 2000. Toxic adenoma and toxic multinodular goiter. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 564–572.
Corvilain B, Laurent E, Lecomte M, . 1994. Role of the cyclic adenosine 3’,5’-monophosphate and the phosphatidylinositol-Ca^2+^ cascades in mediating the effects of thyrotropin and iodide on hormone synthesis and secretion in human thyroid slices. J Clin Endocrinol Metab 79(1):152–159.8027219
Corvilain B, Van Sande J, Dumont JE. 1988. Inhibition of iodide by iodide binding to proteins: The “Wolff-Chaikoff” effect is caused by inhibition of H_2_O_2_ generation. Biochem Biophys Res Commun 154(3):1287–1292.2841932
*Corvilain B, Van Sande J, Dumont JE, . 1998. Autonomy in endemic goiter. Thyroid 8(1):107–113.9492160
Cosmetic Ingredient Review Expert Panel. 1995. Final report on the safety assessment of sodium iodate. J Am Coll Toxicol 14(3):231–239.
Coughtrey PJ, Jackson D, Thorne MC. 1983. Iodine. In: Radionuclide distribution and transport in terrestrial and aquatic ecosystems: A critical review of data. Rotterdam: A.A. Balkema, 322–372.
Cowin AJ, Bidey SP. 1995. Porcine thyroid follicular cells in monolayer culture activate the iodide-responsive precursor form of transforming growth factor-beta1. J Endocrinol 144:67–73.7891027
*Cox RA, Bloss WJ, Jones RL, . 1999. OIO and the atmospheric cycle of iodine. Geophys Res Lett 26(13):1857–1860.
*Cox RJ, Pickford CJ, Thompson M. 1992. Determination of iodine-129 in vegetable samples in inductively coupled plasma mass spectrometry. J Anal Atom Spectrom 7:635–640.
Craswell PWT. 1972. Vocal cord paresis following radioactive iodine therapy. Br J Clin Pract 26(12):571–572.4649367
Creutzig H, Hundeshagen H. 1977. [Thyroid cancer risk from Iodine-131 treatment.] Med Klin 72(19):855–857. (German)865388
Crile GJ, Esselstyn CBJ, Cook SA. 1979. Cancer of the thyroid appearing after (but probably not caused by) treatment with radioactive iodine. Cleve Clin Q 46(4):159–162.535165
*CRISP. 2001. CRISP Database. Computer Retrieval of Information on Scientific Projects.
Crocker DG. 1984. Nuclear reactor accidents-the use of KI as a blocking agent against radioiodine uptake in the thyroid-a review. Health Phys 46(6):1265–1279.6373674
Croughs W, Visser HKA. 1965. Familial iodide-induced goiter. Evidence for an abnormality in the pituitary-thyroid homeostatic control. J Pediatr 67:353–362.14339393
*Crout NMJ, Beresford NA, Mayes RW, . 2000. A model of radioiodine transfer to goat milk incorporating the influence of stable iodine. Radiat Environ Biophys 39(1):59–65.10789897
*Cuddihy RG. 1966. Thyroidal iodine-131 uptake, turnover and blocking in adults and adolescents. Health Phys 12:1021–1025.6013191
Culpepper RM, Hirsch JI, Fratkin MJ. 1992. Clearance of ^131^I by hemodialysis. Clin Nephrol 28(2):110–114.
Cundiff JG, Portugal L, Sarne DH. 2001. Parathyroid adenoma after radioactive iodine therapy for multinodular goiter. Am J Otolaryngol 22(5):374–375.11562893
Cunnien AJ, Hay ID, Gorman CA, . 1982. Radioiodine-induced hypothyroidism in Graves’ disease: Factors associated with the increasing incidence. J Nucl Med 23:978–983.6897075
*Cunningham WC, Anderson DL, Baratta EJ. 1994. Radionuclides in domestic and imported foods in the United States, 1987-1992. J AOAC Int 77(6):1422–1427.7819751
*Cunningham WC, Stroube WB, Baratta EJ. 1989. Radionuclides in domestic and imported foods in the United States, 1983-1986. J Assoc Off Anal Chem 72(1):15–18.2715131
*Curd JG, Milgrom H, Stevenson DD, . 1979. Potassium iodide sensitivity in four patients with hypocomplementemic vasculitis. Ann Intern Med 91:853–857.517884
*Curran PG, DeGroot LJ. 1991. The effect of hepatic enzyme-inducing drugs on thyroid hormones and the thyroid gland. Endocrine Rev 12(2):135–150.2070777
Cvejic D, Savin S, Sinadinovic J. 1997. Effects of thyrotropin and insulin-like growth factor I (IGF-I) on ^3^H-thymidine incorporation and iodine metabolism in cultured porcine thryoid follicles. Iugosl Physiol Pharmacol Acta 33:33–43.
*Dai G, Levy O, Carrasco N. 1996. Cloning and characterization of the thyroid iodide transporter. Nature 379:458–460.8559252
*Dai YD, Rao VP, Carayanniotis G. 2002. Enhanced iodination of thyroglobulin facilitates processing and presentation of a cryptic pathogenic peptide. J Immunol 168(11):5907–5911.12023396
*Dalmark M. 1976. Effects of halides and bicarbonate on chloride transport in human red blood cells. J Gen Physiol 67:223–234.1255128
*Dams R, Robbins JA, Rahn KA, . 1970. Nondestructive neutron activation analysis of air particulates. Anal Chem 42:861–867.5431523
Daniels AL, Everson GJ. 1935. The relation of manganese to congenital debility. J Nutr 9(2):191–203.
*Darras VM, Hume R, Visser TJ. 1999. Regulation of thyroid hormone metabolism during fetal development. Mol Cell Endocrinol 151:37–47.10411318
Das SC, Isichei UP. 1993. The “feto-maternal” thyroid function interrelationships in an iodine-deficient region in Africa-the role of T_3_ in possible fetal defence. Acta Endocrinol 128:116–119.
Datz FL. 1986. Cerebral edema following iodine-131 therapy for thyroid carcinoma metastatic to the brain. J Nucl Med 27:637–640.3712081
Daunt N. 1998. Iodine allergy. [Letter]. Am J Roentgenol 171(2):518. See also Coakley & Panicek, 1998.9694486
Davidovich D, Stigliano H, Garcis JRAR, . 1970. [Study of thyroid function in 20 inhabitants of a zone with an excess of iodine in the drinking water.] Rev Argent Endocrinol Metab 16(3):75–79. (Spanish)5525307
Davidson DC, Ford JA, Fox EG. 1974. Iodide sialadenitis in childhood. Arch Dis Child 49(1):67–68.4818097
Davies TF. 1996. Graves’ disease: The pathogenesis of Graves’ disease. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 525–536.
Davies TF, Yang C, Platzer M. 1989. The influence of antithyroid drugs and iodine on thyroid cell MHC class II antigen expression. Clin Endocrinol 31:125–135.
Davis RJ. 1980. To the editor. Ann Intern Med 92(5):712–713.
Dawson CA, Skebba SC, Linehan JH, . 1985. Influence of pulmonary embolism on absorption of inhaled iodide-125. J Appl Physiol 58(4):1061–1068.3988662
Dawson KP. 1970. Congenital goitrous cretinism due to iodide. Br Med J 2(701):112–113.
De SK, Ganguly CK, Chakraborty TK, . 1985. Endocrine control of extrathyroidal peroxidases and iodide metabolism. Acta Endocrinol 110:383–387.
De Braekeleer M, Mayer G, Chaventre A. 1998. Genetic factors in iodine deficiency disorders: A general review. Coll Antropol 1:9–15.
*DeCheke ME. 1989. Chemical analysis of water and wastewater. Inorganics. Journal WCPF 61(6):727–755.
de Groot LJ. 1997. Radioiodine and the immune system. Thyroid 7(2):259–264.9133697
de Groot LJ, Reilly M. 1982. Comparison of 30- and 50-mCi doses of iodine-131 for thyroid ablation. Ann Intern Med 96:51–53.7053702
de Groot LJ, Reilly M, Pinnameneni K, . 1983. Retrospective and prospective study of radiation-induced thyroid disease. Am J Med 74:852–862.6837608
*de Groot R. 1979. The hazards of iodine-125 labeling-a recommended code of practice. Australas Phys Sci Med 2(7):386–393.
*Delange F. 1990. Iodine nutrition and risk of thyroid irradiation from nuclear accidents. In: Rubery E, Smales E, eds. Iodine prophylaxis following nuclear accidents. Oxford, UK: Pergamon Press, 45–54.
*Delange F. 1996. Administration of iodized oil during pregnancy: A summary of the published evidence. Bull W H O 74(1):101–108.8653811
Delange F. 1998a. Screening for congenital hypothyroidism used as an indicator of the degree of iodine deficiency and of its control. Thyroid 8(12):1185–1192.9920376
Delange F. 1998b. Search for effective immunomodulating strategies against sepsis. Lancet 351:922–923.9734931
*Delange FM, Ermans A-M. 1996. Iodine deficiency. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 296–316.
Delange F, Lecomte P. 2000. Iodine supplementation. Benefits outweigh risks. Drug Saf 22(2):89–95.10672891
Delange F, Chanoine JP, Abrassari C, . 1988. Topical iodine, breastfeeding, and neonatal hypothyroidism [Letter]. Arch Dis Child 63(1):106–107.
*Delange F, de Benoist B, Alnwick D. 1999. Risks of iodine-induced hyperthyroidism after correction of iodine deficiency by iodized salt. Thyroid 9(6):545–556.10411116
Delange F, de Benoist B, Burgi H, . 2002. Determining median urinary iodine concentration that indicates adequate iodine intake at population level. Bull World Health Organ 80(8):633–636.12219154
Delange F, Van Minh N, Vanderlinden L, . 1980. Influence of goitrogens in pregnant and lactating rats on thyroid function in the pups. In: Ermans AM, Mbulamoko NM, Delange F, ., eds. Role of cassava in the etiology of endemic goitre and cretinism, 167–182.
Delange F, Wolff P, Gnat D, . 2001. Iodine deficiency during infancy and early childhood in Belgium: Does it pose a risk to brain development? Eur J Pediatr 160(4):251–254.11317650
*Dellavalle ME, Barbano DM. 1984. Iodine content of milk and other foods. J Food Prot 47:678–684.30934447
Deleu S, Allory Y, Radulescu A, . 2000. Characterization of autonomous thyroid adenoma: Metabolism, gene expression, and pathology. Thyroid 10(2):131–140.10718549
DeLong GR. 1996. ‘Iodine and brain development’ [Letter]. Dev Med Child Neurol 38:278–282.8631525
*De Luca Rebello A, Herms FW, Wagener K. 1990. The cycling of iodine as iodate and iodide in a tropical estuarine system. Marine Chemistry 29:77–93.
Demangeat K-L, Lautier F, Demangeat C, . 1982. [Consequences of the chronic cutaneous application of iodinated antiseptics on the thyroid function in the guinea-pig.] Zentralbl Bakteriol [B] 176:277–290. (German)
*Deme D, Doussuere J, de Sandro V . 1994. The Ca^2+^/NADPH-dependent H_2_O_2_ generator in thyroid plasma membrane: Inhibition by diphenyleneiodium.
Demir M, Kabasakal L, Onsel C. 1996. Evaluation of external radiation exposure rate from radioiodine­ treated hyperthyroid patients and radiation safety considerations. Nucl Med Commun 17:692–695.8878129
Denef J-F, Many M-C, van den Hove MF. 1996. Iodine-induced thyroid inhibition and cell necrosis: Two consequences of the same free-radical mediated mechanism? Mol Cell Endocrinol 121:101–103.8865171
Denham MJ, Himsworth RL. 1974. Hyperthyroidism induced by potassium iodide given in the course of ^125^I-fibrinogen test. Age Ageing 3:221–225.4458424
De Prospo N, De Martino LJ, McGuinness ET. 1968. Melatonin’s effect on ^131^I uptake by the thyroid glands in normal and ovariectomized rats. Life Sci 7:183–188.5639817
*Derwahl M, Studer H. 2001. Nodular goiter and goiter nodules: Where iodine deficiency falls short of explaining the facts. Exp Clin Endocrinol Diabetes 109(5):250–260.11507648
Derwahl M, Manole D, Sobke A, . 1998. Pathogenesis of toxic thyroid adenomas and nodules: Relevance of activating mutations in the TSH-receptor and Gs-alpha gene, the possible role of iodine deficiency and secondary and TSH-independent molecular mechanisms. Exp Clin Endocrinol Diabetes 106(Suppl 4):S6–S9.9867188
De Sandro V, Catinot R, Kriszt W, . 1992. Male rat hepatic UDP-glucuronosyltransferase activity toward thyroxine: Activation and induction properties-relation with thyroxine plasma disappearance rate. Biochem Pharmacol 43(7):1563–1569.1567478
DeSantis DM, Chabot GE. 2001. An alternative method for the release criteria and calculation of the total dose equivalent to another individual from a patient treated with a therapeutic dose of ^131^I. Health Phys 81(1):15–26.11414620
De Vathaire F, Fragu P, Francois P, . 1993. Long-term effects on the thyroid of irradiation for skin angiomas in childhood. Radiat Res 133:381–386.8451391
De Vathaire F, Le Vu B, Challeton-De Vathaire C. 2000. Thyroid cancer in French Polynesia between 1985 and 1995: Influence of atmospheric nuclear bomb tests performed at Mururoa and Fangataufa between 1966 and 1974. Cancer Causes Control 11(1):59–63.10680730
*De Vathaire F, Schlumberger M, Delisle MJ, . 1997. Leukemia and cancers following iodine-131 administration for thyroid cancer. Br J Cancer 75(5):734–739.9043033
Deves JR, Tonkin JP. 1980. Vocal cord paralysis in benign thyroid disease before operation. Med J Aust 2(11):632.
de Vijlder JJM, Vulsma T. 1996. Hereditary metabolic disorders causing hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 749–755.
DeWitte M, Eberhart RJ, Griel LCJ. 1980. Mastitis caused by teat-dipping error. Vet Med Small Anim Clin 75(10):1613–1616.6904078
*de Zegher F, Vanhole C, Van den Berghe G, . 1994. Properties of thyroid-stimulating hormone and cortisol secretion by the human newborn on the day of birth. J Clin Endocrinol Metab 79:576–581.8045979
Diamond ML, Mackay D, Cornett RJ, . 1990. A model of the exchange of inorganic chemicals between water and sediments. Environ Sci Technol 24:713–722.
*Dickman PW, Holm LE, Lundell G, . 2003. Thyroid cancer risk after thyroid examination with 131I: a population-based study. Int J Cancer 10(106):580–587.
Dienhart KJ. 1974. Suppurative ulcerating iododerma [Letter]. N Engl J Med 290(9):521.
Dietlein M, Dederichs B, Weigand A, . 1999. Radioiodine therapy and thyroid-associated orbitopathy: Risk factors and preventive effects of glucocoticoids. Exp Clin Endocrinol Diabetes 107:S190–S194.10614920
*Dietrich AM, Costa WFD. 1997. Measurement and monitoring of pollutants. Chemical species. Water Environ Res 69(4):391–403.
Di Girolamo M, D’Arcangelo D, Bizzarri C, . 1991. Muscarinic regulation of phospholipase A_2_ and iodide fluxes in FRTL-5 thyroid cells. Acta Endocrinol 125:192–200.
Di Lauro E. 1966. [Ludwig’s pseudoangina due to iodism.] Ann Laringol Otol Rinol Faringol 65(2):261–263. (Italian)5952880
Dixon GW. 1996. Processed product for skin and hair treatment. Application: USA 5,554,361, 10 Sep 1996. USA Patent 5,554,361, issued 10 Sep 1996.
Dluhy RG. 1996a. The adrenal cortex in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 841–844.
Dluhy RG. 1996b. The adrenal cortex in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 656–660.
Dmitrev AI, Istomina GN. 1978. [Long term changes in the endurance of rats after combined external gamma irradiation and contamination with radioactive iodine.] Radiobiologiia 18(5):777–779. (Russian)715210
DNA. 1992. Evaluation of residual radioactivity in human tissues associated with weapons testing at the Nevada test site. Alexandria, VA: Defense Nuclear Agency. DNA-TR-91-166.
Dobyns BM. 1975. Radiation effects of radioiodine on the thyroid: Effects vary with dosage and sensitivity of the gland to radiation. R I Med J 58(3):94–97.124920
Dobyns BM, Sheline GE, Workman JB, . 1974. Malignant and benign neoplasms of the thyroid in patients treated for hyperthyroidism: A report of the cooperative thyrotoxicosis therapy follow-up study. J Clin Endocrinol 38:976–998.
*Docter R, Krenning EP, Bernard HF, . 1987. Active transport of iodothyronines into human cultured fibroblasts. J Clin Endocrinol Metab 65(4):624–628.2443527
*DOE. 1954. Thyroid absorbed dose for people at Rongelap, Utirik, and Sifo on March 1, 1954. U.S. Department of Energy. BNL 51882.
*DOE. 1978a. Iodine-129: A review of its potential impact on the environment. U.S. Department of Energy. NTIS Y/OWI/Sub-7278/1.
*DOE. 1978b. Methodology for the determination of environmental exp 129 U and exp 99 TC. U.S. Department of Energy. NTIS DPMS7775.
DOE. 1980. Measurements of deposition and biological half-life of iodine on vegetation. Washington, DC: U.S. Department of Energy. NTIS DE83000759.
DOE. 1985. Volatilization of iodine from soils and plants. Washington, DC: U.S. Department of Energy. NTIS DE85018226.
*DOE. 1986. U.S. Department of Energy. A literature review of the concentration ratios of selected radionuclides in freshwater and marine fish. NTIS DE86 015820. 1021, 82–87, 243–272.
*DOE. 1990. U.S. Department of Energy. Savannah River site radionuclide atmospheric releases and offsite maximum doses. NTIS DE93 004259.
DOE. 1992a. Analysis of iodine-129 in aqueous samples by inductively coupled plasma-mass spectrometry. Washington, DC: U.S. Department of Energy. NTIS DE93002694.
DOE. 1992b. Chemical contaminants on DOE lands and selection of contaminant mixtures for subsurface science research. Washington, DC: U.S. Department of Energy. NTIS DE92-014826.
DOE. 1992c. External radiation doses in a household from a patient receiving a therapeutic amount of ^131^I. New York, NY: U.S. Department of Energy, Environmental Measurements Laboratory. EML-547.
DOE. 1992d. National low-level waste management program radionuclide report series: Volume 4: Iodine-129. Idaho: U.S. Department of Energy, Office of Environmental Restoration and Waste Management, Idaho Field Office. NTIS DE93 007049.
*DOE. 1993. U.S. Department of Energy. Air pathway effects of nuclear materials production at the Hanford site, 1983 to 1992. NTIS DE94002708.
*DOE. 1994. U.S. Department of Energy. Iodine-129 in the Snake River plain aquifer at and near the Idaho National Engineering Laboratory, Idaho, 1990-91. NTIS DE95001913.
DOE. 1995. U.S. Department of Energy. Technetium-99, iodine-129 and tritium in the waters of the Savannah River site. NTIS DE95004803.
*DOE. 1996a. Closing the circle on the splitting of the atom: The environmental legacy of nuclear weapons production in the United States and what the department of energy is doing about it. Washington, DC: Office of Environmental Management, U.S. Department of Energy. DOE/EM-0266.
*DOE. 1996b. Selected radionuclides important to low-level radioactive waste management: National low-level waste management program. U.S. Department of Energy. DOE/LLW-238.
DOE. 1996c. Radiological effluents released from U.S. continental tests 1961 through 1992. Nevada: U.S. Department of Energy, Nevada Operations Office. NTIS DOE/NV-317.
*DOE. 1996d. High-level waste inventory, characteristics, generation, and facility assessment for treatment, storage, and disposal alternatives considered in the U.S. Department of Energy.
*DOE. 1998. Assessment of radionuclides in the Savannah River Site. Environmental summary. Oak Ridge TN: US Department of Energy. Office of Scientific and Technical Information. DE-AC09­ 96SR18500.
*DOE. 1999. In: Arnett MW, Mamatey AR, eds. Savannah River site environmental data for 1999. Oak Ridge TN: U.S. Department of Energy Office of Scientific and Technical Information. DE-AC09-96SR18500.
*DOE. 2001a. Derived air concentrations (DAC) for workers from external exposure during immersion in a contaminated atmospheric cloud. U.S. Department of Energy. Code of Federal Regulations. 10 CFR 835, Appendix C. http://ecfrback.access.gpo.gov/otcgi/otfilter.cgi….cgi…d&QUERY=159004&RGN=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM-1. May 16, 2001.
*DOE. 2001b. Derived air concentrations (DAC) for controlling radiation exposure to workers at DOE facilities. U.S. Department of Energy. Code of Federal Regulations. 10 CFR 835, Appendix A. http://ecfrback.access.gpo.gov/otcgi/otilter.cgi…d&QUERY=22008*RGN=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. May 16, 2001.
*DOE. 2001c. Values for establishing sealed radioactive source accountability and radioactive material posting and labeling requirements. U.S. Department of Energy. Code of Federal Regulations. 10 CFR 835, Appendix E. http://ecfrback.access.gpo.gov/otcgi/. May 16, 2001.
*DOE. 2001d. Timeline/Milestones for the Yucca Mountain Project. http://www.ymp.gov/timeline/index.htm. May 10, 2001.
Doniach I. 1956. Comparison of the carcinogenic effect of x-irradiation with radioactive iodine on the rat’s thyroid. Br J Cancer XI:67–76.
Doniach I. 1963. Effects including carcinogenesis of I^131^ and x-rays on the thyroid of experimental animals: A review. Health Phys 9:1357–1362.14086683
Donaich I. 1974. Carcinogenic effect of 100, 250 and 500 rad x-rays on the rat thyroid gland. Br J Cancer 30:487–495.4447781
Doniach I, Logothetopoulos JH. 1955. Effects of radioactive iodine on the rat thyroid’s function, regeneration and response to goitrogens. Br J Cancer IX:117–127.
Doniach I, Shale DJ. 1976. Biological effects of ^131^I and ^125^I isotopes of iodine in the rat. J Endocrinol 71:109–114.978110
Donaich I, Williams ED. 1986. Biologic effects of radiation on the thyroid. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott, 432–444.
Donovan JW, Adelstein AM. 1974. Mutiple-cause analysis of deaths of patients treated with radio-iodine. Br J Prev Soc Med 28:69.
Doshi GR, Joshi SN, Pillai KC. 1991. ^129^I in soil and grass samples around a nuclear reprocessing plant. J Radioanal Nucl Chem 155(2):115–127.
*DOT. 2001a. Shippers-general requirements for shipments and packagings. Table of A1 and A2 values for radionuclides. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 173.435. http://ecfrback.access.gpo.gov/otcgi/cfr/ May 16, 2001.
*DOT. 2001b. List of hazardous substances and reportable quantities. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101, Appendix A. http://ecfrback.access.gpo.gov/. May 16, 2001.
Dottorini ME. 1996. Genetic risk assessment after iodine-131 exposure: An opportunity and obligation for nuclear medicine. J Nucl Med 37(4):612–615.8691250
Dottorini ME, Lomuscio G, Mazzucchelli L, . 1995. Assessment of female fertility and carcinogenesis after iodine-131 therapy for differentiated thyroid carcinoma. J Nucl Med 36:21–27.7799075
Douglas WS, Alexander JOD. 1975. Dermatitis herpetiformis, iodine compounds and thyrotoxicosis [Letter]. Br J Dermatol 92(5):596–598.1174473
Downie SE, Wasnidge C, Floto F, . 1977. Lithium-induced inhibition of ^125^I accumulation by thyroids and growing oocytes of Japanese quail. Poult Sci 56:1254–1258.605082
Draper A, Lewis J, Malhotra N, . 1993. The energy and nutrient intakes of different types of vegetarian: A case for supplements. Br J Nutr 69:3–19.8457537
Dreicer M, Bouville A. 1989. Variability of I-131 thyroid doses from Nevada weapons testing: Discussion of the most sensitive parameters. Health Phys 56(Suppl 1):S51.
Dreicer M, Bouville A, Wachholz BW. 1990. Pasture practices, milk distribution, and consumption in the continental U.S. in the 1950’s. Health Phys 59(5):627–636.2211120
*Dremier S, Coppee F, Delange F, . 1996. Clinical review 84: Thyroid autonomy: Mechanism and clinical effects. J Clin Endocrinol Metab 81(12):4187–4193.8954013
Drew B, Barber WP, Williams DG. 1975. The effect of excess dietary iodine on pregnancy mares and foals. Vet Rec 97:93–95.1154632
Driscoll J, Hintz HF, Schryver HF. 1978. Goiter in foals caused by excessive iodine. J Am Vet Med Assoc 173:858–859.711608
*Drobyshevskaya IM, Astakhova LN, Nalivko AS, . 1996. Thyroid cancer in children of Belarus following the Chernobyl accident. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, the Netherlands: Elsevier, 49–65.
Duan SB, Wu HW, Luo JA, . 1999. Assessment of renal function in the early stages of nephrotoxicity induced by iodinated contrast media. Nephron 83:122–125.10516490
Duan Y, Zhang H, Jiang X, . 1995. A simple, innovative method for the determination of iodide by using gas-phase molecular absorption spectrometry after volatile species evolution. J Environ Sci Health Part A 30(7):1577–1593.
Duffy BJ, Fitzgerald PJ. 1950. Cancer of the thyroid in children: A report of 28 cases. J Clin Endocrinol Metab 10:1296–1308.14794754
*Duffield AJ, Thomson CD, Hill KE, . 1999. An estimation of selenium requirements for New Zealanders. Am J Clin Nutr 70:896–903.10539752
Dugrillon A. 1996. Iodolactones and iodoaldehydes-mediators of iodine in thyroid autoregulation. Exp Clin Endocrinol Diabetes 104(Suppl 4):41–45.8981000
Dugrillon A, Gartner R. 1992. The role of iodine and thyroid cell growth. Thyroidology 4:31–36.1284330
Dugrillon A, Gartner R. 1995. Gamma-iodolactones decrease epidermal growth factor-induced proliferation and inositol-1,4,5-triphosphate generation in porcine thyroid follicles-a possible mechanism of growth inhibition by iodide. Eur J Endocrinol 132:735–743.7788015
Dugrillon A, Bechtner G, Uedelhoven WM, . 1990. Evidence that an iodolactone mediates the inhibitory effect of iodide on thyroid cell proliferation but not on adenosine 3’,5’-monophosphate formation. Endocrinology 127(1):337–343.2163315
Dugrillon A, Uedelhoven WM, Pisarev MA, . 1994. Identification of gamma-iodolactone in iodide treated human goiter and its inhibitory effect on proliferation of human thyroid follicles. Horm Metab Res 26:465–469.7851869
Dumas D, Guibout M. 1978. Effect of catecholamines on iodide transport in isolated thyroid cells. FEBS Lett 88(2):287–291.206465
Dumont JE. 1991. Iodine supply in diet in various European regions and risks of iodine prophylaxis. In: Gerber G, ed. Improvement of practical countermeasures: Preventive medication. Commission of the European Communities. EUR 12256:19–34.
Dumont JE, Corvilain B, Contempre B. 1994. The biochemistry of endemic cretinism: Roles of iodine and selenium deficiency and goitrogens. Mol Cell Endocrinol 100:163–166.7520008
Dunn AD. 1996. Thyroglobulin retrieval and the endocytic pathway. In: Braverman LW, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 81–84.
Dunn JT. 1993. Iodine supplementation and the prevention of cretinism. Ann N Y Acad Sci 678:158–168.8494259
Dunn JT. 1996. Thyroglobulin: Chemistry and biosynthesis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 85–95.
Dunn JT, Dunn AD. 2001. Update in intrathyroidal iodine metabolism. Thyroid 11(5):407–414.11396699
Dunn JT, Semigran MJ, Delange F. 1998. The prevention and management of iodine-induced hyperthyroidism and its cardiac features. Thyroid 8(1):101–106.9492159
*Dunn MJ, Dunscombe PB. 1981. Levels of airborne ^125^I during protein labeling. Radiat Prot Dosim 1(2):143–146.
*Dunning DE, Schwarz G. 1981. Variability of human thyroid characteristics and estimates of dose from ingested ^131^I. Health Phys 40:661–675.7263254
Dunscombe PB, Dunn MJ, Bhattacharyya AK. 1980. Activated carbon badges as detectors of airborne ^125^I. Health Phys 39:717–721.7204023
*Dupuy C, Virion A, de Sandro V . 1991. Mechanism of hydrogen peroxide formation catalyzed by NADPH oxidase in thyroid plasma membrane. J Biol Chem 266:3739–3743.1995628
Dussault JH. 1990. Thyroid antibodies in congenital hypothyroidism. In:, ed. Transplacental disorders: Perinatal detecion, treatment and management (including pediatric AIDS). Alan R. Liss, Inc., 77–83.
DuVaull GE, Dunn WE, Ljegren JC, . 1989. Field measurement and model evaluation program for assessment of the environmental effects of military smokes: Analysis methods and results of hexachloroethane smoke dispersion experiments conducted as part of Atterbury-87 field studies. Fort Detrick, Frederick, MD: U.S. Army Medical Research and Development Command. AD A 216 048.
Dwivdei R, Skierczynski P, Park H-M. 2002. Thymus gland uptake of radioactive iodine. Thyroid 12(2):179–180.11916289
Dybing E, Sanner T. 1999. Species differences in chemical carcinogenesis of the thyroid gland, kidney and urinary bladder. In: Capen CC, Dybing E, Rice JM, ., eds. Species differences in thyroid, kidney and urinary bladder carcinogenesis. Lyon, France: International Agency for Research on Cancer, 15–32.
*Dyck RF, Bear RA, Goldstein MB, . 1979. Iodine/iodide toxic reaction: Case report with emphasis on the nature of the metabolic acidosis. Can Med Assoc J 120:704–706.35279
*Dydek GJ, Blue PW. 1988. Human breast milk excretion of iodine-131 following diagnostic and therapeutic administration to a lactating patient with Graves’ disease. J Nucl Med 29:407–410.3346746
*Dyer NC, Brill AB. 1972. Maternal-fetal transport of iron and iodine in human subjects. Adv Exp Med Biol 27:351–366.4680130
*Eadie AS, Horton PW, Hilditch TE. 1980. Monitoring of airborne contamination during the handling of technetium-99m and radioiodine. Phys Med Biol 25(6):1079–1087.7208620
*Ebner SA, Lueprasitsakul W, Fang AS, . 1992. Iodine content of rat thyroglobin affects its antigenicity in inducing lymphocytic thyroiditis in the BB/Wor rat. Autoimmunity 13(3):209–214.1472632
*Eckhardt K, Gocke E, King M-T, . 1982. Mutagenic activity of chlorate, bromate, and iodate. Mutat Res 97:185.
Edington GM. 1976. Dietary iodine and risk of breast, endometrial, and ovarian cancer. Lancet 1(7974):1413–1414.
Edmonds CJ, Smith T. 1986. The long-term hazards of the treatment of thyroid cancer with radioiodine. Br J Radiol 59:45–51.3947807
*Eeckhout E, Willemsen M, Deconinck A, . 1987. Granulomatous vasculitis as a complication of potassium iodide treatment for Sweet’s syndrome. Acta Derm Venereol (Stockh) 67(4):362–364.2445160
Egan RW, Gale PH, Beveridge GC, . 1978. Radical scavenging as the mechanism for stimulation of prostaglandin cyclooxygenase and depression of inflammation by lipioc acid and sodium iodide. Prostaglandins 16(6):861–869.107544
Ehrfeld A, Planas-Bohne F, Lucke-Huhle C. 1986. Amplification of oncogenes and integrated SV40 sequences in mammalian cells by the decay of incorporated iodine-125. Radiat Res 108:43–51.3022326
Einhorn N, Wasserman J, Packalen T. 1970. Cellular autoimmune reactions following radioiodine treatment for hyperthyroidism. Acta Radiol Ther Phys Biol 9:225–232.4916356
*Eipe J, Johnson SA, Kiamko RT, . 1968. Hypoparathyroidism following ^131^I therapy for hyperthyroidism. Arch Intern Med 121:270–272.5642747
*Eisenbud M, ed. 1987. Environmental radioactivity: From natural, industrial, and military sources. New York, NY: Academic Press, Inc.
*Eisenbud M, Mochizuki Y, Laurer G. 1963. ^131^ dose to human thyroids in New York City from nuclear tests in 1962. Health Phys 9:1291–1298.14086676
Ekholm R. 1981. Iodination of thyroglobulin: An intracellular or extracellular process? Mol Cell Endocrinol 24:141–163.7028537
*Ekman L, Eriksson A, Fredriksson L, . 1967. Studies on the relationship between iodine-131 deposited on pasture and its concentration in milk. Health Phys 13:701–706.6026816
Ellingsen DG, Efskind J, Haug E, . 2000. Effects of low mercury vapour exposure on the thyroid function in Chloralkali workers. J Appl Toxicol 20(6):483–489.11180271
Elliott JE, Scheuhammer AM. 1997. Heavy metal and metallothionein concentrations in seabirds from the Pacific coast of Canada. Mar Pollut Bull 34(10):794–801.
Elmalak O, Lovich MA, Edelman E. 2000. Correlation of transarterial transport of various dextrans with their physicochemical properties. Biomaterials 21(22):2263–2272.11026632
*Elmore D, Phillips FM. 1987. Accelerator mass spectrometry for measurement of long-lived radioisotopes. Science 236:543–550.17740475
*Elmore D, Gove HE, Ferraro R, . 1980. Determination of ^129^I using tandem accelerator mass spectrometry. Nature 286:138–140.
*Elnagar B, Eltom M, Karlsson FA, . 1995. The effects of different doses of oral iodized oil on goiter size, urinary iodine, and thyroid-related hormones, J Clin Endocrinol Metab 80(3):891–897.7883848
Elnour A, Hambraeus L, Elton M, . 2000. Endemic goiter with iodine sufficiency: A possible role for the consumption of pearl millet in the etioloy of endemic goiter. Am J Clin Nutr 71(1):59–66.10617947
Elstner EF, Adamczyk R, Kroner R, . 1985. [Uptake and biochemical activity of potassium iodide in isolated rabbit eyes.] Ophthalmologica 191:122–126. (German)4058858
Eltom A, Elnagar B, Gebre-Medhin M. 1999. Thyroid hormones and iodine status in Sudanese pregnant women with goitre. Int J Food Sci Nutr 50:105–109.10616650
Eltom A, Eltom M, Elnagar B, . 2000. Changes in iodine metabolism during late pregnancy and lactation: A longitudinal study among Sudanese women. Eur J Clin Nutr 54(5):429–433.10822292
Eltom A, Eltom M, Idris M, . 2001. Thyroid function in the newborn in relation to maternal thyroid status during labour in a mild iodine deficiency endemic area in Sudan. Clin Endocrinol 2001(55):485–490.
Emerson CH. 1996. Thyroid disease during and after pregnancy. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 1021–1031.
EML. 1992. EML Procedures Manual, 27^th^ ed, Vol 1, February 1992. Environmental Measurements Laboratory, U.S. Department of Energy.
*EML. 1997. EML Procedures Manual, HASL-300, 28^th^ ed, Vol 1, February 1997. Environmental Measurements Laboratory, U.S. Department of Energy.
Emrich D. 1977. [Effect of etiroxate hydrochloride on iodine metabolism in man.] Arzneim Forsch 27(2):422–426. (German)405021
Emrich D, Schicha H, Facorro U, . 1980. Correlation of iodine excretion to hormone concentrations in different states of thyroid function. J Mol Med 4:183–189.
*Endo T, Kaneshige M, Nakazato M, . 1997. Thyroid transcription factor-1 activated the promoter activity of rat thyroid Na^+^/I^−^ symporter gene. Mol Endocrinol 11:1747–1755.9328356
*Eng PHK, Cardona GR, Fang S-L, . 1999. Escape from the acute Wolff-Chaikoff effect is associated with a decrease in thyroid sodium/iodide symporter messenger ribonucleic acid and protein. Endocrinology 140:3404–3410.10433193
*Engler D, Burger AG. 1984. The deiodination of the iodothyronines and of their derivatives in man. Endocrine Rev 5(2):151–184.6376077
Engler H, Taurog A, Luthy C, . 1983. Reversible and irreversible inhibition of thyroid peroxidase-catalyzed iodination by thioureylene drugs. Endocrinology 112(1):86–95.6847836
*Environcare. 2001. Envirocare receives first low-level shipments from LEHR. http://www.envirocareutah.com. May 22, 2001.
EPA. 1974. The behavior of ^131^I in an artificial rumen and in the stimulated fluids of the abomasum and intestine. Las Vegas, NV: U.S. Environmental Protection Agency. NERC-LV-539-32.
EPA. 1975. ^131^I levels in cow’s milk following ingestion of contaminated alfalfa or sudan grass. Las Vegas, NV: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory, Monitoring Systems Research and Development Division. EMSL-LV-539-1.
*EPA. 1976. Interim radiochemical methodology for drinking water. Cincinnati, OH. U.S. Environmental Protection Agency. Environmental Monitoring and Support Laboratory. EPA 600/4-75-008.
EPA. 1978. Follow-up of patients receiving diagnostic doses of 131 iodine during childhood. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Health Effects Research Laboratory. EPA-600/1-78-059.
*EPA. 1980. Method 902.0. Prescribed procedures for measurement of radioactivity in drinking water. Cincinnati, OH. U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA-600/4-80-032.
*EPA. 1983. Method 345.1. Methods for chemical analysis of water and wastes. Cincinnati, OH: U.S Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA-600/4-79-020.
*EPA. 1986. Iodination of nutrients in the presence of chlorine based disinfectants used in drinking water treatment. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Health Effects Research Laboratory. NTIS PB87180683.
*EPA. 1988. Limiting values of radionuclide intake and air concentration and dose conversion factors for inhalation, submersion, and ingestion. Federal Guidance Report No. 11. Office of Radiation and Indoor Air. U.S. Environmental Protection Agency. EPA-520/1-88-020.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA 600/8-90/066A.
*EPA. 1993. External exposure to radionuclides in air, water, and soil. Federal Guidance Report No. 12. Office of Radiation and Indoor Air. U.S. Environmental Protection Agency. EPA-402-R-93-081.
EPA. 1994. Estimating radiogenic cancer risks. Washington, DC: U.S. Environmental Protection Agency, Office of Radiation and Indoor Air. EPA 402-R-93-076. NTIS PB96-139860.
EPA. 1997a. Environmental radiation data report 79: July - September 1994. Montgomery, AL: U.S. Environmental Protection Agency, National Air and Radiation Environmental Laboratory. NTIS EPA-402-R-97-002.
EPA. 1997b. Environmental radiation data report 80: October-December 1994. Montgomery, AL: U.S. Environmental Protection Agency, National Air and Radiation Environmental Laboratory. NTIS EPA-402-R-97-003.
EPA. 1997c. Environmental radiation data report 81: January - March 1995. Montgomery, AL: U.S. Environmental Protection Agency, National Air and Radiation Environmental Laboratory. NTIS EPA-402-R-97-004.
EPA. 1997d. Environmental radiation data report 82: April-June 1995. Montgomery, AL: U.S. Environmental Protection Agency, National Air and Radiation Environmental Laboratory. NTIS EPA-402-R-97-005.
EPA. 1997e. U.S. Environmental Protection Agency. National primary drinking water regulations: Analytical methods for radionuclides; Final Rule and Proposed Rule. Fed Reg 62(43):10167–10174.
*EPA. 1997f. Exposure factors handbook. Vol 1. General factors. Washington, DC: U.S. Environmental Protection Agency. EPA/600/P-95/002Fa.
*EPA. 1997g. Health Effects Assessment Summary Tables. FY-1997 Update. Office of Research and Development, Office of Emergency and Remedial Response. Washington, DC: U.S. Environmental Protection Agency. EPA/540/R-97/036. NTIS PB 97-921199.
*EPA. 1998. United States Environmental Protection Agency. Health risks from low-level environmental exposure to radionuclides. Office of Radiation and Indoor Air. EPA 402-R-97-014.
*EPA. 1999. Cancer risk coefficients for environmental exposure to radionuclides. Federal Guidance Report No. 13. Office of Radiation and Indoor Air. U.S. Environmental Protection Agency. EPA402-R-99-001.
*EPA. 2001a. Annual possession quantities for environmental compliance. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Appendix E, Table 1. http://ecfrback.access.gpo.gov/otcgi/. May 16, 2001.
*EPA. 2001b. Iodine production subcategory. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 415, Subpart AQ. http://ecfrback.access.gpo.gov/otcgi/cfr…1&RGN=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. May 16, 2001.
*EPA. 2002a. Perchlorate environmental contamination: Toxicological review and risk characterization. U.S. Environmental Protection Agency. Office of Research and Development. NCEA-1-0503.
*EPA. 2002b. Radionuclide carcinogenicity slope factors. U.S. Environmental Protection Agency. Washington, DC. http://www.epa.gov/radiation/heast/docs/heast2_table_4-d2_0401.pdf. November 1, 2002.
*ERD 1993. Environmental Radiation Data Report 75, July-September 1993. Environmental Protection Agency http://www.epa.gov/narel/erdonline.htm.
*ERD 1997. Environmental Radiation Data Report 91, July-September 1997. Environmental Protection Agency http://www.epa.gov/narel/erdonline.htm.
ERDA. 1978. Iodine-129 in thyroids and tellurium isotopes in meteorites by neutron activation analysis. U.S. Energy Research and Development Administration. NTIS COO24501.
Ericson LE, Nilsson M. 1996. Effects of insulin-like growth factor I on growth, epithelial barrier and iodide transport in polarized pig thyrocyte monolayers. Eur J Endocrinol 135:118–127.8765983
*Ermans AM, Camus M. 1972. Modifications of thyroid function induced by chronic administration of iodide in the presence of >>autonomous<< thyroid tissue. Acta Endocrinol 70:463–475.
*Eskandari S, Loo DD, Dai G, . 1997. Thyroid Na+/I− symporter: Mechanism, stoichiometry, and specificity. J Biol Chem 272(43):27230–27238.9341168
*Eskin BA. 1970. Iodine metabolism and breast cancer. Trans N Y Acad Sci 32(8):911–947.5279909
Eskin BA. 1976. Dietary iodine and cancer risk [Letter]. Lancet 2(7989):807.
Eskin BA. 1977. Iodine and mammary cancer. Adv Exp Med Biol 91:293–304.343535
Eskin BA, Merion JA, Stamieszkin I. 1976. Estrogen-iodine interaction in breast dysplasia. [Abstract]. Proc Am Assoc Cancer Res 17:169.
Eskin BA, Shuman R, Krouse T, . 1975. Rat mammary gland atypia produced by iodine blockade with perchlorate. Cancer Res 35:2332–2339.167953
*Esselstyn CB, Schumacher OP, Eversman J, . 1982. Hyperparathyroidism after radioactive iodine therapy for Graves disease. Surgery 92:811–813.6897129
Eszlinger M, Krohn K, Kratzsch J. 2001. Growth factor expression in cold and hot thyroid nodules. Thyroid 11(2):125–135.11288981
Etling N, Gehin-Fouque F. 1984. Iodinated compounds and thyroxine binding to albumin in human breast milk. Pediatr Res 18(9):901–903.6435083
*Etling N, Vielh JP. 1979. [Iodine overloads in amniotic fluids.] Nouv Presse Med 8:1647–1648. (French)471733
*Etling N, Gehin-Fouque F, Vielh JP, . 1979. The iodine content of amniotic fluid and placental transfer of iodinated drugs. Obstet Gynecol 53(3):376–380.424113
*Etling N, Padovani E, Gehin-Fouque F, . 1983. Iodine and thyroid hormone levels in serum and urine of full term newborn infants. Helv Paediatr Acta 38:117–122.6874381
Evans PMS, Webster J, Evans WD, . 1998. Radioiodine treatment in unsuspected pregnancy. Clin Endocrinol 48:281–283.
*Evans TC, Kretzschmar RM, Hodges RE, . 1967. Radioiodine uptake studies of the human fetal thyroid. J Nucl Med 8:157–165.6024129
Exss R, Graewe B. 1974. Congenital athyroidism in the newborn infant from intra-uterine radioiodine action. Biol Neonate 24:289–291.
Fagin JA. 1996. Molecular pathogenesis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 909–916.
Fanelli A, Berlin WK, Grollman EF. 1995. Inhibition of iodide transport in rat thryoid cells using N-substituted anthranilic acid derivatives. Thyroid 5(3):223–230.7580272
Farris WT, Napier BA, Ikenberry TA, . 1996. Radiation doses from Hanford site releases to the atmosphere and the Columbia river. Health Phys 71:588–601.8830759
Fatourechi V. 1996. Localized myxedema and thyroid acropachy. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 553–558.
*Fawcett DM, Kirkwood S. 1953. The mechanism of the antithyroid action of the iodide ion and of the “aromatic” thyroid inhibitors. Journal of Biological Chemistry 204:787–796.13117855
FDA. 1973. Scientific literature reviews on generally recognized as safe (GRAS) food ingredients - Iodine and iodine salts. Washington, DC: U.S. Food and Drug Administration. PB 223 849.
*FDA. 1974. Iodine in foods: Chemical methodology and sources of iodine in the human diet. Washington, DC: U.S. Food and Drug Administration, Bureau of Foods, Division of Nutrition. PB-233-559.
*FDA. 1978. Potassium iodide as a thyroid-blocking agent in a radiation emergency. U.S. Food and Drug Administration. Federal Register 43:58798–800.
FDA. 1989a. A follow-up study of persons who had iodine-131 and other diagnostic procedures during childhood and adolescence. Rockville, MD: U.S. Food and Drug Administration, Public Health Service, Center for Devices and Radiological Health. FDA 89-8276.
*FDA. 1989b. Iodine toxicity. Washington, DC: U.S. Food and Drug Administration, Center for Food Safety and Applied Nutrition. NTIS PB89 183016.
*FDA. 1998. Accidental radioactive contamination of human food and animals feeds: Recommendations for state and local agencies. U.S. Department of Health and Human Services. Food and Drug Administration. Center for Devices and Radiological health. Rockville, MD 20850. August 13, 1998.
*FDA. 2000a. Drug products containing certain active ingredients offered over-the-counter (OTC) for certain uses. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 310.545. http://frewebgate.access.gpo.gov/. May 16, 2001.
*FDA. 2000b. Drugs; recommended warning and caution statements. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 369.20. http://frewebgate.access.gpo.gov/. May 16, 2001.
*FDA. 2000c. Food additives permitted for direct addition to food for human consumption. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 172.375. http://frwebgate.access.gpo.gov/. March 06, 2001.
*FDA. 2000d. Indirect food additives: Adjuvants, production aids, and sanitizers. Sanitizing solutions. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 178.1010. http://frewebgate.access.gpo.gov/. May 16, 2001.
*FDA. 2000e. Nutritional labeling of dietary supplements. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 101.36. http://frewebgate.access.gpo.gov/. May 16, 2001.
*FDA. 2000f. Nutritional quality guidelines for foods. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 104.20. http://frewebgate.access.gpo.gov/. May 16, 2001.
*FDA. 2000g. Requirements regarding certain radioactive drugs. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 310.503. http://ecfrback.access.gpo.gov/otcgi/. May 16, 2001.
*FDA. 2000h. Sources of radiation used for inspection of food, for inspection of packaged food, and for controlling food processing. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 179.21. http://ecfrback.access.gpo.gov/otcgi/. May 16, 2001.
*FDA. 2000i. Trace minerals added to animal feed. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 582.80. http://frewebgate.access.gpo.gov/cgi-bin/…&PART=582&SECTION=80&YEAR=2000&TYPE=TEXT. May 16, 2001.
*FDA. 2001a. Nutrients. U.S. Food and Drug Administration. http://www.verity.fda.gov/opacom/laws/fdrgact.htm. March 6, 2001.
*FDA. 2001b. U.S. Food and Drug Administration. Code of Federal Regulations. 21CFR101.9.
*FEDRIP. 2000. Federal Research in Progress. Dialog Information Services, Inc. Palo Alto, CA.
Feek CM, Sawers JS, Irvine WJ, . 1980. Combination of potassium iodide and propanolol in preparation of patients with Graves’ disease for thyroid surgery. N Engl J Med 302:883–885.6892650
Feinendegen LE, Henneberg P, Tisljar-Lentulis G. 1977. DNA strand breakage and repair in human kidney cells after exposure to incorporated iodine-125 and cobalt-60 gamma rays. Curr Top Radiat Res Q 12:436–452.
Feldkamp J, Pascher E, Perniok A, . 1999. Fas-mediated apoptosis is inhibited by TSH and iodine in moderate concentrations in primary human thyrocytes in vitro. Horm Metab Res 31:355–358.10437622
*Feldt-Rasmussen U. 2001. Iodine and cancer. Thyroid 11(5):483–486.11396706
*Fenner FD, Martin JE. 1997. Behavior of Na^131^I and meta(^131^I) iodobenzylguanidine (MIBG) in municipal sewerage. Health Phys 73:333–339.9228168
Ferguson MM, Alexander WD, Connell JMC, . 1984. Peroxidase activity in relation to iodide. 17beta-oestradiol and thioreylene drug uptake in human polymorphoneutrophils. Biochem Pharmacol 33(5):757–762.6324798
Ferriols Lisart F, Rodilla Calvelo F, Ciges Sanmartin E, . 1995. [Use of Lugol to protect thyroid from a radiologic exposure.] Farm Clin 12:683–685. (Spanish)
Field JB, Dekker A, Titus G, . 1979. In vitro and in vivo refractoriness to thyrotropin stimulation of iodine organification and thyroid hormone secretion. J Clin Invest 64:265–271.221545
Fike JR, Gobbel GT, Marton LJ, . 1994. Radiation brain injury is reduced by the polyamine inhibitor alpha-difluoromethylornithine. Radiat Res 138:99–106.8146307
*Filetti S, Rapoport B. 1983. Evidence that an organic iodine attenuates the adenosine 3’5’ monophosphate response to thyrotropin stimulation in thyroid tissue by an action at or near the sdenylate cyclase catalytic unit. Endocrinology 113:1608.6313325
Filetti S, Bidart J-M, Arturi F, . 1999. Sodium/iodide symporter: A key transport system in thyroid cancer cell metabolism. Eur J Endocrinol 141(5):443–457.10576759
*Filistovic V, Nedveckaite T. 1998. Reaction pathways involving ^127^I and ^131^I in the atmospheric air. Environ Phys 20(2):5–12.
*Finkelstein R, Jacobi M. 1937. Fatal iodine poisoning: A clinico-pathologic and experimental study. Adv Intern Med 60:1283–1296.
Fischer PWF, Giroux A. 1993. Iodine content of Canadian retail milk samples II. After the ethylenediamine dihydroiodide ban. Food Res Int 26:277–281.
Fischer PWF, Campbell JS, Giroux A. 1989. Effect of dietary iodine on autoimmune thyroiditis in the BB Wistar rat. J Nutr 119:502–507.2921647
Fischman RA, Fairclough GF, Cheigh JS. 1978. Iodide and negative anion gap [Letter]. N Engl J Med 298(18):1035–1036.
Fish RE, Swanson EW. 1982. Effects of excessive intakes of iodine upon growth and thyroid function of growing Holstein heifers. J Dairy Sci 65:605–610.7096725
Fisher DA. 1989. Upper limit of iodine in infant formulas. J Nutr 119:1865–1868.2693650
Fisher DA. 1996. Thyroid physiology in the perinatal period and during childhood. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 974–983.
*Fisher DA, Oddie TH, Burroughs JC. 1962. Thyroidal radioiodine uptake rate measurement in infants. Am J Dis Child 103:738–749.13893227
*Fisher DA, Oddie TH, Epperson D. 1965. Effect of increased dietary iodide on thyroid accumulation and secretion in eurthyroid Arkansas subjects. J Clin Endocrinol 25:1580–1590.
Fisher NS, Fowler SW, Boisson F, . 1999. Radionuclide bioconcentration factors and sediment partition coefficients in Arctic seas subject to contamination from dumped nuclear wastes. Environ Sci Technol 33:1979–1982.
Fisher WD, Voorhess ML, Gardner LI. 1965. Congenital hypothyroidism in infant following maternal I^131^ therapy: With a review of hazards of environmental radioiosotope contamination. J Pediatr 62:132–146.
Fisherman EW, Cohen GN. 1977. A vascular test to detect iodide hypersensitivity (intolerance). Ann Allergy 38:163–168.842904
*Fjälling M, Dackenberg A, Hedman I, . 1983. An evaluation of the risk of developing hyperparathyroidim after ^131^I treatment for thyrotoxicosis. Acta Chir Scand Suppl 149:681–686.6650083
Floyer C, Wilkinson JD. 1988. Treatment of venous leg ulcers with cadexomer iodine with particular reference to iodine sensitivity. Acta Chir Scand Suppl 544:60–61.
Folb PI, Graham Dukes MN. 1990. Thyroid and antithyroid drugs. In: Drug safety in pregnancy. Cape Town, South Africa: University of Cape Town, 305–314.
Foley TP. 1991. Maternally transferred thyroid disease in the infant: Recognition and treatment. In: Bercu BB, Shulman DI, eds. Advances in perinatal thyroidology. New York, NY: Plenum Press, 209–226.
*Foley TP. 1992. The relationship between autoimmune thyroid disease and iodine intake: A review. Endokrynol Pol 43 (Suppl 1):53–69.1345585
Foley TPJ. 1996. Congenital hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 988–994.
Foley TP, Charron M. 1997. Radioiodine treatment of juvenile Graves disease. Exp Clin Endocrinol Diabetes 105(Suppl 4):61–65.
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Fontana B, Curti G, Biggi A, . 1980. The incidence of hypothyroidism after radioactive iodine (^131^I) therapy for autonomous hyperfunctioning thyroid nodule evaluated by means of life-table method. J Nucl Med Allied Sci 24(1–2):85–91.7205395
*Forbes. GB, Bruining GJ. 1976. Urinary creatinine excretion and lean body mass. Am J Clin Nutr 29:1359–1366.998546
Foster HD. 1987. Disease family trees: The possible roles of iodine in goitre, cretinism, multiple sclerosis, amyotrophic lateral sclerosis, Alzheimer’s and Parkinson’s diseases and cancer of the thyroid, nervous system and skin. Med Hypotheses 24:249–263.3320695
Foster HD. 1993. The iodine-selenium connection: Its possible roles in intelligence, cretinism, sudden infant death syndrome, breast cancer and multiple sclerosis. Med Hypotheses 40:61–65.8455469
*Fradkin JE, Wolff J. 1983. Iodide-induced thryotoxicosis. Medicine 62(1):1–20.6218369
Fragu P, Othman SB, Nataf BM. 1979. Effect of PTU added to a low iodine diet on peroxidase activity and other parameters of thyroid function in rats. Acta Endocrinol 91:462–472.
*Franceschi S. 1998. Iodine intake and thyroid carcinoma-a potential risk factor. Exp Clin Endocrinol Diabetes 106(Suppl 3):S38–S44.9865553
*Franceschi S, Dal Maso L. 1999. Hormonal imbalances and thyroid cancers in humans. In: Capen CC, Dybing E, Rice JM, ., eds. Species differences in thyroid, kidney and urinary bladder carcinogenesis. Lyon, France: International Agency for Research on Cancer, 33–43.
Franceschi S, Levi F, Negri E, . 1991. Diet and thyroid cancer: A pooled analysis of four European case-control studies. Indian J Cancer 48:395–398.
Franceschi S, Talamini R, Fassina A, . 1990. Diet and epithelial cancer of the thyroid gland. Tumori 76:331–338.2205027
Francis AR, Shetty TK, Bhattacharya RK. 1988. Modifying role of dietary factors on the mutagenicity of aflatoxin B_1_: In vitro effect of trace elements. Mutat Res 199:85–93.3129656
Francois PJ, Szmigielski M, De Rouck A, . 1966. [Electrophysiologic and histologic study of experimental tapeto-retinal degeneration evoked by sodium iodide. I. Electrophysiologic study.] Ophthalmologica 152:131–148. (French)5966196
Franklyn J, Sheppard M. 1992. Radioiodine for hyperthyroidism: Perhaps the best option. Br Med J 305:727–728.1422325
Franklyn JA, Daykin J, Holder R, . 1995. Radioiodine therapy compared in patients with toxic nodular or Graves’ hyperthyroidism. Q J Med 88:175–180.
Franklyn JA, Maisonneuve P, Sheppard MC, . 1998. Mortality after the treatment of hyperthyroidism with radioactive iodine. N Engl J Med 338:712–718.9494147
*Franklyn JA, Maisonneuve P, Sheppard M, . 1999. Cancer incidence and mortality after radioiodine treatment for hyperthyroidism: A population-based cohort study. Lancet 353:2111–2115.10382695
*Freeman M, Guiliani M, Schwartz E, . 1969. Acute thyroiditis, thyroid crisis, and hypocalcemia following radioactive iodine therapy. N Y State J Med 69(14):2036–2041.5256185
Fregly MJ, McCarthy JS. 1973. Effect of diuretics on renal iodide excretion by humans. Toxicol Appl Pharmacol 25:289–298.4715491
Freidman NB, Catz B. 1996. The reactions of euthyroid and hyperthyroid glands to radioactive iodine. Arch Pathol Lab Med 120:660–661.8757471
Freitas JE, Swanson DP, Gross MD, . 1979. Iodine-131: Optimal therapy for hyperthyroidism in children and adolescents? J Nucl Med 20:847–850.583469
Fritzsche H, Benzer W, Furlan W, . 1993. [Prophylaxis of iodine-induced thyrotoxicosis after coronary angiography.] Acta Med Austriaca 20:13–17. (German)8386417
Frohmberg E, Goble R, Sanchez V, . 2000. The assessment of radiation exposures in Native American communities from nuclear weapons testing in Nevada. Risk Anal 20(1):101–111.10795343
From E, Thomsen K. 1974. Dermatitis herpetiformis: A case provoked by iodine. Br J Dermatol 91(2):221–224.4606418
From GLA, Lawson VG. 1997. Solitary thyroid nodule: Concepts in diagnosis and treatment. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 411–429.
*Fuge R. 1987. Iodine in the environment: Its distribution and relationship to human health. In: Hemphill DD, ed. Trace substances in environmental health. Columbia, Mo: Curators of the University of Missouri, 74–87.
*Fujimori K, Takahashi T, Ohtomo H, . 1996. Preliminary medical findings of the Marshall Islands nationwide thyroid study. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, The Netherlands: Elseiver, 167–173.
*Fujiwara H, Tatsumi K, Miki K, . 1997. Congenital hypothyroidism caused by a mutation in the Na^+^/I^−^ symporter. Nat Genet 16:124–125.9171822
*Fujiwara H, Tatsumi K-I, Miki K, . 1998. Recurrent T354P mutation of the Na^+^/I^−^ symporter in patients with iodide transport defect. J Clin Endocrinol Metab 83(8):2940–2943.9709973
*Fujiwara H, Tatsumi K, Tanaka S, . 2000. A novel V59E missense mutation in the sodium iodide symporter gene in a family with iodide transport defect. Thyroid 10(6):471–474.10907989
Fujiwara S, Ezaki H, Sposto R, . 1990. Hyperparathyroidism among atomic bomb survivors in Hiroshima, 1986-88. DCBN 22-0058403 (Upstate) TR 8–90:1–12.
Fukuda H, Yasuda N, Greer MA. 1975. Acute effects of thyroxine, triiodothyronine, and iodide on thyrotropin secretion. Endocrinology 97:924–931.1193014
Fukui M, Fujikawa Y, Satta N. 1996. Factors affecting interaction of radioiodine and iodate species with soil. J Environ Radioact 31(2):199–216.
Fulop M. 1971. Hypoparathyroidism after ^131^I therapy. Ann Intern Med 75(5):808.
Furr AK, Parkinson TF, Heffron CL, . 1978. Elemental content of tissues and excreta of lambs, goats, and kids fed white sweet clover growing on fly ash. J Agric Food Chem 26:847–851.670567
Furrer J, Dillman H-G (1986): Apparatus for detecting iodine isotopes. (to Kernforschungszentrum Karlsrube G.m.b.H.) Application: Germany 4,626,692, 2 Dec 1986. United States Patent 4,626,692, issued 2 Dec 1986.
*Furudate S, Nishimaki T, Muto T. 1997. ^125^I uptake competing with iodine absorption by the thyroid gland following povidone-iodine skin application. Exp Anim 46(3):197–202.9250480
*Gabay JJ, Paperiello CJ, Goodyear S, . 1974. A method for determining iodine-129 in milk and water. Health Phys 26:89–96.4479622
*Gäbler H-E, Heumann KG. 1993. Determination of atmospheric iodine species using a system of specifically prepared filters and IDMS. Fresenius J Anal Chem 345:53–59.
Gadzhiev KM. 1990. [A case of anaphylactic shock in response to the topical application of 5 percent alcohol tincture of iodine.] Azerb Med Zh 4:56–57. (Azerbaijani)
*Gaffney GW, Gregerman RI, Shock NW. 1962. Relationship to age to the thyroidal accumulation, renal excretion and distribution of radioiodide in euthyroid man. J Clin Endocrinol Metab 22:784–794.13896179
Gaitan E, Cooksey RC, Meydrech EF, . 1989. Thyroid function in neonates from goitrous and nongoitrous iodine-sufficient areas. J Clin Endocrinol Metab 69(2):359–363.2753978
*Galina MP, Avnet NL, Einhorn A. 1962. Iodides during pregnancy: An apparent cause of neonatal death. N Engl J Med 267:1124–1127.13960330
Galla JH, Kotchen TA, Luke RG. 1977. Failure of sodium iodide loading to inhibit renin in the rat. Proc Soc Exp Biol Med 154:30–32.840843
Gambal D, Quackenbush FW. 1968. Essential fatty acids, plasma protein bound iodine, and the thyroid gland. Proc Soc Exp Biol Med 127(4):1137–1138.5690319
Gambert SR. 1996. Intrinsic and extrinsic variables. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 254–259.
Gao F, Fu C, Zhang C, . 1992. [Further studies on the carcinogenic effects of radioiodine in rats.] Zhong Fan Yixue Yu Fanghu Zazhi 12(4):249–252. (Chinese)
Garcia-Mayor RV, Rios M, Fluiters E. 1999. Effect of iodine supplementation on a pediatric population with mild iodine deficiency. Thyroid 9(11):1089–1093.10595457
Garcia Pascual L, Simo R, Mesa J, . 1992. [Myelodysplastic syndrome following radioiodine treatment of differentiated carcinoma of the thyroid [Letter]. Rev Clin Esp 191(3):169–170. (Spanish)
*Gardner DF, Centor RM, Utiger RD. 1988. Effects of low dose oral iodide supplementation on thyroid function in normal men. Clin Endocrinol 28:283–288.
Gardner DF, Mars DR, Thomas RG, . 1986. Iodine retention and thyroid dysfunction in patients on hemodialysis and continuous ambulatory peritoneal dialysis. Am J Kidney Dis VII(6):471–476.
Gardner DF, Rothman J, Utiger RD. 1979. Serum thyroglobulin in normal subjects and patients with hyperthyroidism due to Graves’ disease: Effects of T3, iodide, ^131^I and antithyroid drugs. Clin Endocrinol 11:585–594.
*Garijo MAG, Quintana JAD, Gonzalez PB, . 1996. Anaphylactic shock following povidone. Ann Pharmacother 30:37–40.8773164
Gartner R, Dugrillon A, Bechtner G. 1996. Evidence that iodolactones are the mediators of growth inhibition by iodine on the thyroid. Acta Med Austriaca 23:47–51.8767514
Gartner R, Greil W, Demharter R, . 1985. Involvement of cyclic AMP, iodide and metabolites of arachidonic acid in the regulation of cell proliferation of isolated porcine thyroid follicles. Mol Cell Endocrinol 42:145–155.2998905
*Gautier MA. 1983. Manual of Analytical methods for radiobioassay, DOE Report No. LA-9763-M (National Technical Information Services), Springfield, VA.
*Gavin LA, Livermore BM, Cavalieri RR, . 1980. Serum concentration, metabolic clearance, and production rates of 3,5,3’-triiodothyroacetic acid in normal and athyreotic man. J Clin Endocrinol Metab 51(3):529–534.7410532
Gedik O, Ozdemir T, Akalin S. 1991. Discordant hypothyroxinemia and hypertriiodothyroninemia in treated patients with hyperthyroid Graves’ disease and toxic multinodular goiter. Isr J Med Sci 27:361–364.1712765
Geisthovel W. 1984. [Hyperthyroidism after administration iodine-containing eyedrops.] Dtsch Med Wochenschr 109(34):1304–1305. (German)6468293
*Gélinas Y, Iyengar GV, Barnes RM. 1998. Total iodine in nutritional and biological reference materials using neutron activation analysis and inductively coupled plasma mass spectrometry. Fresenius J Anal Chem 362:483–488.
Gembicki M. 1996. Physiological basis of iodine prophylaxis in case of a nuclear accident. In: Radiodosimetry and preventative measures in the event of a nuclear accident. Austria: International Atomic Energy Agency, 87–100. IAEA-TECDOC-893.
*Gembicki M, Stozharov AN, Arinchin AN, . 1997. Iodine deficiency in Belarusian children as a possible factor stimulating the irradiation of the thyroid gland during the Chernobyl catastrophe. Environ Health Perspect Suppl 105(6):1487–1490.9467069
*Georgitis WJ, McDermott MT, Kidd GS. 1993. An iodine load from water-purification tablets alters thyroid function in humans. Mil Med 158:794–797.8108021
Germani MS, Zoller WH. 1988. Vapor-phase concentrations of arsenic, selenium, bromine, iodine, and mercury in the stack of a coal-fired power plant. Environ Sci Technol 22:1079–1085.22148663
*Germani MS, Gokmen I, Sigleo AC, . 1980. Concentrations of elements in the antional bureau of standards’ bituminous and subbituminous coal standard reference materials. Anal Chem 52:240–245.
Geselowitz DA, McManaway MM, Hofer KG, . 1995. Low-let radiotoxicity from incorporated ^3^H or ^125^I during the cell cycle: Implications for mechanisms of high-let damage. In: Fuciarelli AF, Zimbrick JD, eds. Radiation damage in DNA: Structure/function relationships at early times. Columbus, OH: Battelle Press, 223–230.
*Ghahremani GG, Hoffer PB, Oppenheim BE, . 1971. New normal values for thyroid uptake of radioactive iodine. JAMA 217(3):337–339.5109200
Gibberd M, McMillan M, Staffurth JS. 1974. Thyrotropin (T.S.H.) after iodine-131 therapy. Lancet 1(7865):1048.
Gibbs RA, Camakaris J, Hodgson GS, . 1987. Molecular characterization of ^125^I decay and x-ray-induced HPRT mutants in CHO cells. Int J Radiat Biol 51(2):193–199.
*Gilbert ES, Tarone R, Bouville A, . 1998. Thyroid cancer rates and ^131^I doses from Nevada atmospheric nuclear bomb tests. J Natl Cancer Inst 90(21):1654–1660.9811315
Gilbert-Dreyfus Z, Gali P. 1958. Cataracte tetanique apres IRA-therapie. Sem Hop 34:1301–1304.13568848
Gilchrist B. 1997. Should iodine be reconsidered in wound management? J Wound Care 6(3):148–150.
Gillespie FC, Orr JS, Greig WR. 1970. Microscopic dose distribution from ^125^I in the toxic thyroid gland and its relation to therapy. Br J Radiol 43:40–47.5411566
Gimeno EJ, Walinder G, Feinstein RE, . 1986. Effect of high ^131^I doses to the thyroid gland on tumorigenicity of ^90^Sr and ^90^Y in mice. Acta Radiol Oncol 25:4–6.
Ginsberg J, Murray PG. 1991. Stimulation of TSH-mediated iodide organification in porcine thyroid cells following protein kinase C inhibition. In: Gordon A, Gross J, Hennemann G, eds. Progress in thyroid research. Rotterdam, the Netherlands: Balkema, 599–602.
Ginsberg J, Matowe W, Murray PG. 1993. Enhancement of thyrotropin-stimulated iodide organification in porcine thyroid cells after protein kinase-C inhibition. Endocrinology 132(4):1815–1819.8462478
Gittoes NJL, Franklyn JA. 1995. Drug-induced thyroid disorders. Drug Saf 13(1):46–55.8527019
Gittoes NJL, Franklyn JA. 1998. Hyperthyroidism: Current treatment guidelines. Drugs 55(4):543–553.9561343
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.7902273
Glanzmann C, Horst W. 1979. [Treatment of thyrotoxicosis with 125-iodine: Results in 93 patients 3 to 5 years after treatment, and comparison with 131-iodine therapy.] Strahlentherapie 155:1–5. (German)760268
Glanzmann C, Horst W. 1980. Iodine-125 and iodine-131 in the treatment of hyperthyroidism. Clin Nucl Med 5(7):325–333.6893021
*Glassock RF. 1954. The secretion of a single tracer dose of labeled iodine in the milk of the lactating cow. J Dairy Res 21:318.
*Glazebrook GA. 1987. Effect of decicurie doses of radioactive iodine 131 on parathyroid function. Am J Surg 154:368–373.3661839
Glennon JA, Gordon ES, Sawin CT. 1972. Hypothyroidism after low-dose ^131^I treatment of hyperthyroidism. Ann Intern Med 76:721–723.5025322
Glick PL, Guglielmo BJ, Winter ME, . 1990. Iodine toxicity secondary to continuous povidone-iodine mediastinal irrigation in dogs. J Surg Res 49:428–434.2246887
Glinoer D. 1999. What happens to the normal thyroid during pregnancy? Thyroid 9(7):631–635.10447005
*Glinoer D. 2001. Pregnancy and iodine. Thyroid 11(5):139–149.
Globel B, Globel H, Andres C. 1985. The risk of hyperthyroidism following an increase in the supply of iodine. J Hosp Infect 6(Supplement):201–204.
Gluzman BE, Coleoni AH, Targovnik HM, . 1977. Effects of amiodarone on thyroid iodine metabolism in vitro. Acta Endocrinol 85:781–790.
Gobbel GT, Marton LJ, Lamborn K, . 1991. Modification of radiation-induced brain injury by alpha-difluoromethylornithine. Radiat Res 128:306–315.1961928
*Goh K. 1981. Radioiodine treatment during pregnancy: Chromosomal aberrations and cretinsim associated with maternal iodine-131 treatment. J Am Med Womens Assoc 36(8):262–265.
Goldberg RC, Chaikoff IL. 1951. Development of thyroid neoplasms in the rat following a single injection of radioactive iodine. Proc Soc Exp Biol Med 76:563–566.14844275
Goldberg REA, Miraldi F. 1987. Radionuclide imaging of potassium iodide-induced sialadenitis. Clin Nucl Med 12:370–372.3034466
Golden MHN. 1982. Trace elements in human nutrition. Hum Nutr Clin Nutr 36C:185–202.
Goldman M, Grau TJ. 1974. A comparative study on the influence of dimethyl sulfoxide on iodine metabolism in male Long-Evans rats and male CF_1_ mice. Toxicol Appl Pharmacol 29:340–347.4283697
Goldman M, Landry D. 1976. The effect of povidone-iodine on thyroid function in rats. Toxicol Appl Pharmacol 35:341–346.1265751
*Goldman MB, Maloof F, Monson RR, . 1988. Radioactive iodine therapy and breast cancer: A follow-up study of hyperthyroid women. Am J Epidemiol 127(5):969–980.3358416
*Goldschmidt VM. 1958. Geochemistry. Oxford University Press, London, pp.602–620.
Goldsmith JR, Grossman CM, Morton WE, . 1999. Juvenile hypothyroidism among two populations exposed to radioiodine. Environ Health Perspect 107(4):303–308.10090710
Goldstein R, Hart IR. 1983. Follow-up of solitary autonomous thyroid nodules treated with ^131^I. N Engl J Med 309(24):1473–1476.6646172
Golstein J, Dumont JE. 1996. Cytotoxic effects of iodide on thyroid cells: Difference between rat thyroid FRTL-5 cell and primary dog thyrocyte responsiveness. J Endocrinol Invest 19:119–126.8778164
Golstein P, Abramow M, Dumont JE, . 1992. The iodide channel of the thyroid: A plasma membrane vesicle study. Am J Physiol 263(32):C590–C597.1384345
Gomez JM, Virgili N, Soler J, . 1989. Transient hypothyroidism after iodine-131 treatment of Graves’ disease. Thyroidology 3:149–152.
Gomez N, Gomez JM, Orti A, . 1995. Transient hypothyroidism after iodine-131 therapy for Grave’s disease. J Nucl Med 36:1539–1542.7658207
Gomez N, Gomez JM, Villabona C, . 1998. Transient hypothyroidism after iodine-131 therapy for Graves’ disease. Clin Endocrinol 48:526–527.
Goncharov AT, Ametov AS. 1977. [The effect of chrome on the thyroid in rats kept on an iodine-deficient diet.] Probl Endokrinol (Mosk) 23(6):59–61. (Russian)74828
*Gonzalez AJ. 1998. Radioactive residues of the cold war period. A radiological legacy. IAEA Bulletin 40(4):2–11.
Goolden AWG, Stewart JSW. 1986. Long-term results from graded low dose radioactive iodine therapy for thyrotoxicosis. Clin Endocrinol 24:217–222.
Goolden AWG, Kam KC, Fitzpatrick ML, . 1986. Oedema of the neck after ablation of the thyroid with radioactive iodine. Br J Radiol 59:583–586.3708267
*Gordon CM, Rowitch DH, Mitchell ML, . 1995. Topical iodine and neonatal hypothyroidism. Arch Pediatr Adolesc Med 149:1336–1339.7489070
Gorman CA. 1995. Radioiodine therapy does not aggravate Graves’ ophtalmopathy. J Clin Endocrinol Metab 80:340–342.7852485
Gorman CA. 1999. Radioiodine and pregnancy. Thyroid 9(7):721–726.10447020
*Gorodinskiy SM, Yes’kova-Soskovets LS, Rokhlin MI, . 1979. Penetration of gaseous I131 through human skin. Ohio: Foreign Technology Division, Wright-Patterson Air Force Base. NTIS ADA087882.
Gorowski T, Gabryelewicz MB, Jastrzebska H. 1992. [Anaplastic thyroid carcinoma developed after treatment of “hot” thyroid nodule with radioiodine.] Endokrynol Pol 43(3):308–313. (Russian)1345570
Gossage AAR, Neal FE, Ross CMD, . 1984. Cases of carcinoma of thyroid following iodine-131 therapy for hyperthyroidism. Oncology 41:8–12.6700935
Gotoh T, Ito A, Yamada K, . 1996a. [Occurrence of time and dose-dependent rat thyroid tumors induced by radioiodine (131I) and fission neutron (252Cf).] Nagasaki Igakkai Zasshi 71:375–379. (Japanese)
Gotoh T, Watanabe H, Tanizaki M, . 1996b. Promotion of thyroid tumors in F344 male rats given a low iodine diet after treatment with n-methyl-n-nitrosourea in their drinking water. J Toxicol Pathol 9:191–197.
*Goyens P, Golstein J, Nsombola B . 1987. Selenium deficiency as a possible factor in the pathogenesis of myxoedamatous cretinism. Acta Endocrinol 114:497–502.
Graham GD, Burman KD. 1986. Radioiodine treatment of Graves’ disease. Ann Intern Med 105:900–905.3777715
*Gramlich JW, Murphy TJ. 1989. Determination of trace level iodine in biological and botanical reference materials by isotope dilution mass spectrometry. J Res Nat Inst Stand Technol 94(4):215–220.
Granter SR, Cibas ES. 1997. Cytologic findings in thyroid nodules after ^131^I treatment of hyperthyroidism. Am J Clin Pathol 107:20–25.8980362
Gray B, Galton VA. 1974. The transplacental passage of thyroxine and foetal thyroid function in the rat. Acta Endocrinol 75:725–733.
Gray HW, McKillop JH, McGurk FM, . 1982. Carcinoma of trachea following iodine-125 therapy for thyrotoxicosis. Lancet 1:688.
*Green DM, Edge SB, Penetrante RB, . 1995. In situ breast carcinoma after treatment during adolescence for thyroid cancer with radioiodine. Med Pediatr Oncol 24:82–86.7990768
*Green HG, Gareis FJ, Shepard TH, . 1971. Cretinism associated with maternal sodium iodide I 131 therapy during pregnancy. Am J Dis Child 122:247–249.5109602
Green WL. 1970. Relationships between the effects of iodide, methimazole and thyrotropin on the intermediary metabolism of bovine thyroid slices. Endocrinology 86:708–712.
*Green WL. 1996. Antithyroid compounds. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 266–276.
*Green WL, Ingbar SH. 1961. The peripheral metabolism of tri- and tetraiodothyroacetic acids in man. J Clin Endocrinol Metab 21:1548–1565.13901458
Greer MA. 1996. Thyrotoxicosis of extrathyroid origin. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 592–594.
Greig WR, Smith JFB, Gillespie FC, . 1969. Iodine-125 treatment for thyrotoxicosis. Lancet 1:755–757.4180219
Greig WR, Smith JFB, Orr JS, . 1970. Comparative survivals of rat thyroid cells in vivo after ^131^I, ^125^I and X irradiations. Br J Radiol 43:542–548.5433365
Gresham DG, Wool MS. 1984. Hypoparathyroidism after radioiodine therapy for Graves’ disease: Is its incidence increasing? Postgrad Med 75(4):299–305.6546620
Griem ML, Malkinson FD. 1967. Some studies on the effects of radiation and radiation modifiers on growing hair. Radiat Res 30:431–443.4163844
Gross MD, Shapiro B, Sisson JC. 1999. Radioiodine therapy for thyrotoxicosis. Rays 24(2):334–347.10509135
Grossman CM, Nussbaum RH, Morton WE. 1996. Hypothyroidism and spontaneous abortions among Hanford, Washington, downwinders. Arch Environ Health 51(3):175–176.8687236
Grossman CM, Nussbaum RH, Nussbaum FD. 2002. Thyrotoxicosis among Hanford, Washington, downwinders: A community-based health survey. Arch Environ Health 57(1):9–15.12071367
Gruffat D, Gonzalvez S, Mauchamp J, . 1991. Phenol red: An inhibitor of thyroglobulin iodination in cultured porcine thyroid cells. Mol Cell Endocrinol 81:195–203.1665828
Gruffat D, Venot N, Marriq C, . 1992. Thyroid hormone synthesis in thyroglobulin secreted by porcine thyroid cells cultured on porous bottom chambers: Effect of iodide. Endocrinology 131(6):2921–2927.1446629
Grumbach MM, Werner SC. 1956. Transfer of thyroid hormone across the human placenta at term. J Clin Endocrinol Metab 16:1392–1395.13367179
Grunditz T, Sundler F. 1996. Autonomic nervous control: Adrenergic, cholinergic, and peptidergic regulation. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 247–253.
Grunwald F, Palmedo H, Biersack HJ. 1995. Unilateral iodine-131 uptake in the lactating breast. J Nucl Med 36(9):1724–1725.7658239
Gu Y, Ciu Y, Liu X. 1984. Changes in peripheral T and B lymphocytes of rat after intravenous injection of ^131^I. Chin Med J 97(10):773–776.
Gumarnik S. 1988. Skin preparation and spinal headache. Anaesthesia 43(12):1057–1058.
Gupta GS, Chopra VK. 1977. Biological damage in testis by iodine-125 in partially blocked thyriod of rats. Radiat Environ Biophys 14:147–152.197564
Gupta GS, Chopra VK. 1980. Biological damage in spleen by iodine-125 in potassium perchlorate blocked thyroid of rats. Strahlentherapie 156:579–582.6158148
Gupta SM, Goyal PK, Dev PK. 1981. Weight changes in mice after intrauterine treatment with MPG (2-mercaptopropionylglycine) against I^131^ irradiation. Experientia 37:898–899.7286150
Gutiérrez S, Carbonell E, Galofre P, . 1995. A cytogenetic follow-up study of thyroid cancer patients treated with ^131^I. Cancer Lett 91:199–204.7767910
*Gutiérrez S, Carbonell E, Galofre P, . 1998a. The alkaline single-cell gel electrophoresis (SCGE) assay applied to the anaylsis of radiation-induced DNA damage in thyroid cancer patients treated with ^131^I. Mutat Res 413:111–119.9639687
Gutierrez S, Carbonell E, Galofre P, . 1998b. Application of the single cell gel electrophoresis (SCGE) assay to the detection of DNA damage induced by ^131^I treatment in hyperthyroidism patients. Mutagenesis 13(1):95–98.9491402
*Gutierrez S, Carbonell E, Galofre P, . 1999a. Cytogenic damage after 131-iodine treatment for hypothyroidism and thyroid cancer. Eur J Nucl Med 26(12):1589–1596.10638411
Gutierrez S, Carbonell E, Galofre P, . 1999b. Low sensitivity of the sister chromatid exchange assay to detect the genotoxic effects of radioiodine therapy. Mutagenesis 14(2):221–226.10229925
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haddow J, Hermos R, Mitchell M, . 1998. Maternal hypothyroidism and child development. Horm Res 50:18.9691208
Haffenden GP, Blenkinsopp WK, Ring NP, . 1980. The potassium iodide patch test in dermatitis herpetiformis in relation to treatment with a gluten-free diet and dapsone. Br J Dermatol 102:313–317.
*Hagmar L, Persson-Moschos M, Akesson B, . 1998. Plasma levels of selenium, selenoprotein P and glutathione peroxidase and their correlations to fish intake and serum levels of thyrotropin and thyroid hormones: A study on Latvian fish consumers. Eur J Clin Nutr 52:796–800.9846591
Haggard DL, Stowe HD, Conner GH, . 1980. Immunologic effects of experimental iodine toxicosis in young cattle. Am J Vet Res 41(4):539–543.6996540
*Hahn K, Schrell-Inderst P, Grosche B, . 2001. Thyroid cancer after diagnostic administration of iodine-131 in childhood. Radiat Res 156(1):61–70.11418074
Halford DK, Markham OD. 1984. Iodine-129 in waterfowl muscle from a radioactive leaching pond complex in southeastern Idaho. Health Phys 46(6):1259–1263.6724936
Hall MT. 1973. Chemical antagonism by iodine of the pharmacological activity of sympathomimetic amines. J Pharm Pharmacol 25(11):923–925.4149664
*Hall PE, Holm LE. 1996. Thyroid cancer incidence among Swedish patients exposed to diagnostic doses of iodine-131: A preliminary report. In: Radiodosimetry and preventative measures in the event of a nuclear accident. Austria: International Atomic Energy Agency, 55–63. IAEA-TECDOC-893.
Hall PFL. 1991. Cancer risks in humans after iodine-131 exposure. Diss Abstr Int C 53-03C:458.
Hall P, Holm L-E. 1995a. Cancer in iodine-131 exposed patients. J Endocrinol Invest 18:147–149.7629384
Hall P, Holm L-E. 1995b. Cancer incidence and mortality after iodine-131 therapy for hyperthyroidism. Adv Chem Ser 243:103–112.
Hall P, Holm L-E. 1997. Late consequences of radioiodine for diagnosis and therapy in Sweden. Thyroid 7(2):205–208.9133685
*Hall P, Berg G, Bjelkengren G, . 1992a. Cancer mortality after iodine-131 therapy for hyperthyroidism. Int J Cancer 50:886–890.1555888
Hall P, Boice JDJ, Berg G, . 1992b. Leukemia incidence after iodine-131 exposure. Lancet 340(8810):1–4.1351599
Hall P, Holm L-E, Lundell G, . 1991. Cancer risks in thyroid cancer patients. Br J Cancer 64:159–163.1854616
Hall P, Holm L-E, Lundell G, . 1992c. Tumors after radiotherapy for thyroid cancer. Acta Oncol 31(4):403–407.1632973
Hall P, Lundell G, Holm L-E. 1993. Mortality in patients treated for hyperthyroidism with iodine-131. Acta Endocrinol 128:230–234.
*Hall P, Furst CJ, Mattsson A, . 1996a. Thyroid nodularity after diagnostic administration of iodine-131. Radiat Res 146:673–682.8955718
*Hall P, Mattsson A, Boice JDJ. 1996b. Thyroid cancer after diagnostic administration of iodine-131. Radiat Res 145:86–92.8532842
*Hall R, Turner-Warwick M, Doniach D. 1966. Autoantibodies in iodide goitre and asthma. Clin Exp Immunol 1:285–296.5911904
Halmi NS. 1961. Thyroidal iodide transport. Vitam Horm 19:133–163.
Halmi NS, Gifford TH, Glesne RE. 1967. Further observations concerning the effect of actinomycin D on thyroidal iodide transport in rats. Endocrinology 81:893–898.4167146
Halmi NS, King LT, Widner RR, . 1958. Renal excretion of radioiodide in rats. Am J Physiol 193:379–385.13533559
Halmi NS, Nissen WM, Scranton JR. 1969. The kinetics of the enhancement of thyroidal iodide accumulation after actinomycin D administration. Endocrinology 84:943–945.5766549
Halnan KE. 1958. The radioiodine uptake of the human thyroid in pregnancy. Clin Sci 17:281–290.13537345
Halnan KE. 1983. Risks from radioiodine treatment of thyrotoxicosis. Br Med J 287:1821–1822.6423030
Halnan KE. 1992. Leukemia after iodine-131 exposure [Letter]. Lancet 340:437.
Halpern S, Alazraki N, Littenberg R, . 1973. ^131^I thyroid uptakes: Capsule versus liquid. J Nucl Med 14(7):507–510.4711267
Hamby DM, Benke RR. 1999. Uncertainty of the iodine-131 ingestion dose conversion factor. Radiat Prot Dosim 82(4):245–256.
*Hamill GC, Jarman JA, Wynne MD. 1961. Fetal effects of radioactive iodine therapy in a pregnant woman with thyroid cancer. Am J Obstet Gynecol 81(3):1018–1023.13711002
*Hamilton TE, van Belle G, LoGerfo JP. 1987. Thyroid neoplasia in Marshall Islanders exposed to nuclear fallout. JAMA 258(5):629–636.3612986
Hampel R, Grodalla A, Zollner H, . 2000. Continuous rise of urinary iodine excretion and drop in thyroid gland size among adolescents in Mecklenburg-West-Pomerania from 1993 to 1997. Exp Clin Endocrinol Diabetes 108:197–201.10926316
*Han JS. 1992. Effects of various chemical compounds on spontaneous and hydrogen peroxide-induced reversion in strain TA104 of salmonella typhimurium. Mutat Res 266(2):77–84.1373841
Hanauer G, Schroth HJ. 1990. [Estimation of the radioiodine dose necessary for complete ablation of the thyroid gland in male Wistar rats.] Zentralbl Veterinarmed A 37:747–751. (German)2127495
*Handelsman DJ, Turtle JR. 1983. Testicular damage after radioactive iodine (I-131) therapy for thyroid cancer. Clin Endocrinol 18:465–472.
Handelsman DJ, Conway AJ, Donnelly PE, . 1980. Azoospermia after iodine-131 treatment of thryoid carcinoma. Br Med J 281:1527.
*Handl J, Pfau A. 1989. Long-term transfer of I-129 into the food chain. Sci Total Environ 85:245–252.2814452
*Handl J, Pfau A, Huth FW. 1990. Measurements of ^129^I in human and bovine thyroids in Europe-Transfer of ^129^I into the food chain. Health Phys 58(5):609–618.2341250
Hang J, Rillema JA. 1998. Possible involvement of PI3K in prolactin-stimulated milk product formation and iodide transport in mouse mammary explants. Proc Soc Exp Biol Med 219:154–159.9790174
*Hansch C, Leo A, eds. 1995. Exploring QSAR: Fundamentals and applications in chemistry and biology. Washington, DC: American Chemical Society.
*Harach HR, Williams ED. 1995. Thyroid cancer and thyroiditis in the goitrous region of Salta, Argentina, before and after iodine prophylaxis. Clin Endocrinol 43:701–706.
*Harach HR, Escalante DA, Onativia A, . 1985. Thyroid carcinoma and thyroiditis in an endemic goitre region before and after iodine prophylaxis. Acta Endocrinol 108:55–60.
Harapanhalli RS, Narra VR, Yaghmai V, . 1994. Vitamins as radioprotectors in vivo II. Protection by vitamin A and soybean oil against radiation damage caused by internal radionuclides. Radiat Res 139:115–122.8016300
Harden RM, Alexander WD, Chisholm CJS, . 1968. The salivary iodide trap in nontoxic goiter. J Clin Endocrinol Metab 28:117–120.5635445
Harden RM, Harrison MT, Alexander WD. 1963. Phosphate excretion and parathyroid function after radioiodine therapy and thyroidectomy. Clin Sci 25:27–36.14058241
*Harii N, Endo T, Ohmori M, . 1999. Extracellular adenosine increases Na^+^/I^−^ symporter gene expression in rat thyroid FRTL-5 cells. Mol Cell Endocrinol 157(1–2):31–39.10619395
Harley NH, Harley JH. 1986. Fallout inhalation [Letter]. Health Phys 50(3):422.3949535
Harrington RM, Shertzer HG, Bercz JP. 1985. Effects of ClO_2_ on the absorption and distribution of dietary iodide in the rat. Fundam Appl Toxicol 5:672–678.4043591
Harris PF, Sanchez JF, Mode DG. 1970. Iodide mumps [Letter]. JAMA 213(13):2271–2272.
Harris SJ, Gilmore A. 1980. Penetration of protective gloves as a route of intake for tritiated water and ^125^I-labeled sodium iodide solution. Phys Med Biol 25(6):1089–1094.7208621
*Harrison J. 1963. The fate of radioiodine applied to human skin. Health Phys 9:993–1000.14067808
Harrison LC, Buckley JD, Martin FIR. 1977. Use of a computer-based postal questionnaire for the detection of hypothyroidism following radioiodine therapy for thyrotoxicosis. Aust N Z J Med 7:27–32.326246
Harrop JS, Hopton MR, Lazarus JH. 1981. Concentration of serum thyroid hormone binding proteins after ^131^I treatment of hyperthyroidism. Ann Clin Biochem 18:211–214.6269478
Hartman PE, Morgan RW. 1982. Nitrate/nitrite/iodide/ascorbate ingestion and gastric/esophageal cancer mortality. Environ Mutagen 4(3):339–340.
Harvey RD, Metcalfe RA, Morteo C, . 1995. Acute pre-tibial myxodema following radioiodine therapy for thyrotoxic Graves’ disease. Clin Endocrinol 42:657–660.
Hasan SS, Mazumdar S, Prasad GC, . 1984. The effect of radioactive iodine on brain acetylcholine and serotonin in normal and stress subjected rats. Folia Biol 32(3):201–208.
Hashizume K, Akasu F, Takazawa K, . 1976. The inhibitory effect of acute administration of excess iodide on the formation of adenosine 3’,5’-monophosphate induced by thyrotropin in mouse thyroid lobes. Endocrinology 99:1463–1468.187410
Hashizume K, Ichikawa K, Komiya I, . 1984. Thyrotropin-induced acceleration of calcium efflux from mouse thyroid: Evidence for inhibition by excess iodide. Endocrinology 114:1672–1677.6325130
*Hassan AI, Aref GH, Kassem AS. 1968. Congenital iodide-induced goitre with hypothyroidism. Arch Dis Child 43:702–704.5702231
Hauben M. 1993. Seizures after povidone-iodine mediastinal irrigation [Letter]. N Engl J Med 328(5):355.
Hawe P, Francis HH. 1962. Pregnancy and thyrotoxicosis. Br Med J 2:817–822.13905498
*Hawkes WC, Keim NL. 1995. The effect of selenium (Se) on triiodothyronine (T_3_) and weight changes in healthy men in a metabolic research unit. FASEB J 9(5):A160.
Hay ID, Morris JC. 1996. Toxic adenoma and toxic multinodular goiter. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 566–572.
Hayek A. 1978. Thyroid storm following radioiodine for thyrotoxicosis. J Pediatr 93(6):978–980.722446
Hayek A, Brooks M. 1975. Neonatal hyperthyroidism following intrauterine hypothyroidism. J Pediatr 87(3):446–448.1165528
Hayek A, Chapman EM, Crawford JD. 1970. Long-term results of treatment of thyrotoxicosis in children and adolescents with radioactive iodine. N Engl J Med 283(18):949–953.4097116
*Hays MT. 2001. Estimation of total body iodine content in normal young men. Thyroid 11(7):671–675.11484896
Hays MT. 1979. Kinetics of the human thyroid trap: Effects of iodide, thyrotropin, and propylthiouracil. J Nucl Med 20:944–949.536840
Hays MT. 1982. Hypothyroidism following iodine-131 therapy. J Nucl Med 23(2):176–179.6173470
Hays MT. 1984. Compartmental models for human iodine metabolism. Math Biosci 72:317–335.
*Hays MT. 1993. Colonic excretion of iodide in normal human subjects. Thyroid 3(1):31–35.8499762
*Hays MT, Solomon DH. 1965. Influence of the gastrointestinal iodide cycle on the early distribution of radioactive iodide in man. J Clin Invest 44:117–127.14254247
Hays MT, Wesselossky B. 1973. Simultaneous measurement of thyroidal trapping (^99m^TcO_4_^−^ and binding ^131^I^−^: Clinical and experimental studies in man. J Nucl Med 14(11):785–792.4743029
Hays MT, Carr LJ, Turrel JM. 1987. Effect of sampling site on early kinetics of blood radioiodide and pertechnetate. Am J Physiol 253(16):E691–E700.2827503
*Hays MT, Hsu L, Kohatsu S. 1992. Transport of the thyroid hormones across the feline gut wall. Thyroid 2:45–56.1525566
*HazDat. 2004. Agency of Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. June 2003.
Heath CW, Fullerton HW. 1935. The rate of absorption of iodide and glycine from the gastrointestinal tract in normal persons and in disease conditions. J Clin Invest 14:475–481.16694321
*Heaton RW, Rahn KA, Lowenthal DH. 1990. Determination of trace elements, including regional tracers, in Rhode Island precipitation. Atmos Environ 24A(1):147–153.
*Hedrick WR, DiSimone RN, Keen RL. 1986. Radiation dosimetry from breast milk excretion of radioiodine and pertechnetate. J Nucl Med 27:1569–1571.3020191
Hegedus L, Perrild H, Poulsen LR, . 1983. The determination of thyroid volume by ultrasound and its relationship to body weight, age, and sex in normal subjects. J Clin Endocrinol Metab 56(2):260–263.6822636
Heidenreich WF, Kayro I, Jacob P, . 2001. Age- and sex-specific relative thyroid radiation exposure to ^131^I in Ukraine after the Chernobyl accident. Health Phys 80(3):242–250.11219536
*Heinemann K, Vogt KJ. 1980. Measurements of the deposition of iodine onto vegetation and of the biological half-life of iodine on vegetation. Health Phys 39:463–474.7440159
Held KR, Cruz ME, Moncayo F. 1990. Clinical pattern and the genetics of the fetal iodine deficiency disorder (endemic cretinism): Results of a field study in highland Ecuador. Am J Med Genet 35:85–90.2301474
Helds A, Lehrs E, Bolshevica J, . 1980. Function of thyroid and hypotalamic-pituitary-thyroid axis in radioiodine treated thyrotoxic patients. Endokrinologie 76(3):345–350.6781880
Hemken RW. 1980. Estimates of human iodine consumption and implications for human health. Annual meeting of the National Mastitis Council, Vol. 19, 81–86.
Hempelmann LH, Hall WJ, Phillips M, . 1975. Neoplasms in persons treated with x-rays in infancy: Fourth survey in 20 years. J Natl Cancer Inst 55(3):519–530.1159831
Hendrich CE, Jackson WJ, Porterfield SP. 1984. Behavioral testing of progenies of Tx (hypothyroid) and growth hormone-treated Tx rats: An animal model for mental retardation. Neuroendocrinology 38:429–437.6539858
Hengstler JG, Bockisch A, Fuchs J, . 1997. Increase in DNA single-strand break rejoining by continuous exposure of human mononuclear blood cells to radioiodine (^131^I) in vitro. Int J Radiat Biol 72(5):607–613.9374440
Henrichs K, Mueller-Brunecker G, Paretzke HG. 1983. [Radiation exposure of the thyroid on incorporation of iodine isotopes: Age dependence and reliability of dose factors.] GSF-Ber S 960:1–56. (German)
Henzen C, Buess M, Brander L. 1999. [Iodine-induced thyrotoxicosis)"fodbasedow"): An up-to-date clinical picture.] Schweiz Med Wochenschr 129(17):658–664. (German)10407936
*Hermus AR, Huysmans DA. 2000. The epidemiology of thyroid diseases. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 474–482.
Hernberg S, Kurppa K, Ojajarvi J, . 1983. Congenital malformations and occupational exposure to disinfectants: A case-referent study. Scand J Work Environ Health 9:55.
Herrera E, Escobar del Rey F, Morreale de Escobar G. 1968. Mechanism of goitrogenesis by very low doses of propylthiouracil and the role of iodine intake. Acta Endocrinol 59:529–544.
Hershman JM. 1996. Trophoblastic tumors. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 573–576.
Hershman JM, Lee H-Y, Sugawara M, . 1988. Human chorionic gonadotropin stimulates iodide uptake, adenylate cyclase, and deoxribonucleic acid synthesis in cultured rat thyroid cells. J Clin Endocrinol Metab 67:74–79.3379138
Hetzel BS. 1994. Iodine deficiency and fetal brain damage. N Engl J Med 331(26):1770–1771.7984200
Heufelder AE, Hofbauer LC. 1996. How iodide gets access to thyrocytes: Molecular details on the thyroid iodide transporter. Eur J Endocrinol 135:34–36.8765970
Heymann WR. 2000. Potassium iodide and the Wolff-Chaikoff effect: relevance for the dermatologist. J Am Acad Dermatol 42(3):490–492.10688722
Hiasa Y, Kitahori Y, Kato Y, . 1987. Potassium parchlorate, potassium iodide, and propylthiouracil: Promoting effect on the development of thyroid tumors in rats treated with n-bis(2-hydroxypropyl)-nitrosamine. Jpn J Cancer Res 78:1335–1440.2828294
Hildebrandt JD, Halmi NS. 1981. Intrathyroidally generated iodine: The role of transport in its utilization. Endocrinology 106(3):842–849.
Hillman D. 1980. Chronic iodide toxicity in dairy herds. J Dairy Sci 63(Suppl 1):67–68.
Hillman D, Curtis AR. 1980. Chronic iodine toxicity in dairy cattle: Blood chemistry, leukocytes, and milk iodide. J Dairy Sci 63:55–63.7372897
Himsworth RL. 1985. Hyperthyroidism with a low iodine uptake. Clin Endocrinol Metab 14(2):397–415.2415276
Hindie E, Bourahla K, Petiet A, . 1997. Microscopic distribution of radioactive iodine, and side-effects of thyroid protection in iodine-deficient new-born rats: Insights into the aftermath of the Chernobyl accident. J Trace Microprobe Tech 15(4):701–705.
Hintze G, Emrich D, Richter K, . 1988. Effect of voluntary intake of iodinated salt on prevalence of goitre in children. Acta Endocrinol 117:333–338.
Hnilica P, Langer P. 1983. Incidence of malignity in cystic nontoxic nodular goitre. Acta Endocrinol Suppl 252:14–15.
Hobel M, Asmar F, Kruger FW, . 1967. Uber die ausscheidung von ^131^J- in das broncho-trachaelsekret von laboratoriums-tieren und deren beeinflussung durch pharmaka (II). Arch Int Pharmacodyn 168(1):116–140.4167404
Hodges RE, Evans TC, Bradbury JT, . 1955. The accumulation of radioactive iodine by human fetal thyroids. J Clin Endocrinol Metab 15(6):661–667.14367481
Hodgson-Jones IS. 1970. Clioquinol and iodine metabolism. Trans St Johns Hosp Dermatol Soc 56(1):51–53.4098635
*Hoecker WH, Machta L. 1990. Meteorological modeling of radioiodine transport and deposition within the continental United States. Health Phys 59(5):603–617.2211119
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hofbauer LC, Rafferzeder M, Janssen OE, . 1995. Insulin-like growth factor I messenger ribonucleic acid expression in porcine thyroid follicles is regulated by throtropin and iodine. Eur J Endocrinol 132:605–610.7749503
Hofer KC, Keough G, Smith JM. 1977. Biological toxicity of auger emitters: Molecular fragmentation versus electron irradiation. Curr Top Radiat Res Q 12:335–354.
Hofer KG, Van Loon N, Schneiderman MH, . 1992. The paradoxical nature of DNA damage and cell death induced by ^125^I decay. Radiat Res 130:121–124.1561311
Hofer KG, van Loon N, Schneiderman MH, . 1993. Targets for radiation-induced cell death: Target replication during the cell cycle evaluated in cells exposed to X-rays or ^125^I decays. Int J Radiat Biol 64(2):205–216.8103545
Hoffman DA. 1976. Delayed effects of therapeutic levels of iodine-131 mortality experience in patients treated with hyper thyroidism. Radiat Res 67(3):556.
Hoffman DA, McConahey WM. 1983. Breast cancer following iodine-131 therapy for hyperthroidism. J Natl Cancer Inst 70(1):63–67.6571923
Hoffman DA, McConahey WM, Diamong EL, . 1982a. Mortality in women treated for hyperthyroidism. Am J Epidemiol 115(2):243–254.7058783
Hoffman DA, McConahey WM, Fraumeni JFJ, . 1982b. Cancer incidence following treatment of hyperthyroidism. Int J Epidemiol 11(3):218–224.7129736
Hoffman FO. 1978. A review of measured values of the milk transfer coefficient (f_m_) for iodine. Health Phys 35(2):413–416.701044
Hoffman FO, Dunning DEJ. 1979. Some uncertainties associated with parameter values and models in U.S. NRC regulatory guide 1. 109: Prediction of the ^131^I thyroid dose to children via the grass-cow-milk pathway [Abstract]. Health Phys 37(6):848–849.
Hoffman L, De Luise M, Martin FIR. 1981. Falliblity of postal questionnaire follow-up for detection of hypothyroidism after iodine-131 therapy. Med J Aust 1:303–304.7242402
Hohenwald H, Ramm C. 1970. [Iodide sialadenitis and lipids in guinea pigs.] Acta Histochem Bd 36(2):414–416. (German)
Holbreich M. 1982. Asthma and other allergic disorders in pregnancy. Am Fam Physician 25(3):187–192.
*Holland JZ. 1963. Physical origin and dispersion of radioiodine. Health Physics 9:1095.14086650
Hollingsworth DR, Austin E. 1969. Observations following I^131^ for Graves disease during first trimester of pregnancy. South Med J 62:1555–1556.
Hollowell JG, Hannon WH. 1997. Teratogen update: Iodine deficiency, a community teratogen. Teratology 55:389–405.9294885
*Hollowell JG, Staehling NW, Flanders WD, . 2002. Serum TSH, T4, and thyroid antibodies in the United States population (1998 to 1994): National Health and Nutrition Examination Survey (NHANES III). J Clin Endocrinol Metab 87(2):486–488.11836273
Holm J-E, Lundell G, Wallnder G. 1980. Incidence of malignant thyroid tumors in humans after exposure to diagnostic doses of iodine-131. I. Retrospective cohort study. J Natl Cancer Inst 64(5):1055–1059.6929011
Holm L-E. 1980. Thyroid treatment and its possible influence on occurrence of malignant tumors after diagnostic ^131^I. Acta Radiol Oncol 19:455–459.6165226
Holm LE. 1982a. Carcinogenic and genetic risks of ionizing radiation with special reference to radioiodines. In: Thyroid disease. France: Pergamon Press, 159–186.
Holm L-E. 1982b. Changing annual incidence of hypothyroidism after iodine-131 therapy for hyperthyroidism, 1951-1975. J Nucl Med 23:108–112.7057249
Holm LE. 1984. Malignant disease following iodine-131 therapy in Sweden. In: Boice JDJ, Fraumeni JFJ, eds. Radiation carcinogenesis: Epidemiology and biological significance. New York, NY: Raven Press, 263–271.
Holm L-E. 1985. Thyroid cancer after exposure to radioiodine. Strahlenschutz ForschPrax 25:36–56.
*Holm L-E. 1991. Cancer risks after diagnostic doses of ^131^I with special reference to thyroid cancer. Cancer Detect Prev 15(1):27–30.2044071
Holm L-E, Hall PFL. 1993. Swedish iodine-131 study. Radiat Res 133(1):134–135.
Holm LE, Dahlqvist I, Israelsson A, . 1980a. Malignant thyroid tumors after iodine-131 therapy. N Engl J Med 303(4):188–191.7383089
Holm LE, Eklund G, Lundell G. 1980b. Incidence of malignant thyroid tumors in humans after exposure to diagnostic doses of iodine-131. II. Estimation of thyroid gland size, thyroid radiation dose, and predicted versus observed number of malignant thyroid tumors. J Natl Cancer Inst 63(6):1221–1224.
*Holm L-E, Hall P, Wiklund K, . 1991. Cancer risk after iodine-131 therapy for hyperthyroidism. J Natl Cancer Inst 83:1072–1077.1875414
Holm L-E, Lundell G, Israelsson A, . 1982. Incidence of hypothyroidism occurring long after iodine-131 therapy for hyperthyroidism. J Nucl Med 23:103–107.7057248
Holm LE, Lundell G, Walinder G. 1980c. Incidence of malignant thyroid tumors in humans after exposure to diagnositc doses of iodine-131. I. Retrospective cohort study. J Natl Cancer Inst 64(5):1055–1059.6929011
Holm L-E, Wiklund KE, Lundell GE, . 1988. Thyroid cancer after diagnostic doses of iodine-131: A retrospective cohort study. J Natl Cancer Inst 80:1132–1138.3411626
*Holm L-E, Wiklund DE, Lundell GE, . 1989. Cancer risk in population examined with diagnostic doses of ^131^I. J Natl Cancer Inst 81:302–306.2913329
Hooper PL, Turner JR, Conway MJ, . 1980. Thyroid uptake of ^123^I in a normal population. Arch Intern Med 140:757–758.7387268
*Horn B, Kabins SA. 1972. Iodide fever. Am J Med Sci 264(6):467–471.4650803
*Horn-Ross PL, Morris JS, Lee M, . 2001. Iodine and thyroid cancer risk among women in a multiethnic population: the Bay Area Thyroid Cancer Study. Cancer Epidemiol Biomarkers Prev 10(9):979–985.11535551
Hoshi M, Takada J, Oka T, . 1996. A possible explanation for the DS86 discrepancy between the data and calculation in Hiroshima. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, The Netherlands: Elsevier, 175–191.
Hoshi M, Yamamoto M, Kawamura H, . 1994. Fallout radioactivity in soil and food samples in the Ukraine: Measurements of iodine, plutonium, cesium, and strontium isotopes. Health Phys 67(2):187–191.7619095
Hoskin PJ, Spathis GS, McCready VR, . 1985. Low-dose radiation given six-monthly in Graves’ disease. J R Soc Med 78:893–898.3840844
*Hou X, Chai C, Qian Q, . 1997a. The study of iodine in Chinese total diets. Sci Total Environ 193:161–167.9092075
*Hou X, Chai X, Qian Q, . 1997b. Determination of bromine and iodine in normal tissues from Beijing health adults. Biol Trace Elem Res 56:225–230.9164667
*Hou X, Dahlgaard H, Rietz B, . 1999. Determination of chemical species of iodine in seawater by radiochemical neutron activation analysis combined with ion-exchange preseparation. Anal Chem 71:2745–2750.
Houssay AB, Gamper GH, Arias NH, . 1978. Effects of indomethacin upon ^131^I uptake by thyroid and submaxillary glands in mice. J Dent Res 57(1):83–86.277505
*Howard JE, Vaswani A, Heotis P. 1997. Thyroid disease among the Rongelap and Utirik population-an update. Health Phys 73(1):190–198.9199229
Howarth DM, Epstein MT, Thomas PA, . 1997. Outpatient management of patients with large multinodular goitres treated with fractionated radioiodine. Eur J Nucl Med 24(12):1465–1469.9391180
*Howe JR. Bowlt C. 1991. A rapid method for estimating iodine-125 in water samples using x-ray fluorescence for yield correction. J radioanal Nucl Chem 152:347–357.
*HSDB. 2000. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Program, Bethesda, MD. July 2000.
*HSDB. 2001. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Program, Bethesda, MD. July 2001.
*Huang W, Kukes, GD. 1999. Hashimoto’s thyroiditis: An organ-specific autoimmune disease - pathogenesis and recent developments. Lab. Invest. 79(10): 1175–1180.10532582
*Huang T-S, Lu F-J. 1991. Iodide binding by humic acid. Environ Toxicol Chem 10:179–184.
Hughes WL, Weinblatt AC, Prensky W. 1977. Chromosome damage in Chinese hamster cells produced by ^125^I-UdR at the site of its incorporation. Curr Top Radiat Res Q 12:453–471.
Hugo AC, Pisarev MA, Juvenal GJ, . 1990. Further studies on iodide uptake autoregulation in calf thyroid slices. 40:149–154.
Hunermann B. 1976. [Iodine-131 treatment of hyperthyroidism.] Therapiewoche 26(2):129–133. (German)
Hurley JR. 1994. Orbitopathy after treatment of Graves’ disease. J Nucl Med 35(5):918–920.8176482
Hurley LS. 1980. Trace elements I: Iron, copper, iodine. In: Developmental nutrition. Englewood Cliffs, NJ: Prentice-Hall, 183–197.
Hurrell RF. 1997. Bioavailability of iodine. Eur J Clin Nutr 51(Suppl 1):S9–S12.
*Hutchings PR, Verma S, Phillips JM, . 1999. Both CD4(+) T cells and CD8(+) T cells are required for iodine accelerated thyroiditis in NOD mice. Cell Immunol 192(2):113–121.10087179
Huysmans DAKC, Buijs WCAM, van de Ven MTP, . 1996. Dosimetry and risk estimates of radioiodine therapy for large, multinodular goiters. J Nucl Med 37(12):2072–2079.8970537
*Huysmans DAKC, Hermus ARMM, Edelbroek MAL, . 1997a. Autoimmune hyperthyroidism occurring late after radioiodine treatment for volume reduction of large multinodular goiters. Thyroid 7(4):535–539.9292939
Huysmans D, Hermus A, Edelbroek M, . 1997b. Radioiodine for nontoxic multinodular goiter. Thyroid 7(2):235–239.9133693
*IAEA. 1962. Whole-body counting. International Atomic Energy Agency. Vienna: IAEA Publication No. STI/PUB/47.
*IAEA. 1970. Directory of whole-body radioactivity monitors. International Atomic Energy Agency. Vienna: IAEA Publication No. STI/PUB/213.
*IAEA. 1972. Assessment of radioactive contamination in man. International Atomic Energy Agency. Vienna: IAEA Publication No. STI/PUB/290.
*IAEA. 1976. Diagnosis and treatment of incorporated radionuclides. International Atomic Energy Agency. Vienna: IAEA Publication No. STI/PUB/411.
*IAEA. 1985. Assessment of radioactive contamination in man. International Atomic Energy Agency. Vienna: IAEA Publication No. STI/PUB/674.
*IAEA. 1988. The radiological accident in Goiania. International Atomic Energy Agency. Vienna: IAEA Publication No. STI/PUB/815.
IAEA. 1989. Measurement of radionuclides in food and the environment. International Atomic Energy Agency. Vienna: IAEA Publication No. STI/DOC/10/295.
*IAEA. 1991. The international Chernobyl project. Technical Report. Assessment of radiological consequences and evaluation of protective measures. International Atomic Energy Agency. Vienna.
*Iancu T, Boyanower Y, Laurian N. 1974. Congenital goiter due to maternal ingestion of iodide. Am J Dis Child 128:528–530.4369886
IARC. 1977. IARC monographs on the evaluation of the carcinogenic risk of chemicals to man: Some fumigants, the herbicides 2,5-D and 2,4,5-T, chlorinated dibenzodioxins and miscellaneous industrial chemicals. Lyon, France: International Agency for Research on Cancer.
Ichikawa R. 1978. A comment on the paper “Thyroidal burdens of ^129^I from various dietary sources” by S.A. Book et al. Health Phys 34:277–278.
*ICRP. 1979. Limits for intakes of radionuclides by workers. ICRP Publication 30, Part 1. International Commission on Radiological Protection. Pergamon Press, Oxford, 88–90.
*ICRP. 1981. Report of the task group on reference man. The International Commission on Radiological Protection. Pergamon Press. IRCP Publ No. 23.
*ICRP. 1988. Radiation dose to patients from radiopharmaceuticals. International Commission on Radiological Protection. Pergamon Press, Oxford. ICRP publ No. 53, 259–277.
*ICRP. 1989. Age-dependent doses to members of the public from intake of radionuclides: Part 1. International Commission on Radiological Protection. Pergamon Press, Oxford. P.45–51.
*ICRP. 1991. 1990 Recommendations of the International Commission on Radiological Protection, ICRP Publication 60. Oxford: Pergamon Press, 46.
*ICRP. 1993. Age dependent doses to members of the public from intake of radionuclides: Part 2 ingestion dose coefficients. International Commission on Radiological Protection. Annals of the ICRP. Vol. 23(3/4). ICRP publication 67.
*ICRP. 1994a. Dose coefficients for intakes of radionuclides by workers. International Commission on Radiological Protection. Annals of the ICRP. Vol. 24(4). ICRP publication 68.
*ICRP. 1994b. Human respiratory tract model for radiological protection. International Commission on Radiological Protection. Pergamon Press, Oxford.
*ICRP. 1995. Age-dependent doses to members of the public from intake of radionuclides: Part 4. Inhalation dose coefficients. International Commission on Radiological Protection. Pergamon Press, Oxford, 195–232.
*ICRP. 1996. Age-dependent doses to members of the public from intake of radionuclides: Part 5. Compilation of ingestion and inhalation dose coefficients. Ann ICRP 26(1):60–61.
*ICRP. 2001. The ICRP database of dose coefficients: Workers and members of the public. Version 2.01. Elsevier Science Ltd. International Commission on Radiological Protection.
Idee JM, Beaufils H, Bonnemain B. 1994. Iodinated contrast media-induced nephropathy: Pathophysiology, clinical aspects and prevention. Fundam Clin Pharmacol 8:193–206.7927115
*IEA 2000. Key world energy statistics from the IEA, 2000 Web edition (http://www.iea.org/statist/index.htm. International Energy Agency, Paris, France.
*Iff HW, Wilbrandt W. 1963. [The dependency of iodine accumulation in thyroid slices on the ional composition of the incubation medium; influence of heart glycosides.] Biochim Biophys Acta 70:711–752. (German)14102762
Igumnov S, Drozdovitch V. 2000. The intellectual development, mental and behavioural disorders in children from Belarus exposed in utero following the Chernobyl accident. Eur Psychiatry 15(4):244–253.10951608
*Iiyin LA, Balonov MI, Buldakov LA, . 1990. Radiocontamination patterns and possible health consequences of the accidents at the Chernobyl nuclear power station. J Radiol Prot 10(13):3–29.
Ilundain A, Larralde J, Toval M. 1987. Iodide transport in rat small intestine: Dependence on calcium. J Physiol 393:19–27.3446797
Ingbar DH. 1996a. The respiratory system in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 805–810.
Ingbar DH. 1996b. The respiratory system in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 616–627.
Inman P. 1974. Iododerma. Br J Dermatol 91(6):709–711.
*International Isotopes. 2001. International Isotopes Inc achieves beam in CP-42 MeV accelerator. http://www.nuclear-medicine.com. May 22, 2001.
*IRIS. 2001. Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.htm.
Isaacs GH, Rosenberg IN. 1967. Effect of thyrotropin on thyroid clearance of iodide and pertechnetate: Comparative observations at normal and high plasma iodide concentrations. Endocrinology 81:981–992.6052946
*Ishigaki K, Namba H, Takamura N. 2001. Urinary iodine levels and thyroid diseases in children; comparison between Nagasaki and Chernobyl. Endocr J (Tokyo) 48(5):591–595.
Ishikawa M, Izawa G, Omori T, . 1985. Application of proton induced x-ray emission to the qualitative and quantitative analysis of iodine in biological samples. J Radioanal Nucl Chem 91(1):163–171.
Ishizuki Y, Hirooka Y, Tanigawa S, . 1996. Confirmation of the safety of iodine-overloaded women during lactation. Nippon Naibunpi Gakkai Zasshi 72(3):523–532.
Isozaki O, Emoto N, Tsushima T, . 1992. Opposite regulation of deoxyribonucleic acid synthesis and iodide uptake in rat thyroid cells by basic fibroblast growth factor: Correlation with opposite regulation of c-fos and thyrotropin receptor gene expression. Endocrinology 131(6):2723–2732.1332847
Itikawa A, Kawada J, Ito Y. 1967. Iodide goiter in the mouse. Endocrinol Jpn 14(4):333–341.5631358
Ito K. 1999. Semi-micro ion chromatography of iodide in seawater. J Chromatogr 830:211–217.
Ito K, Tsuchiya T, Sugino K, . 1996. [An evaluation of the incidence of hyperparathyroidism after 131I treatment for Basedow disease (Part II).] Kaku Igaku 33(7):737–742. (Japanese)8803442
Ivanov VK, Gorsky AI, Tsyb AF, . 1999. Dynamics of thyroid cancer incidence in Russia following the Chernobyl accident. J Radiol Prot 19(4):305–318.10616777
Ivanov VK, Tsyb AF. 1996. Chernobyl radiation risks: Assessments of morbidity, mortality and disability rates according to the data of the National Radiation and Epidemiological Registry, 1995. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, the Netherlands: Elsevier, 31–42.
Izembart M, Chavaudra J, Aubert B, . 1992. Retrospective evaluation of the dose received by the ovary after radioactive iodine therapy for thyroid cancer. Eur J Nucl Med 19:243–247.1597239
Jackson GL, Flickinger FW, Graham WP, . 1979. Thymus accumulation of radioactive iodine. Pa Med 82(11):37–38.
Jackson HJ, Sutherland RM. 1981. Effect of povidone-iodine on neonatal thyroid function [Letter]. Lancet 2(8253):992.
*Jacob P, Goulko G, Heidenreich WF, . 1998. Thyroid cancer risk to children calculated. Nature 392(6671):31–32.9510245
*Jacobson AP, Plato PA, Toeroek D. 1978. Contamination of the home environment by patients treated with iodine-131: Initial results. Am J Public Health 68(3):225–230.637168
Jacobson JM, Hankins GV, Murray JM, . 1981. Self-limited hyperthyroidism following intravaginal iodine administration. Am J Obstet Gynecol 140(4):472–473.7246670
*Jacobson JM, Hankins GV, Young RL, . 1984. Changes in thyroid function and serum iodine levels after prepartum use of a povidone-iodine vaginal lubricant. J Reprod Med 29(2):98–100.6708034
*Jafek BW, Small R, Lillian DL. 1974. Congenital radioactive iodine-induced stridor and hypothroidism. Arch Otolaryngol 99:369–371.4832618
Jagetia GC, Gupta SM, Kumar S, . 1982. Response of peripheral blood to ^131^I treatment by Swiss albino mice. Radiobiol Radiother 23:187–190.
*Jahreis G, Hausmann W, Kiessling G, . 2001. Bioavailability of iodine from normal diets rich in dairy products-results of balance studies in women. Exp Clin Endocrinol Diabetes 109(3):163–167.11409299
Jahreis G, Hesse V, Plenert W, . 1985. Influence of phytogenic substances with thyreostatic effects in combination with iodine on the thyroid hormones and somatomedin level in pigs. Exp Clin Endocrinol 85(2):183–190.2410286
Jambut-Absil AC, Buxeraud J, Lagorce JF, . 1987. Charge transfer complexes of drugs with iodine investigation by UV/visible spectroscopy. Int J Pharm 35:129–137.
James RA 1964. Calculation of radioactive iodine concentrations in milk and human thyroid as a result of nuclear explosions. Lawrence Radiation Laboratory, University of California at Livermore. Livermore, California. UCRL-7716.
Jay K, Stieglitz L. 1995. Identification and quantification of volatile organic components in emissions of waste incineration plants. Chemosphere 30(7):1249–1260.
Jefferies AL, Coates G, Webber CE, . 1984. Measurement of pulmonary clearance of radioaerosol using a portable sodium iodide probe. J Appl Physiol 57(6):1908–1912.6392229
Jelovsek FR, Mattison DR, Chen JJ. 1989. Prediction of risk for human developmental toxicity: How important are animal studies for hazard identification? Obstet Gynecol 74:624–636.2797639
Jendrasiak GL, Estep TN. 1977. The inhibition of iodide uptake in the thyroid gland by the fluorescent dye, ANS. Life Sci 21:149–158.142190
Jenkins KJ, Hidiroglou M. 1990. Effects of elevated iodine in milk replacer on calf performance. J Dairy Sci 73:804–807.2341652
Jensen RH, Reynolds JC, Robbins J, . 1997. Glycophorin A as a biological dosimeter for radiation dose to the bone marrow from iodine-131. Radiat Res 147:747–752.9189175
*Jialal I, Pillay NL, Asmal AC. 1980. Radio-iodine-induced hypoparathyroidism. S Afr Med J 58:939–940.7444692
*Jirousek L, Pritchard ET. 1971. On the chemical iodination of tyrosine with protein sulfenyl iodide and sulfenyl periodide derivatives: The behavior of thiol protein-iodine systems. Biochemica Biophysica Acta 243:230–238.
Jirousek L, Soodak M. 1974. Studies of positive iodine compounds as models of the thyroidal “active iodine”: Reaction of N-iodosuccinimide and of N-iodophtalimide with thiocarbamide goitrogens. J Pharmacol Exp Ther 191(2):341–348.4421149
Joesfsson M, Grunditz T, Ohlsson T, . 2002. Sodium/iodide-symporter: Distribution in different mammals and role in entero-thyroid circulation of iodide. Acta Physiol Scand 175(2):129–137.12028133
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johansson H, Nylander G. 1968. Effect of iodine and thyroxine on the thyroid in thiouracil-treated rats. Acta Soc Med Ups 74:151–160.
*John W, Kaifer R, Rahn K, . 1973. Trace element concentrations in aerosols from the San Francisco bay area. Atmos Environ 7:107–118.4685063
Johnson CE, Cohen IA. 1988. Theophylline toxicity after iodine 131 treatment for hyperthyroidism. Clin Pharm 7:620–622.3168415
Johnson JK. 1993. Outcome of treating thyrotoxic patients with a standard dose of radioactive iodine. Scott Med J 38:142–144.8290939
Johnson JR. 1978. Summary of bioassay and thyroid monitoring results following an accidental exposure to ^125^I. Health Phys 34:106–107.621148
*Johnson JR. 1982. Fetal thyroid dose from intakes of radioiodine by the mother. Health Phys 43(4):573–582.7152917
*Johnson JR. 1986. A review of age dependent radioiodine dosimetry. In: Gerber, GB, Metivier H, Smith H, eds. Workshop on age, related factors in radionuclide metabolism and dosimetry. Angers, France, 249–260.
Johnson JR, Lamothe ES. 1987. Dose to the basal layer of the skin grom ^125^I skin contamination. Radiat Prot Dosim 20(4):253–256.
Johnson TM, Rapini RP. 1988. The Wolff-Chaikoff effect: Hypothyroidism due to potassium iodide [Letter]. Arch Dermatol 124:1184–1185.3401021
Jonadet M, Chopineau J, Bastide P. 1982. [Optotoxic effects of sodium iodate on several enzymatic activities of the retina (glycolysis, Krebs cycle, pentose cycle.] Ann Pharm Fr 40(3):281–289. (French)7181424
Jonckheer MH, Velkeniers B, Vanhaelst L, . 1992. Further characterization of iodide-induced hyperthyroidism based on the direct measurement of intrathyroidal iodine stores. Nucl Med Commun 13:114–118.1436897
Jones AR, Edwards K. 1973. Alkylating esters VII. The metabolism of iso-propyl methanesulphonate and iso-propyl iodide in the rat. Experientia 29(5):538–539.4354193
*Jones RE, Aulerich RJ, Ringer RK. 1982a. Feeding supplemental iodine to mink: Reproductive and histopathologic effects. J Toxicol Environ Health 10:459–471.7175974
*Jones SD, Spencer CP, Truesdale VW. 1982b. Determination of total iodine and iodate-iodine in natural freshwater. Analyst 107:1417–1424.
*Jönsson H, Mattsson S. 1998. Thyroid burdens of ^125^I in hospital laboratory workers during a 20-y period. Health Phys 75(5):475–478.9790555
Jooste PL, Weight MJ, Lombard CJ. 2000. Short-term effectiveness of mandatory iodization of table salt, at an elevated iodine concentration, on the iodine and goiter status of schoolchildren with endemic goiter. Am J Clin Nutr 71(1):75–80.10617949
Jorgensen JV, Brandrup F, Schroll M. 1973. Possible synergism between iodine and lithium carbonate. JAMA 223(2):192–193.
Joseph K, Mahlstedt J, Welcke U. 1980. [Early recognition of autonomous thyroid tissue by a combination of quantitative thyroid pertechnetate scintigraphy with the free T_4_ equivalent.] Nuklearmedizin 19(2):54–63. (German)7413438
Joshi P. 1989. A complication of povidone-iodine. Anaesthesia 44(8):692.
Jost DT, Gaggeler HW, Baltensperger U, . 1986. Chernobyl fallout in size-fractionated aerosol [Letter]. Nature 324(6092):22–23.3785367
Joyce WT, Cowan RJ. 1995. A potential false-positive posttherapy radioiodine scan secondary to I-131 excretion in perspiration. Clin Nucl Med 20:368–369.7788999
*Jubiz W, Carlile S, Lagerquist LD. 1977. Serum thyrotropin and thyroid hormone levels in humans receiving chronic potassium iodide. J Clin Endocrinol Metab 44:379–382.838843
Juhasz F, Stenszky V, Bartha I, . 1983. A complex clinical and genetic analysis of patients with medullary thyroid carcinoma. Acta Endocrinol Suppl 252:16–17.
Juvenal GJ, Pregliasco LB, Krawiec L, . 1997. Long-term effect of norepinephrine on iodide uptake in FRTL-5 cells. Thyroid 7(5):795–800.9349587
*Kada T. 1970. Radio-sensitization with iodine compounds: II. Studies on mutant strains of Escherichia coli K12 resistant to radiation-induced toxic products from iodoacetic acid, potassium iodide or potassium iodate. Int J Radiat Biol 17(5):419–430.
*Kada T, Noguti T, Namiki M. 1970. Radio-sensitization with iodine compounds: I. Examination of damage in deoxyribonucleic acid with Bacillus subtilis transformation system by irradiation in the presence of potassium iodide. Int J Radiat Biol 17(5):407–418.
Kader A, Ahmad S, El-Gendy AE, . 1994. Spectrophotometric studies on molecular interactions I. Complexation of iodine with polyvinylpyrrolidone polymer and with the monomer n-methyl-2-pyrrolidone. Bull Fac Pharm (Cairo Univ) 32(1):17–23.
Kagan RJ, Miller RW, Wagner WM. 1976. Radioiodine breathing zone monitor efficiency as a function of radioiodine concentration and sampling rate. Health Phys 31(6):555–556.
*Kahaly G, Dienes HP, Beyer J, . 1997. Randomized, double blind, placebo-controlled trial of low dose iodide in endemic goiter. J Clin Endocrinol Metab 82(12):4049–4053.9398711
*Kahaly GJ, Dienes HP, Beyer J, . 1998. Iodide induced thyroid autoimmunity in patients with endemic goitre: A randomised, double-blind, placebo-controlled trial. Eur J Endocrinol 139:290–297.9758438
Kalaria VG, Porsche R, Ong LS. 2001. Iodine mumps: Acute sialadenitis after contrast administration for angioplasty. Circulation 104(19):2384.11696482
Kalk WJ, Durbach D, Kantor S, . 1980. Very low doses of radio-iodine for hyperthyroidism: Failure to prevent a high incidence of early hypothyroidism. S Afr Med J 57:479–482.7368008
Kanda T, Ghidoni JJ. 1970. Light and electron microscopic observations on iodide-induced sialoadenitis of hamster submaxillary glands. Laryngoscope 80(3):455–466.5436965
Kang Z, Zhou Q, Liu S. 1995. [The early development of hypothyroidism after 131I treatment for hyperthyroid Graves’ disease.] Zhonghua Heyixue Zazhi 15(1):26–28. (Chinese)
Kanno J, Onodera H, Furuta K, . 1992. Tumor-promoting effects of both iodine deficiency and iodine excess in the rat thyroid. Toxicol Pathol 20(2):226–235.1475583
Kapitola J, Kuechel O, Schreiberova O, . 1968. Decreased thyroid radioiodine uptake after diazoxide in rats. Experientia 24(1):50–51.5637616
Kapitola J, Schullerova M, Schreiberova O. 1970. Blood flow and radioiodine uptake in the thyroid gland of rats after administration and discontinuation of methylthiouracil. Acta Endocrinol 65:435–441.
*Kaplan DI, Serne RJ, Parker KE, . 2000. Iodide sorption to subscribe sediments and illitic minerals. Environ Sci Technol 34:399–405.
Kaplan MM, Garnick MB, Gelber R, . 1983. Risk factors for thyroid abnormalities after neck irradiation for childhood cancer. Am J Med 74:272–280.6824006
Kaplan MM, Meier DA, Dworkin HJ. 1998. Treatment of hyperthyroidism with radioactive iodine. Endocrinol Metab Clin North Am 27(1):205–223.9534037
Kapuscinski W, Bacin F, Kantelip B, . 1979. [Experimental retinopathy induced by sodium iodate: Comparison with human retinitis pigmentosa.] Bull Soc Ophtalmol Fr 79(3):231–238. (French)527168
Kargacin B, Kostial K. 1985. Reduction of ^85^Sr, ^137^Cs, ^131^I and ^141^Ce retention in rats by simultaneous oral administration of calcium alginate, ferrihexacyanoferrate(II), KI and Zn-DTPA. Health Phys 49:858–864.
Karlan MS, Pollock WF, Snyder WH. 1964. Carcinoma of the thyroid following treatment of hyperthyroidism with radioactive iodine. Calif Med 101(3):196–199.14199090
Kasatkina EP, Shilin DE, Matkovskaya AN, . 1995. [Radiation-induced pathomorphism of endemic goiter in children and adolescents in a focus of iodine deficiency (initial manifestations of remote effects of the Chernobyl accident).] Probl Endokrinol (Mosk) 41(3):17–23. (Russian)
Kassis AI, Fayad F, Kinsey BM, . 1987a. Radiotoxicity of ^125^I in mammalian cells. Radiat Res 111:305–318.3628718
Kassis AI, Sastry KSR, Adelstein SJ. 1987b. Kinetics of uptake, retention, and radiotoxicity of ^125^IUdR in mammalian cells: Implications of localized energy deposition by auger processes. Radiat Res 109:78–89.3809393
Katagiri K, Shimizue T, Akatsu Y, . 1997. Study on the behavior of ^129^I in the terrestrial environment. J Radioanal Nucl Chem 226(1–2):23–27.
*Katayama Y, Widdicombe JH. 1991. Halide transport in xenopus oocytes. J Physiol 443:587–599.1822540
Kato GT (1981): A comparison study between I-123 and I-131 in thyroid uptakes in adults. Master of Science in Medical Physics Thesis, University of California, Los Angeles, p. 38.
Kaul A, Roedler HD. 1980. Radioiodine: Biokinetics, mean dose and dose distribution. Radiat Environ Biophys 18:185–195.7454972
*Kaurin DGL, Carsten AL, Baum JW. 2000. Effective half-lives for patients administered radiolabeled antibodies and calculated dose to the public in close proximity to patients. Health Phys 78(2):215–221.10647987
*Kay C, Abrahams S, McClain P. 1966. The weight of normal thyroid glands in children. Arch Pathol 82:349–352.5954048
Kay TWH, Heyma P, Harrison LC, . 1987. Graves disease induced by radioactive iodine. Ann Intern Med 107(6):857–858.3688680
*Kearns JE, Philipsborn HF. 1962. Values for thyroid uptake of I^131^ and protein-bound iodine in “normal” individuals from birth to twenty years. Q Bull Northwest Univ Med Sch 36:47–50.14454725
Keating FR, Albert A. 1949. The metabolism of iodine in man as disclosed with the use of radioiodine. Recent Prog Horm Res IV:429–481.
Keith RL, McGuinness SJ, Gandolfi AJ, . 1995. Interaction of metals during their uptake and accumulation in rabbit renal cortical slices. Environ Health Perspect Suppl 103(1):77–80.
Keldsen N, Mortensen BT, Hansen HS. 1990. Hematological effects from radioiodine treatment of thyroid carcinoma. Acta Oncol 29:1035–1039.2278724
Kellen JA. 1973. Induction of rat mammary tumours in altered iodine metabolism. Oncology 28:269–273.4767112
Kelly GN. 1977. Global circulation of iodine 129. In:, ed. Iodine 129: Proceedings of an NEA specialist meeting. Paris, France: Organisation for Economic Co-Operation and Development, 40–42.
Kemp WN. 1939. Iodine deficiency in relation to the stillbirth problem. Can Med Assoc J 41:356–361.20321492
Kendall-Taylor P, Keir MJ, Ross WM. 1984. Ablative radioiodine therapy for hyperthyroidism: Long term follow up study. Br Med J 289:361–363.6432100
Kennedy JS, Thomson JA. 1974. The changes in the thyroid gland after irradiation with ^131^I or partial thyroidectomy for thyrotoxicosis. J Pathol 112:65–81.4834051
Kennish MJ. 1998. Trace metal-sediment dynamics in estuaries: Pollution assessment. Rev Environ Contam Toxicol 155:69–110.
*Kerber RA, Till JE, Simon SL, . 1993. A cohort study of thyroid disease in relation to fallout from nuclear weapons testing. JAMA 270:2076–2082.8411574
*Kereiakes JG, Wellman HN, Simmons G, . 1972. Radiopharmaceutical dosimetry in pediatrics. Semin Nucl Med 2(4):316–327.4630073
*Kerl W, Becker JS, Dietze H-J, . 1996. Determination of iodine using a special sample introduction system coupled to a double-focusing sector field inductively coupled plasma mass spectrometer. J Anal Atom Spectrom 11:723–726.
*Kessler FK, Laskin DL, Borzelleca JF, . 1980. Assessment of somatogenotoxicity of povidone-iodine using two in vitro assays. J Environ Pathol Toxicol 4(2–3):327–335.7462908
*Khan F, Einbinder JM, Seriff NS. 1973. Suppurative ulcerating iododerma-a rare manifestation of inorganic iodide hypersensitivity. N Engl J Med 289:1018–1020.4270248
*Khan LK, Ruowel LI, Gootnick D, . 1998. Thyroid abnormalities related to iodine excess from water purification units. Lancet 352:1519.9820302
Khanna CM, Jain SK, Walia RP. 1994. Thyrotoxicosis-treatment by ^131^I therapy and early prediction of hypothyroidism following this therapy. J Assoc Physicians India 42(1):36–38.7836246
*Kidd PS, Trowbridge FL, Goldsby JB, . 1974. Sources of dietary iodine. Journal of the American Dietary Association 65:420–422.
Kilbane MT, Ajjan RA, Weetman AP, . 2000. Tissue iodine content and serum-mediated 125I uptake-blocking activity in breast cancer. J Clin Endocrinol Metab 85(3):1245–1250.10720070
*Killough GG, Eckerman KF. 1986. Age- and sex-specific estimation of dose to a normal thyroid from clinicacal adminstration of iodine-131. Oak Ridge, Tennessee: Oak Ridge National Laboratory, 1–29.
*Kim WS, McGlothlin JD, Kupel RE. 1981. Sampling and analysis of iodine in the industrial atmosphere. Am Ind Hyg Assoc J 42(3):187–190.
*Kimura S, Kotani T, McBride OW . 1987. Human thyroid peroxidase: Complete cDNA and protein sequence, chromosome mapping and identification of two alternately spliced mRNAs. Proc Natl Acad Sci USA 84:5555–5559.3475693
*Kincaid MC, Green WR, Hoover RE, . 1981. Iododerma of the conjunctiva and skin. Ophthalmology 88:1216–1220.7322470
*Kint A, Van Herpe L. 1977. Iododerma. Dermatologica 155(3):171–173.142670
Kinuya S, Hwang E-H, Ikeda E, . 1997. Mallory-Weiss syndrome caused by iodine-131 therapy for metastatic thyroid carcinoma. J Nucl Med 38(11):1831.
*Kirchner G. 1994. Transport of iodine and cesium via the grass-cow-milk pathway after the Chernobyl accident. Health Phys 66(6):653–665.8181940
*Kiviniitty K, Nasman P, Leppaluoto J. 1984. Accumulation of ^125^I in the thyroid glands of laboratory workers. Health Phys 46(1):234–236.6693246
*Klebanoff SJ, Green WL. 1973. Degradation of thyroid hormones by phagocytosing human leukocytes. J Clin Invest 52:60–72.4629909
Kleiman de Pisarev DL, Pisarev MA, Juvenal GJ. 1978. Action of KI and several iodocompounds on [^3^H]uridine incorporation into thyroid RNA. Acta Endocrinol 89:316–322.
Klein E. 1972. [Thyroid hormones following iodine isotope therapy.] Dtsch Med Wochenschr 97:42. (German)
Klein I, Levey GS. 1983. Iodide excess and thyroid function. Ann Intern Med 98(3):406–407.6830082
Klein I, Levey GS. 1996. The cardiovascular system in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 607–615.
Klein I, Ojamaa K. 1996. The cardiovascular system in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 799–804.
Klein RZ, Mitchell ML. 1996. Hypothyroidism in infants and children. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 984–988.
Klett M, Ohlig M, Manz F, . 1999. Effect of iodine supply on neonatal thyroid volume and TSH. Acta Paediatr Suppl 432:18–20.
Klett M, Ohlig M, Troger F, . 2001. Newborn thyroid volume reflects maternal iodine supply and smoking habit. Pediatr Res 49(2):300.
Klonecke A, Peterson MM, McDougall IR. 1990. Thyrotoxicosis with low thyroidal uptake of radioiodine. Semin Nucl Med XX(4):364–366.
Knudsen N, Bulow I, Jorgensen T, . 2000a. Comparative study of thyroid function and types of thyroid dysfunction in two areas in Denmark with slightly different iodine status. Eur J Endocrinol 143(4):485–491.11022194
Knudsen N, Bulow I, Jorgensen T, . 2000b. Goitre prevalence and thyroid abnormalities at ultrasonography: A comparative epidemiological study in two regions with slightly different iodine status. Clin Endocrinol 53(4):479–485.
Knudsen N, Christiansen E, Brandt-Christiansen M, . 2000c. Age- and sex-adjusted iodine/creatinine ratio. A new standard in epidemiological surveys? Evaluation of three different estimates of iodine excretion based on casual urine samples and comparison to 24h values. Eur J Clin Nutr 54(4):361–363.10745289
Knudsen N, Perrild H, Christiansen E, . 2000d. Thyroid structure and size and two-year follow-up of solitary cold thyroid nodules in an unselected population with borderline iodine deficiency. Eur J Endocrinol 142(3):224–230.10700715
Ko YI, Kim SS, Han SK. 1995. Transdermal permeation-enhancing activities of some inorganic anions. Arch Pharmacal Res 18(4):231–236.
Kobberling J, Hintze G, Becker HD. 1985. Iodine-induced thyrotoxicosis- A case for subtotal thyroidectomy in severely ill patients. Klin Wochenschr 63:1–7.
*Kocher DC. 1981. On the long-term behavior of ^129^I in the terrestrial environment. International Symposium on Migration in the Terrestrial Environment of Long-Lived Radionuclides from the Nuclear Fuel Cycle. IAEA-SM-257/56.
Kocher DC. 1991. A validation test of a model for long-term retention of ^129^I in surface soils. Health Phys 60(4):523–531.2001948
*Kogai T, Endo T, Saito T, . 1997. Regulation by thyroid-stimulating hormone of sodium/iodide symporter gene expression and protein levels in FRTL-5 cells. Endocrinology 138(6):2227–2232.9165005
*Kogai T, Hershman JM, Motomura K, . 2001. Differential regulation of the human sodium/iodide symporter gene promoter in papillary thyroid carcinoma cell lines and normal thyroid cells. Endocrinology 142(8):3369–3379.11459780
Kogai T, Schultz JJ, Johnson LS, . 2000. Retinoic acid induces sodium/iodide symporter gene expression and radioiodide uptake in the MCF-7 breast cancer cell line. Proc Natl Acad Sci USA 91(15):8519–8524.
*Koh T, Ono M, Makino I. 1988. Spectrophotometric determination of iodide at the 10^-6^ mol 1^-1^ level by solvent extraction with methylene blue. Analyst 113:945–948.
Kohan SL, Guillen CE, Pardes EM, . 1992. Effects of keotconazole on the iodide uptake by FRTL-5 cells. Acta Endocrinol 127:449–453.
*Kohn LA. 1975. A look at iodine-induced hyperthyroidism: Recognition. Bull N Y Acad Med 51(8):959–966.1102000
*Kohn LA. 1976. The midwestern American “epidemic” of iodine-induced hyperthyroidism in the 1920s. Bull N Y Acad Med 52(7):770–781.782612
Kohn LD, Suzuki K, Nakazato M, . 2001. Effects of thyroglobulin and pendrin on iodide flux through the thyrocyte. Trends in Endocrinology & Metabolism 12(1):10–16.11137035
*Köhrle J. 1994. Thyroid hormone deiodination in target tissues-a regulatory role for the trace element selenium. Exp Clin Endocrinol 102:63–89.8056056
*Kolonel LN, Hankin JH, Wilkens LR, . 1990. An epidemiologic study of thyroid cancer in Hawaii. Cancer Causes Control 1:223–234.2102295
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Kondo H, Fukuda H, Ono H, . 2001. Sodium thiosulfate solution spray for relief of irritation caused by Lugol’s stain in chromoendoscopy. Gastrointest Endosc 53(2):199–202.11174292
Konermann G. 1992. Biokinetics of radioiodine (^125^I) during pre and post-natal development and the interference with the induction of developmental effects in the mouse brain. Radiat Prot Dosim 41:157–162.
*Konno N, Makita H, Yuri K, . 1994. Association between dietary iodine intake and prevalence of subclinical hypothyroidism in the coastal regions of Japan. J Clin Endocrinol Metab 78(2):393–397.8106628
*Konno N, Taguchi H, Miura K, . 1993a. Serum thyrotropin concentration in apparently healthy adults, in relation to urinary iodide concentration. Clin Chem 39(1):174–175.8419053
*Konno N, Yuri K, Miura K, . 1993b. Clinical evaluation of the iodide/creatine ratio of casual urine samples as an index of daily iodine excretion in a population study. Endocrine Journal 40(1):163–169.7951490
Konoplya EF, Fil’chenkov GN, Popov EG, . 1992. [Effect of iodine-131 on sex and thyroid hormone binding to blood plasma proteins in children with functional lesions of the thyroid gland as a result of Chernobyl disaster.] Radiobiologiia 32(4):488–492. (Russian)1410283
Konukoglu D, Hatemi HH, Arikan S, . 1998. Radioiodine treatment and oxidative stress in thyroidectomised patients for differentiated thyroid cancers. Pharmacol Res 38(4):311–315.9774495
Koong S-S, Reynolds JC, Movius EG, . 1999. Lithium as a potential adjuvant to ^131^I therapy of metastatic, well differentiated thyroid carcinoma. J Clin Endocrinol Metab 84(3):912–916.10084570
Korolev GK. 1970. [Metabolism of iodine-131 in relation to the path of entry and the toxic action following entry into the respiratory system.] In: Raspredel kinet obmena biol diestvie radioactiv izotop ioda, 36–45. (Russian)
Korsager S, Kristensen HPO. 1979. Iodine-induced hypothyroidism and its effect on the severity of asthma. Acta Med Scand 205:115–117.760398
Kostial K, Kargacin B, Rabar I, . 1981. Simultaneous reduction of radioactive strontium, caesium and iodine retention by single treatment in rats. Sci Total Environ 22:1–10.7336198
Kostial K, Vnucec M, Tominac C, . 1980. A method for a simultaneous decrease of strontium, caesium and iodine retention after oral exposure in rats. Int J Radiat Biol 37(3):347–350.
*Kosugi S, Inoue S, Matsuda A, . 1998. Novel, missense and loss-of-function mutations in the sodium/iodide symporter gene causing iodide transport defect in three Japanese patients. J Clin Endocrinol Metab 83(9):3373–3376.9745458
*Kosugi S, Okamoto H, Tamada A, . 2002. A novel peculiar mutation in the sodium/iodide symporter gene in Spanish siblings with iodide transport defect. J Clin Endocrinol Metab 87(8):3830–3836.12161518
Kotajima A, Miyamoto Y, Tsuruo M, . 1995. Effects of activin A on deoxyribonucleic acid synthesis, iodine metabolism, and cyclic adenosine monophosphate accumulation in porcine thyroid cells. Endocrinology 136(3):1214–1218.7867575
Kotz D. 2000. Hanford: Study leaves questions about increased thyroid cancer rates unanswered. J Nucl Med 41(4):17N–18N, 21N, 25N.10647600
*Koutras DA. 1996. Control of efficiency and results, and adverse effects of excess iodine administration on thyroid function. Ann Endocrinol (Paris) 57:463–469.9084691
Koutras DA. 2000. Circulating iodide concentrations during and after pregnancy. J Clin Endocrinol Metab 85(3):1345.
Koyanagi T, Hirano S, Matsuba M. 1985. The transfer of radioiodine in different chemical forms through food chain. J Radiat Res 26(1):83.
Kraiem Z, Sadeh O, Blithe DL, . 1994. Human chorionic gonadotropin stimulates thyroid hormone secretion, iodide uptake, organification, and adenosine 3’,5’-monophosphate formation in cultured human thyrocytes. J Clin Endocrinol Metab 79(2):595–599.8045981
Kraiem Z, Sadeh O, Yosef M. 1991. Iodide uptake and organification, tri-iodothyronine secretion, cyclic AMP accumulation and cell proliferation in an optimized system of human thyroid follicles cultured in collagen gel suspended in serum-free medium. J Endocrinol 131:499–506.1664452
Krari N, Berre S, Allain P. 1992. Effects of thyroparathyroidectomy on the distribution of bromine and iodine in rat tissues. Biol Trace Elem Res 32:275–279.1375065
Krawiec L, Ryder E, Campos G. 1981. Excessive ingestions of iodide by the rat during pregnancy and lactation. Effects on ribonucleic acid transcription in the pups brain. Acta Physiol Latinoam 31:241–247.
Kreps EM, Kreps SM, Kreps SI. 1973. Treatment of hyperthyroidism with sodium iodide I 131: Carcinoma of the thyroid after 20 years. JAMA 226(7):774–775.4800630
Krisch RE, Sauri CJ. 1977. DNA breakage, repair, and lethality accompanying ^125^I decay in microorganisms. Curr Top Radiat Res Q 12:355–368.
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Krishnan U, Que Hee SS. 1992. Ear wax: A new biological monitoring medium for metals. Bull Environ Contam Toxicol 48:481–486.1504490
Krohn K, Paschke R. 2002. Somatic mutations in thyroid nodular disease. Molecular Genetics and Metabolism 75(3):202–208.11914031
*Krohn K, Wohlegemuth S, Gerber H, . 2000. Hot microscopic areas of iodine-deficient euthyroid goitres contain constitutively activating TSH receptor mutations. J Pathol 192(1):37–42.10951398
Krouse TB, Eskin BA, Mobini J. 1979. Age-related changes resembling fibrocystic disease in iodine-blocked rat breasts. Arch Pathol Lab Med 103:631–634.583121
*Krzesniak JA, Chomicki OA, Czerminksa M, . 1979. Airborne radioiodine contamination caused by ^131^I treatment. Nuklearmedizin 18(5):246–251.547252
Krzesniak JW. 1978. A laboratory for investigating and monitoring the contamination of air with radioactive iodine. Postepy Fiz Med 13(1):53–65.
Krzesniak JW, Porstendorfer J. 1978. Diffusion coefficients of airborne radioactive iodine and methyl iodide. Health Phys 35:417–421.701046
Krzesniak JW, Chomicki OA, Krajewski P, . 1983. Radiation hazards from inhaled airborne radioiodine in a nuclear medicine unit. In: Nuclear medicine and biology advances: Proceedings of the third World Congress of Nulcear Medicine and Biology, August 29 to September 2, 1982, Paris, France. Oxford, England: Pergamon Press, 2985–2988.
Krzesniak JW, Krajewski P, Emrich D, . 1986. Personnel inhalation hazard during “In-Vitro” and “In-Vivo” work with ^125^I and ^131^I [Abstract]. Nuklearmedizin 25(4):A74.
Krzesniak JW, Schuernbrand P, Porstenduerfer J, . 1984. Levels of airborne contamination while handling ^125^I and ^131^I and ^99m^Tc unsealed sources in medical diagnostic procedures. In: Radiat. Risk. Prot., Int. Congr., 6th., 833–836.
*Kubota Y, Koga T, Nakayama J. 2000. Iodine allergy induced by consumption of iodine-containing food. Contact Dermatitis 42(5):286–287.10789851
Kuleff I, Zotschev S, Stefanov G. 1986. Determination of the ^129^I content of the primary coolant nuclear power reactors. J Radioanal Nucl Chem 97(1):73–79.
Kumamoto T, Toyooka K, Nishida M, . 1990. Effect of 2,4-dihydro-3H-1,2,4-trizole-3-thiones and thiosemicarbazones on iodide uptake by the mouse thyroid: The relationship between their structure and anti-thyroid activity. Chem Pharm Bull 38(9):2595–2596.
Kung AWC, Yau CC, Cheng A. 1994. The incidence of ophthalmopathy after radioiodine therapy for Graves’ disease: Prognostic factors and the role of methimazole. J Clin Endocrinol Metab 79:542–546.7913934
Kung AW, Yau C-C, Cheng AC. 1995. The action of methimazole and L-thyroxine in radioiodine therapy: A prospective study on the incidence of hypothyroidism. Thyroid 5(1):7–12.7787438
Kunze J, Kaiser HJ, Petres J. 1983. [Relevance of a iodine-allergy to commercialized povidone-iodine-preparations.] Z Hautkr 58(4):255–261. (German)6845795
*Kurtz SC, Aber RC. 1982. Potassium iodide as a cause of prolonged fever. Arch Intern Med 142:1543–1544.7103636
*Kwok CS, Hilditch TE. 1982. Airborne iodine-125 arising from surface contamination. Phys Med Biol 27(1):149–151.7071135
Labbe E, Peyroux T. 1984. Mechanisms of adverse reactions to iodinated contrast material. Radiat Med 2(2):93–100.6084257
Labmann M, Hanscheid H, Schelper L-F, . 1998. [Measurement of incorporation in family members of patients with benign thyroid disease after radioiodine therapy.] Nuklearmedizin 37:120–123. (German)9604233
Lachapelle JM. 1984. Occupational allergic contact dermatitis to povidone-iodine. Contact Dermatitis 11(3):189–190.6238793
*Lacroix L, Mian C, Cailou B, . 2001. Na^+^/I^−^ symporter and Pendred syndrome gene and protein expressions in human extra-thyroidal tissues. Eur J Endocrinol 144(3):297–302.11248751
Ladenson PW. 1996a. Diagnosis of hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 878–882.
Ladenson PW. 1996b. Diagnosis of thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 708–712.
LaFranchi S, Mandel SH. 1996. Graves’ disease in the neonatal period and childhood. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 1000–1008.
Laing RW, Saunders MI. 1992. A case of lung carcinoma induced by radioactive iodine given for disseminated thyroid carcinoma. Clin Oncol 4:394–395.
*l’Allemand D, Gruters A, Beyers P, . 1987. Iodine in contrast agents and skin disinfectants is the major cause for hypothyroidism in premature infants during intensive care. Horm Res 28:42–49.3447940
*l’Allemand D, Gruters A, Heidemann P, . 1983. Iodine-induced alterations of thyroid function in newborn infants after prenatal and perinatal exposure to povidone iodine. J Pediatr 102(6):935–938.6854458
Lamberg-Allardt C, Valtonen E, Polojarvi M, . 1991. Characterization of 1,25-dihydroxy-vitamin D_3_ receptor in FRTL-5 cells. Evidence for an inhibitory effect of 1,25-dihydroxy-vitamin D_3_ on thyrotropin-induced iodide uptake. Mol Cell Endocrinol 81:25–31.1665829
*Lambert A, Lowe AG. 1978. Chloride/bicarbonate exchange in human erythrocytes. J Physiol 275:51–63.633149
Lambert JP. 1981. Report of a minor ^125^I exposure in a research laboratory. Health Phys 40:746–748.7263265
*Lambert V, Thierens H, Monsieurs M. 2001. Translocation frequencies measured in patients one year after radioactive iodine therapy for thyrotoxins. Int J Radiat Biol 77(6):679–685.11403707
*Landon S, Smith PG, Staniek SP, . 1980. Advantages of using thin sodium iodide detectors for thyroid monitoring of personnel working with ^125^I. Clin Chem 26(1):18–21.7356565
Lang JCT, Lees JFH, Alexander WD, . 1983a. Effect of variations in acute and chronic iodine intake on the accumulation and metabolism of [^35^S]methimazole by the rat thyroid gland: Differences from [^35^S]propylthiouracil. Biochem Pharmacol 32(2):241–247.6870954
Lang JCT, Lees JFH, Alexander WD, . 1983b. Effect of variations in acute and chronic iodine uptake on the accumulation and metabolism of [^34^S]propylthiouracil by the rat thyroid gland. Biochem Pharmacol 32(2):233–240.6870953
*Langer P, Moravec R, Ohradka B, Foldes O. 1988. Iodothyronines in human bile. Endocrinol Exp 22:35–39.3259503
Laroche D, Namour F, Lefrancois C, . 1999. Anaphylactoid and anaphylactic reactions to iodinated contrast material. Allergy 54:13–16.10735643
*Larsen PR, Berry MJ. 1994. Type I iodothyronine deiodinase: Unexpected complexities in a simple deiodination reaction. Thyroid 4(3):357–362.7833676
Larsen PR, Wolff J. 1967. Iodide transport: Inhibition by agents reacting at the membrane. Science 155:335–336.6016079
*Larsen PR, Davies TF, Hay ID. 1998. The thyroid gland. In: Wilson JD, Foster DW, Kronenberg HM, ., eds. Williams textbook of endocrinolgy. Philadelphia, PA: W.B. Saunders Company, 390–515.
*Lauber K. 1975. Iodine determination in biological material. Kinetic measurement of the catalytic activity of iodide. Anal Chem 47:769–771.1137153
Laurberg P, Bulow Pedersen I, Pedersen KM, . 1999. Low incidence of rate of overt hypothyroidism compared with hyperthyroidism in an area with moderately low iodine intake. Thyroid 9(1):33–38.10037074
Laurberg P, Bulow Pedersen I, Knudsen N, . 2001. Environmental iodine intake affects the type of nonmalignant thyroid disease. Thyroid 11(5):457–469.11396704
*Laurberg P, Pedersen KM, Hreidarsson A, . 1998. Iodine intake and the pattern of thyroid disorders: A comparative epidemiological study of thyroid abnormalities in the elderly in Iceland and in Jutland, Denmark. J Clin Endocrinol Metab 83(3):765–769.9506723
Laurent E, Mockel J, Takazawa K, . 1989. Stimulation of generation of inostiol phosphates by carbamoylcholine and its inhibition by phorbol esters and iodide in dog thyroid cells. Biochem J 263:795–801.2557011
Laurenti L, Salutari P, Sica S, . 1998. Acute myeloid leukemia after iodine-131 treatment for thyroid disorders. Ann Hematol 76:271–272.9692815
Laurie AJ, Lyon SG, Lasser EC. 1992. Contrast material iodides: Potential effects on radioactive iodine thyroid uptake. J Nucl Med 33:237–238.1732445
*Lauterbach A, Ober G. 1995. Iodine and iodine compounds. In: Kirk-Othmer encyclopedia of chemical technology. 4^th^ ed. Vol. 14. New York, NY: John Wiley and Sons, 709–737.
Lavelle KF, Doedens DJ, Kleit SA, . 1975. Toxicity of sodium iodide in the rabbit: Effects on hydrogen ion homeostasis, hepatic and renal functions. Toxicol Appl Pharmacol 33:52–61.240223
Laverock MJ, Stephenson M, Macdonald CR. 1995. Toxicity of iodine, iodide, and iodate to Daphnia magna and rainbow trout (Oncorhynchus mykiss). Arch Environ Contam Toxicol 29:344–350.
Lavu S, Reddy PP, Reddi OS. 1985a. Chromosomal abnormalities induced by iodine-125 in mouse germ cells. Int J Radiat Biol 48(4):603–607.
Lavu S, Reddy PP, Reddi OS. 1985b. Iodine-125 induced micronuclei and sperm head abnormalities in mice. Int J Radiat Biol 47(3):249–253.
*Law LW. 1938. The effects of chemicals on the lethal mutation rate in drosophilia melanogaster. Proc Natl Acad Sci U S A 24:546–550.16577855
*Lawes SC. 1992. ^123^I excretion in breast milk - additional data. Nucl Med Commun 13:570–572.1495684
*Lawrence JC. 1998. The use of iodine as an antiseptic agent. J Wound Care 7(8):421–425.9832752
Lawrence JE, Lamm SH, Braverman LE. 1999. The use of perchlorate for the prevention of thyrotoxicosis in patients given iodine rich contrast agents. J Endocrinol Invest 22:405–407.10401717
Lazarus JH. 1994. Thyroxine excess and pregnancy. Acta Med Austriaca 21:53–56.7527990
Lazarus JH. 1996. Silent thyroiditis and subacute thyroiditis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 577–591.
Lazarus JH. 1999. Thyroid hormone and intellectual development: A clinician’s view. Thyroid 9(7):659–660.10447010
Lazarus JH, Muston HL. 1978. The effect of lithium on the iodide concentrating mechanism in mouse salivary gland. Acta Pharmacol Toxicol (Copenh) 43:55–58.707124
Lazjuk GI, Nikolaev DI, Khmel RD. 2000. Epidemiology of congenital malformations in Belarus and Chernobyl accident. Am J Hum Genet 67:214.
Lecos C. 1983. Tracking trace minerals. FDA Consum 17:16–21.
Lee JY, Sawada S, Satow Y. 1990. Toxicity of iodic kalium to the rat embryos. J Radiat Res 31(1):79.
Lee JY, Shoju S, Satow Y. 1989. Developmental toxicity of potassium iodide in rats. Teratology 40(6):676–677.
Lee K, Bradley R, Dwyer J, . 1999. Too much versus too little: The implications of current iodine intake in the United States. Nutr Rev 57(6):177–181.10439630
Lee TC, Habert JC, Dejter SW, . 1985. Vocal cord paralysis following I-131 ablation of a postthyroidectomy remnant. J Nucl Med 26:49–50.3965651
Lee W-NP, Mpanias PD, Wimmer RJ, . 1978. Use of I-123 in early radioiodide uptake and its suppression in children and adolescents with hyperthyroidism. J Nucl Med 19:985–993.690722
Lee W, Chiacchierini RP, Shleien B, . 1981. Dose responses in thyroid tumor inductions from iodine-131 and localized thyroid and pituitary irradiations in rats. Radiat Res 87(2):452.
Lee W, Chiacchierini RP, Shleien B, . 1982. Thyroid tumors following ^131^I or localized X irradiation to the thyroid and pituitary glands in rats. Radiat Res 92:307–319.7163481
Lee W, Shleien B, Telles NC, . 1979. An accurate method of ^131^I dosimetry in the rat thyroid. Radiat Res 79:55–62.572980
*Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
*Leger AF, Massin JP, Laurent MF, . 1984. Iodine-induced thyrotoxicosis: Analysis of eighty-five consecutive cases. Eur J Clin Invest 14:449–455.6441722
*Leger FA, Doumith R, Courpotin C, . 1987. Complete iodide trapping defect in two cases with congenital hypothyroidism: Adaptation of thyroid to huge iodide supplementation. Eur J Clin Invest 17:249–255.3040420
Le Guen B, Malarbet JL, Roy M, . 1998. Methodology for ^129^I dose calculations, in the case of potential exposure from nuclear waste in France. Radiat Prot Dosim 79(1–4):211–214.
*Lehmann L, Zitzelsberger H, Kellerer AM. 1996. Chromosome translocations in thyroid tissues from Belarussian children exposed to radioiodine from the Chernobyl accident, measured by FISH-painting. Int J Radiat Biol 70(5):513–516.8947531
*LeMar HJ, Georgotis WJ, McDermott MT. 1995. Thyroid adaptation to chronic tetraglycine hydroperiodide water purification tablet use. J Clin Endocrinol Metab 80:220–223.7829615
Lengemann FW. 1966. Reduction of iodine transfer to milk of cows after perchlorate ingestion. J Dairy Sci 56:753–756.
Lengemann FW. 1979. Effects of low and high ambient temperatures on metabolism of radioiodine by the lactating goat. J Dairy Sci 62:412–415.447891
*Lengemann FW, Comar CL. 1964. Metabolism of ^131^I by dairy cows during long term daily administration of the radioscope. Health Phys 10:55–59.14118811
*Lengemann FW, Wentworth RA. 1979. Extremes of environmental temperature and the transfer of radioiodide into milk. Health Phys 36:267–271.573754
*Leonard JL, Koehrle J. 1996. Intracellular pathways of iodothyronine metabolism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 125–161.
Lequesne M. 1967. [Alsodystrophy of chemotherapeutic origin. Pseudorheumatism due to isoniazid, ethionamide, phenobarbital and radioactive iodine.] Sem Hop 43(42):2581–2595. (French)4168672
*Lessard ET, Miltenberger RP, Conard RA, . 1985. Thyroid absorbed dose for people at Rongelap Uterik and Sifo on March 1, 1954. Brookhaven National Library. BNL 51882.
Leszynsky HE, Gross-Kielselstein EG, Abrahamov A. 1971. Hyperthyroidism in a 3-month-old baby. Pediatrics 47:1069–1083.4258884
*Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Leung PMK, Nikolic M. 1998. Disposal of therapeutic ^131^I waste using a multiple holding tank system. Health Phys 75(3):315–321.9721842
LeValley MJ. 1982. Acute toxicity of iodine to channel catfish (Ictalurus punctatus). Bull Environ Contam Toxicol 29:7–11.7115997
Levenson D, Gulec S, Sonenberg M, . 1994. Peripheral facial nerve palsy after high-dose radioiodine therapy in patients with papillary thyroid carcinoma. Ann Intern Med 120(7):576–578.8116996
*Levy O, Dai G, Riedel C, . 1997. Characterization of the thyroid Na^+^/I^−^ symporter with an anti-COOH terminus antibody. Proc Natl Acad Sci U S A 94:5568–5573.9159113
*Levy O, De la Vieja A, Carrasco N. 1998a. The Na^+^/I^−^ symporter (NIS): Recent advances. J Bioenerg Biomembr 30(2):195–206.9672241
Levy O, De la Vieja A, Ginter CS, . 1998b. N-linked glycosylation of the thyroid Na^+^/I^−^ symporter (NIS). J Biol Chem 273(35):22657–22663.9712895
*Levy O, Ginter CS, De la Viega A, . 1998c. Identification of a structural requirement for thyroid Na^+^/I^−^ symporter (NIS) function from analysis of a mutation that causes human congenital hypothyroidism. FEBS Lett 429:36–40.9657379
Lewitus Z. 1983. Thyroid carcinoma in Israel. Acta Endocrinol Suppl 252:15.
Lewitus Z, Lubin E, Rechnic J, . 1971. The problem of iodine-125 for treatment of thyrotoxicosis. Hormones 2:115–128.5006654
*Li M, Boyages SC. 1994. Iodide induced lymphocytic thyroiditis in the BB/W rat: Evidence of direct toxic effects of iodide on thyroid subcellular structure. Autoimmunity 18:31–40.7999954
Li M, Eastman CJ, Boyages SC. 1993. Iodine induced lymphocytic thyroiditis in the BB/W rat: Early and late imuune phenomena. Autoimmunity 14:181–187.8329556
*Li W, Qu C, Jia G, . 1987. Endemic goitre in Central China caused by excessive iodine intake. Lancet, August 1:257–258.
Li W, Xiong JQ, Cohen BS. 1998. The deposition of unattached radon progeny in a tracheobronchial cast as measured with iodine vapor. Aerosol Sci Technol 28:502–510.
*Libert F, Lefort A, Gerard C, . 1989. Cloning, sequencing and expression of the human thyrotropin (TSH) receptor: Evidence for binding of autoantibodies. Biochem Biophys Res Commun 165(3):1250–1255.2610690
*Libert F, Ruel J, Ludgate M . 1987. Complete nucleotide sequence pf the human thyroperoxidase-microsomal antigen cDNA. Nucleic Acids Res 15:6735.3453124
*Lide DR, ed. 2000. CRC handbook of chemistry and physics. 81^st^ ed. Boca Raton, FL: CRC Press.
*Liesenkötter KP, Gopel W, Bogner U, . 1996. Earliest prevention of endemic goiter by iodine supplementation during pregnancy. Eur J Endocrinol 134:443–448.8640295
Lightner ES, Fismer DA, Giles H, . 1977. Intra-amniotic injection of thyroxine (T4) to a human fetus: Evidence for conversion o fT4 to reverse T3. Am J Obstet Gynecol 127:487–490.836646
Lightowler HJ, Davies GJ, Trevan MD. 1996. Iodine in the diet: Perspectives for vegans. J R Soc Health 116:14–20.8683536
Likhtarev IA, Gulko GM, Kairo IA, . 1994. Thyroid doses resulting from the Ukraine Chernobyl accident-Part I: Dose estimates for the population of Kiev. Health Phys 66(2):137–146.8282553
Likhtarev IA, Kairo I, Tronko ND, . 1998. Thyroid cancer risk to children calculated. Nature 392:31–32.9510245
*Likhtarev IA, Shandala NK, Gulko GM, . 1993. Ukranian thyroid doses after the Chernobyl accident. Health Phys 64(6):594–599.8491614
*Likhtarev IA, Sobolev BG, Kairo IA, . 1995. Thyroid cancer in the Ukraine. Nature 375:365.7760928
Lim C-F, Bernard BF, de Jong M, . 1993. A furan fatty acid and indoxyl sulfate are the putative inhibitors of thyroxine hepatocyte transport in uremia. J Clin Endocrinol Metab 76(2):318–324.8432774
Lima FRS, Gervais A, Colin C, . 2001. Regulation of microglial development: A novel role for thyroid hormone. J Neurosci 21(6):2028–2038.11245686
*Lin JD, Wang HS, Weng HF, . 1998. Outcome of pregnancy after radioactive iodine treatment for well differentiated thyroid carcinomas. J Endocrinol Invest 21:662–667.9854681
Lin TJ, Tanaka Y, Aznar R, . 1973. Contraceptive effect of intrauterine application of Lugol’s solution. Am J Obstet Gynecol 116(2):167–174.4634105
Lin W-Y, Shen Y-Y, Wang S-J. 1996. Short-term hazards of low-dose radioiodine ablation therapy in postsurgical thyroid cancer patients. Clin Nucl Med 21(10):780–782.8896926
*Lind P, Langsteger W, Molnar M, . 1998. Epidemiology of thyroid diseases in iodine sufficiency. Thyroid 8(12):1179–1183.9920375
Linder N, Davidovitch N, Reichman B, . 1997a. Topical iodine-containing antiseptics and subclinical hypothyroidism in preterm infants. J Pediatr 131:434–439.9329422
Linder N, Sela B, German B, . 1997b. Iodine and hypothyroidism in neonates with congenital heart disease. Arch Dis Child 77:F239–F240.
Lindsay S, Nichols CWJ, Chaikoff IL. 1968. Carcinogenic effect of irradiation: Low doses of radioactive iodine on the thyroid gland of the rat and mouse. Arch Pathol 85:487–492.5650785
Lindsay S, Potter GD, Chaikoff IL. 1963. Radioiodine-induced thyroid carcinomas in female rats. Arch Pathol 75:20–24.
*Lindstrom RM, Lutz GJ, Norman BR. 1991. High-sensitivity determination of iodine isotopic ratios by thermal and fast neutron activation. J Trace Microprobe Tech 9(1):21–32.
Ling CC, Li WX, Anderson LL. 1995. The relative biological effectiveness of I-125 and Pd-103. Int J Radiat Oncol Biol Phys 32(2):373–378.7751179
Links JM. 1996. Radiation physics. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 330–341.
Linsley GS. 1977. Criteria for safe working with iodine-125. Radiography 43(508):91–93.860017
Lione A. 1988. Nonprescription drugs as a source of aluminum, bismuth, and iodine during pregnancy. Reprod Toxicol 1:243–252.
*Lipsztein JL, Bertilli L, Melo DR, . 1991. Application of in-vitro bioassy for 137Cs during the emergency phase of the Goiania accident. Health Physics 60:43–49.1983980
Little JR, Murray PR, Traynor PS, . 1999. A randomized trial of povidone-iodine compared with iodine tincture for venipuncture site disinfection: Effects on rats of blood culture contamination. Am J Med 107:119–125.10460041
Liu J, Liu Y, Barter RA, . 1995. Alteration of thyroid homeostasis by UDP-glucuronosyltransferase inducers in rats: A dose-response study. J Pharmacol Exp Ther 273:977–985.7752103
*Liu K, Edwards FM. 1979. Radiation exposure to medical personnel during iodine-125 seed implantation of the prostate. Radiology 132:748–749.472263
Liu Z, Fu C, Li C, . 1982. ^131^I and ^132^I carcinogenic effects in rat thyroid glands. Chin Med J 95(9):641–648.6817987
Liu Z, Fu C, Li Z, . 1986. Study on late effects of radioiodine on rats. Sci Sin [B] XXIX(10):1039–1053.
Liu Z, Fu C, Li Z, . 1987. Carcinogenic effects of ^131^I, ^132^I and ^125^I on rat thyroids. Chin Med J 100(2):92–96.3109848
*Livadas DP, Koutras DA, Souvatzoglou A, . 1977. The toxic effects of small iodine supplements in patients with autonomous thyroid nodules. Clin Endocrinol 7:121–127.
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
LiVolsi VA. 1996. Pathology. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 497–520.
LiVolsi VA. 1997. Pathology of thyroid disease. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 65–104.
Lloyd DC, Purrott RJ, Dolphin GW, . 1976. A comparison of physical and cytogenetic estimates of radiation dose in patients treated with iodine-131 for thyroid carcinoma. Int J Radiat Biol 30(5):473–485.
Lloyd RD, Tripp DA, Kerber RA. 1996. Limits of fetal thyroid risk from radioiodine exposure. Health Phys 70(4):559–562.8617598
Lloyd WE. 1982. Toxicology of ethylenediamine dihydriodide [Letter]. J Am Vet Med Assoc 180(5):476,478.
Lo MT, Hill DC. 1971. Effect of dietary rapeseed meal on the serum proteins of rats. Can J Physiol Pharmacol 49:1100–1105.5142315
Loeb JN. 1996a. Metabolic changes in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 858–862.
Loeb JN. 1996b. Metabolic changes in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 687–693.
Long Y, France J-L, Giraud A. 1990. Inhibition of N-glycan processing affects iodide organification in porcine thyroid cells. Mol Cell Endocrinol 73:217–224.2148533
*Longcope C. 2000a. The male and female reproductive systems in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ Philadelphia, PA: Lippincott-Raven, 824–827.
*Longcope C. 2000b. The male and female reproductive systems in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ Philadelphia, PA: Lippincott-Raven, 653–658.
*Lopez Saez MP, de Barrio M, Zubeldia JM, . 1998. Acute IgE-mediated generalized urticaria-angioedema after topical application of povidone-iodine. Allergol Immunopathol (Madr) 26(1):23–26.9585824
LoPresti JS, Singer PA. 1997. Physiology of thyroid hormone synthesis, secretion, and transport. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 29–40.
Loran M, Kleinmann K. 1975. Semiquantitative test of iodine vapor above complexed iodine solutions. Am J Hosp Pharm 32:431–432.1130417
Lowdell CP, Dobbs HJ, Spathis GS, . 1985. Low-dose ^131^I in treatment of Graves’ disease. J R Soc Med 78:197–202.3838347
*Luckett LW, Stotler RE. 1980. Radioiodine volatilization from reformulated sodium iodide I-131 oral solution. J Nucl Med 21:477–479.7373420
Lueprasitsakul W, Abend S, Alex S, . 1990. Effect of thalidomide on the incidence of iodine-induced and spontaneous lymphocytic thyroiditis and spontaneous diabetes mellitus in the BB/Wor rat. Acta Endocrinol 123:79–83.
Lundell G, Holm L-E. 1980. Hypothyroidism following ^131^I therapy for hyperthyroidism in relation to immunologic parameters. Acta Radiol Oncol 19:449–454.6263058
Lundell G, Jonsson J. 1973. Thyroid antibodies and hypothyroidism in ^131^I therapy for hyperthyroidism. Acta Radiol Ther Phys Biol 12(5):443–453.4777976
Lundell G, Holm L-E, Ljunggren J-G, . 1981. Incidence of hypothyroidism after ^131^I therapy for hyperthyroidism. Acta Radiol Oncol 20(4):225–230.6277151
Lupulescu A, Petrovici A. 1964. The fine structure of thyroid tumours induced by low iodine diet in rats. Acta Anat 57:294–305.14197614
Lupulescu A, Stebner F. 1974. Effect of synthetic salmon calcitonin in iodine metabolism in rabbits. Proc Soc Exp Biol Med 146:56–58.4207995
Luther GW, Swartz CB, Ullman WJ. 1988. Direct determination of iodide in seawater by cathodic stripping square wave volammetry. Anal Chem 60:1721–1724.
*Lutz GJ, Rook HL, Lindstrom RM. 1984. Determination of I-129 at natural levels by thermal neutron activation analysis. J Trace Microprobe Tech 2(1):33–51.
Lybeck H, Leppaluoto J, Virkkunen P, . 1973. Suppression of TRH-mediated thyroidal release of ^131^I by a synthetic analog. Neuroendocrinology 12:366–370.4202483
Maas LC, Gelzayd EA. 1978. Endoscopic removal of an ulcerated appendiceal stump. JAMA 240(3):248–249.660853
Maayan ML. 1977. TSH and catecholamines: Independent effects on active transport and iodine organification in isolated thyroid cells. Acta Endocrinol 86:763–767.
Maayan ML, Ingbar SH. 1968. Epinephrine: Effect on uptake of iodine by dispersed cells of calf thyroid gland. Science 162:124–125.4300044
Maayan ML, Miller SL, Ingbar SH. 1971. Effects of serotonin on iodide and intermediary metabolism in isolated thyroid cells. Endocrinology 88:620–626.4322382
Maayan ML, Shapiro R, Ingbar SH. 1973. Epinephrine precursors: Effects on the iodine and intermediary metabolism of isolated calf thyroid cells. Endocrinology 92:912–916.4701491
Maayan ML, Volpert EM, From A. 1981. Norepinephrine and thyrotropin effects on the thyroid in vitro: Simultaneous stimulation of iodide organification and antagonism of thyroxine release. Endocrinology 109:930–934.6167436
Macaron C. 1996. An epidemic of hyperthyroidism following salt iodination in Lebanon. J Med Liban 44(4):200–202.9248231
*Machta L. 1963. Metereological processes in the transport of weapon radionuclides. Health Physics 9:43.
Madaoui S, Rappaport L, Nunez J. 1974. Prostaglandins and in vitro TSH-dependent iodide binding by rat thyroid glands. Biochimie 56:109–113.4136209
Maekoshi H, Orito T, Nishizawa K, . 1979. [Measurement of 131I concentration in saliva of a patient and monitoring of exposure and contamination in a ward.] Radioisotopes 28(3):180–183. (Chinese)554180
*Magnusson RP, Chazenbalk GD, Gestautas J . 1987. Molecular cloning of the complementary deoxyribonucleic acid from human thyroid peroxidase. Mol Endocrinol 1:856.3153466
Mahillon I, Peers W, Bourdoux P, . 1989. Effect of vaginal douching with povidone-iodine during early pregnancy on the iodine supply to mother and fetus. Biol Neonate 56:210–217.2804185
Mahn DC, Vallet JL. 1997. Vitamin and mineral transfer during fetal development and the early postnatal period in pigs. J Anim Sci 75:2731–2738.9331877
Maienchenko AF, Seregin VV, Kuz’mina TS. 1976. [Effect of uranium on the metabolism of radioactive and stable iodine in the thyroid gland.]. Dokl Akad Nauk SSSR 20(4):373–376.
Maier H, Bihl H. 1987. Effect of radioactive iodine therapy on parotid gland function. Acta Otolaryngol (Stockh) 103:318–324.
Maillie HD. 1986. Should the annual limit on intake for ^125^I and ^131^I be lowered? [Letter]. Health Phys 50(3):425.3949538
Makhon’ko KP, Kim VM. 1997. Calculation of the dose load to the thyroid gland from consumption of milk after the Chernobyl accident. At Energ (English) 83(1):534–537. Translation from Atomnaya Energiya, 83(1):57-60.
Malarbet JL, Aurengo A, Roy M, . 1998. [Dose coefficients from incorporated iodine-129. Influence of dietary intake.] Radioprotection 33(1):15–33. (French)
Malcolm RL. 1989. The relative importance of pH, charge, and water solubility on the movement of organic solutes in soils and ground water. Ecol Stud 73:288–301.
Malinauskas AP, Bell JT. 1987. The chemistry of fission-product iodine under nuclear reactor accident conditions. Nuclear Safety 28(4):505–514.
Malone JF. 1993. Consequences of iodine fall out: Dosimetric and radiobiological considerations. In: Delange F , ed. Iodine deficiency in Europe. New York, NY: Plenum Press, 229–235.
Malone JF, Cullen MJ. 1976. Two mechanisms for hypothyroidism after ^131^I therapy. Lancet 2(7976):73–75.59154
Malone JF, Cullen MJ. 1977. Hypothyroidism after ^125^I therapy [Letter]. Ann Intern Med 86(6):823.577385
Maloof F, Dobyns BM, Vickery AL. 1952. The effect of various doses of radioactive iodine on the function and structure of the thyroid of the rat. Endocrinology 50(6):612–638.12980071
Malpani BL, Samuel AM, Jasiwar RK. 1998. Salivary gland scintigraphy after radioiodine therapy. Nucl Med Commun 19:183–184.9548203
*Mandel SJ, Mandel L. 1999. Persistent sialadenitis after radioactive iodine therapy: Report of two cases. J Oral Maxillofac Surg 57:738–741.10368102
*Mandel SJ, Mandel L. 2003. Radioactive iodine and the salivary glands. Thyroid 13:265–271.12729475
Mandell RB, Mandell LZ, Link CJJ. 1999. Radioisotope concentrator gene therapy using the sodium/iodide symporter gene. Cancer Res 59:661–668.9973215
Mandell R, McCann L, Link CJ. 1997. Gene therapy of cancer by retroviral transfer and expression of the rat sodium/iodide symporter (NIS) [Abstract]. Proc Am Assoc Cancer Res 38:381.
*Mand PA, Poggi G. 1988. In vivo measurements of ^131^I build-up in human thyroids after the Chernobyl reactor accident. Health Phys 54(2):207–209.3338920
Mangkoewidjojo S. 1979. I. Pathologic effects of polybrominated biphenyls in rats fed a diet containing excessive iodine. II. Pathologic changes in calves after oral administration of excessive iodine for six months. Ph.D. Dissertation, Michigan State University, p. 193.
Mangkoewidjojo S, Sleight SD, Convey EM. 1980. Pathologic features of iodide toxicosis in calves. Am J Vet Res 41(7):1057–1061.7436098
Manley SW, Bourke JR, Huxham GJ. 1987. Ionic mechanisms regulating thyroidal secretion: Effects of ouabain and medium sodium concentration on radioiodine release from cultured porcine thyroid cells. J Endocrinol 112:399–405.3559450
Manley SW, Huxham GJ, Bourke JR. 1986. Role of sodium influx in thyrotrophin action: Effects of the sodium channel agonist veratridine and thyrotropin on radioiodine turnover and membrane potential in cultured porcine thyroid cells. J Endocrinol 110:459–466.2428893
Mano MT, Potter BJ, Belling GB, . 1989. The effect of thyroxine, 3,5-dimethyl-3’-isopropyl-L-thyronine and iodized oil on fetal brain development in the iodine-deficient sheep. Acta Endocrinol 121:7–15.
Manso PG, Fulanetto RP, Wolosker AMB, . 1998. Prospective and controlled study of ophthalmopathy after radioiodine therapy for Graves’ hyperthyroidism. Thyroid 8(1):49–52.9492153
Many MC, Denef JF. 1992. Iodine and goiter involution. Thyroidology 4:23–26.1284328
Many M-C, Denef JS, Hamudi S, . 1986. Effects of iodide and thyroxine on iodine-deficient mouse thyroid: A morphological and functional study. J Endocrinol 110:203–210.3746158
Many M-C, Denef J-F, Haumont S, . 1985. Morphological and functional changes during thyroid hyperplasia and involution in C3H mice: Effects of iodine and 3,5,3’-triiodothyronine during involution. Endocrinology 116:798–806.3967628
Many M-C, Maniratunga S, Varis I, . 1995. Two-step development of Hashimoto-like thyroiditis in genetically autoimmune prone non-obese diabetic mice: effects of iodine-induced cell necrosis. J Endocrinol 147:311–320.7490561
Many M-C, Papadopoulos J, Martin C, . 1991. Iodine induced cell damage in mouse hyperplastic thyroid is associated to lipid peroxidation. In: Gordon A, Gross J, Hennemann G, eds. Progress in thyroid research. Rotterdam, The Netherlands: Balkema, 635–638.
Manz F, van’t Hof MA, Haschke F, . 2000. Iodine supply in children from different European areas: The Euro-growth study. J Pediatr Gastroenterol Nutr 31:S72–S75.10896091
*Mao IF, Chen ML, Ko YC. 2001. Electrolyte loss in sweat and iodine deficiency in a hot environment. Arch Environ Health 56(3):271–277.11480505
*Marcocci C, Chiovato L. 2000a. The epidemiology of thyroid diseases. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 474–482.
*Marcocci C, Chiovato L. 2000b. Thyroid-directed antibodies. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 414–431.
Marcocci C, Cohen JL, Grollman EF. 1984. Effect of actinomycin D on iodide transport in FRTL-5 thyroid cells. Endocrinology 115:2123–2132.6499763
Marcocci C, Luini A, Santisteban P, . 1987. Norepinephrine and thyrotropin stimulation of iodide efflux in FRTL-5 thyroid cells involves metabolits of arachidonic acid and is associated with the iodination of thyroglobulin. Endocrinology 120:1127–1133.3100285
Margulies K, Schirger J, Burnett JJ. 1991. Radiocontrast-induced nephropathy: Current status and future prospects. Int Angiol 11:20–25.
Marine D, Feiss HO. 1915. The absorption of potassium iodide by perfused thyroid glands and some of the factors modifying it. J Pharmacol Exp Ther 7:557–576.
Mariotti S, Martino E, Francesconi M, . 1986. Serum thyroid autoantibodies as a risk factor for development of hypoparathyroidism after radioactive iodine therapy for single thyroid ‘hot’ nodule. Acta Endocrinol 113:500–507.
*Markou K, Georgopopoulos, Kyriazopoulou V, . 2001. Iodine-indiced hypothyroidism. Thyroid 11(5): 501–510.11396709
*Maros L, Káldy M, Igaz S. 1989. Simultaneous determination of bromide and iodide as acetone derivatives by gas chromatography and electron capture detection in natural waters and biological fluids. Anal Chem 61:733–735.2719269
*MARSSIM. 1997. Multi-agency radiation survey and site investigation manual. Nuclear Regulatory Commission, Energy Department, Environmental Protection Agency, and Defense Department. 660p. NUREG 1575, EPA 402 R 97 016.
*Marter WL. 1993. Savannah River site radioiodine atmospheric releases and offsite maximum doses (U). Westinghouse Savannah River Company, Savannah River Laboratory, SRL-ETS-900317 (NTIS/DE93004259), pp. 1–35.
Martin ES, Godley PJ. 1993. Letter to the editor. N Engl J Med 328(5):355–356.
Martin JE, Fenner FD. 1997. Radioactivity in municipal sewage and sludge. Public Health Reports 112:308–316.9258296
Martin MM, Matus RN. 1966. Neonatal exophthalmos with maternal thyrotoxicosis. Am J Dis Child 111:545–547.
*Martin MM, Rento RD. 1962. Iodide goiter with hypothyroidism in 2 newborn infants. J Pediatr 61:94–99.14470425
Martin RF, Haseltine WA. 1981. Range of radiochemical damage to DNA with decay of iodine-125. Science 213:896–898.7256283
*Martin WE, Turner FB. 1964. Project Sedan. Food-chain relationships of iodine-131 in Nevada following the Sedan test of July 1962. NTIS AD-A076 363/1 (AEC-PNE-236F), 5–58.
Martinez-Galan JR, Pedraza P, Santacana M, . 1997. Early iodine deficiency on radial glial cells of the hippocampus of the rat fetus. J Clin Invest 99:2701–2709.9169500
Martino E, Bartalena L, Faglia G, . 1996. Central hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 779–791.
Martino E, Bartalena L, Mariotti S, . 1988. Radioactive iodine thyroid uptake in patients with amiodarone-iodine-induced thyroid dysfunction. Acta Endocrinol 119:167–173.
Martins MC, Lima N, Knobel M, . 1989. Natural course of iodine-induced thyrotoxicosis (jodbasedow) in endemic goiter area: A 5 year follow-up. J Endocrinol Invest 12:239–244.2745935
Martmer EE, Corrigan KE, Charbeneau HP, . 1956. A study of the uptake of iodine (I-131) by the thyroid of premature infants. Pediatrics 17:503–509.13310083
Maruyama H, Yamamoto I. 1992. Suppression of ^125^I-uptake in mouse thyroid by seaweed feeding: Possible preventative effect of dietary seaweed on internal radiation injury of the thyroid by radioactive iodine. Kitasato Arch Exp Med 65(4):206–216.
Mashita K, Kawamura S, Kishino B, . 1982. Effects of iodide and propyltiouracil on the release of 3,5,3’-triiodothyronine and of cyclic adenosine 3’,5’-monophosphate from perifused rat thyroids. Endocrinology 110:1023–1029.6173207
Masri MT, Menne M, Rooney BL, . 1995. A simplified method for treating Graves’ disease with radioactive ^131^I. Wis Med J 94(1):21–25.7871797
Mathieu I, Caussin J, Smeesters P, . 1997. Doses in family members after ^131^I treatment. Lancet 350(9084):1074–1075.
Matovinovic J, Nishiyama RH, Hill HC, . 1969. The role of sex and iodine deficiency in the growth and function of the rat thyroid transplantable tumor. Cancer Res 29:1398–1406.5799158
Matsumoto T, Itoh H, Akiba Y. 1969. Effect of (-)-5-vinyl-2-oxazolidinethione on the radioiodine metabolism in growing chicks. Poult Sci 48(3):1061–1069.
Matsunaga E, Shiota K. 1980. Search for maternal factors associated with malformed human embryos: A prospective study. Teratology 21:323–331.7455921
*Maxon HR, Saenger EL. 1996. Biologic effects of radioiodines on the human thyroid gland. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 342–351.
*Maxon HR, Saenger EL. 2000. Biologic effects of radioiodines on the human thyroid gland. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 345–354.
Maxon HR, Saenger EL, Thomas SR, . 1980. Clinically important radiation-associated thyroid disease: A controlled study. JAMA 244(16):1802–1805.7420680
Maxon HR, Thomas SR, Hertzberg VS, . 1983. Relation between effective radiation dose and outcome of radioiodine therapy for thyroid cancer. N Engl J Med 309(16):937–941.6621620
Maxon HR, Thomas SR, Saenger EL, . 1977. Ionizing irradiation and the induction of clinically significant disease in the human thyroid gland. Am J Med 63:967–978.343589
Maxon R, Thomas SR, Maxon H. 1987. Effect of gut retention on the effective body half-time of iodine-131 in thyroid cancer patients. J Nucl Med Technol 15:13–15.
May W, Wu D, Eastman C, . 1990. Evaluation of automated urinary iodine methods: Problems of interfering substances identified. Clin Chem 36:865–869.2357823
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Mazzaferri E. 1996a. Radioiodine and other treatments and outcomes. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 937–938.
Mazzaferri EL. 1996b. Radioiodine and other treatments and outcomes. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 922–945.
*Mazzaferri EL, Jhiang SM. 1994. Long-term impact of initial surgical and medical therapy on papillary and follicular thyroid cancer. Am J Med 97:418.7977430
Mazzaferri Z. 1996. Radioiodine and other treatments and outcomes. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid. Philadelphia, PA: Lippincott Raven, 937–939.
McAlexander RA, Stevenson JK, Olch PD, . 1962. Accelerated mammary tumor development in C3H mice fed an iodine-deficient diet. Surg Forum 13:105–106.
McBride JA. 1964. Acute leukaemia after treatment for hyperthyroidism with radioactive iodine. Br Med J 2:736.14172040
McCarthy JS, Fregly MJ, Nechay BR. 1967. Effect of diuretics on renal iodide excretion by rats and dogs. J Pharmacol Exp Ther 158(2):294–304.6065152
McCauley EH, Linn JG, Goodrich RD. 1973. Experimentally induced iodide toxicosis in lambs. Am J Vet Res 34(1):65–70.4683976
McClain RM. 1989. The significance of hepatic microsomal enzyme induction and altered thyroid function in rats: Implications for thyroid gland neoplasia. Toxicol Pathol 17(2):294–306.2675280
McClain RM. 1992. Thyroid gland neoplasia: Non-genotoxic mechanisms. Toxicol Lett 64/65:397–408.
McClain RM, Rice JM. 1999. A mechanistic relationship between thyroid follicular cell tumours and hepatocellular neoplasms in rodents. In: Capen CC, Dybing E, Rice JM, ., eds. Species differences in thyroid, kidney and urinary bladder carcinogenesis. Lyon, France: International Agency for Research on Cancer, 61–68.
*McClellan RO, Rupprecht FC, eds. 1968. Radioiodine metabolism in the beagle dog - the importance of age and mode of ^131^I exposure. Fission product inhalation program annual report 1967-1968. Albuquerque, NM: Lovelace Foundation for Medical Education and Research, 122–127.
McClintock JT. 1974. Thyroid cancer after radioactive iodine therapy [Letter]. JAMA 228(3):290.
McComb DE, Whittum JA. 1973. Chick-embryo deaths traced to tincture of iodine. J Infect Dis 127(5):581.4698645
McCruden DC, Hilditch TE, Connell JMC, . 1985. Kinetics of [123I]iodide uptake and discharge by perchlorate in studies of inhibition of iodide binding by antithyroid drugs. Acta Endocrinol 110:499–504.
McCullagh FP, Jelden GL, Rodriguez-Antunez A. 1976. Incidence of hypothyroidism following small doses of ^131^I in the treatment of Graves’ disease. Ohio State Med J 72(9):538–540.989600
McDermott MT. 1997. Oncogenes and thyroid cancer. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippinocott-Raven Publishers, 231–239.
McDermott MT, Kidd GS, Dodson LE, . 1983. Radioiodine-induced thyroid storm. Am J Med 75:353–359.6349350
McDougall IR. 1974. Thyroid cancer after iodine-131 therapy [Letter]. JAMA 227(4):438.
McDougall IR. 1977. In comment: [Letter]. Ann Intern Med 86(6):823–824.577385
McDougall IR. 1993. Does radioiodine cause the ophthalmopathy of Graves’ disease? Nucl Med Commun 14:79–81.8429998
McDougall IR. 1997. 74 MBq radioiodine ^131^I does not prevent uptake of therapeutic doses of ^131^I (i.e. it does not cause stunning) in differentiated thyroid cancer. Nucl Med Commun 18:505–512.9259520
McDougall IR. 1999. Cancer deaths after ^131^I therapy for thyrotoxicosis. Nucl Med Commun 20:407–409.10404524
*McDougall IR, Cavalieri RR. 2000. In vivo radionuclide tests and imaging. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 355–375.
McDougall IR, Greig WR. 1976. ^125^I therapy in Graves’ disease: Long-term results in 355 patients. Ann Intern Med 85:720–723.1036667
McDougall IR, Greig WR, Gillespie FC. 1971a. Persistence of ^125^I in thyroid. N Engl J Med 286(3):161. See also 79280; Van Middlesworth.
McDougall IR, Kennedy JS, Thomson JA. 1971b. Thyroid carcinoma following iodine-131 therapy. Report of a case and review of the literature. J Clin Endocrinol 33:287–292.
McDougall IR, Nelsen TS, Kempson RL. 1981. Papillary carcinoma of the thyroid seven years after I-131 therapy for Graves’ disease. Clin Nucl Med 6(8):368–371.6894894
McFarlane IA, Shalet SM, Beardwell CG, . 1979. Transient hypothyroidism after iodine-131 treatment for thyrotoxicosis. Br Med J 2:421.
McGavack TH, Seegers W. 1959. Status of the thyroid gland after age 50. Metabolism 8:136–150.13632396
McGhee D, John S, Williams JB. 1998. Expression of the sodium-dependent iodide symporter in rat organs and identification of a potential isoform generated by alternative mRNA splicing. In: The Endocrine Society-annual meeting, program and abstracts. Bethesda, MD: Endocrine Society.
McGuire RA, Berman M. 1978. Maternal, fetal, and amniotic fluid transport of thyroxine, triiodothyronine, and iodide in sheep: A kinetic model. Endocrinology 103(2):567–576.744102
McKenzie JM, Zakarija M. 1996. Antibodies in autoimmune thyroid disease. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 416–432.
McKillop JH, Doig JA, Kennedy JS, . 1978. Laryngeal malignancy following iodine-125 therapy for thyrotoxicosis. Lancet 2(8101):1177–1179.82143
*McLachlan SM, Rapaport B. 1992. The molecular biology of thyroid peroxidase: Cloning, expression and role as an autoantigen in autoimmune thyroid disease. Endocr Rev 13:192–206.1618162
*McLachlan SM, Rapoport B. 1996. Genetic factors in thyroid disease. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 483–496.
McMonigal KA, Braverman LE, Dunn JT, . 2000. Thyroid function changes related to use of iodinated water in the U.S. Space Program. Aviat Space Environ Med 71(11):1120–1125.11086666
Meck RA, Chen MS, Kenny PJ. 1985. Criteria for the administration of KI for thyroid blocking of radioiodine. Health Phys 48(2):141–157.3882630
Medeiros-Neto GA. 1971. Respiration and iodine transport by thyroid slices as influenced by ouabain, succinate, alpha-ketoglutarate, sodium and potassium. Acta Physiol Latinoam 21:126–136.
Medeiros-Neto G. 1994. Letter to the Editor. Clin Endocrinol 40:435.
Medeiros-Neto GA, Billerbeck AE, Wajchenberg BL, . 1993. Defective organification of iodide causing hereditary goitrous hypothyroidism. Thyroid 3(2):143–159.8369653
Medeiros-Neto GA, Hollander CS, Knobel M, . 1978. Effects of iodides on the hypothalamic-pituitary-thyroid axis in neurological endemic cretinism: Evidence for compensated thyroidal failure in adult life. Clin Endocrinol 8:213–218.
*Mehta RD, von Borstel RC. 1982a. Effect of growth phase and different solvents on the genetic activity and cell toxicity of diethylstilbesterol in Saccharomyces cerevisiae. Environ Mutagen 4:417.
*Mehta RD, von Borstel RC. 1982b. Genetic activty of diethylstilbesterol in Saccharomyces cerevisiae: Enhancement of mutagenicity by oxidizing agents. Mutat Res 92:49–61.7045652
*Meier CA, Burger AG. 1996. Effects of pharmacologic agents on thyroid hormone homeostasis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 276–286.
*Meinhold H, Beckert A, Wenzel KW. 1981. Circulating diiodotyrosine: Studies of its serum concentration, source, and turnover using radioimmunoassay after immunoextraction. J Clin Endocrinol Metab 53(6):1171–1178.7028774
*Meinhold H, Gramm HJ, Meissner W, . 1991. Elevated serum diiodotyrosine (DIT) in severe infections and sepsis: DIT, a possible new marker of leukocyte activity. J Clin Endocrinol Metab 72:945–953.2005222
*Meinhold H, Olbricht T, Schwartz-Porsche D. 1987. Turnover and urinary excretion of circulating diiodotyrosine. J Clin Endocrinol Metab 64(4):794–800.3818904
Mello RS, Callisen H, Winter J, . 1983. Radiation dose enhancement in tumors with iodine. Med Physics 10(1):75–78.
*Mendel CM, Weisiger RA, Cavalieri RR. 1988. Uptake of 3,5,3’-triiodothyronine by the perfused rat liver: Return to the free hormone hypothesis. Endocrinology 123:1817–1824.3416816
Mendel CM, Weisiger RA, Jones AL, . 1987. Thyroid hormone-binding proteins in plasma facilitate uniform distribution of thyroxine within tissues: A perfused rat liver study. Endocrinology 120:1742–1749.3106010
Mercantini ES. 1970. Iododerma from seafood. Can Med Assoc J 102:759–760.
*Merkle J, Zeller H. 1979. Absence of povidone-iodine induced mutagenicity in mice and hamsters. J Pharm Sci 68:100–102.758440
Merwin SE, Balonov MI. 1993. The Chernobyl papers: Vol. I. Doses to the Soviet population and early health effects studies. Richland, WA: Research Enterprises.
Messerli FH, Schmieder RE. 2002. Salt and hypertension. Going to the heart of the matter. Arch Intern Med 162(1):104–105.11784238
Mestdagh C, Many M-C, Halpern S, . 1990. Correlated autoradiographic and ion-microscopic study of the role of iodine in the formation of “cold” follicles in young and old mice. Cell Tissue Res 260:449–457.2372804
Meyer MA. 1994. Re: Cancer risk after iodine-131 therapy for hyperthyroidism [Letter]. J Natl Cancer Inst 86(13):1026–1027.8007013
*MHR. 2001. Nuclear waste dry cask storage. Information brief. St. Paul, Mn: Minnesota House of Representatives Research Department. http://www.leg.state.mn.us/hrd/pubs/nucwaste.pdf.
Michelangeli VP, Poon C, Topliss DJ, . 1995. Specific levels of radioiodine treatment on TSAb and TBAb levels in patients with Graves’ disease. Thyroid 5(3):171–176.7580264
Mikkonen R. 1998. Incidence and risk factors for delayed allergy-like reactions to x-ray contrast media adult and pediatric populations. Pharmacoepidemiol Drug Saf 7:S11–S15.15073953
Mikulecky M, Beno M, Komornik I. 1993. Time delay of maximal human thyroid ^131^I uptake after the Chernobyl accident. Naturwissenschaften 80:125–127.8464520
*Millard RK, Saunders M, Palmer AM, . 2001. Approximate distribution of dose among foetal organs radioiodine uptake via placenta transfer. Phys Med Biol 46(11):2773–2783.11720346
*Miller JK, Swanson EW. 1963. Some factors affecting iodine secretion in milk. J Dairy Sci 46:927.
Miller KL, Coen PE, White WJ, . 1989. Effectiveness of skin absorption of tincture of I in blocking radioiodine from the human thyroid gland. Health Phys 56(6):911–914.2722514
Miller KL, White WJ, Lang CM, . 1985. Skin exposure to I blocks thyroid uptake to ^131^I. Health Phys 49(5):791–794.4066341
Miller M. 1998. Risk modeling can be key to determining radiation exposures. J Natl Cancer Inst 90(21):1596–1598.9811307
Miller WJ. 1975. New concepts and developments in metabolism and homeostasis of inorganic elements in dairy cattle. A review. J Dairy Sci 58(10):1549–1560.1102574
Mills I, Sherwin JR. 1985. A comparison of the mechanisms of alpha-adrenergic inhibition of thyrotropin-stimulated adenosine 3’,5’-monophosphate in cat, rat, mouse, hamster, beef, and pig tissues with the stimulatory effect of epinephrine on beef thyroid iodination: Evidence for multiple, species-specific adrenergic mechanisms. Endocrinology 116:1310–1315.2982584
*Minelli R, Braverman LE, Guiberti T, . 1997. Effects of excess iodine administration on thyroid function in euthyroid patients with a previous episode of thyroid dysfunction induced by interferon-alpha treatment. Clin Endocrinol 47:357–361.
*Minelli R, Braverman LE, Valli MA, . 1999. Recombinant interferon alpha (rIFN-alpha) does not potentiate the effect of iodine excess on the development of thyroid abnormalities in patients with HCV chronic active hepatitis. Clin Endocrinol 50:95–100.
Misaki T, Miyamoto S, Alam MS, . 1996. Tumoricidal cytokines enhance radioiodine uptake in cultured thyroid cancer cells. J Nucl Med 37(4):646–648.8691260
Mittag TW, Guo W-B, Taniguchi T. 1993. Interaction of vanadate and iodate oxyanions with adenylyl cyclase of ciliary processes. Biochem Pharmacol 45(6):1311–1316.8466550
Mityukova TA, Astakhova LN, Asenchyk LD, . 1995. Urinary iodine excretion in Belarus children. Eur J Endocrinol 133:216–217.7655647
Miura S, Hara Y, Iitaka M, . 1991. Disturbance of thyroidal iodine metabolism in BB/W rat. Endocrinol Jpn 38:647–653.1823032
*Miyake Y, Tsunogai S. 1963. Evaporation of iodine from the ocean. J Geophys Res 68:3989.
Miyake Y, Eguchi W, Adachi M, . 1979. Effect of carbon dioxide on the absorption rate and mechanism of iodine vapor. J Chem Eng Jpn 12(6):436–442.
*Miyazaki A, Bansho K. 1987. Differential determination of trace amounts of iodide and iodate in water by solvent extraction-inductively coupled plasma atomic emission spectrometry. Spectrochim Acta, Part B 42B:227–233.
Mizukami Y, Michigishi T, Nonomura A, . 1993. Iodine-induced hypothyroidism: A clinical and histological study of 28 patients. J Clin Endocrinol Metab 76(2):466–471.8432791
M’Kacher R, Legal J-D, Schlumberger M, . 1997. Sequential biological dosimetry after a single treatment with iodine-131 for differentiated thyroid carcinoma. J Nucl Med 38:377–380.9074522
M’Kacher R, Schlumberger M, Legal J-D, . 1998. Biologic dosimetry in thyroid cancer patients after repeated treatments with iodine-131. J Nucl Med 39:825–829.9591584
*Mochizuki Y, Mowafy R, Pasternack B. 1963. Weights of human thyroids in New York City. Health Phys. 9:1299–1301.14086677
*Moiseyev IT, Tikhomirov FA, Perevezentsev VM, Rerikh LA. 1984. Role of soil properties, interspecific plant differences, and other factors affecting the accumulation of radioactive iodine in crops. Soviet Soil Science 16:60–66.
*Momotani N, Hisaoka T, Noh J, . 1992. Effects of iodine on thyroid status of fetus versus mother in treatment of Graves’ disease complicated by pregnancy. J Clin Endocrinol Metab 75(3):738–744.1517362
Monakhov AS. 1988. [Cytogenetic and blastomogenic effects of 45Ca and 131I administered to rats.] Eksp Onkol 10(4):27–30. (Russian)
*Moneret-Vautrin DA, Mata E, Gerard H, . 1989. Probable allergy to polyvidon, responsible for a reaction to iodinated contrast medium: A case of asthma after hysterosalpingography. Allerg Immunol 21(5): 198–199. (French)
*Monteiro Gil O, Oliveira NG, Rodrigues AS, . 2000. Cytogenic alterations and oxidative stress in thyroid cancer patients after iodine-131 therapy. Mutagenesis 15(1):69–75.10640533
*Moody KD, Miller KL, White WJ, . 1988. The effects of topical povidone I solution on serum iodide levels and thyroid uptake of ^131^I in dogs. Health Phys 55(1):9–13.3391783
Mooij P, De Wit HJ, Bloot AM, . 1993a. Iodine deficiency induces thyroid autoimmune reactivity in Wistar rats. Endocrinology 133(3):1197–1204.8103449
Mooij P, De Wit HJ, Drexhage HA. 1993b. An excess of dietary iodine accelerates the development of a thyroid-associated lymphoid tissue in autoimmune prone BB rats. Clin Immunol Immunopathol 69(2):189–198.8403556
Mooij P, De Wit HJ, Drexhage HA. 1994. A high iodine intake in Wistar rats results in the development of a thyroid-associated ectopic thymic tissue and is accompanied by a low thyroid autoimmune reactivity. Immunology 81:309–316.8157280
Moore MJ. 1975. Leukemia incidence in adults not increased after ^131^I. N Engl J Med 292(25):1353–1354.
Morales de Villalobos LM, Campos G, Ryder E. 1986. Effect of chronic ingestion of iodide during pregnancy and lactation on rat pup brain enzymes. Enzyme 35:96–101.2943585
*Moran JE, Oktay S, Santschi PH, . 1999. Atmospheric dispersal of ^129^iodine from nuclear fuel reprocessing facilities. Environ Sci Technol 33:2536–2542.
Moreno AJ, Hartshome MF, Yedinak MA, . 1986. Tinea corporis overlying the thyroid gland after radioiodine (^131^I) treatment of Graves’ disease. Cutis 37(4):271–273.3754806
*Morgan A, Morgan DJ, Arkell GM. 1967a. A study of the retention and subsequent metabolism of inhaled methyl iodide. In. Davies CN, ed. Inhaled Particles and Vapours II. Pergamon Press, Oxford, 309–321.
*Morgan A, Morgan DJ, Black A. 1968. A study on the deposition, translocation and excretion of radioiodine inhaled as iodine vapour. Health Phys 15:313–322.5696997
*Morgan A, Morgan DJ, Evans JC, . 1967b. Studies on the retention and metabolism of inhaled methyl iodide-II: Metabolism of methyl iodide. Health Phys 13:1067–1074.6048954
*Morgan DJ, Morgan A. 1967. Studies on the retention and metabolism of inhaled methyl iodide-I: Retention of inhaled methyl iodide. Health Phys 13:1055–1065.6048953
Morgan KG, Entrikin RK, Bryant SH. 1975. Mytonia and block of chloride conductance by iodide in avian muscle. Am J Physiol 229(5):1155–1158.1200133
*Morita S, Umezaki N, Ishibashi M, . 1998. Determining the breast-feeding interruption schedule after administration of ^123^I-iodide. Ann Nucl Med 12(5):303–306.9839494
Morizono T, Sikora MA. 1983. Compound action potential input-output decruitment: Effect of topically applied antiseptics. Arch Otolaryngol 109:677–681.6615320
Morreale de Escobar G, Calvo R, Obregon MJ, . 1992. Homeostatis of brain T3 in rat fetuses and their mothers: Effects of thyroid status and iodine deficiency. Acta Med Austriaca 19(Suppl 1):110–116.1519443
Morreale de Escobar G, Obregon MJ, Calvo R, . 1991. Maternal thyroid hormones during pregnancy: Effects on the fetus in congenital hypothyroidism and in iodine deficiency. In: Bercu BB, Shulman DI, eds. Advances in perinatal thyroidology. New York, NY: Plenum Press, 133–156.
Morreale de Escobar G, Obregon MJ, Calvo R, . 1993. Effects of iodine deficiency on thyroid hormone metabolism and the brain in fetal rats: The role of the maternal transfer of thyroxin. Am J Clin Nutr Suppl(57):280S–285S.8427205
Morreale de Escobar G, Obregon MJ, Escobar del Rey F. 1987. Fetal and maternal thyroid hormones. Horm Res 26:12–27.3297961
Morrish DW, Jackson FI, Lalani ZH, . 1989. Cystic thyroid mass following I-131 treatment of papillary thyroid carcinoma: An unusual complication. Clin Nucl Med 14(12):894–896.2605846
*Morrison RT, Birkbeck JA, Evans TC, . 1963. Radioiodine uptake studies in newborn infants. J Nucl Med 4:162–166.
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Mortensen JD, Woolner LB, Bennett WA. 1955. Gross and microscopic findings in clinically normal thyroid glands. J Clin Endocrinol Metab 15:1270–1280.13263417
Moschizuki Y, Mowafy R, Pasternack B. 1963. Weights of human thyroids in New York City. Health Phys 9:1299–1301.14086677
Moses AM, Scheinman SJ. 1996a. The kidneys and electrolyte metabolism in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 812–815.
Moses AM, Scheinman SJ. 1996b. The kidneys and electrolyte metabolism in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 628–631.
Mosher BW, Winkler P, Jaffrezo J-L. 1993. Seasonal aerosol chemistry at Dye 3, Greenland. Atmos Environ 27A(17/18):2761–2772.
*Mostbeck A, Galvan G, Bauer P, . 1998. The incidence of hyperthyroidism in Austria form 1987 to 1995 before and after an increase in salt iodization in 1990. Eur J Nucl Med 25(4):367–374.9553166
Mothersill C, Seymour C, Malone JF, . 1986. Survival and transformation frequency of differentiated sheep thyroid cells exposed to iodine-131 and gamma-irradiation. Int J Radiat Biol 49(3):524–525.
Mothersill C, Seymour CB, Moriarty MJ, . 1984. Further studies on the transformation of thyroid cultures by gamma-irradiation and by iodine-131. Int J Radiat Biol 46(5):648.
*Mould RF. 2000. Chernobyl record: The definitive history of the Chernobyl catastrophe. Philadelphia, PA: Institute of Physics Publishing.
Mountford PJ, Coakley AJ. 1989. A review of the secretion of radioactivity in human breast milk: Data, quantitative analysis and recommendations. Nucl Med Commun 10:15–27.2645546
*Mountford PJ, O’Doherty MJ. 1999. Exposure of critical groups to nuclear medicine patients. Appl Radiat Isot 50:89–111.10028630
*Mountford PJ, Steele HR. 1995. Fetal dose estimates and the ICRP abdominal dose limit for occupational exposures of pregnant staff to technetium-99m and iodine-131 patients. Eur J Nucl Med 22(10):1173–1179.8542902
Moura EG, Ramos CF, Nascimento CCA, . 1987. Thyroid function in fasting rats: Variations in ^131^I uptake and transient decrease in peroxidase activity. Braz J Med Biol Res 20:407–410.3451788
*Movius EG, Phyillaier MM, Robbins J. 1989. Phloretin inhibits cellular uptake and nuclear receptor binding of triiodothyronine in human hep G2 hepatocarcinoma cells. Endocrinology 124(4):1988–1997.2538319
*Moxon RE. 1984. Automatic methods for the determination of total inorganic iodine and free iodide in waters. Analyst 109:425–430.
Mu L, Chengyi Q, Qidong Q, . 1987. Endemic goitre in central China caused by excessive iodine intake. Lancet 2(8553):257–259.2886725
Mukherjee B. 1983. Inhibition and recovery of the iodine uptake function of rat thyroids after 18 MeV proton irradiation in vivo. Br J Radiol 56:67–68.6295537
Murakami S, Nasu M, Fukayama H, . 1993. Propranolol has direct antithyroid activity: Inhibition of iodide transport in cultured thyroid follicles. Cell Biochem Funct 11:159–165.8104735
Muraki T, Tsukahara F, Fujii E, . 1991. Alpha_1_-adrenergic stimulation of iodide organification in mouse thyroid-inhibition by protein kinase C inhibitors. Arch Int Pharmacodyn 314:122–132.1688097
*Muramatsu Y, Yoshida S. 1995. Volatilization of methyl iodide from the soil-plant system. Atmos Environ 29(1):21–25.
Muramatsu Y, Sumiya M, Ohomo Y. 1986. Levels and behavior of ^127^I and ^129^I in the environment in Japan. In: Spurenelement-Symposium Iodine, 5^th^ ed, 35–41.
Muramatsu Y, Uchida S, Sriyotha P, . 1990. Some considerations on the sorption and desorption phenomena of iodide and iodate on soil. Water Air Soil Pollut 49:125–138.
*Muramatsu Y, Uchida S, Sumiya M, . 1985. Iodine separation procedure for the determination of ^129^I and ^127^I in soil by neutron activation analysis. J Radioanal Nucl Chem 94(5):329–338.
Murphy PC, Burson ZG. 1973. Personnel exposures due to inadequate leak test methods for ^125^I sources. Health Phys 24:443–444.4698194
*Murray JL. 1969. Thyroid uptake of iodine-131 from skin exposure. Health Phys 17:730–731.5350122
*Murray RL. 1994. Understanding radioactive waste. 4th ed. Columbus, OH: Battelle Press, 60–193.
Mutaku JF, Many M-C, Colin I, . 1998. Antigoitrogenic effect of combined supplementation with dl-alpha-tocopherol, ascorbic acid and beta-carotene and of dl-alpha-tocopherol alone in the rat. J Endocrinol 156:551–561.9582512
*Myant NB. 1956. Enterohepatic circulation of thyroxine in humans.
*Myant NB. 1958. Passage of thyroxine and tri-iodo-thyronine from mother to foetus in pregnant women. Clin Sci 17:75–79.13511722
*Myant NB, Pochin EE. 1950. The metabolism of radiothyroxine in man. Clin Sci 9:421–440.24540022
Myers DK. 1971. DNA repair in E. coli B/r after X-irradiation in the presence of iodide or iodoacetamide. Int J Radiat Biol 19(3):293–295.
Myers DK. 1977. Repair of the double-strand breaks produced by ^125^I disintegrations in the DNA of Micrococcus radiodurans. Curr Top Radiat Res Q 12:369–388.
*Myers DK, Chetty KG. 1973. Effect of radiosensitizing agents on DNA strand breaks and their rapid repair during irradiation. Radiat Res 53:307–314.4571942
Nagata C, Tagashira T, Inomata M, . 1971. Effect of iodine on the carcinogenicity of 3,4-benzopyrene. Jpn J Cancer Res 62:309–314.
*Nagata K, Takasu N, Akamine H, . 1998. Urinary iodine and thyroid antibodies in Okinawa, Yamagata, Hyogo, and Nagano, Japan: The differences in iodine intake do not affect thyroid antibody positivity. Endocrine Journal 45(6):797–803.10395237
Nagataki S, Nagayama Y. 1997. Molecular biology of the thyroid stimulating hormone receptor. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 209–222.
*Nagataki S, Yokoyama N. 1996. Other factors regulating thyroid function: Autoregulation: Effects of iodide. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 241–247.
Nagataki S, Shibata Y, Inoue S, . 1994. Thyroid diseases among atomic bomb survivors in Nagasaki. JAMA 272:364–370.8028167
*Nagataki S, Shizume K, Nakao K. 1967. Thyroid function in chronic excess iodide ingestion: Comparison of thyroidal absolute iodine uptake and degradation of thyroxine in euthyroid Japanese subjects. J Clin Endocrinol 27:638–647.
Nagataki S, Uchimura H, Masuyama Y, . 1973. Is TSH-stimulated thyroid hormone release inhibited by iodide? Endocrinology 93:532–539.4124492
Nair SK, Apostoaei AI, Hoffman FO. 2000. A radioiodine speciation, deposition, and dispersion model with uncertainty propagation for the Oak Ridge Dose Reconstruction. Health Phys 78(4):394–413.10749523
Nakajima H, Sasaki N, Kubimura N, . 1974. [Infantile hypothyroidism caused by 131 I in mother’s milk.] Nippon Rinsho 32(7):2430–2432. (Japanese)4474439
Nakajima T, Wang R-S, Elovaara E, . 1992. A comparative study on the contribution of cytochrome P450 isozymes to metabolism of benzene, toluene and trichloroethylene in rat liver. Biochem Pharmacol 43(2):251–257.1739413
Nakamoto Y, Saga T, Misaki T, . 2000. Establishment and characterization of a breast cancer cell line expressing Na+/I− symporters for radioiodide concentrator gene therapy. J Nucl Med 41(11):1898–1904.11079502
*Nakamura Y, Kotani T, Ohtaki S. 1990. Transcellular iodide transport and iodination on the apical plasma membrane by monolayer porcine thyroid cells cultured on collagen-coated filters. J Endocrinol 126:275–281.2401868
Nakane Y, Honda S, Mine M, . 1996. The mental health of atomic bomb survivors. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, The Netherlands: Elsevier, 239–249.
Nakayama S. 1970a. [Studies on hematologic changes after administration of therapeutic doses of radioactive iodine: I. Statistical studies on the occurrence of leukemia.] Nippon Ketsueki Gakkai Zasshi 33(5):560–577. (Japanese)5535814
Nakayama S. 1970b. [Studies on the hematological changes after administration of therapeutic doses of radioactive iodine.] Nippon Ketsueki Gakkai Zasshi 33(5):578–597. (Japanese)5535815
*Namba H, Yamashita S, Kimura H, . 1993. Evidence of thyroid volume increase in normal subjects receiving excess iodide. J Clin Endocrinol Metab 76(3):605–608.8445017
Nanping W, Guangjun Y, Zijin T. 1998. Kinetic effect of testosterone of estradiol on iodine absorption in castrating rat intestine. Wei Sheng Yen Chiu 27(6):396–399.11939028
Napier BA, Eslinger PW, Nichols WE, . 2001. Improvements in modeling sagebrush concentrations of radioiodine released from the Hanford site. J Environ Radioact 54(3):377–389.11381944
Narra VR, Howell RW, Harapanhalli RS, . 1992. Radiotoxicity of some iodine-123, iodine-125 and iodine-131-labeled compounds in mouse testes: Implications for radiopharmaceutical design. J Nucl Med 33(12):2196–2201.1460515
Narra VR, Howell RW, Sastry KSR, . 1993. Vitamin C as a radioprotector against iodine-131 in vivo. J Nucl Med 34:637–640.8455081
Narra VR, Howell RW, Thanki KH, . 1991. Radiotoxicity of ^125^I-iodoeoxyuridine in pre-implantation mouse embryos. Int J Radiat Biol 60(3):525–532.1679091
*NAS. 1974. Geochemistry and the environment: Volume I: The relation of selected trace elements to health and disease. Washington, DC: National Academy of Sciences. NTIS PB80-135197.
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
Nasu M, Sugaware M. 1994. Exogenous free iodotyrosine inhibits iodide transport through the sequential intracellular events. Eur J Endocrinol 130:601–607.8205262
Nauman J, Wolff J. 1993. Iodide prophylaxis in Poland after the Chernobyl reactor accident: Benefits and risks. Am J Med 94:524–532.8498398
*NCI. 1997. Estimated exposures and thyroid doses received by the American people from iodine-131 in fallout following Nevada atmospheric nuclear bomb tests. National Cancer Institute. http://rex.nci.nih.gov/massmedia/Fallout.
*NCRP. 1977. Protection of the thyroid gland in the event of releases of radioiodine. Washington, DC: National Council on Radiation Protection and Measurements. NCRP Report No. 55, 19–29.
*NCRP. 1983. Iodine-129: Evaluation of releases from nuclear power generation. Bethesda, MD: National Council on Radiation Protection and Management. NCRP Report No. 75.
*NCRP. 1985. General concepts for the dosimetry of internally deposited radionuclides. National Council on Radiation Protection and Measurements. Bethesda, MD: NCRP Report No.84.
*NCRP. 1987. Use of bioassay procedures for assessment of internal radionuclide deposition. National Council on Radiation Protection and Measurements. Bethesda, MD: NCRP Report No. 87.
*NCRP. 1993. Limitation of exposure to ionizing radiation. National Council on Radiation Protection and Measurements. Report No. 116. National Council on Remediation Protection and Measurement.
NCRP. 1996. A guide for uncertainty analysis in dose and risk assessments related to environmental contamination. Bethesda, MD: National Council on Radiation Protection and Management. NCRP Commentary No. 14.
*NCRP. 1997. Deposition, retention and dosimetry of inhaled radioactive substances. National Council on Radiation Protection and Measurements. Report No. 125.
*NCSL. 2002. Radioactive waste news. A quarterly summary of generation, transportation, storage and disposal issues. National Conference of Sate Legislatures. Vol. 19(2) 1–8.
*Negretti de Bratter VE, Bratter P, Tomiak A. 1990. An automated microtechnique for selenium determination in human body fluids by flow injection hydride atomic absorption spectrometry (Fl-HAAS). J Trace Elem Electrolytes Health Dis 4(1):41–48.2135957
Nelson M, Phillips DIW. 1985. Seasonal variations in dietary iodine intake and thyrotoxicosis. Hum Nutr Appl Nutr 39A:213–216.
Nemec J, Neradilova M, Zamrazil V, . 1968. [Hematological changes during treatment of thyrotoxicosis and thyroid carcinoma with radioactive iodine 131.] Cas Lek Cesk 107(25):742–748. (Czech)5664846
Nemec J, Soumar J, Zeman V, . 1978. Differentiated thyroid cancer following radioiodide ^131^I therapy of hyperthyroidism - a case report. Oncology 35:277–280.745812
Netelenbos JC, Lips P. 1981. Hyperparathyroidism after radioactive iodine therapy. Arch Intern Med 141:1555–1556.
Neu F, Rebai T, Denef J-F, . 1994. Involvement of T cell immunity in the transient thyroid inflammation induced by iodide in goitrous BALB/C and nude mice. Autoimmunity 17:209–216.7948605
Neve P, Starling JR, Golstein J, . 1988. Effects of iodine intake on thyroid secondary lysosomes after subtotal thyroidectomy. Endocrinology 1988:478–486.
Newkirk KA, Ringel MD, Wartofsky L, . 2000. The role of radioactive iodine in salivary gland dysfunction. Ear Nose Throat J 79(6):460–468.10893838
Newton GL, Clawson AJ. 1974. Iodine toxicity: Physiological effects of elevated dietary iodine on pigs. J Anim Sci 39(5):879–884.4426879
Newton GL, Barrick ER, Harvey RW, . 1974. Iodine toxicity. Physiological effects of elevated dietary iodine on calves. J Anim Sci 38(2):449–455.4812297
*Ng YC, Anspaugh LR, Cederwall RT. 1990. ORERP internal dose estimates for individuals. Health Phys 59(5):693–713.2211124
Nicoloff JT, LoPresti JS. 1996. Nonthyroidal illnesses. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 286–296.
*Nikiforov YE, Fagin JA. 1998. Radiation-induced thyroid cancer in children after the Chernobyl accident. Thyroid Today: 21(2):1–10.
Nilsson G. 1973. Self-limiting episodes of Jodbasedow. Acta Endocrinol 74:475–482.
Nilsson M, Ericson LE. 1994. Effects of epidermal growth factor on basolateral iodide uptake and apical iodide permeability in filter-cultured thyroid epithelium. Endocrinology 135(4):1428–1436.7925105
*Nilsson M, Bjorkman U, Ekholm R, . 1990. Iodide transport in primary cultured thyroid follicle cells: Evidence of a TSH-regulated channel mediating iodide efflux selectively across the apical domain of the plasma membrane. Eur J Cell Biol 52:270–281.1706997
*NIOSH. 2001. Documentation for immediately dangerous to life or health concentrations. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/idlh/intridl4.html.
NIREX. 1987. Radionuclide interactions with marine sediments. Harwell, England: Nuclear Industry Radioactive Waste Executive. NTIS DE90630517.
Nishimaki T, Furudate S. 1997. Effects of stable KI administration on iodine-125 distribution in various mouse organs. Radioisotopes 46(10):720–723.
*Nishioka K, Seguchi T, Yasuno H, . 2000. The results of ingredient patch testing in contact dermatitis elicited by povidone-iodine preparations. Contact Dermatitis 42(2):90–94.10703631
*Nishiyama H, Lukes S, Mayfield G, . 1980. Internal contamination of laboratory personnel by ^131^I. Radiology 137:767–771.7444060
*Nishizawa K, Hamada N, Sadayuki S. 1985. In vitro monitoring of salivary ^125^I. Health Phys 49(2):290–295.4019200
*Noble B, Yoshida T, Rose NR, . 1976. Thyroid antibodies in spontaneous autoimmune thyroiditis in the Buffalo rat. J Immunol 117:1447.794410
*Nobukuni K, Kawahara S. 2002. Thyroid function in nurses: The influence of povidone-iodine hand washing and gargling. Dermatology 204:99–102.12011531
*Nobukini K, Hayakawa N, Namba R, . 1997. The influence of long-term treatment with providone-iodine on thyroid function. Dermatology 195(Suppl 2):69–72.
*Noguti T, Sadaie H, Kada T. 1971. Radiosentization with iodine compounds: III. Macromolecular synthesis and repair in Bacillus subtilis irradiated in the presence of iodoacetic acid, potassium iodide or potassium iodate. Int J Radiat Biol 19(4):305–322.
Nohr SB, Jorgensen A, Pedersen KM, . 2000. Postpartum thyroid dysfunction in pregnant thyroid peroxidase antibody-positive women living in an area with mild to moderate iodine deficiency: is iodine supplementation safe? J Clin Endocrinol Metab 85(9):3191–3198.10999807
Nolte W, Mueller R, Huefner M. 1995. [Treatment of iodine induced hyperthyroidism. Possibilities and limits of the pharmacotherapy.] Med Klin 90(5):246–253. (German)
Nomura T, Katagiri H, Kitahara Y, . 1980. Methods of I-129 analysis for environmental monitoring. In: Ed. Radiation protection: A systematic approach to safety. Oxford, England: Pergamon Press, 935–938.
*Nordenson I, Beckman G, Beckman L, . 1978. Occupational and environmental risks in and around a smelter in northern Sweden: II. Chromosomal aberrations in workers exposed to arsenic. Hereditas 88:47–50.649424
Norfray JF, Quinn JLIII. 1974. Furosemide mediated elevations of thyroid iodide uptake in the rat. Proc Soc Exp Biol Med 145:286–288.4812863
*Norman JA, Pickford CJ, Sanders TW, Waller M. 1988. Human intake of arsenic and iodine from seaweed-based supplements and health foods available in the UK. Food Additives and Contaminants 5:103–109.3356276
*North DL, Shearer DR, Hennessey JV, . 2001. Effective half-life of ^131^I in thyroid cancer patients. Health Phys 81(3):325–329.11513465
Noteboom JL, Hummel WA, Broerse JJ, . 1997a. Protection of the infant thyroid from radioactive contamination by the administration of stable iodide. An experimental evaluation in chimpanzees. Radiat Res 147:698–706.9189168
Noteboom JL, Hummel WA, Broerse JJ, . 1997b. Protection of the maternal and fetal thyroid from radioactive contamination by the administration of stable iodide during pregnancy. An experimental evaluation in chimpanzees. Radiat Res 147:691–697.9189167
Noteboom JL, Hummell WA, Jansen JTM, . 1997c. Simulation of measurements of uptake of ^123^I-iodide in the thyroid of fetal chimpanzees. Radiat Res 147:686–690.9189166
*Nourok DS, Gassock RJ Solomon DH, Maxwell MH. 1964. Hypothyroidism following prolonged sodium nitroprusside therapy. Am J Med Sci 284:129–138.
*Novaes M, Biancalana MM, Garcia SA, . 1994. Elevation of cord blood TSH concentration in newborn infants of mothers exposed to acute povidone iodine during delivery. J Endocrinol Invest 17:805–808.7699215
*NRC. 1989. National Research Council. Iodine. In: Recommended dietary allowances. 10^th^ edition. Washington, DC: National Academy Press, 213–217.
*NRC. 1993. Pesticides in the diets of infants and children. National Research Council. Washington, DC: National Academy Press.
*NRC. 1995. Radiation dose reconstruction for epidemiologic uses. Committee on Assessment of CDC Radoation Studies, National Research Council. National Academy Press, Washington, 103–111.
*NRC. 1999. Exposure of the American people to iodine-131 from Nevada nuclear-bomb tests. National Research Council. National Academy Press, Washington, DC.
*NRC. 2000. Review of the Hanford thyroid disease study draft final report. National Reaserch Council. National Academy Press, Washington, D.C.
*NRC. 2004. Distribution and administration of potassium iodide in the event of a nuclear incident. National Research Council. National Academy Press, Washington, DC., 28–29.
*NRCC. 1980. National Research Council of Canada. Radioactivity in the Canadian environment. Ottawa, Ontario. NTIS DE82701242.
Nygaard B, Faber J, Veje A, . 1995a. Appearance of Graves’-like disease after radioiodine therapy for toxic as well as non-toxic multinodular goitre. Clin Endocrinol 43:129–131.
Nygaard B, Faber J, Veje A, . 1999. Transition of nodular toxic goiter to autoimmune hyperthyroidism triggered by ^131^I therapy. Thyroid 9(5):477–481.10365679
Nygaard B, Hegedus L, Gervil M, . 1993. Radioiodine treatment of multinodular non-toxic goitre. Br Med J 307:828–832.8401123
Nygaard B, Hegedus L, Gervil M, . 1995b. Influence of compensated radioiodine therapy on thyroid volume and incidence of hypothyroidism in Graves’ disease. J Int Med 238:491–497.
Nygaard B, Knudsen JH, Hegedus L, . 1997. Thyrotropin receptor antibodies and Graves’ disease, a side-effect of ^131^I treatment in patients with nontoxic goiter. J Clin Endocrinol Metab 82(9):2926–2930.9284721
Ober KP, Hennessy JF. 1981. Jodbasedow and thyrotoxic periodic paralysis. Arch Intern Med 141:1225–1227.7259385
Oberhausen E. 1990. Side effects of iodine-containing chemical. In: Rubery E, Smales E, eds. Iodine prophylaxis following nuclear accidents. Oxford, UK: Pergamon Press, 93–100.
Oberhausen E. 1991. Risk of thyroid carcinoma after iodine-131 treatment. EUR 12556:111–144.
O’Connell MEA, Flower MA, Hinton PJ, . 1993. Radiation dose assessment in radioiodine therapy. Dose-response relationships in differentiated thyroid carcinoma using quantitative scanning and PET. Radiother Oncol 28:16–26.8234866
*Oddie TH, Fisher DA. 1967. Mean euthyroid 24-hour radioiodine uptake as a characteristic of different patient populations. J Clin Endocrinol Metab 27:11–14.6019393
Oddie TH, Fisher DA, Criner G. 1966. Lag time for oral radioiodide tracer doses. J Clin Endocrinol Metab 26(5):581–582.5940264
Oddie TH, Fisher DA, Long JM. 1964. Factors affecting the estimation of iodine entering the normal thyroid gland using short-term clearance studies. J Clin Endocrinol 24:924–933.
*Oddie TH, Fisher DA, McConahey WM, . 1970. Iodine intake in the United States: A reassessment. J Clin Endocrinol 30:659–665.
*Oddie TH, Meschan I, Wortham J. 1955. Thyroid function assay with radioiodine. I. Physical basis of study of early phase of iodine metabolism and iodine uptake. J Clin Invest 34:95–105.13221659
*Oddie TH, Myhill J, Pirnique FG, . 1968a. Effect of age and sex on the radioiodine uptake in euthryoid subjects. J Clin Endocrinol 28:776–782.
Oddie TH, Pirnique FG, Fisher DA, . 1968b. Geographic variation of radioiodine uptake in euthyroid subjects. J Clin Endocrinol 28:761–775.
*Oddie TJ, Thomas ID, Rundle FF, . 1960. Diagnostic limits for thyroidal radioiodine uptake rates. J Clin Endocrinol Metab 20:389–400.14428252
O’Doherty MJ, Coakley AJ. 1998. Drug therapy alternatives in the treatment of thyroid cancer. Drugs 55:801–812.9617595
O’Doherty MJ, Kettle AG, Eustance CNP, . 1993. Radiation dose rates from adult patients receiving ^131^I therapy for thyrotoxicosis. Nucl Med Commun 14:160–168.8455905
O’Doherty MJ, McElhatton PR, Thomas SHL. 1999. Treating thyrotoxicosis in pregnant or potentially pregnant women: The risk to the fetus is very low. Br Med J 318:5–6.9872862
O’Donnell AL, Spaulding SW. 1997. Hyperthyroidism: Systemic effects and differential diagnosis. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 241–252.
O’Donnell E, Duckart EC, Schulz RK. 1993. Anion retention in soil: Possible application to reduce migration of buried technetium and iodine-development of a field test. In: Waste management ‘93: Working towards a cleaner environment: Waste processing, transportation, storage and disposal, technical programs and public education: Technology and programs for radioactive waste management and environmental restoration. Tuscon, AZ: Arizona Board of Regents, 1541–1551.
O’Donoghue JA, Wheldon TE. 1996. Targeted radiotherapy using Auger electron emitters. Phys Med Biol 41:1973–1992.8912375
*Ogborn RE, Waggener RE, VanHove E. 1960. Radioactive-iodine concentration in thyroid glands of newborn infants. Pediatrics :771–776.
Ogris E. 1997. [Exposure with J-131 during pregnancy: Significance for mother and child.] Acta Med Austriaca 24:150–153. (German)9441552
O’Hare NJ, Gilligan P, Murphy D, . 1997. Estimation of foetal brain dose from I-131 in the foetal thyroid. Phys Med Biol 42:1717–1726.9308078
O’Hare NJ, Murphy D, Malone JF. 1998. Thyroid dosimetry of adult European populations. Br J Radiol 71:535–543.9691899
O’Hare NJ, Murphy D, Malone JF. 2000. Thyroid dosimetry in Europe following the Chernobyl accident. Br J Radiol 73:636–640.10911787
Ohmomo Y, Nakamura Y, Honma Y, . 1978. [Studies on the estimation of radiation dose to thyroid gland through foods contaminated by gaseous radioactive iodine.] Hoshasen Igaku Sogo Kenkyusho, [Tech Rep] NIRS-R 8:29–35. (Japanese)
*Ohno S. 1971. Determination of iodine and bromine in biological materials by neutron activation analysis. Analyst 96:423–426.5093147
*Ohno M, Zannini M, Levy O, . 1999. The paired-domain transcription factor Pax8 binds to the upstream enhancer of the rat sodium/iodide symporter gene and participates in both thyroid-specific and cyclic-AMP-dependent transcription. Mol Cell Biol 19(3):2051–2060.10022892
Ohshima M, Ward JM. 1986. Dietary iodine deficiency as a tumor promoter and carcinogen in male F344/NCr rats. Cancer Res 46:877–883.3940650
Ohtake M, Onaya T, Sato A, . 1973. Studies on the mechanism of inhibitory action of excess iodide on thyroid hormone secretion. Proc Soc Exp Biol Med 144(2):538–543.4746927
Ohtaki S, Nakagawa H, Nakamura M, . 1996. Thyroid peroxidase: Experimental and clinical integration. Endocr J (Tokyo) 43(1):1–14.
*Okano M. 1989. Irritant contact dermititis caused by the povidone-iodine. J Am Acad Dermatol 20(5):860.
Okuno Y, Kunimatsu T, Tanahashi K, . 1996. Effect of simultaneous treatment of large amounts of vitamin A and thiourea on thyroidal iodine uptake and organification in rats. J Toxicol Pathol 9:385–390.
*Oliner L, Kohlenbrener RM, Fields T, . 1957. Thyroid function studies in children: Normal values for thyroidal I^131^ uptake and PBI^131^ levels up to the age of 18. J Clin Endocrinol Metab 17:61–75.13385318
Olinescu R, Bartoc R, Militaru M, . 1992. The changes of peroxides and total antioxidant in the plasma of patients who received ^131^I therapeutically. Rev Roum Med Med Interne 30(2):113–117.
Oliver LL, Ballad RV, Manuel OK. 1982a. Iodine-129 in Missouri rain and milk. J Radioanal Chem 68(1–2):233–244.
*Oliver LL, Ballad RV, Manuel OK. 1982b. ^129^I in Missouri thyroids. Health Phys 42:425–432.7085289
Olsen KJ, Ehlers N, Schonheyder F. 1979. Studies on the handling of retinotoxic doses of iodate in rabbits. Acta Pharmacol Toxicol (Copenh) 44:241–250.433617
Olson WG, Stevens JB, Anderson J, . 1984. Iodine toxicosis in six herds of dairy cattle. J Am Vet Med Assoc 184(2):179–181.6698850
Olurin E. 1983. Epidemiology of cancer of the thyroid gland in Ibadan (Nigeria). Acta Endocrinol Suppl 252:16.
Ondov JM, Choquette CE, Zoller WH, . 1989. Atmospheric behavior of trace elements on particles emitted from a coal-fired power plant. Atmos Environ 23(10):2193–2204.
*O’Neill B, Magnolato D, Semenza G. 1987. The electrogenic, Na^+^-dependent I^−^ transport system in plasma membrane vesicles from thyroid glands. Biochim Biophys Acta 896:263–274.3801472
*Oppenheimer JH, Schwartz HL. 1985. Stereospecific transport of triiodothyronine from plasma to cytosol and from cytosol to nucleus in rat liver, kidney, brain, and heart. J Clin Invest 75:147–154.3965501
Oppenheimer JH, Schwartz HL, Strait KA. 1996. The molecular basis of thyroid hormone actions. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 162–184.
Orazio AF, Dunkleberger JD. 1988. New York’s development of low-level radioactive waste disposal capability. In:, ed. Proceedings of the ACPA annual meeting. Air Pollution and Control Association, 88–23.10.
Orme MCL, Connolly ME. 1971. Hypoparathyroidism after iodine-131 treatment of thyrotoxicosis. Ann Intern Med 75(1):136–137.5091558
Orr MM, Tamarind DL, Cook J, . 1975. Chronic lesions of rabbit bowel due to contact with antiseptic skin preparation. Gut 16(5):401.
Oscarson DW, Hume HB, Sawatsky NG, . 1992. Diffusion of iodide in compacted bentonite. Soil Sci Soc Am J 56:1400–1406.
*OSHA. 2001a. Air contaminants. Shipyards. Occupational Safety and Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1915.1000, Table Z. http://www.osha-slc.gov/OshStd_data/1915_1000.html. March 26, 2001.
*OSHA. 2001b. Limits for air contaminants. Occupational Safety and Health Administration, U.S. Department of Labor. http://www.osha-slc.gov/OshStd_data/1910_1000_TABLE_Z-1.html. February 22, 2001.
*OSHA. 2001c. Threshold limit values of airborne contaminants for construction. Occupational Safety and Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha-slc.gov/OshStd_data/1926_0055_APP_A.html. March 26, 2001.
Osmanagaoglu K, Foulon W. 1998. Concerns about risks of irradiation during pregnancy. J Nucl Med 39(12):2194–2195.
OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-438.
Othman S, Phillips DIW, Lazarus JH, . 1992. Iodine metabolism in postpartum thyroiditis. Thyroid 2(2):107–111.1525577
Ott RA, Hofmann C, Oslapas R, . 1987. Radioidine sensitivity of parafollicular C cells in aged Long-Evans rats. Surgery 102(6):1043–1048.3686344
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Ozakay H, Unak P, Biber Z, . 1998. Determination of iodide in drinking water by isotope dilution analysis. J Radioanal Nucl Chem 230(1–2):231–233.
Ozaki O, Ito K, Mimura T, . 1994. Thyroid carcinoma after radioactive iodine therapy for Graves’ disease. World J Surg 18:518–521.7725738
Ozawa Y, Migita M, Watanabe T, . 1994. Development of Graves’ ophthalmopathy and uveitis after radioiodine therapy for Graves’ disease in a patient with HTLV-I associated myelopathy (HAM). Intern Med 33:564–568.8000111
*Pacini F, Gasperi M, Fugazzola L, . 1994. Testicular function in patients with differentiated thyroid carcinoma treated with radioiodine. J Nucl Med 35(9):1418–1422.8071685
*Pacini F, Vorontsova T, Demidchik EP, . 1997. Post-Chernobyl thyroid carcinoma in Belarus children and adolescents: Comparison with naturally occurring thyroid carcinoma in Italy and France. J Clin Endocrinol Metab 82(11):3563–3569.9360507
Pacyna JM. 1995. The origin of Arctic air pollutants: Lessons learned and future research. Sci Total Environ 160/161:39–53.
Pahjua DN, Rajan MGR, Borkar AV, . 1993. Potassium iodate and its comparison to potassium iodide as a blocker of ^131^I uptake by the thyroid in rats. Health Phys 65(5):545–549.8225995
Pahuja DN, Rajan MGR, Chaudhari PR, . 1997. On thyroid protection against radioiodine. Radiat Prot Environ 20(2):93–95.
Paindakhel SM, Begum N, Shah H, . 1980. Iodine induced thyrotoxicosis-case reports and review of literature. JPMA JPakMedAssoc 30(5):122–124.
Painter RB, Young BR. 1977. Anomalous effects of ^125^I after its incorporation into mammalian cell DNA. Curr Top Radiat Res Q 12:472–479.
*Palmer HE, Branson BM, Cohn SH, . 1976. Standard field methods for determining ^131^I in vivo. Health Phys 30:113.1244328
Palms JM, Veluri VR, Boone FW. 1975. The environmental impact ^129^I released by a nuclear fuel-reprocessing plant. Nuclear Safety 16(5):593–602.
Panariti E. 1995. The secretion of radioactive iodine (^131^J) into the milk of small ruminants following their experimental contamination. DtschTieraerztlWochenshr 102:198–200.
Panday CS, Kochupillai N. 1982. Iodine prophylaxis and endemic goitre. Indian J Pediatr 49:819–822.7182359
Papa CM. 1976. Acne and hidden iodides [Letter]. Arch Dermatol 112:555–556.
Papadopoulos D, Thomas P. 1977. [Ratio of the dose factors of the isotopes of iodine.] Kernforschungszentrum Karlsruhe, [Ber.], KFK 2544, 14 pp. (German)
Papadopoulos I, Schnapka C, Kelami A. 1986. Examinations of polyvidone-iodine as an irrigation solution for spermatic duct occlusions. Andrologia 18(6):649–658.3813053
Papas A, Ingalls JR, Campbell LD. 1979. Studies on the effects of rapeseed meal on thyroid status of cattle, glucosinolate and iodine content of milk and other parameters. J Nutr 109:1129–1139.448457
Park YK, Harland BF, Vanderveen JE, . 1981. Estimation of dietary iodine intake of Americans in recent years. J Am Diet Assoc 79:17–24.6894602
*Parmentier M, Libert F, Maenhaut C, . 1989. Molecular cloning of the thyrotropin receptor. Science 246:1620–1622.2556796
Parrott MW, Johnston ME, Durbin PW. 1960. The effects of thyroid and parathyroid deficiency on reproduction in the rat. Endocrinology 67:467–483.13732992
*Paschke R, Vogg M, Winter J, . 1994. The influence of iodine on the intensity of the intrathyroidal autoimmune process in Graves’ disease. Autoimmunity 17:319–325.7948614
*Pastan I. 1957. Absorption and secretion of iodide by the intestine of the rat. Endocrinol 61:93–97.
Pasternak FP, Socolow EL, Ingbar SH. 1969. Synergistic interaction of phenazone and iodide on thyroid hormone biosynthesis in the rat. Endocrinol 84:769–777.
Patten JR, Whitford GM, Stringer GI, . 1978. Oral absorption of radioactive fluoride and iodide in rats. Arch Oral Biol 23:215–217.278556
*Patton GW, Cooper AT. 1993. Air pathway effects of nuclear materials production at the Hanford site, 1983 to 1992. Battelle Pacific Northwest Laboratories, Richland WA. NTIS:DE94002708.
*Paul T, Meyers B, Witorsch RJ, . 1988. The effect of small increases in dietary iodine on thyroid function in euthyroid subjects. Metabolism 37(2):121–124.3340004
Pavlovic-Hournac M, Delbauffe D. 1977. Discontinuity of thyroid gland response to hormonal stimulation: Effect of TSH and cAMP on iodide organification. Mol Cell Endocrinol 8:157–173.200507
Pawels EK, Thompson WH, Blokland JAK, . 1999. Aspects of fetal thyroid dose following iodine-131 administration during early stages of pregnancy in patients suffering from benign thyroid disorders. Eur J Nucl Med 26(11):1453–1457.10552087
*Pearce EN, Gerber AR, Gootnick DB, . 2002. Effect of chronic iodine excess in a cohort of long-term American workers in West Africa. J Clin Endocrinol Metab 87(12):5499–5502.12466344
Peden NR, Hart IR. 1984. The early development of transient and permanent hypothyroidism following radioiodine therapy for hyperthyroid Graves’ disease. Can Med Assoc J 130:1141–1144.6546895
*Pedersen KM, Laurberg P, Iverson E, . 1993. Amelioration of some pregnancy-associated variations in thyroid function by iodine supplementation. J Clin Endocrinol Metab 77(4):1078–1083.8408456
*Peeters R, Fekete C, Goncalves C, . 2001. Regional physiological adaptation of the central nervous system deiodinases to iodine deficiency. Am J Physiol Endocrinol Metab 281(1):E54–E61.11404222
*Pekary AE, Hershman JM, Berg L. 1998. Tumor necrosis factor, ceramide, transforming growth factor-beta_1_, and aging reduce Na^+^/I^−^ symporter messenger ribonucleic acid levels in FRTL-5 cells. Endocrinology 139(2):703–712.9449644
*Peňa-Penabad C, De Unamuno P, Garcis-Silva J, . 1993. Vegetating iododerman and conjunctival involvement. EJD Eur J Dermatol 3:671–673.
Pendergrast WJ, Milmore BK, Marcus SC. 1961. Thyroid cancer and thyrotoxicosis in the United States: Their relation to endemic goiter. J Chronic Dis 13:22–38.13734092
*Pendleton RC, Lloyd RD, Mays CW, Lloyd RD. 1963. Iodine-131 in Utah during July and August 1962. Science 141(3581):640–642.17781762
*Pendleton RC, Mays CW, Lloyd RD. 1963. Differential accumulation of ^131^I from local fallout in people and milk. Health Phys 19:1253–1262.
*Penfold JL, Pearson CC, Savage JP, . 1978. Iodide induced goitre and hypothyroidism in infancy and childhood. Aust Paediatr J 14:69–73.687254
Pennington JS, Martin FIR. 1967. Hypothyroidism following treatment of thyrotoxicosis with radioiodine. Med J Aust 2(14):641–643.4168352
*Pennington JT. 1988. Iodine. In: Smith KT, ed. Handbook on Trace Minerals in Foods: Their Relationship to Health and Nutrition. New York, NY: Marcel Dekker.
*Pennington JT. 1990a. Iodine concentrations in US milk: Variation due to time, season, and region. J Dairy Sci 73:3421–3427.
*Pennington JT. 1990b. A review of iodine toxicity reports. J Am Diet Assoc 90:1571–1581.2229854
*Pennington JT, Young BE, Wilson DB, . 1986. Mineral content of foods and total diets: The selected minerals in foods survery, 1982-1984. J Am Diet Assoc 86:876–891.3722652
*Pennington JT, Wilson, Harland BF, . 1984. Selected minerals in foods surveys, 1974 to 1981/82. J Amer Diet Assoc 84:771–780.6736504
Pepe F, Calvo G, Chirico E, . 1993. [Obstetric and perinatal implications of thyroid pathology in pregnancy. Review of the literature.] Minerva Ginecol 45(11):565–585. (Italian)8121605
*Pereira A, Braekman JC, Dumont JE, . 1990. Identification of a major iodoloipid form horse thyroid gland as 2-iodohexadecanol. J Biol Chem 271:23006.
*Perkins 1963. Physical and chemical form of I^131^ in fallout. Health Physics 9:1113.14086652
Perlman JA, Sternthal PM. 1983. Effect of ^131^I on the anemia of hyperthyroidism. J Chronic Dis 36(5):405–412.6853667
*Perrault G, Thieblemont P, Pasquier C, . 1967. Cinetique du passage du radioide soluble a travers les epitheliums respiratoires, apres inhalation. Health Phys 13:707–718.4961139
*Perret J, Ludgate M, Libert F, . 1990. Stable expression of the human TSH receptor in CHO cells and characterization of differentially expressing clones. Biochem Biophys Res Commun 171(3):1044–1050.2171505
*Perron B, Rodriguez A-M, Leblanc G, . 2001. Cloning of the mouse sodium iodide symporter and its expression in the mammary gland and other tissues. J Endocrinol 170:185–196.11431151
*Pesavento M, Profumo A. 1985. General procedure for the determination of trace amounts of iodine in natural water samples of unknown composition by spectrophotometric titration. Analyst 110:181–183.
Peter HJ, Burgi U, Gerber H. 1996. Pathogenesis of nontoxic diffuse and nodular goiter. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 890–895.
Peters J, O’Reilly S, Barragry JM. 1993. Anaplastic carcinoma of the thyroid following radio-iodine therapy. Isr J Med Sci 162(1):3–4.
Petersen RB, Goren H, Cohen M, . 1997. Transthyretin amyloidosis: A new mutation associated with dementia. Ann Neurol 41:307–313.9066351
*Petrova A, Gnedko T, Maistrova I, . 1997. Morbidity in a large cohort study of children born to mothers exposed to radiation from Chernobyl. Stem Cells 15(Suppl 2):141–150.
*Pettersson B, Adami H-O, Wilander E, . 1991. Trends in thyroid cancer incidence in Sweden, 1958-1981, by histopathologic type. Indian J Cancer 48:28–33.
*Pettersson B, Coleman MP, Ron E, . 1996. Iodine supplementation in Sweden and regional trends in thyroid cancer incidence by histopathologic type. Indian J Cancer 65:13–19.
Petty CS, DiBenedetto RL. 1957. Goiter of the newborn. N Engl J Med 256:1103–1105.13452002
*Phaneuf D, Cote I, Dumas P, . 1999. Evaluation of the contamination of marine algae (seaweed) from the St. Lawrence river and likely to be consumed by humans. Environ Res 80:S175–S182.10092431
Pharoah POD. 1996. ‘Iodine and brain development’ [Letter]. Dev Med Child Neurol 38:278–282.8631525
Pharoah POD, Connolly KJ. 1991. Effects of maternal iodine supplementation during pregnancy. Arch Dis Child 66(1):145–147.1994844
Pharoah POD, Connolly KJ. 1995. Iodine and brain development. Dev Med Child Neurol 37(8):744–748.7672472
Pharoah POD, Buttfield IH, Hetzel BS. 1971. Neurological damage to the fetus resulting from severe iodine deficiency during pregnancy. Lancet 1:308–310.4100150
Pharoah POD, Buttfield IH, Hetzel BS. 1972. The effect of iodine prophylaxis on the incidence of endemic cretinism. Adv Exp Med Biol 30:201–221.4350935
*Phelps E, Wu P, Bretz J, . 2000. Thyroid cell apoptosis. Autoimmune Thyroid Disease 29(2)375–388.
Phillips DIW, Lazarus JH, Hall R. 1988a. Iodine metabolism and the thyroid. J Endocrinol 119:361–363.3065432
Phillips DIW, Nelson M, Barker DJP, . 1988b. Iodine in milk and the incidence of thyrotoxicosis in England. Clin Endocrinol 28:61–66.
Pic P, Michel-Bechet M, Bottini J. 1984. TSH stimulation of iodine organification in early foetal rat thyroid in vitro. Biol Cell 51:105–108.6237696
Piermattei A, Arcovito G, Azario L. 1990. Assessment of ^125^I clinical dose specification from recent dose rate evaluations. Med Physics 17(5):934–936.
Piers DA, Janssen S, Oosten HR, . 1988. Mediastinal hemorrhage after treatment of thyrotoxicosis using radioiodine. Clin Nucl Med 13(8):574–576.3168373
Pietrzyk Z, Michalkiewicz M, Huffman LJ, . 1992. Vasoactive intestinal peptide enhances thyroidal iodide uptake during dietary iodine deficiency. Endocr Res 18(3):213–228.1446660
Pietsch J, Meakins JL. 1976. Complications of povidone-iodine absorption in topically treated burn patients. Lancet 1(7954):280–282.55590
Pilch BZ, Kahn CR, Ketcham AS, . 1973. Thyroid cancer after radioactive iodine diagnostic procedures in childhood. Pediatrics 51(5):898–902.4735739
Piletta P, Rieckhoff L, Saurat JH. 1994. Triggering of bullous pemphigoid by iodine [Letter]. Br J Dermatol 131(1):145–147.
Pinchera A, Bartalena L, Marcocci C. 1995. Radioiodine may be bad for Graves’ ophthalmopathy, but… J Clin Endocrinol Metab 80(2):342–345.7852486
Pinchera A, Fenzi GF, Mariotti S, . 1990. Iodine and autoimmune thyroid disease. In: Rubery E, Smales E, eds. Iodine prophylaxis following nuclear accidents. Oxford, UK: Pergamon Press, 39–44.
Pisarev MA. 1985. Thyroid autoregulation. J Endocrinol Invest 8:475–484.3001170
Pisarev MA, Aiello LO. 1976. Studies on the mechanism of action of potassium iodide on thyroid protein biosynthesis. Acta Endocrinol 82:298–305.
Pisarev MA, Altschuler N. 1973. Action of potassium iodide on thyroid acid protease. Acta Endocrinol 74:703–710.
*Pisarev MA, Gärtner R. 2000. Autoregulatory actions of iodine. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Williams and Wilkins, 85–90.
Pisarev MA, Itoiz ME. 1972. Action of KI on stimulated thyroid protein biosynthesis. Endocrinol 90:1409–1412.
Pisarev MA, Aiello LO, Kleiman de Pisarev DL. 1976. Action of KI, thyroxine and cyclic AMP on [^3^H]uridine incorporation into the RNA of thyroid slices. Acta Endocrinol 83:313–320.
Pisarev MA, DeGroot LJ, Hati R. 1971. KI and imidazole inhibition of TSH and c-AMP induced thyroidal iodine secretion. Endocrinology 88:1217–1221.4323117
Pitslavas V, Smerdely P, Li M, . 1997. Amiodarone induces a different pattern of ultrastructural change in the thyroid to iodine excess alone in both the BB/W rat and the Wistar rat. Eur J Endocrinol 137:89–98.9242208
*Pittman CS, Buck ME, Chambers JB. 1972. Urinary metabolites of ^14^C-labeled thyroxine in man. J Clin Invest 51:1759–1766.5032524
*Pittman CS, Shimizu T, Burger A, . 1980. The nondeiodinative pathways of thyroxine metabolism: 3,5,3’,5’-tetraiodothyroacetic acid turnover in normal and fasting human subjects. J Clin Endocrinol Metab 50(4):712–716.7364927
*Pittman JA, Dailey GE, Beschi RJ. 1969. Changing normal values for thyroidal radioiodine uptake. N Engl J Med 280(26):1431–1434.4182338
Pizzulli A, Ranjbar A. 2000. Selenium deficiency and hypothyroidism. A new etiology in the differential diagnosis of hypothyroidism in children. Biol Trace Elem Res 77(3):199–208.11204462
*Plato P, Jacobson AP, Homann S. 1976. In vivo thyroid monitoring for iodine-131 in the environment. Int J Appl Radiat Isot 27:539–545.992879
Ploth DW, Fitz A, Schnetzler D, . 1978. Thyroglobulin-anti-thyroglobulin immune complex glomerulonephritis complicating radioiodine therapy. Clin Immunol Immunopathol 9:327–334.342161
Pochin EE. 1952. The iodine uptake of the human thyroid throughout the menstrual cycle and in pregnancy. Clin Sci 11:441–445.13009897
*Pohlenz J, Refetoff S. 1999. Mutations in the sodium/iodide symporter (NIS) gene as a cause for iodide transport defects and congenital hypothyroidism. Biochimie 81:469–476.10403177
*Pohlenz J, Medeiros-Neto G, Gross JL, . 1997. Hypothyroidism in a Brazilian kindred due to iodide trapping defect caused by a homozygous mutation in the sodium/iodide symporter gene. Biochem Biophys Res Commun 240:488–491.9388506
Poliak AL. 1988a. [Effect of iodine vapors on the oral mucosa of workers in iodine manufacture.] Gig Tr Prof Zabol 7:26–28. (Russian)
Poliak AL. 1988b. [Experimental data on the effect of iodine vapors on the tissues and organs of the oral cavity.] Gig Tr Prof Zabol 9:48–49. (Russian)
*Pomroy C. 1979. Surveys of lab technicians for ^125^I thyroid burdens. Occup Health Safe 48(4):40–42.
Porri F, Vervloet D. 1994. [Reactions to iodinated contrast media.] Allerg Immunol (Paris) 26(10):374–376. (French)7702729
Porterfield SP, Hendrich CE. 1991. The thyroidectomized pregnant rat-an animal model to study fetal effects of maternal hypothyroidism. In: Bercu BB, Shulman DI, eds. Advances in perinatal thyroidology. New York, NY: Plenum Press, 107–132.
Porterfield SP, Hendrich CE. 1993. The role of thyroid hormones in prenatal and neonatal neurological development-current perspectives. Endocrine Rev 14(1):94–106.8491157
Postellon DC, Aronow R. 1982. Iodine in mother’s milk. JAMA 247(4):463.
*Poston TM. 1986. Literature review of the concentration ratios of selected radioisotopes in freshwater and marine fish. Battelle Pacific Northwest Labs Report No. DE86-015820 (NTIS/DE86015820), 1–21, 82–84, 243–272.
Potter GD, Taurog A, Chaikoff IL. 1956. The I^131^-irradiated rat thyroid: It’s altered response to various stimuli and the changes induced in its iodine metabolism. Endocrinology 59(1):12–26.13344401
Pottern LM, Kaplan MM, Larsen PR, . 1990. Thyroid nodularity after childhood irradiation for lymphoid hyperplasia: A comparison of questionnaire and clinical findings. J Clin Epidemiol 43(5):449–460.2324785
Poverennyi AM, Shinkarkina AP, Vinogradova YE, . 1996. [Probable consequence of damage by radioactive iodine to thyroid gland in the period of the Chernobyl accident.] Radiats Biol Radioecol 36(4):632–640. (Russian)8925035
*Povinec PP, Oregioni B, Jull AJT, . 2000. AMS measurements of ^14^C and ^129^I in seawater around radioactive waste dump sites. Nucl Instrum Meth Phys Res Sect B 172:672–678.
Powell E. 1978. Iodine and acetone-containing plastic spray dressings. Br Med J 2(6150):1500.
*Prager EM, Gardner RE. 1979. Iatrogenic hypothyroidism from topical iodine-containing medications. West J Med 130(6):553–555.516694
Pregliasco L, Bocanera L, Chester H, . 1991. Iodide inhibits thyroglobulin synthesis. In: Gordon A, Gross J, Hennemann G, eds. Progress in thyroid research. Rotterdam, the Netherlands: Balkema, 491–494.
Premawardhana LDKE, Parkes AB, Smyth PPA, . 2000. Increased prevalence of thyroglobulin antibodies in Sri Lankan schoolgirls-is iodine the cause? Eur J Endocrinol 143(2):185–188.10913936
Prenger KB, Poeschmann PH, Smits PHJ, . 1984. Massive mediastinal hemorrhage following treatment of hyperthyroidism with radioactive iodine. Thorac Cardiovasc Surg 32:122–123.6204408
Prentice RL, Kato H, Yoshimoto K, . 1982. Radiation exposure and thyroid cancer incidence among Hiroshima and Nagasaki residents. Natl Cancer Inst Monogr 62:207–212.7167191
Press OW, Shan D, Howell-Clark J, . 1996. Comparative metabolism and retention of iodine-125, yttrium-90, and indium-111 radioimmunoconjugates by cancer cells. Cancer Res 56:2123–2129.8616860
Preston RL. 1994. Serum inorganic iodine dynamics in cattle following a single oral dose of several iodine sources. FASEB J 8(4–5):A431.
Preuschof L, Keller F, Bogner U, . 1991. Plasma exchange and hemoperfusion in iodine-induced thyrotoxicosis. Blood Purif 9:164–168.1801858
*Prichard HM, Gesell TF Davis E. 1981. Iodine-131 levels in sludge and treated municipal waste waters near a large medical complex. AJPH 71:47–52.
Primack A. 1971. Potassium iodide interatction with cyclophosphamide in mice. Proc Soc Exp Biol Med 137(2):604–606.
Prinz RA, Oslapas R, Hofmann C, . 1982. Long-term effect of radiation on thyroid function and tumor formation. J Surg Res 32:329–337.7070081
*Prisyazhiuk A, Pjatak OA, Buzanov VA, . 1991. Cancer in the Ukraine, post-Chernobyl. Lancet 338(8878):1134–1135.
Pyati SP, Ramamurthy RS, Krauss MT, . 1977. Absorption of iodine in the neonate following topical used of povidone iodine. J Pediatr 91(5):825–828.909027
*Que Hee SS, Boyle JR. 1988. Simultaneous multielemental analysis of some environmental and biological samples by inductively coupled plasma atomic emission spectrometry. Anal Chem 60:1033–1042.3407946
*Quimby EH, Werner SC, Schmidt C. 1950. Influence of age, sex, and season upon radioiodine uptake by the human thyroid. Proc Soc Exp Biol Med 75:537–543.14808317
Rädlinger G, Heumann KG. 1998. Iodine determination in food samples using inductively coupled plasma isotope dilution mass spectrometry. Anal Chem 70:2221–2224.9624896
*Rädlinger G, Heumann KG. 2000. Transformation of iodine in natural and wastewater systems by fixation on humic substances. Environ Sci Technol 34:3932–3936.
Radvila A, Roost R, Burgi H, . 1976. Inhibition of thyroglobulin biosynthesis and degradation by excess iodide. Synergism with lithium. Acta Endocrinol 81:495–506.
*Rae JE, Malik SA. 1996. The determination of iodine in geochemical samples: The use of pyrohydrolytic decomposition. Chemosphere 33(11):2121–2128.
*Raghavendran KV, Satbhai PD, Abhyankar B, . 1978. Long-term retention studies of ^131^I and ^137^Cs and ^60^Co in Indian workers. Health Phys 34:185–188.632098
*Rajatanavin R, Safran M, Stoller WA, . 1984. Five patients with iodine-induced hyperthyroidism. Am J Med 77:378–384.6235747
Rajendran VM, Geibel J, Binder HJ. 1995. Chloride-dependent Na-H exchange. J Biol Chem 270(19):11051–11054.7744735
*Rallison ML. 1996. Thyroid neoplasia from fallout near the Nevada test site. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, the Netherlands: Elsevier, 147–154.
*Rallison ML, Dobyns BM, Keating FR, . 1974. Thyroid disease in children: A survey of subjects potentially exposed to fallout radiation. Am J Med 56:457–463.4818412
Rallison ML, Dobyns BM, Keating R, . 1975. Thyroid nodularity in children. JAMA 233(10):1069–1072.1174152
*Rallison ML, Lotz TM, Bishop M, . 1990. Cohort study of thyroid disease near the Nevada test site: A preliminary report. Health Phys 59(5):739–746.2211127
Ramírez MJ, Peurto S, Galofre P, . 2000. Multicolour FISH detection of radioactive iodine-induced 17cen-p53 chromosomal breakage in buccal cells from therapeutically exposed patients. Carcinogenesis 21(8):1581–1586.10910962
*Ramírez MJ, Surralles J, Galofre P, . 1997. Radioactive iodine induces clastogenic and age-dependent aneugenic effects in lymphocytes of thyroid cancer patients as revealed by interphase FISH. Mutagenesis 12(6):449–455.9412999
Ramírez MJ, Surralles J, Galofre P, . 1999. FISH analysis of 1cen-1q12 breakage, chromosome 1 numerical abnormalities and centromeric content of micronuclei in buccal cells from thyroid cancer and hyperthyroidism patients treated with radioactive iodine. Mutagenesis 14(1):121–127.10474833
*Ramsden D, Passant FH, Peabody CO, . 1967. Radioiodine uptakes in the thyroid: Studies of the blocking and subsequent recovery of the gland following the administration of stable iodine. Health Phys 13:633–646.6035213
Ranganathan S, Reddy V. 1995. Human requirements of iodine & safe use of iodized salt. Indian J Med Res 102:227–232.8675243
Rani CSS, Field JB. 1988. Comparison of effects of thyrotropin, phorbol esters, norepinephrine, and carbachol on iodide organification in dog thyroid slices, follicles, and cultured cells. Endocrinol 122:1915–1922.
Rao DV, Narra VR, Howell RW, . 1989. In-vivo radiotoxicty of DNA-incorporated ^125^I compared with that of densely ionising alpha-particles. Lancet 2:650–653.2570902
Rao DV, Narra VR, Howell RW, . 1990. Biological consequence of nuclear versus cytoplasmic decays of ^125^I: Cysteamine as a readioprotector against auger cascades in vivo. Radiat Res 124:188–193.2247599
Rapoport B, Spaulding SW. 1996. Mechanism of action of thyrotropin and other thyroid growth factors. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 207–219.
Rapoport B, Adams RJ, Rose M. 1977. Cultured thyroid cell adenosine 3’,5’-cyclic monophosphate response to thyrotropin: Loss and restoration of sensitivity to iodide inhibition. Endocrinology 100:755–764.233822
Rapoport B, Caplan R, DeGroot LJ. 1973. Low-dose sodium iodide I 131 therapy in Graves disease. JAMA 224(12):1610–1613.4122436
Rapoport B, West MN, Ingbar SH. 1976. On the mechanism of inhibition by iodine of the thyroid adenylate cyclase response to thyrotropic hormone. Endocrinol 99:11–22.
Rasmussen AK, Nygaard B, Feldt-Rasmussen U. 2000. ^131^I and thyroid-associated ophthalmopathy. Eur J Endocrinol 143(2):155–160.10913933
*Rasmussen RA, Khalil MAK, Gunwardenena R . 1982. Journal of Geophysical Research 87:3086–3090.
Rasmussen SN, Hjorth L. 1974. Determination of thyroid volume by ultrasonic scanning. J Clin Ultrasound 2(2):143–147.4211917
*Rasooly L, Burek CL, Rose NR. 1996. Iodine-induced autoimmune thyroiditis in NOD-H-2^h4^ mice. Clin Immunol Immunopathol 81(3):287–292.8938107
Raspe E, Dumont JE. 1994. Control of the dog thyrocyte plasma membrane iodide permeability by the Ca^2+^-phosphatidylinositol and adenosine 3’,5’-monophosphate cascades. Endocrinol 135(3):986–995.
*Raspe E, Dumont JE. 1995. Tonic modulation of dog thyrocyte H_2_O_2_ generation and I^−^ uptake by thyrotropin through the cyclic adenosine 3’,5’-monophosphate cascade. Endocrinol 136(3):965–973.
Rebello AD, Herms FW, Wagener K. 1990. The cycling of iodine as iodate and iodide in a tropical estuarine system. Mar Chem 29:77–93.
Reddi OS. 1971. Long term genetic effects of ^131^I in mice. Indian J Med Res 59:1420–1423.5170662
Reddy AR, Kaul A. 1978. Microscopic dose distributions due to iodine isotopes in thyroid. Radiat Environ Biophys 15:229–239.746118
Reddy PP, Reddy SB, Ebenezer DN, . 1982. Response of male germ cells of mouse to acute and fractionated doses of ^131^I induced radiation. Can J Genet Cytol 24:817–820.7182062
Reed HL. 1996. Environmental influences on thyroid hormone regulation. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 259–265.
Reed RR. 1997. Thyroid-associated ophthalmopathy: Treatment. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 359–377.
Rees Smith B, McLachlan SM, Furmaniak J. 1988. Autoantibodies to the thyrotropin receptor. Endocrine Rev 9(1):106–121.3286231
Reeve TS, Hales IB, Smith KV, . 1973. Carcinoma of the thyroid in a patient treated with radioiodine for hyperthyroidism. Med J Aust 1:993–996.4716588
*Reifenhauser C, Heumann KG. 1990. Development of a definitive method for iodine speciation in aquatic systems. Fresenius J Anal Chem 336:559–563.
Reiners C. 1991. Radioiodine treatment of Basedow’s disease: Interference and influence factors, risk estimation. Exp Clin Endocrinol 97:275–285.1915645
Reiners C, Herrmann H, Schaffer R, . 1983. Incidence and prognosis of thyroid cancer with special regard to oncocytic carcinoma of the thyroid. Acta Endocrinol Suppl 252:18.
Reinhard W, Kohl S, Hollmann D, . 1998. Efficacy and safety of iodine in the postpartum period in an area of mild iodine deficiency. Eur J Med Res 3:203–210.9533929
*Reinhardt W, Luster M, Rudorff KH, . 1998. Effect of small doses of iodine on thyroid function in patients with Hashimoto’s thyroiditis residing in an area of mild iodine deficiency. Eur J Endocrinol 139:23–38.9703374
Reinhardt W, Paul TL, Allen EM, . 1988. Effect of l-thyroxine administration on the incidence of iodine induced and spontaneous lymphocytic thryoiditis in the BB/WOR rat. Endocrinology 122(3):1179–1181.3342751
Reish DJ, Geesey GG, Wilkes FG, . 1982. Marine and estuarine pollution. J Water Pollut Control Fed 54:786–812.
Revis NW, McCauley P, Holdsworth G. 1986. Relationship of dietary iodide and drinking water disinfectants to thyroid function in experimental animals. Environ Health Perspect 69:243–248.3816728
Ribela MTCP, Marone MMS, Bartolini P. 1999. Use of radioiodine urinalysis for effective thyroid blocking in the first few hours post exposure. Health Phys 76(1):11–16.9883942
Riccabona G, Zechmann W, Unterkircher S, . 1983. Epidemiology of thyroid cancer in an iodine deficient area during iodized salt prophylaxis. Acta Endocrinol Suppl 252:13.
Richards EM, Marcus RE. 1993. Acute promyelocytic leukaemia following radioiodine therapy. Clin Lab Haematol 15:55–58.8472497
Richards GE, Brewer ED, Conley SB, . 1981. Combined hypothyroidism and hypoparathryoidism in an infant after maternal ^131^I administration. J Pediatr 99(1):141–143.7195929
Riddle WR, Roselli RJ, Pou NA. 1990. Modeling flux of free and protein-bound radioisotopes into the pulmonary interstitium. J Appl Physiol 68(6):2434–2442.2384424
*Riedel C, Levy O, Carrasco N. 2001. Post-transcriptional regulation of the sodium/thyroid symporter by thyrotropin. J Biol Chem 276(24):21458–21463.11290744
Rieger G, Winkler R, Buchberger W, . 1995. Iodine distribution in a porcine eye model following iontophoresis. Ophthalmologica 209:84–87.7746651
*Riggs DS. 1952. Quantitative aspects of iodine metabolism. Pharmacol Rev 4:284–370.12993583
Riley RG, Zachara JM, Wobber FJ. 1992. Chemical contaminants on DOE lands and selection of contaminant mixtures for subsurface science research. Washington, DC: U.S. Department of Energy. DE 92 014 826.
Rillema JA, Marting C. 1998. Cyclic AMP impairs the PRL stimulation of iodide uptake into mouse mammary tissues. Proc Soc Exp Biol Med 219:37–40.9751220
*Rillema JA, Rowady DL. 1997. Characteristics of the prolactin stimulation of iodide uptake in mouse mammary gland explants. Proc Soc Exp Biol Med 215:366–369.9270719
Rillema JA, Yu TX. 1996. Prolactin stimulation of iodide uptake into mouse mammary gland explants. Am J Physiol 271(34):E879–E882.8944675
Rillema JA, Collins S, Williams CH. 2000a Prolactin stimulation of iodide uptake and incorporation into protein is polyamine-dependent in mouse mammary gland explants. Proc Soc Exp Biol Med 224(1):41–44.10782045
*Rillema JA, Yu TX, Jhiang SM. 2000b Effect of prolactin on sodium iodide symporter expression in mouse mammary gland explants. Am J Physiol Endocrinol Metab 279:E769–E772.11001757
Rink T, Schroth H-J, Holle L-H, . 1999. [Effects of iodine and thyroid hormones in inducing and treating Hashimoto’s thyroiditis.] Nuklearmedizin 38:144–149. (German)10488481
Ritter MA. 1981. The radiotoxicity of iodine-125 in ataxia telangiectasia fibroblasts. Biochim Biophys Acta 652:151–159.7213729
Rivera M, Teruel JL, Castano JC, . 1993. Iodine-induced sialadenitis: Report of 4 cases and review of the literature. Nephron 63:466–467.8459885
Rivkees SA, Sklar C, Freemark M. 1998. The management of Graves’ disease in children, with special emphasis on radioiodine treatment. J Clin Endocrinol Metab 83(11):3767–3776.9814445
Rivlin RS. 1996a. Vitamin metabolism in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s The thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 863–865.
Rivlin RS. 1996b. Vitamin metabolism in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 693–695.
Robbins J. 1983. Indications for using potassium iodide to protect the thyroid from low level internal irradiation. Bull N Y Acad Med 59(10):1028–1038.6582964
*Robbins J. 1996. Thyroid hormone transport proteins and the physiology of hormone binding. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 96–110.
Robbins J, Schneider AB. 2000. Thyroid cancer following exposure to radioactive iodine. Reviews in Endocrine & Metabolic Disorders 1(3):197–203.11705004
*Robbins J, Dunn JT, Bouville A, . 2001. Iodine nutrition and the risk from radioactive iodine: A workshop report in the Chernobyl long-term follow-up study. Thyroid 11(5):487–491.11396707
*Robens E, Aumann DC. 1988. Iodine-129 in the environment of a nuclear fuel reprocessing plant: I. 129I and ^127^I contents of soils, food crops and animal products. J Environ Radioact 7:159–175.
Robens E, Hauschild J, Aumann DC. 1988a. Iodine-129 in the environment of a nuclear fuel reprocessing plant: II. Iodine-129 and iodine-127 contents of soils, forage plants and deer thyroids. J Environ Radioact 7:265–274.
Robens E, Hauschild J, Aumann DC. 1988b. Iodine-129 in the environment of a nuclear fuel reprocessing plant: III. Soil-to-plant concentration factors for Iodine-129 and iodine-127 and their transfer factors to milk, eggs and pork. J Environ Radioact 7:37–52.
Robens-Palavinskas E, Hauschild J, Aumann DC. 1989. Iodine-129 in the environment of a nuclear fuel reprocessing plant: VI. Comparison of measurements of ^129^I concentrations in soil and vegetation with predictions from a radiological assessment model. J Environ Radioact 10:67–78.
*Robertson JS, Gorman CA. 1976. Gonadal radiation dose and its genetic significance in radioiodine therapy of hyperthyroidism. J Nucl Med 17:826–835.956897
*Robertson JS, Nolan NG, Wahner HW, . 1975. Thyroid radioiodine uptakes and scans in euthyroid patients. Mayo Clin Proc 50:79–84.1117757
Robinson GA, Easnidge DC, Floto F, . 1976. Ovarian ^125^I transference in the laying Japanese quail: Apparent stimulation by FSH and lack of stimulation by TSH. Poult Sci 55:1665–1671.1033539
*Robinson PS, Barker P, Campbell A, . 1994. Iodine-131 in breast milk following therapy for thyroid carcinoma. J Nucl Med 35:1797–1801.7965159
*Robison LM, Sylvester PW, Birkenfeld P, . 1998. Comparison of the effects of iodine and iodide on thyroid function in humans. J Toxicol Environ Health 55:93–106.
*Robkin MA, Shleien B. 1995. Estimated maximum thyroid doses from ^129^I releases from the Hanford site for the years 1944-1995. Health Phys 69(6):917–922.7493807
Robson AM. 1981. Vocal-cord paralysis after treatment of thyrotoxicosis with radioiodine. Br J Radiol 54:632.7260517
Roddy MT. 1975a. The effect of KI on the DUB/ICR strain mouse. Diss Abstr Int B 36(3):1034.
Roddy MT 1975b. The effect of KI on the DUB/ICR strain mouse. Ph.D. Dissertation, The Catholic University of America. 70 p.
*Rodeheaver G, Bellamy W, Kody M, . 1982. Bactericidal activity and toxicity of iodine-containing solutions in wounds. Arch Surg 117:181–186.7034678
Rodesch F, Rocmans P, Dumont JE. 1967. Stimulation of thyroidal radioiodine uptake by actinomycin D and fluorouracil-an indirect effect. Biochem Pharmacol 16:907–908.6036738
Rodrigues M, Havlik E, Peskar B, . 1998. Prostaglandins as biochemical markers of radiation injury to the salivary glands after iodine-131 therapy? Eur J Nucl Med 25(3):265–269.9580860
Rogahn J, Ryan S, Wells J. 2000. Randomised trial of iodine intake and thyroid status in preterm infants. Arch Dis Child Fetal Neonatal Ed 83(2):F86–F90.10952698
Rogau YI, Amvros’eu AP, Darokhina RI, . 1994. [Retardation of development of rat fetus by incorporation of iodine-131 isotopes during organogensis.] Vestsi Akad Navuk BSSR Ser Biyal Navuk 3:55–58. (Russian)
Rognoni JB, Lemarchand-Beraud T, Berthier C, . 1982. Effect of long-term iodide refeeding on the synthesis and secretion of T_3_, T_4_ and TSH in severe iodine deficient rats. Acta Endocrinol 101:377–385.
Rognoni JB, Lemarchand-Beraud T, Berthier C. 1984. Respective roles of circulating T_4_ and T_3_ in control of TSH secretion in severely iodide-deficient rats. Experientia 40:215–217.6698180
Roland DA, McCready ST, Stonerock RH, . 1977. Hypercalcemic effect of potassium iodide on serum calcium in domestic fowl. Poult Sci 56:1310–1314.605086
Romney BM, Nickoloff EL, Esser PD, . 1986. Radionuclide administration to nursing mothers: Mathematically derived guidelines. Radiology 160:549–554.3726137
Ron E. 1997. Cancer risk following radioactive iodine-131 exposures in medicine. In: Proceedings of the annual meeting of the National Council on Radiation Protection Measures: Implications of new data on radiation cancer risk. Bethesda, MD: National Cancer Institute, 65–77.
Ron E, Modan B. 1984. Thyroid and other neoplasms following childhood scalp irradiation. In: Boice KD, Fraument JF, eds. Radiation carcinogenesis: Epidemiology and biological significance. New York, NY: Raven Press, 139–151.
*Ron E, Doody MM, Becker DV, . 1998. Cancer mortality following treatment for adult hyperthyroidism. JAMA 280(4):347–355.9686552
*Ron E, Lubin JH, Shore RE, . 1995. Thyroid cancer after exposure to external radiation: A pooled analysis of seven studies. Radiat Res 141:259–277.7871153
Ron E, Modan B, Preston D, . 1989. Thyroid neoplasia following low-dose radiation in childhood. Radiat Res 120:516–531.2594972
*Rook HL, Suddueth JE, Becker DA. 1975. Determination of Iodine-129 at natural levels using neutron activation and isotopic separation. Anal Chem 47:1557–1561.1155777
Roos DE, Smith JG. 1999. Randomized trials on radioactive iodine ablation of thyroid remnants for thyroid carcinoma-a critique. Int J Radiat Oncol Biol Phys 44(3):493–495.10348276
Rosado M, Borrego LC, Paniagua ME. 1983. Incidence of hypothyroidism after radioiodine treatment for Graves disease. Bol Asoc Med P R 75(4):167–169.6575789
Rose MR, Prescott MC, Herman KJ. 1990. Excretion of iodine-123-hippuran, technetium-99m-red blood cells, and technetium-99m-macroaggregated albumin into breast milk. J Nucl Med 31(6):978–984.2348243
*Rose NR, Rasooly L, Saboori AM, . 1999. Linking iodine with autoimmune thyroiditis. Environ Health Perspect Suppl 107:749–752.10502541
*Rose NR, Saboori AM, Rasooly L, . 1997. The role of iodine in autoimmune thyroiditis. Crit Rev Immunol 17:511–517.9419438
*Rosen IB, Palmer JA, Rowen J, . 1984. Induction of hyperparathyroidism by radioactive iodine. Am J Surg 148:441–445.6486309
Rosen IB, Strawbridge HG, Bain J. 1975. A case of hyperparathyroidism associated with radiation to the head and neck area. Cancer 36:1111–1114.1182664
Rosenberg D, Grand MJH, Silbert D. 1963. Neonatal hyperthyroidism. N Engl J Med 268(6):292–296.13974884
*Rosenberg FR, Einbinder J, Walzer RA, . 1972. Vegetating iododerma. Arch Dermatol 105:900–905.4260541
Rosenberg G. 1958. Biologic half-life of I^131^ in the thyroid of healthy males. J Clin Endocrinol Metab 18:516–521.13539164
Rosenthal D. 1981. Kinetic analysis of iodine and thyroxine metabolism in “hot” thyroid nodules. Metabolism 30(4):384–392.7207211
Ross DS. 1996a. Subclinical hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 1010–1015.
Ross DS. 1996b. Subclinical thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 1016–1020.
Ross DS. 1998. Syndromes of thyrotoxicosis with low radioactive iodine uptake. Endocrinol Metab Clin North Am 27(1):169–185.9534035
Ross DS, Daniels GH, De Stefano P, . 1983. Use of adjunctive potassium iodide after radioactive iodine (^131^I) treatment of Graves’ hyperthyroidism. J Clin Endocrinol Metab 57(2):250–253.6688081
Rothschild HC. 1974. A criteria digest on radioactivity in the environment. Ottawa, Canada: National Research Council Canada.
*Roti E, Uberti E. 2001. Iodine excess and hyperthyroidism. Thyroid 11(5): 493–500.11396708
*Roti E, Vagenakis AG. 2000. Effect of excess iodide: Clinical aspects. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Williams and Wilkins, 316–329.
Roti E, Gnudi A, Braverman LE. 1983. The placental transport, synthesis and metabolism of hormones and drugs which affect thyroid function. Endocrine Rev 4:131–149.6190648
Roti E, Minelli R, Gardini E, . 1990. Iodine-induced hypothyroidism in euthyroid subjects with a previous episode of subacute thyroiditis. J Clin Endocrinol Metab 70:1581–1585.2112151
Roti E, Minelli R, Gardini E, . 1992. Iodine-induced subclinical hypothyroidism in euthyroid subjects with a previous episode of amiodarone-induced thyrotoxicosis. J Clin Endocrinol Metab 75(5):1273–1277.1331165
Roudebush CP, Hoye KE, DeGroot LJ. 1977. Compensated low-dose ^131^I therapy of Graves’ disease. Ann Intern Med 87:441–443.578665
*Royaux IE, Suzuki K, Mori A, . 2000. Pendrin, the protein encoded by the Pendred Syndrome gene (PDS), is an apical porter of iodide in the thyroid and is regulated by thyroglobulin in FRTL-5 cells. Endocrinology 141(2):839–845.10650967
Rozenson R, Gusev B, Hoshi M, . 1996. A brief summary of results of radiation studies on residents in the Semipalatinsk area, 1957-1993. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, The Netherlands: Elsevier, 127–145.
Rubery ED. 1990. Practical aspects of prophylactic stable iodine usage. In: Rubery E, Smales E, eds. Iodine prophylaxis following nuclear accidents. Oxford, UK: Pergamon Press, 141–150.
*Rubow S, Klopper J, Wasserman H, . 1994. The excretion of radiopharmaceuticals in human breast milk: Additional data and dosimetry. Eur J Nucl Med 21:144–153.8162938
Ruegsegger GJ, Schultz LH. 1980. Iodine in field milk samples [Abstract]. J Dairy Sci 63(Suppl 1):115.
Ruiz De Ona C, Obregon MJ, Escobar Del Rey F, . 1988. Developmental changes in rat brain 5’-deiodinase and thyroid hormones during the fetal period: The effects of fetal hypothyroidism and maternal thyroid hormones. Pediatr Res 24(5):588–594.3205610
Russell JL, Hahn PB. 1971. Public health aspects of iodine-129 from the nuclear power industry. Radiol Health Data Rep 12(4):189–194.5567296
*Russell KP, Rose H, Starr P. 1957. The effects of radioactive iodine on maternal and fetal thyroid function during pregnancy. Surg Gynecol Obstet 104:560–564.13433252
*Ruwhof C, Drexhage HA. 2001. Iodine and thyroid autoimmune disease in animal models. Thyroid 11(5):427–436 11396701
Rybakowa M, Tylek D, Soltysik-Wilk E, . 1991. [Epidemiologic study in children from the Krakow region following the Chernobyl accident.] Endokrynol Pol 42(2):253–261. (Polish)1364477
*Saboori AM, Rose NR, Bresler HS . 1998a. Iodination of human thyroglobulin (Tg) alters its immunoreactivity. I. Iodination alters multiple epitopes of human Tg. Clin Exp Immunol 113:297–302.9717981
*Saboori AM, Rose NR, Burek CL. 1998b. Iodination of human thyroglobulin alters its immunoractivity. II. Fine specificity of a monoclonal antibody that recognizes iodinated thyroglobulin. Clin Exp Immunol 113:303–308.9717982
*Saboori AM, Rose NR, Yuhasz SC, Amzal M, Burek CL. 1999. Peptides of human thyrogolbulin reactive with sera of patients with autoimmune thyroid disease. J Immunol 163:6244–6250.10570317
*Sachs BA, Siegel E, Horwitt BN, . 1972. Bread iodine content and thyroid radioiodine uptake: A tale of two cities. Br Med J 1:79–81.5007073
Saddok C, Gafni M, Gross J. 1978. Effect of iodide on the adenyl cyclase system of the mouse thyroid in vivo. Acta Endocrinol 88:517–527.
Safa A, Schumacher OP. 1976. Follow-up of children treated with ^131^I. N Engl J Med 294(1):54.
Safa AM, Skillern PG. 1975. Treatment of hyperthyroidism with a large initial dose of sodium iodide I 131. Arch Intern Med 135:673–675.1053273
Safa AM, Schumacher OP, Rodriguez-Antunez A. 1975. Long-term follow-up results in children and adolescents treated with radioactive iodine (^131^I) for hyperthyroidism. N Engl J Med 292:167–171.45842
*Safran M, Braverman LE. 1982. Effect of chronic douching with polyvinylpyrrolidone-iodine on iodine absorption and thyroid function. Obstet Gynecol 60(1):35–40.7088448
*Safran M, Paul TL, Roti TL, . 1987. Environmental factors affecting autoimmune thyroid disease. Endocrinol Metab Clin N Am 16(2): 327–342.
Saito K, Kaneko H, Sato K, . 1991. Hepatic UDP-glucuronyltransferase(s) activity toward thyroid hormones in rats: Induction and effects on serum thyroid hormone levels following treatment with various enzyme inducers. Toxicol Appl Pharmacol 111:99–106.1949040
Saito K, Yamamoto K, Takai T, . 1983. Inhibition of iodide accumulation by perchlorate and thiocyanate in a model of the thyroid iodide transport system. Acta Endocrinol 104(4):456–461.
Saji M, Kohn LD. 1990. Effect of hydrocortisone on the ability of thyrotropin to increase deoxyribonucleic acid synthesis and iodide uptake in FRTL-5 rat thyroid cells: Opposite regulation of adenosine 3’,5’-monophosphate signal action. Endocrinology 127(4):1867–1876.2169405
Saji M, Kohn LD. 1991. Insulin and insulin-like growth factor-I inhibit thyrotropin-increased iodide transport in serum-depleted FRTL-5 rat thyroid cells: Modulation of adenosine 3’,5’-monophosphate signal action. Endocrinology 128:1136–1143.1846578
Saji M, Isozaki O, Tsushima T, . 1988. The inhibitory effect of iodide on growth of rat thyroid (FRTL-5) cells. Acta Endocrinol 119:145–151.
*Salbu B, Steinnes E, Pappas AC. 1975. Multielement neutron activation analysis of fresh water using Ge(Li) gamma spectrometry. Anal Chem 47:1011–1016.
*Saller B, Fink H, Mann K. 1998. Kinetics of acute and chronic iodine excess. Exp Clin Endocrinol Diabetes 106(Suppl 3):S34–S38.
Samuel AM, Unnikrishnan TP, Baghel NS, . 1995. Effect of radioiodine therapy on pulmonary alveolar-capillary membrane integrity. J Nucl Med 36:783–787.7738648
Samuel S, Pildes RS, Lewison M, . 1971. Neonatal hyperthyroidism in an infant born of an euthyroid mother. Am J Dis Child 121:440–443.4103882
Santana C, Burek CL, Talor M, . 1997. Evaluation of thyroid glands from NOD-H-2^h-4^ mice with iodine-induced thryoiditis [Abstract]. Mol Biol Cell 8(Suppl):453A.
Santisteban P, Obregon MJ, Rodriguez-Pena A, . 1982. Are iodine-deficient rats euthyroid? Endocrinology 110(5):1780–1789.6804212
Sapozink MD, Palos B, Goffinet DR, . 1983. Combined continuous ultra low dose rate irradiation and radiofrequency hyperthermia in the C3H mouse. Int J Radiat Oncol Biol Phys 9:1357–1365.6885549
Sarkar SD, Beierwaltes WH, Gill SP, . 1976. Subsequent fertility and birth histories of children and adolescents treated with ^131^I for thyroid cancer. J Nucl Med 17:460–464.944243
Sasaki H, Matsumoto S, Shuyo H, . 1992. Gross ascites as a first manifestation of primary hypothyroidism due to post-treatment of radioiodine therapy for Graves’ disease. Intern Med 31:256–259.1600276
Sastry KSR. 1992. Biological effects of the Auger emitter iodine-125: A review. Report No. 1 of AAPM Nuclear Medicine Task Group No. 6. Med Physics 19(6):1361–1370.
Sato A, Ohtake M, Kotani M, . 1972. Effects of methimazole and propylthiouracil on blood disappearance and urinary excretion of iodide in the rat. Proc Soc Exp Biol Med 141(1):119–122.5082284
Sato K, Robbins J. 1981. Thyroid hormone metabolism in primary cultured rat hepatocytes. J Clin Invest 68:475–493.7021591
Sato T, Inoue M, Suzuki Y, . 1975. [Hypothyroidism caused by 131I contained in mothers’ milk: Its association with polycystic ovary and kidney calculus.] Horumon To Rinsho 23(6):535–538. (Japanese)1173794
*Savoie JC, Massin JP, Thomopoulos P, . 1975. Iodine-induced thyrotoxicosis in apparently normal thyroid glands. J Clin Endocrinol Metab 41:685–691.1176580
Sawers JSA, Toft AD, Irvine WJ, . 1980. Transient hypothyroidism after iodine-131 treatment of thyrotoxicosis. J Clin Endocrinol Metab 50:226–229.7354108
Sawin CT, Castelli WP, Hershman JM, . 1985. The aging thyroid: Thyroid deficiency in the Framingham study. Arch Intern Med 145:1386–1388.4026469
*Saxena Km, Chapman EM, Pryles CV. 1962. Minimal dosage of iodide required to suppress uptake of iodine-131 by normal thyroid. Science 138:430–431.13986973
Scanlon MF, Toft AD. 1996. Regulation of thyrotropin secretion. In: Braverman LE, Utiger RD, eds. Warner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 220–240.
Schaffer R, Muller HA, Ebelt R. 1983. Distribution pattern of malignant thyroid tumors in an endemic goitre area. Acta Endocrinol Suppl 252:13–14.
*Schaug J, Rambaek JP, Steinnes E, . 1990. Multivariate analysis of trace element data from moss samples used to monitor atmospheric deposition. Atmos Environ 24A(10):2625–2631.
Scherbaum WA. 1996. Iodine-induced thyroiditis in the non-obese diabetic (NOD) mouse-more questions than answers. Exp Clin Endocrinol Diabetes 104(Suppl 3):20–23.
Scheuttelkopf H. 1979. [Radioecological reduction of acute and long-term contamination of the environment by iodine-129]. (German). In: Kernforshungszent. Karlsruhe, [Ber.] KFK, KFK 2770, Samml. Vortr. Jahreskolloquim 1978 Proj Nukl Sicherheit, 206–225.
Schilling YR, Abellan F, Escribano JRD, . 1998. Acute leukemias after treatment with radioiodine for thyroid cancer. Haematologica 83(8):767–768.9793274
Schlenker RA. 1985. Internal emitter limits for iodine, radium and radon daughters. Proc Annu Meet Natl Counc Radiat Prot Meas 6:131–181.
Schlumberger MJ. 1988. Papillary and follicular thyroid carcinoma. N Engl J Med 338(5):297–306.
Schlumberger M, Caillou B. 1996. Miscellaneous tumors of the thyroid. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 961–965.
Schlumberger M, De Vathaire F. 1996. [131 Iodine: Medical use. Carcinogenetic and genetic effects.] Ann Endocrinol (Paris) 57:166–167. (French)8949411
Schlumberger M, De Vathaire F, Ceccarelli C, . 1996. Exposure to radioactive iodine-131 for scintigraphy or therapy does not preclude pregnancy in thyroid cancer patients. J Nucl Med 37(4):606–612.8691249
Schlumberger M, Parmentier N, Chavaudra J, . 1988. [Management in cases of accidental contamination by iodine radioisotopes.] Presse Med 17(8):386–388. (French)2966371
Schlumberger M, Parmentier C, de Vathaire F, . 1997. Iodine-131 and external radiation in the treatment of local and metastatic thyroid cancer. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 601–617.
*Schmidt A, Schnabel C, Handle J, . 1998. On the analysis of iodine-129 and iodine-127 in environmental materials by accelerator mass spectrometry and ion chromatography. Sci Total Environ 223:131–156.9861732
*Schmitt TL, Espinoza CR, Loos U. 2000. Cloning and characterization of repressory and stimulatory DNA sequences upstream the Na/I-symporter gene promoter. Horm Metab Res 32(1):1–5.10727005
*Schmitt TL, Espinoza CR, Loos U. 2001. Transcriptional regulation of the human sodium/iodide symporter gene by Pax8 and TTF-1. Exp Clin Endocrinol Diabetes 109(1):27–31.11573135
Schmucki O, Sulmoni A, Pupato F. 1973. [Late bladder complications after radioactive iodine therapy of thyroid tumors.] Urologe A 12(3):130–133. (German)4751627
Schmutzler C. 2001. Regulation of the sodium/iodide symporter by retinoids-a review. Exp Clin Endocrinol Diabetes 109(1):41–44.11573138
Schneeweiss FHA, Myers DK, Tisljar-Lentulis G, . 1985. Low oxygen enhancement ratios for strand breaks induced by decays of ^125^I in DNA of human T1 cells stored at 0 degrees C. Radiat Prot Dosim 13(1–4):237–239.
Schneider AB, Ron E. 1996. Carcinoma of follicular epithelium. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 902–909.
Schneider AB, Gierlowski TC, Shore-Freedman E, . 1995. Dose-response relationships for radiation-induced hyperparathyroidism. J Clin Endocrinol Metab 80(1):254–257.7829622
Schneider AB, Recant W, Pinsky SM, . 1986. Radiation-induced thyroid carcinoma. Ann Intern Med 105:405–412.3740680
Schneider AB, Ron E, Lubin J, . 1993. Dose-response relationships for radiation-induced thyroid cancer and thyroid nodules: Evidence for the prolonged effects of radiation on the thyroid. J Clin Endocrinol Metab 77(2):362–369.8345040
Schneider AB, Shore-Freedman E, Ryo UY, . 1985. Radiation-induced tumors of the head and neck following childhood irradiation. Medicine 64(1):1–15.3965855
Schneppe MM. 1972. Determination of total iodine and iodate in sea water and in various evaporites. Anal Chim Acta 58:83–89.
Schnyder UW, Taugner M, Rossbach J. 1969. [Histology of pathological iodine reactions of the skin.] Dermatologica 139(4):266–270. (German)5374665
Schober O, Gunter H-H, Schwazrock R, . 1987. [Hematologic long-term modifications after radio-iodine therapy of the carcinoma of the thyroid gland: I. Peripheral blood count modifications.] Strahlenther Onkol 163:464–474. (German)3616905
Schreiber G, Southwell BR, Richardson SJ. 1995. Hormone delivery systems to the brain-transthyretin. Exp Clin Endocrinol 103:75–80.
Schreiber V, Rohacova J. 1971. Increase in thyroid radioiodine uptake following the administration of cyproterone acetate. Experientia 27(7):848–849.5139514
Schroder-van der Elst JP, van der Heide D, Kastelijn J, . 2001. The expression of the sodium/iodide symporter is up-regulated in the thyroid of fetuses of iodine-deficient rats. Endocrinology 142(9):3736–3741.11517148
*Schull WJ, Otake M, Yoshimaru H. 1988. Effect on intelligence test score of prenatal exposure to ionizing radiation in Hiroshima and Nagasaki: A comparison of the T65DR and DS86 dosimetry systems. Radiation Effects Research Foundation. RERF TR 3-88. Research project 24-62.
*Schuppert F, Ehrenthal D, Frilling A, . 2000. Increased major histocompatibility complex (MHC) expression in nontoxic goiters is associated with iodide depletion, enhanced ability of the follicular thyroglobulin to increase MHC gene expression, and thyroid antibodies. J Clin Endocrinol Metab 85(2):858–867.10690902
Schurizek BA, Kraglund K, Andreasen F, . 1989. Antroduodenal motility and gastric emptying. Gastroduodenal motility and pH following ingestion of paracetamol. Aliment Pharmacol Ther 3:93–101.2491461
Schwarz G, Hoffman FO. 1979. Imprecision of dose predictions for radionuclides released to the atmosphere: An application of the Monte-Carlo-Simulation-Technique for iodine transported via the pasture-cow-milk pathway. Presented at the 1979 Winter Meeting of the American Nuclear Society, November 11-16, 1979. San Francisco, California. CONF-791103–48.
Schwarzfischer P, Harlass G, Kreul H-G, . 1981. [Iodine induced hyperthyroidism in old age. Part 1: Multimorbidity, autonomous tissue and possibilities for iodine contamination.] Fortschr Med 99(44):1834–1838. (German)7308948
Schwarzfischer P, Harlass G, Kreul H-G, . 1982. [Iodine-induced hyperthyroidism in the aged. 2. Pathomechanism, differential diagnosis and therapy problems.] Fortschr Med 100(5):153–158. (German).7076085
*Scott DA, Wang R, Kreman TM, . 2000. Functional differences of the PDS gene product are associated with phenotypic variation in patients with Pendred syndrome and non-syndromic hearing loss (DFNB4). Hum Mol Gen 9(11):1709–1715.10861298
Scott GR, Forfar JC, Toft AD. 1984. Graves’ disease and atrial fibrillation: The case for even higher doses of therapeutic iodine-131. Br Med J 289:399–400.6432116
Scully JM, Uno JM, McIntyre M, . 1990. Radiation-induced prostatic sarcoma: A case report. J Urol 144:746–748.2388344
*Seabold JE, Ben-Haim S, Pettit WA, . 1993. Diuretic-enhanced I-131 clearance after ablation therapy for differentiated thyroid cancer. Radiology 187:839–842.8497641
Sedelnikova OA, Panyutin IG, Thierry AR, . 1998. Radiotoxicity of iodine-125-labeled oligodeoxyribonucleotides in mammalian cells. J Nucl Med 39(8):1412–1418.9708519
Segers O, Musch W, Schoors DF. 1993. Early complications of radioiodine treatment for hyperthyroidism. Acta Clin Belg 48(4):253–258.8212977
*Segers O, Spapen H, Steenssens L, . 1988. Treatment of severe iodine-induced hyperthyroidim with plasmapheresis. Acta Clin Belg 43:335–343.2462773
Segura ET, Roussel JD, Satterlee DG, . 1979. Interaction of exogenous corticotropin and environment on protein bound iodine and other plasma biochemical parameters. J Dairy Sci 62:278–283.222818
*Sekura RD, Sato K, Cahnmann HJ, . 1981. Sulfate transfer to thyroid hormones and their analogs by hepatic aryl sulfotransferases. Endocrinology 108(2):454–456.6778682
Self GJ, Rigby PJ, Passarelli MC, . 1990. Characteristics and localisation of ^125^I ion binding in mammalian airways. Eur J Pharmacol 176:169–176.2311664
Senczuk W, Slusarek D. 1981. [Effect of detergents on iodophor toxicity. I. Effect of detergents on acute toxicity and iodophor cumulation coefficient.] Rocz Panstw Zakl Hig 32(3):197–200. (Czech.)7313460
Senczuk W, Slusarek D. 1982. [Effect of detergents on iodophor toxicity. III. Effect of detergents on iodine absorption into blood, retention in the organs and urinary excretion.] Rocz Panstw Zakl Hig 33(3):207–213. (Czech.)7146776
Senczuk W, Slusarek D, Sadowski C. 1982. [Effect of detergents on iodophor toxicity. IV. Iodine content of the blood, urine and tissues of animals exposed to the long-term action of iodophor.] Rocz Panstw Zakl Hig 33(4):307–309. (Czech.)7170594
Senekowitsch R, Kriegel H. 1984. Diaplacental transfer and distribution of some radionuclides in fetal organs at different stages of gestation - experimental results. EUR 8067:183–197.
Senior B, Chernoff HL. 1971. Iodide goiter in the newborn. Pediatrics 47(3):510–515.4251257
*Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Shafer RB, Nuttall FQ. 1975. Acute changes in thyroid function in patients treated with radioactive iodine. Lancet 2(7936):635–637.52005
Shah DH, Patel MC, Sulkhe PV. 1969. Effect of actinomycin D on the uptake of radioiodine by thyroidal and extrathyroidal tissues-I. Biochem Pharmacol 18:1487–1493.5799119
Shah KH, Oslapas R, Calandra DB, . 1983. Effects of radiation on parafollicular C cells of the thyroid gland. Surgery 94(6):989–994.6648815
Shanshiashvill TA, Gracheva LM. 1981. Genetic effects of decay of radionuclde products of division of nucleofuel in cells of the yeast saccharomyces cerevisiae. Role of transmutation: I. Lethal mutagenic effects and the nature of mutations induced by yttrium-91 decay. Sov Genet 17:1370–1376. Translation of Genetika, 17(12):2115–2124.
Shao J, Chen Q, Guo C, . 1995. [Effect of lithium on iodine uptake in thyroid cells in culture.] Zhonghua Heyixue Zazhi 15(4):242–244. (Chinese)
Shapiro B. 1993. Optimization of radioiodine therapy of thyrotoxicosis: What have we learned after 50 years? J Nucl Med 34(10):1638–1644.8410274
Sheeler LR, Skillern PG, Schumacher OP, . 1984. Radioiodine-induced thyroid storm: A point of controversy. Am J Med 76(4):A98.6546834
Sheldon J. 1983. Effects of amiodarone in thyrotoxicosis. Br Med J 286:267–268.6402067
*Shelly WB. 1967. Generalized pustular psoriasis induced by potassium iodide. JAMA 201(13):133–138.
*Shen DHY, Kloos RT, Mazzaferri EL, Jhiang SM. 2001. Sodium iodide symporter in health and disease. Thyroid 11(5):415–425.11396700
Shennan DB. 2001. Iodine transport in lactating rat mammary tissues via a pathway independent from the Na^+^/I^−^ cotransporter: evidence for sulfate/iodide exchange. Biochem Biophys Res Commun 280(5):1359–1363.11162679
Sheppard MI, Hawkins JL. 1995. Iodine and microbial interactions in an organic soil. J Environ Radioact 29(2):91–109.
Sheppard MI, Thibault DH. 1988. Migration of technetium, iodine, neptunium, and uranium in the peat of two minerotrophic mires. J Environ Qual 17(4):644–653.
Sheppard MI, Thibault DH. 1991. A four-year mobility study of selected trace elements and heavy metals. J Environ Qual 20:101–114.
*Sheppard MI, Thibault DH, Mcmurry J, . 1995. Factors affecting the soil sorption of iodine. Water Air Soil Pollut 83:51–67.
Sheppard SC. 1995. When does chemical toxicity of ^129^I become important? In: Environmental impact of radioactive releases: Proceedings of an international symposium on environmental impact of radioactive releases. Vienna, Austria: International Atomic Energy Agency, 837–883.
Sheppard SC, Evenden WG. 1995. Toxicity of soil iodine to terrestrial biota, with implications for ^129^I. J Environ Radioact 27(2):99–116.
*Sheppard SC, Evenden WG, Amiro BD. 1993. Investigation of the soil-to-plant pathway for I, Br, Cl and F. J Environ Radioact 21:9–32.
*Sheppard SC, Evenden WG, Schwartz WJ. 1995. Ingested soil: Bioavailability of sorbed lead, cadmium, cesium, iodine, and mercury. J Environ Qual 24:498–505.
Sherer TT, Thrall KD, Bull RJ. 1991. Comparison of toxicity induced by iodine and iodide in male and female rats. J Toxicol Environ Health 32:89–101.1987365
*Sheridan PJ, Zoller WH. 1989. Elemental composition of particulate material sampled from the Arctic haze aerosol. J Atmos Chem 9:363–381.
Sherwin JR. 1978. Iodide induced suppression of thyrotropin-stimulated adenosine 3’,5’-monophosphate production in cat thyroid slices. Horm Res 9:271–278.210098
Sherwin JR, Seaford JW. 1986. Effect of valinomycin on thyroid iodide transport and TSH-stimulated cAMP formation. Am J Physiol 250(13):E164–E168.3006501
*Shetty KR, Duthie EH. 1990. Thyrotoxicosis induced by topical iodine application. Arch Intern Med 150:2400–2401.2241453
Shevchenko VA, Ramaya LK, Pomerantseva MD, . 1989. Genetic effects of ^131^I in reproductive cells of male mice. Mutat Res 226:87–91.2733721
Shibuya M. 1991. Studies on the iodine-binding factors of human parotid saliva. Shika Gakuho 91(12):1587–1603.
*Shilo S, Hirsch HJ. 1986. Iodine-induced hyperthyroidism in a patient with a normal thyroid gland. Postgrad Med J 62:661–662.3748931
Shimizu T, Shishiba Y. 1975. Effect of triidothyronine or iodide on the thyroidal secretion in vitro: Inhibition of TSH- and dibutyryl-cyclic-AMP induced endocytosis. Endocrinol Jpn 22(1):55–60.165072
Shimon I, Kneller A, Olchovsky D. 1995. Chronic myeloid leukaemia following ^131^I treatment for thyroid carcinoma: A report of two cases and review of the literature. Clin Endocrinol 43:651–654.
Shimura H, Endo T, Tsujimoto G, . 1990. Characterization of alpha_1_-adrenergic receptor subtypes linked to iodide efflux in rat FRTL cells. J Endocrinol 124:433–441.2159046
*Shimura H, Haraguchi K, Miyazaki A, . 1997. Iodide uptake and experimental ^131^I therapy in transplanted undifferentiated thyroid cancer cells expressing the Na^+^/I^−^ symporter gene. Endocrinology 138(10):4493–4496.9322970
Shinohara K. 1994. [A preliminary study on the effects of start age of uptake on dose assessment for chronic ingestion of radionuclides.] Hoken Butsuri 29(2):201–205. (Japanese)
*Shinonaga T, Gerzabek MH, Strebl F, . 2001. Transfer of iodine from soil to cereal grains in agricultural areas of Austria. Sci Total Environ 267(1–3):33–40.11286214
*Shipler DB, Napier BA, Farris WT, . 1996. Hanford environmental dose reconstruction project - an overview. Health Phys 71:532–544.8830754
Shishiba Y, Solomon DH. 1967. Effect of amphotericin B on thyroidal iodide concentration. Endocrinology 81:467–474.4226711
Shleien B, Halperin JA, Bilstad JM, . 1983. Recommendations on the use of potassium iodide as a thyroid-blocking agent in radiation accidents: An FDA update. Bull N Y Acad Med 59(10):1009–1019.6582962
Sho FK, Kondo Y. 1988. Inhibition by islet-activating protein, pertussis toxin, of P_2_-purinergic receptor-mediated iodide efflux and phosphoinositide turnover in FRTL-5 cells. Endocrinology 123(2):1035–1043.2840260
Sho K, Okajima F, Akiyama H, . 1989. Requirement of insulin growth factor I plus hydrocortisone for the regeneration of thyrotropin (TSH)-dependent mechanism of I^−^ efflux and CA^2+^ mobilization in FRTL-5 cells during TSH depletion. Endocrinology 124:598–604.2536314
Shopsin B, Shenkman L, Blum M, . 1973. Iodine and lithium-induced hypothyroidism: Documentation of synergism. Am J Med 55:695–699.4749208
Shore RE. 1989. Risk of thyroid cancer after diagnostic doses of radioiodine. J Natl Cancer Inst 81(9):713–715.2757687
*Shore RE. 1992. Issues and epidemiological evidence regarding radiation-induced thyroid cancer. Radiat Res 131:98–111.1385649
Shore RE, Albert RE, Pasternack BS. 1976. Follow-up study of patients treated by x-ray epilation for tinea capitis. Arch Environ Health 31:14–24.
Shore RE, Hildreth N, Dvoretsky P, . 1993a. Benign thyroid adenomas among persons x-irradiated in infancy for enlarged thymus glands. Radiat Res 134:217–223.8488255
Shore RE, Hildreth N, Dvoretsky P, . 1993b. Thyroid cancer among persons given x-ray treatment in infancy for an enlarged thymus gland. Am J Epidemiol 137(10):1068–1080.8317436
Sichuk G, Money WL, Der BK, . 1968. Cancer of the thyroid, goitrogenesis and thyroid function in Syrian (golden) hamsters. Cancer 21(5):952–963.4172049
Siegemund B, Weyers W. 1987. [Teratological studies of low-molecular weight polyvinylpyrrolidone-iodine complex in rabbits.] Arzneim Forsch 37(3):340–341. (German)3593449
Sikov MR. 1969. Effect of age on the iodine-131 metabolism and the radiation sensitivity of the rat thyroid. Radiat Res 38:449–459.5771809
Sikov MR, Meznarich HK, Traub RJ. 1991. Comparison of placental transfer and localization of caesium strontium and iodine in experimental animals and women. Int J Radiat Biol 60(3):553–555.1679097
Silberstein T, Hallak M, Gonen R, . 2001. Toxic trace elements (TE) can be found in the maternal and fetal compartments. Am J Obstet Gynecol 184(1):S177.
Silva CAM, Merkt H, Bergamo PNL, . 1987. Consequence of excess iodine supply in a thoroughbred stud in southern Brazil. J Reprod Fertil Suppl 35:529–533.
*Silva JE. 2000a. Catecholamines and the sympathoadreanl system in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 642–651.
*Silva JE. 2000b. Catecholamines and the sympathoadrenal system in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 820–823.
Sim RTS. 1993. Thrombocytopenia associated with exposure to iodine. Hawaii Med J 52(10):262.8270415
Simon SL. 1996. A summary of health, environmental and sociological consequences from atomic testing in the Marshall Islands. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, The Netherlands: Elsevier, 155–165.
Simon SL, Graham JC. 1996. Dose assessment activities in the Republic of the Marshall Islands. Health Phys 71(4):438–456.8830746
*Simon SL, Graham JC. 1997. Findings of the first comprehensive radiological monitoring program of the Republic of the Marshall Islands. Health Phys 73(1):66–85.9199219
*Simon SL, Lloyd RD, Till JE, . 1990. Development of a method to estimate thyroid dose from fallout radioiodine in a cohort study. Health Phys 59(5):669–691.2211123
*Simon SL, Luckyanov N, Bouville A, . 2002. Transfer of ^131^I into human breast milk and transfer coefficients for radiological dose assessments. Health Phys 82(6):796–806.12046751
Simonnet F, Orts JC, Simonnet G. 1989. Destruction of genotoxic wastes mixed with radioactive products. Health Phys 57(6):885–890.2555315
Simonovic I, Kargarcin B, Kostial K. 1986. The effect of composite oral treatment for internal contamination with several radionuclides on ^131^I thyroid uptake in humans. J Appl Toxicol 6(2):109–111.3700959
Simonovic I, Kostial K, Kargacin B. 1984. ^131^I uptake in human thyroid after antidote treatment for mixed fission products contamination. Int J Radiat Biol 46(4):459–462.
Simpson CL, Hempelmann LH, Fuller LM. 1955. Neoplasia in children treated with x-rays in infancy for thyroid enlargement. Radiology 64:840–845.14385062
Sinclair WK, Abbatt JD, Farran HEA, . 1956. A quantitative autoradiographic study of radioiodine distribution and dosage in human thyroid glands. Br J Radiol 29:36–41.13276622
Sindainovic J, Liewendahl K. 1976. Studies on proteolytic activity and function of the thyroid gland in rats administered excess iodide. Acta Endocrinol 82:728–736.
Singh B, Dhawan D, Chand B, . 1994. Biokinetics of iodine-131 in rat thyroid following lead and lithium supplementation. Biol Trace Elem Res 40:287–293.7517166
Singh B, Dhawan D, Mangal PC, . 1992. The influence of lead toxicity on the biological half-life of iodine-131 Rose Bengal in rat liver. Med Sci Res 20(17):623–624.
Singh VN, Chaikoff IL. 1966. Effects of 1-methyl-2-mercaptoimidazole and perchlorate on the insulin-mediated enhancement of ^131^I incorporation into iodoamino acids by fetal thyroid glands in organ culture. Endocrinology 78:339–342.4285812
Singhal RK, Narayanan U, Bhat IS. 1998. Investigations on interception and translocation of airborne ^85^Sr, ^131^I, ^137^Cs in beans, spinach and radish plants. Water Air Soil Pollut 101:163–176.
Sinniah R, Lye WC. 2001. Acute renal failure from hemoglobinuric and interstitial nephritis secondary to iodine and mefenamic acid. Clin Nephrol 55(3):254–258.11316248
Sit KH, Kanagasuntheram R. 1972. A structural analysis of congenital limb deformities in experimental hyperthyroid tadpoles. J Embryol Exp Morphol 28(1):223–234.4342289
Skare S, Frey HMM. 1980. Iodine induced thyrotoxicosis in apparently normal thyroid glands. Acta Endocrinol 94:332–336.
Sleight SD, Mangkoewidjojo S, Akoso BT, . 1978. Polybrominated biphenyl toxicosis in rats fed an iodine-deficient, iodine-adequate, or iodine-excess diet. Environ Health Perspect 23:341–346.209997
*Small MD, Bezman A, Longarni AE, . 1961. Absorption of potassium iodide from gastro-intestinal tract. Proc Soc Exp Biol Med 106:450–452.
Smallridge RC. 1996. Metabolic, physiologic, and clinical indexes of thyroid function. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 397–405.
Smallridge RC, Gist ID, Ambroz C. 1991. 8-Diethylamino-octyl-3,4,5-trimethyoxybenzoate, a calcium store blocker, increases calcium influx, inhibits alpha-1 adrenergic receptor calcium mobilization, and alters iodide transport in FRTL-5 rat thyroid cells. Endocrinology 129(1):542–549.1647311
Smallridge RC, Gist ID, Kiang JG. 1992. Na^+^-H^+^ antiport and monesin effects on cytosolic pH and iodide transport in FRTL-5 rat thyroid cells. Am J Physiol 262(25):E834–E839.1319679
Smallridge RC, Wartofsky L, Burman KD. 1982. The effect of experimental hyperthyroidism and hypothyroidism on 5’-monodeiodination of 3,3’,5’-triiodothyronine and 3’,5’-diiodothyronine by rat liver and kidney. Endocrinology 111:2066–2069.7140645
*Smanik PA, Liu Q, Furminger TL, . 1996. Cloning of the human sodium iodide symporter. Biochem Biophys Res Commun 226:339–345.8806637
*Smanik PA, Ryu K-Y, Theil KS, . 1997. Expression, exon-intron organization, and chromosome mapping of the human sodium iodide symporter. Endocrinology 138(8):3555–3558.9231811
Smerdely P, Boyages SC, Wu D, . 1989. Topical iodine-containing antiseptics and neonatal hypothyroidism in very-low-birthweight infants. Lancet 2(8664):661–664.2570908
Smidt KP, Johnson E. 1975. Undetected iatrogenic hypothyroidism: A late complication of radio-iodine therapy. N Z Med J 81:325–328.1056550
Smit E, Whiting DA, Feld S. 1994. Iodine-induced hyperthyroidism caused by acne treatment. J Am Acad Dermatol 31(1):115–117.8021354
Smit JWA, Schroder-van der Elst JP, Karperien M, . 2000. Reestablishment of in vitro and in vivo iodide uptake by transfection of the human sodium iodide symporter (hNIS) in a hNIS defective human thyroid carcinoma cell line. Thyroid 10(11):939–943.11128720
Smith CS, Howard NJ. 1973. Propanolol in treatment of neonatal thyrotoxicosis. J Pediatr 83(6):1046–1048.4757519
Smith GE. 1917. Fetal athyrosis. A study of the iodine requirement of the pregnant sow. J Biol Chem 29:215–225.
Smith JM, Broadway JA, Strong AB. 1978. United States population dose estimates for iodine-131 in the thyroid after the Chinese atmospheric nuclear weapons tests. Science 200:44–46.565079
*Smith MB, Xue H, Takahashi H, . 1994. Iodine 131 thyroid ablation in female children and adolescents: Long-term risk of infertility and birth defects. Ann Surg Oncol 1(2):128–131.7834437
Smith RN, Wilson GM. 1967. Clinical trial of different doses of ^131^I in treatment of thyrotoxicosis. Br Med J 1:129–132.5333307
Smith TJ. 1996a. Connective tissue in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 796–798.
Smith TJ. 1996b. Connective tissue in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 598–606.
Smyth PPA. 1999. Variation in iodine handling during normal pregnancy. Thyroid 9(7):637–642.10447006
*Snyder PJ. 2000a. The pituitary in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 836–840.
*Snyder PJ. 2000b. The pituitary in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 634–636.
Snyder RD. 1988. Role of active oxygen species in metal-induced DNA strand breakage in human diploid fibroblasts. Mutat Res 193:237–246.3362151
Snyder S. 1978. Vocal cord paralysis after radioiodine therapy. J Nucl Med 19(8):975–976.581086
Sobrinho LG, Limbert ES, Santos MA. 1977. Thyroxine toxicosis in patients with iodine induced thyrotoxicosis. J Clin Endocrinol Metab 45:25–29.577497
Socolow EL, Hashizume A, Neriishi S, . 1963. Thyroid carcinoma in man after exposure to ionizing radiation. N Engl J Med 268(8):406–410,444.13989805
*Sodd VJ, Velten RJ, Saenger EL. 1975. Concentrations of the medically useful radionuclides, technetium-99m and iodine-131 at a large metropolitan waste water treatment plant. Health Phys 28:355–359.1120667
*Solans R, Bosch J-A, Galofre P, . 2001. Salivary and lacrimal gland dysfunction (Sicca Syndrome) after radioiodine therapy. J Nucl Med 42(5):738–743.11337569
*Soldat JK. 1976. Radiation doses from iodine-129 in the environment. Health Phys 30:61–70.1244339
Soliman M, Kaplan E, Abdel-Latif A, . 1995. Does thyroidectomy, radioactive iodine therapy, or antithyroid drug treatment alter reactivity of patients’ T cells to epitopes of thyrotropin receptor in autoimmune thyroid diseases? J Clin Endocrinol Metab 80:2312–2321.7543112
Sololowska R, Fuks T, Olejnik E. 1976. [Determination of the level of iodine content in milk caused by the penetration of same from iodophoric preparations used during milking.] Rocz Panstw Zakl Hig 27(1):33–40. (Czech.).946331
Solomon BL, Evaul JE, Burman KD, . 1987. Remission rats with antithyroid drug therapy: Continuing influence of iodine intake? Ann Intern Med 107:510–512.2443050
Solov’ev AS, Gurova NV, Shchebnikova NE. 1996. [The effect of incorporation of various doses of 131I on the immunological reactions.] Byull Eksp Biol Med 121(6):664–666. (Russian)
Sonmez S, Ikbal M, Yildirim M, . 1997. Sister chromatid exchange analysis in patients exposed to low dose of iodine-131 for thyroid scintigraphy. Mutat Res 393:259–262.9393618
Sorcini MC, Diodata A, Fazzini C, . 1988. Influence of environmental iodine deficiency on neonatal thyroid screening results. J Endocrinol Invest 11:309–312.3411090
*Soria C, Allegue F, Espana A, . 1990. Vegetating iododerma with underlying systemic diseases: Report of three cases. J Am Acad Dermatol 22:418–422.2138178
Spate VL, Morris JS, Nichols TA, . 1998. Longitudinal study of iodine in toenails following IV administration of an iodine-containing contrast agent. J Radioanal Nucl Chem 236(1–2):71–76.
*Spaulding SW, Burrow WR Himmelhoch HM . 1972. The inhibitory effect of lithium on thyroid hormone release in both euthyroid and thyrotoxic patients. J Clin Endocrinol Metab 35:905–911.4634489
Speck WT, Carr HS, Rosenkranz HS. 1976. DNA damage produced by povidone-iodine in cultured human diploid cells. J Toxicol Environ Health 1:977–980.966325
Spector R, Lorenzo AV. 1974. The effects of salicylate and probenecid on the cerebrospinal fluid transport of penicillin, aminosalicylic acid and iodide. J Pharmacol Exp Ther 188(1):55–65.4809276
Speert H, Quimby EH, Werner SC. 1951. Radioiodine uptake by the fetal mouse thyroid and resultant effects in later life. Surg Gynecol Obstet 91:230–242.
Speight JW, Baba WI, Wilson GM. 1968. The effect of propylthiouracil and ^131^I on rat thyroid chromosomes. J Endocrinol 42:267–275.5731787
Spencer CA. 1996. Thyroglobulin. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 406–415.
Spencer RP, Chapman CN, Rao H. 1983. Thyroid carcinoma after radioiodide therapy for hyperthyroidism: Analysis based on age, latency, and administered dose of I-131. Clin Nucl Med 8(5):216–219.6872383
*Spencer RP, Spitznagle LA, Karimeddini MK, . 1986. Breast milk content of ^131^I in a hypothyroid patient. Nucl Med Biol 13(5):585.
Spezzano P, Giacomelli R. 1990. Radionuclide concentrations in air and their deposition at Saluggia (northwest Italy) following the Chernobyl nuclear accident. J Environ Radioact 12:79–91.
Spiegel W, Reiners C, Borner W. 1985. Sialadenitis following iodine-131 therapy for thyroid carcinoma. J Nucl Med 26(7):816–817.4009293
*Spitzweg C, Dutton CM, Castro MR, . 2001. Expression of the sodium iodide symporter in human kidney. Kidney Int 59(3):1013–1023.11231356
*Spitzweg C, Joba W, Eisenmenger W. 1998. Analysis of human sodium iodide symporter gene expression in extrathyroid tissues and cloning of its complementary deoxyribonucleic acids from salivary gland, mammary gland, and gastric mucosa. Journal of Endocrinology & Metabolism 83(5):1746–1751.
*Spitzweg C, Joba W, Schriever K, . 1999. Analysis of human sodium iodide symporter immunoreactivity in human exocrine glands. Journal of Endocrinology & Metabolism 84(11):4178–4184.
Spryshkova NA, Egorova LT, Palinkashi DG. 1976. [Study of different states of iodine metabolism in rats by means of whole-body radiometry.] Probl Endokrinol (Mosk) 22(2):70–75. (Russian)818632
Sridama V, McCormick M, Kaplan EL, . 1984. Long-term follow-up study of compensated low-dose ^131^I therapy for Graves’ disease. N Engl J Med 311(7):426–432.6205272
Stabin MG, Watson EE, Marcus CS, . 1991. Radiation dosimetry for the adult female and fetus from iodine-131 administration in hyperthyroidism. J Nucl Med 32(5):808–813.2022987
Stadel BV. 1976. Dietary iodine and risk of breast, endometrial, and ovarian cancer. Lancet 1(7965):890–891.58152
Staffurth JS. 1987. Hypothyroidism following radioiodine treatment of thyrotoxicosis. J R Coll Phys London 21(1):55–57.
Staffurth JS, Holl-Allen RTJ. 1988. Follicular carcinoma of the thyroid following radioactive iodine treatment for Graves’ disease. Postgrad Med J 64:878–880.3255938
Stanbury JB. 1990. The physiological basis for blockade of radioiodine retention by iodine. In: Rubery E, Smales E, eds. Iodine prophylaxis following nuclear accidents. Oxford, UK: Pergamon Press, 57–64.
Stanbury JB. 1992. Iodine and human development. Med Anthropol 13:413–423.1545696
*Stanbury JB, Wyngaarden JB. 1952. Effect of perchlorate on the human thyroid gland. Metabolism 1:533–539.13002073
*Stanbury JB, Ermans AE, Bourdoux P, . 1998. Iodine-induced hyperthyroidism: Occurrence and epidemiology. Thyroid 8(1):83–100.9492158
Stara JF, Hoar RM, Ball HH. 1966. Localization of radioiodine during early organogenesis by means of autoradiography [Abstract]. Health Phys 12:1206.
Starr P. 1974. Thyroid cancer after iodine-131 therapy [Letter]. JAMA 227(8):940.
*Stassi G, DiLiberto, Todaro, . 2000. Control of target cell survival in thyroid autoimmunity by T helper cytokines via regulation of apoptotic proteins. Nat Immunol 6:483–488.
*Stather JB, Greenhalgh JR. 1983. The metabolism of iodine in children and adults. National Radiation Protection Board, Chilton, Didcot, Oxfordshire, England. Report No. NRPB-R140.
Steen M. 1993. Review of the use of povidone-iodine (PVP-I) in the treatment of burns. Postgrad Med J 69(Suppl 3):S84–S92.8290464
Steidle B. 1989. Iodine-induced hyperthyroidism after contrast media: Animal experimental and clinical studies. Fortschr Geb Rontgenstrahlen Nuklearmed Erganzungsbd 128:6–14.2568809
Steidle B, Grehn S, Seif FJ. 1980. [Hyperthyroidism induced by iodine-containing contrast medium.] Minerva Med 71(22):1560–1565. (Italian)
Steinnes E. 1995. A critical evaluation of the use of naturally growing moss to monitor the deposition of atmospheric metals. Sci Total Environ 160/161:243–249.
Steinnes E, Rambek JP, Hanssen JE. 1992. Large scale multi-element survey of atmospheric deposition using naturally growing moss as biomonitor. Chemosphere 25(5):735–752.
Stenback F, Rowland J. 1978. Carcinogenic activation of benzo(a)pyrene by iodine and ferric chloride in the respiratory tract of Syrian golden hamsters. Experientia 34(8):1065–1066.700030
Stepanov SA, Tupikinia EB. 1997. [Histofunctional state of the thyroid gland in pregnancy and in progeny under experimental regime of iodine intake.] Arkh Patol 59(5):39–44. (Russian)9446535
*Stephenson M, Motycka M. 1994. Review and assessment of methods for the measurement and speciation of iodine in fresh water. Atomic Energy of Canada Ltd., Whiteshell Laboratories, Pinawa, Manitoba (NTIS PB95-160487).
*Sternthal E, Lipworth L, Stanley B, . 1980. Suppression of thyroid radioiodine uptake by various doses of stable iodide. N Engl J Med 303(19):1083–1088.7421914
*Stetar EA, Boston HL, Larsen IL, . 1993. The removal of radioactive cobalt, cesium, and iodine in a conventional municipal wastewater treatment plant. Water Environ Res 65(6):630–639.
Stevens RH, Cheng HF. 1987. Lymphocyte proliferative responses to mitogens in rats having an ancestry of a perinatal iodine-131 insult. Environ Res 44:94–102.3653071
Stevens RH, Cole DA, Liu PT, . 1983. Postpartum cell-mediated immunity induced in the rat following perinatal exposure to iodine-131. Anticancer Res 3:347–352.6651236
Stevens RH, Lindholm PA, Cole DA, . 1986. Genealogical memory to perinatal iodine-131 exposure in rats: I. Alteration in natural immunity. Anticancer Res 6:925–930.3800335
*Stewart JC. 1975. Epidemiology and pathogenesis of iodine-induced thyrotoxicosis in Northern Tasmania. N Z Med J 81:25–26.1055312
*Stewart JC, Vidor GI. 1976. Thyrotoxicosis induced by iodine contamination of food-a common unrecognised condition? Br Med J 1:372–375.946162
Stewart RB, May FE, Cullen SI. 1979. Dermatologic adverse drug reactions in hospitalized patients. Am J Hosp Pharm 36:609–612.156496
*St. Germain DL. 1997. Molecular basis of thyroid disease. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 183–208.
*Stieglitz KJL. 1995. Identification and quantification of volatile organic components in emissions of waste incinerator plants. Chemosphere 30:1249–1260.
*Stockigt JR. 2000. Serum thyrotropin and thyroid hormone measurements and assessment of thyroid hormone transport. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 376–392.
Stockton LK, Thomas WC. 1978. Absence of neonatal goiter during maternal use of iodinated water. Am J Clin Nutr 31:717.
Stoffer SS, Hamburger JI. 1976. Inadvertent ^131^I therapy for hyperthyroidism in the first trimester of pregnancy. J Nucl Med 17(2):146–149.1245878
Stoffer SS, Hamburger JI. 1978. Avoiding inadvertent fetal radiation resulting from 131I therapy for hyperthyroidism. In: Spencer RP, ed. Therapy in nuclear medicine. New York, NY: Grune & Stratton, 129–138.
Stolberg HO, McClennan BL. 1991. Ionic versus nonionic contrast use. Curr Probl Diagn Radiol 20(2):47–88.2049958
Stolc V. 1972. Regulation of iodine metabolism in human leukocytes by adenosine 3’,5’-monophosphate. Biochim Biophys Acta 264:285–288.4338623
Stolc V. 1975. Effect of pituitary factor on iodine uptake and cyclic adenosine 3’,5’-monophosphate formation in human polymorphonuclear leukocytes. Biochem Med 12:226–233.166640
Stoll R, Maraud R. 1963. [Induction of thyroid tumors in rats treated with propylthiouracil and radioactive iodine.] Bull Assoc Fr Etude Cancer 50(3):389–398. (French)
Stoll R, Maraud R, Laplanche P, . 1966. [On gamma adenomas of the thyroid in rats subjected to cancerogenic and non-cancerogenic treatments.] C R Seances Soc Biol Fil 160(12):2288–2291. (French)4228366
Stone OJ. 1971. What are the non-endocrine biologic effects of iodides? Med Times 99(12):143–149,155,200.5160892
*Stone OJ. 1985. Proliferative iododerma: A possible mechanism. Int J Dermatol 24(9):565–566.2933346
Stowe CM. 1981. Iodine, iodides, and iodism. J Am Vet Med Assoc 179(4):334–336.7287552
Stowe HD, Rangel F, Anstead C, . 1980. Influence of supplemental dietary vitamin A on the reproductive performance of iodine-toxic rats. J Nutr 110:1947–1957.7420203
Strain GM, Flory W. 1981. Toxicology of ethylenediamine dihydriodide [Letter]. J Am Vet Med Assoc 179:751,72.7341589
*Straub CP, Murthy GK, Campbell JE. 1966. Iodine-131 in foods. Residue Rev 13:33–68.4865096
Strum JM. 1979. Effect of iodide-deficiency on rat mammary gland. Virchows Arch B 30:209–220.38565
Stubbe P, Schulte F-J, Heidemann P. 1986. Iodine deficiency and brain development. Bibl Nutr Dieta 38:206–208.
Stubner D, Gartner R, Greil W, . 1987. Hypertrophy and hyperplasia during goitre growth and involution in rats - separate bioeffects of TSH and iodine. Acta Endocrinol 116:537–548.
Studer H, Kohler H, Burgi H, . 1970. Goiters with high radioiodine uptake and other characteristics of iodine deficiency in rats chronically treated with aminoglutethimide. Endocrinology 87:905–914.4098398
Studer H, Kohler H, Burgi H, . 1972. Possible importance of thyroidal iodine compartments in the adaptation of thyroid hormone secretion to antithyroid drugs. Endocrinology 91:1154–1159.5072796
Stuges WT, Shaw GE. 1993. Halogens in aerosols in central Alaska. Atmos Environ 27A(17/18):2969–2977.
Sturgis CD. 1999. Radioactive iodine-associated cytomorphologic alterations in thyroid follicular epithelium: Is recognition possible in fine-needle aspiration specimens? Diagn Cytopathol 21(3):207–210.10450109
Suarez RC, Lopez Bejerano GM, Arado JO, . 1998. [System for whole-body measurement and estimation of doses by different irradiation routes in a group of infants from areas affected by the Chernobyl accident.] Rev Cubana Fis 15(2):130–133. (Spanish)
Subramanyam S, Murthy DK, Reddi OS. 1975. Cytological investigations on the effects of I^131^ in male mice. Indian J Med Res 63(12):1680–1687.1225828
Sugawara M, Yamaguchi DT, Lee HY, . 1990. Hydrogen peroxide inhibits iodide influx and enhances iodide efflux in cultured FRTL-5 rat thyroid cells. Acta Endocrinol 122:610–616.
Sunder S, Vikis AC. 1987. Raman spectra of iodine oxyacids produced by the gas-phase reaction of iodine with ozone in the presence of water vapour. Can J Spectrosc 32(2):45–48.
Sundick RS. 1990. Iodine in autoimmune thyroiditis. Immunol Ser 52:213–228.2151126
*Sundick RS, Herdegen DM, Brown TR, . 1987. The incorporation of dietary iodine and thyroglobulin increases its immunogenicity. Endocrinology 120:2078–2084.3569125
Sunitha Y, Udaykumar P, Raghunath M. 1997. Changes in blood-brain barrier nutrient transport in the offspring of iodine-deficient rats and their preventability. Neurochem Res 22(7):785–790.9232629
Surks MI. 1967. Determination of iodide clearance and exit rate constants in incubated thyroid lobes. Endocrinology 80:1020–1027.4290679
Svadlenkova M, Konecny J, Obdrzalek M, . 1990. Distribution and transport kinetics of radionuclides ^99^Mo and ^131^I in a simulated aquatic ecosystem. Bull Environ Contam Toxicol 44:535–541.2322680
Swedlund HA. 1971. Iodide myxedema with facial swelling simulating angioneurotic edema. Allergy 47(6):341–345.
*Szabolcs I, Podoba J, Feldkamp J, . 1997. Comparative screening for thyroid disorders in old age in areas of iodine deficiency, long-term iodine prophylaxis and abundant iodine intake. Clin Endocrinol 47:87–92.
Szabolcs I, Schultheiss H, Astier H, . 1991. Effects of triiodothyronine, triiodothyroacetic acid, iopanoic acid and iodide on the thyrotropin-releasing hormone-induced thyrotropin release from superfused rat pituitary fragments. Acta Endocrinol 125:427–434.
Sztanyik LB, Turai I. 1988. Modification of radioiodine incorporation into the fetuses and newborn rats by thyroid blocking agents. Acta Physiol Hung 72(3–4):343–354.2471388
Tabintharan S, Sundram FX, Chew LS. 1997. Radioiodine (I-131) therapy and the incidence of hypothyroidism. Ann Acad Med Singapore 26:128–131.9140591
Tadrose TG, Maisey MN, Fui SCNT, . 1981. The iodine concentration in benign and malignant thyroid nodules measured by x-ray fluorescence. Br J Radiol 54:626–629.7260515
Taher MA, Loken MK, Bantle JP. 1991. Radioiodine therapy in thyrotoxicosis. J Indian Med Assoc 89(4):86–88.1940400
Tai M, Zhi-heng Y, Ti-zhang L, . 1982. High-iodide endemic goiter. Chin Med J 95(9):692–696.6817996
*Tajiri J, Higashi K, Morita M, . 1986. Studies of hypothyroidism in patients with high iodine intake. J Clin Endocrinol Metab 63:412–417.3722332
*Takahashi T, Fujimori K, Simon SL, . 1999. Thyroid nodules, thyroid function and dietary iodine in the Marshall Islands. Int J Epidemiol 28:742–749.10480705
*Takahahi T, Schoemaker MJ, Trott KR, . 2003. The relationship of thyroid cancer with radiation exposure from nuclear weapon testing in the Marshall islands. J Epidemiol 13(2):99–107.12675119
*Takahashi T, Trott KR, Fujimori K, . 1997. An investigation into the prevalence of thyroid disease on Kwajalein Atoll, Marshall Islands. Health Phys 73(1):199–213.9199230
*Takasu N, Handa Y, Shimizu Y, . 1984. Electrophysiological and morphological cell polarity and iodine metabolism in cultured porcine and human (normal and Graves’) thyroid cells. J Endocrinol 101:189–196.6325571
Takasu N, Ohno S, Takasu M, . 1988. Polarized thyroid cells in monolayers cultured on collagen gel: Their cytoskeleton organization, iodine uptake, and resting membrane potentials. Endocrinology 122:1021–1026.3342742
Takasu N, Sato A, Yamada T, . 1982. Refractoriness of TSH- and PGE_2_-stimulated iodine metabolism in cultured porcine thyroid cells, evidence for refractoriness at the level of cAMP action. Acta Endocrinol 99:530–539.
Takegawa K, Mitsumori K, Onodera H, . 1998. Induction of squamous cell carcinomas in the salivary glands of rats by potassium iodide. Jpn J Cancer Res 89:105–109.9548435
Takegawa K, Mitsumori K, Onodera H, . 2000. Studies on the carcinogenicity of potassium iodide in F344 rats. Food Chem Toxicol 38(9):773–781.10930698
Takeuchi K, Suzuki H, Sawada M, . 1970. Effect of excessive iodide administration on the proteolytic activity of the thyroid gland. Endocrinology 86:1239–1244.5441868
Takeuchi S, Hosokawa S, Kachi T, . 1966. [A case of thyroid crisis followed to ^131^I therapy-with special reference to the hepatic lesions.] Naika 18(1):163–166. (Japanese)6013661
Takiyama Y, Tanaka H, Takiyama Y, . 1994. The effects of hydrocortisone and RU486 (mifepristone) on iodide uptake in porcine thyroid cells in primary culture. Endocrinology 135(5):1972–1979.7956919
Tallstedt L, Lundell G. 1997. Radioiodine treatment, ablation, and ophthalmopathy: A balanced perspective. Thyroid 7(2):241–245.9133694
Tallstedt L, Lundell G, Torring O, . 1992. Occurrence of ophthalmopathy after treatment for Graves’ hyperthyroidism. N Engl J Med 326:1733–1738.1489388
Tam M. 1988. Australian Dermato-Pathology Society case presentation: Acute painful nodules on the head and neck. Australas J Dermatol 29:179–180.3272128
Tamdor J. 1971. Consideration of stable iodine in the environment in the evaluation of maximum permissible concentrations for iodine-129. Radiol Health Data Rep 12(12):611–614.5172415
Tamura T, Mitsumori K, Onodera H, . 1999. Inhibition of thyroid iodine uptake and organification in rats treated with kojic acid. Toxicol Sci 47:170–175.10220853
Tan TT, Morat P, Ng ML, . 1989. Effects of Lugol’s solution on the thyroid function in normals and patients with untreated thyrotoxicosis. Clin Endocrinol 30:645–649.
Tanaami S, Katamine S, Hoshino N, . 1985. Histopathological study on rats fed iodine-enriched eggs long-term (7 and 9 months). J Nutr Sci Vitaminol 31:29–42.4020492
Tanigawa K, Yamishita S, Nagataki S. 1995. Pancytopenia after repeated radioiodine treatment on metastatic thyroid cancer to bone. Chin Med J 108:796–797.8565674
Taniguchi S-I, Shong M, Giuliani C, . 1998. Iodide suppression of major histocompatibility class I gene expression in thyroid cells involves enhancer A and the transcription factor NF-kb. Mol Endocrinol 12:19–33.9440807
Tarasenko LV, Varga SV, Demchenko VN, . 1994. [Effect of 131I incorporation on male rat reproductive system and dose-dependent effects.] Probl Endokrinol (Mosk) 40(3):45–47. (Russian)
Targovnik HM, Gluzman BE, Coleoni AH, . 1980. Effects of phenylbutazone on thyroid iodine metabolism in vitro. Acta Endocrinol 94:64–70.
Tarutani O, Kondo T, Horiguchi-Sho K. 1975. The effect of iodide administration on hog thyroid gland and the composition of thyroglobulin and 27-S iodoprotein. Endocrinol Jpn 22(5):389–397.1212981
Taurog A. 1970. Thyroid peroxidase-catalyzed iodination of thyroglobulin; inhibition by excess iodide. Arch Biochem Biophys 139:212–220.5528498
*Taurog A. 1996. Hormone synthesis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 47–84.
*Taurog A. 2000. Hormone synthesis: Thyroid iodine metabolism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Williams and Wilkins, 61–84.
*Taurog A, Dorris M, Doerge DR. 1994. Evidence for a radical mechanism in peroxidase-catalyzed coupling: I. Steady state experiments with various peroxidases. Arch Biochem Biophys 315:82.7979410
*Taylor JP, Metcalfe RA, Watson PF, . 2002. Mutations of the PDS gene, encoding pendrin, are associated with protein mislocalization and loss of iodide efflux: Implications for thyroid dysfunction in Pendred Syndrome. J Clin Endocrinol Metab 87(4):1778–1784.11932316
Taylor DM. 1981. The radiotoxicology of iodine. J Radioanal Chem 65(1–2):195–208.
*Tazebay UH, Wapnir IL, Levy O, . 2000. The mammary gland iodide transporter is expressed during lactation and in breast cancer. Nat Med 6(8):859–860.10932214
Terahara A, Nakano T, Ishikawa A, . 1996. Dose-volume histogram analysis of high dose rate intracavitary brachytherapy for uterine cervix cancer. Int J Radiat Oncol Biol Phys 35(3):549–554.8655379
Teraoka K, Minakuchi K, Kuzime T, . 1991. Lithium and carbamazepine effects on iodide metabolising enzymes from the porcine thyroid. Lithium 2:37–42.
Tezelman S, Grossman RF, Siperstein AE, . 1994. Radioiodine-associated thyroid cancers. World J Surg 18:522–528.7725739
Theodoropoulos LE, Braverman LE, Vagenakis AG. 1979. Iodide-induced hypothyroidism: A potential hazard during perinatal life. Science 205:502–503.451615
*Thieblemont P, Marble G, Perrault G, . 1965. Evaluation de la retention respiratoire et de l’elimination du radioiode apres contamination aerienne du singe. Int J Radiat Biol 9(3):219–231.
Thiessen KM, Thorne MC, Maul PR, . 1999. Modelling radionuclide distribution and transport in the environment. Environ Pollut 100:151–177.15093116
Thomas GA, Williams ED. 1999. Thyroid stimulating hormone (TSH)-associated follicular hypertrophy and hyperplasia as a mechanism of thyroid carcinogenesis in mice and rats. In: Capen CC, Dybing E, Rice JM, ., eds. Species differences in thyroid, kidney and urinary bladder carcinogenesis. Lyon, France: International Agency for Research on Cancer, 45–59.
Thomas PJ. 1997. Predicting Chernobyl childhood thyroid cancers from incoming data. Nucl Energy (Br Nucl Energy Soc) 36(3):209–221.
*Thomas RL, Scott JK, Chiffelle TL. 1970. Metabolism and toxicity of inhaled and injected ^131^I in the rat. Am Ind Hyg Assoc J 31:213–220.5423229
Thomas WC, Malagodi MH, Oates TW, . 1979. Effects of an iodinated water supply. Trans Am Clin Climatol Assoc 90:153–162.516226
*Thompson DE, Mabuchi K, Ron E, . 1994. Cancer incidence in atomic bomb survivors. Part II: Solid tumors, 1958-1987. Radiat Res 137:S17–S67.8127952
Thomson CD, Packer MA, Butler JA, . 2001. Urinary selenium and iodine during pregnancy and lactation. J Trace Elem Med Biol 14(4):210–217.11396779
Thomson CD, Woodruffe S, Colls AJ, . 2001. Original communication. Urinary iodine and thyroid status of New Zealand residents. Eur J Clin Nutr 55(5):387–392.11378813
Thomson JA, Riley ID. 1966. Neonatal thyrotoxicosis associated with maternal hypothyroidism. Lancet 1(7438):635–636.4159675
Thomson WH, Harding LK. 1995. Radiation protection issues associated with nuclear medicine outpatients. Nucl Med Commun 16:879–892.8587752
Thorpe SM. 1976. Increased uptake of iodide by hormone-responsive compared to hormone-independent mammary tumors in GR mice. Int J Cancer 18:345–350.182648
Thorsteinsson B, Kirkegaard C. 1977. Iodine-induced hyperthyroidism and bronchial asthma. Lancet 2(8032):294.
*Thrall KD, Bull RJ. 1990. Differences in the distribution of iodine and iodide in the Sprague-Dawley rat. Fundam Appl Toxicol 15:75–81.2373302
Thrall KD, Sauer RL, Bull RJ. 1992. Evidence of thyroxine formation following iodine administration in Sprague-Dawley rats. J Toxicol Environ Health 37:535–548.1464908
Thurston V, Williams ED. 1982. The effect of radiation on thyroid C cells. Acta Endocrinol 99:72–78.
Tighe WJ. 1952. Temporary hypoparathyroidism following radioactive iodine treatment for thyrotoxicosis. J Clin Endocrinol Metab 12:1220–1222.12981157
Tiku ML, Farias AE, Johnson SC. 1976. Iodide myxoedema simulating filariasis. Indian J Med Sci 30(9):291–292.1032622
Tisell L-E, Carlsson S, Fjalling M, . 1985. Hyperparathyroidism subsequent to neck irradiation. Cancer 56:1529–1533.4027889
*Todd CH, Allain T, Gomo ZAR, . 1995. Increase in thyrotoxicosis associated with iodine supplements in Zimbabwe. Lancet 346:1563–1564.7491075
Toft AD, Irvine WJ, Hunter WM, . 1974a. Anomalous plasma TSH levels in patients developing hypothyroidism in the early months after ^131^I therapy for thyrotoxicosis. J Clin Endocrinol Metab 39:607–609.4412033
Toft AD, Seth J, Hunter WM, . 1974b. Plasma-thyrotropin and serum-thyroxine in patients becoming hypothyroid in the early months after iodine-131. Lancet 1(7860):704–705.4132423
Tokuda Y, Kasagi K, Iida Y, . 1988. Inhibition of thyrotropin-stimulated iodide uptake in FRTL-5 thyroid cells by crude immunoglobulin fractions from patients with goitrous and atrophic autoimmune thyroiditis. J Clin Endocrinol Metab 67(2):251–258.2899088
Tomlinson C, Nowles KW, McDougall IR. 1991. Papillary cancer in a patient treated with radioiodine for Graves’ hyperthyroidism: Case report and a review of the risk. Clin Nucl Med 16(10):729–731.1742925
Tomonaga M, Nonaka H, Matsuo T. 1996. Atomic bomb irradiation and human leukemias. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, The Netherlands: Elsevier, 197–215.
Tonacchera M, Agretti P, Ceccarini G, . 2001. Autoantibodies from patients with autoimmune thyroid disease do not interfere with the activity of the human iodide symporter gene stably transfected in CHO cells. Eur J Endocrinol 144(6):611–618.11375795
*Tong Q, Ryu K-Y, Jhiang SM. 1997. Promoter characterization of the rat Na^+^/I^−^ symporter gene. Biochem Biophys Res Commun 239:34–41.9345265
Tony JC, Verghese R, Mathew G. 1994. Radio iodine induced thyroid storm. J Assoc Physicians India 42(11):924–925.
*Topliss DJ, Kolliniatis E, Barlow JW, . 1989. Uptake of 3,5,3’-triiodothyronine by cultured rat hepatoma cells is inhibitable by nonbile acid cholephils, diphenylhydantoin, and nonsteriodal antiinflammatory drugs. Endocrinology 124:980–986.2912709
Toran L. 1994. Radionuclide contamination in groundwater: Is there a problem? In: Environmental science pollution control series. New York, NY: M. Dekker, 437–453.
*Tosti A, Vincenzi C, Bardazzi F, . 1990. Allergic contact dermatitis due to povidone-iodine. Contact Dermatitis 23:197–198.2149327
Townsend JD. 1961. Hypoparathyroidism following radioactive iodine therapy for intractable angina pectoris. Ann Intern Med 55:662–663.13922209
*Tracy BL, Walker WB, McGregor RG. 1989. Transfer of milk to ^131^I and ^137^Cs released during the Chernobyl reactor accident. Health Phys 56(2):239–243.2917852
Tran N, Laplante M, LeBel E, . 1970. The effect of sodium iodide on the oxidation in vivo of [1-^14^C] L-tyrosine to ^14^CO_2_ in normal rats: A vibrating-reed electrometer-ionization chamber method. Arch Int Physiol Biochim 78:909–917.4101923
Trapasso F, Martelli ML, Battaglia C, . 1996. The v-erbA oncogene selectively inhibits iodide uptake in rat thyroid cells. Oncogene 12(9):1879–1888.8649848
Traynor K. 2002. FDA offers guidance on prophylaxis for exposure to radioiodines. Am J Health Syst Pharm 59(4):324–326.
*Tresch DD, Sweet DL, Keelan MHJ, . 1974. Acute iodide intoxication with cardiac irritability. Arch Intern Med 134:760–762.4411847
Triggs SM, Williams ED. 1977. Irradiation of the thyroid as a cause of parathyroid adenoma. Lancet 1:593–594.
*Tronko ND, Bogdanova TI, Epstein EV, . 1996. Thyroid cancer in children and adolescents in Ukraine (analysis of the situation in 1994). In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, The Netherlands: Elsevier, 3–13.
*Trowbridge FL, Matovinovic J, McLaren GD, . 1975. Iodine and goiter in children. Pediatrics 56:82–90.1153253
*Truesdale VW, Smith PJ. 1975. The automatic determination of iodide or iodate in solution by catalytic spectrophotometry, with particular reference to river water. Analyst 100:111–123.
Tseng F-Y, Rani CSS, Field JB. 1989. Effect of iodide on glucose oxidation and ^32^P incorporation into phospholipids stimulated by different agents in dog thyroid slices. Endocrinology 124(3):1450–1455.2537182
Tsuchiya T, Ito K, Murata M. 1996. [An evaluation of the incidence of hyperparathyroidism after 131I treatment for Basedow disease (Part I).] Kaku Igaku 33(7):729–735. (Japanese)8803441
Tsuchiya Y, Saji M, Isozaki O, . 1990. Effect of litium on deoxyribonucleic acid synthesis and iodide uptake in porcine thyroid cells in culture. Endocrinology 126(1):460–465.2152871
*Tsukada H, Ishida J, Narita O. 1991. Particle-size distributions of atmospheric ^129^I and ^127^I aerosols. Atmos Environ 25A(5/6):905–908.
*Tsunoda A, Shibusawa M, Kamiyama G, . 2000. Iodine absorption after intraperative bowel irrigation with povidone-iodine. Dis Colon Rectum 43(8):1127–1132.10950012
*Tsunogai S. 1971. Determination of iodine in sea water by an improved Sugawara method. Anal Chim Acta 55:444–447.
Tsushima T, Arai M, Isozaki O, . 1994. Interaction of endothelin-1 with porcine thyroid cells in culture: A possible autocrine factor regulating iodine metabolism. J Endocrinol 142:463–470.7964297
Tsushima T, Arai M, Saji M, . 1988. Effects of transforming growth factor-bets on deoxyribonucleic acid synthesis and iodine metabolism in porcine thyroid cells in culture. Endocrinology 123:1187–1194.2840263
*Tubiana M. 1982. Metabolism and radiotoxicity of radionuclides: Iodine. In: Radionuclide: Metabolism and toxicity. Proceedings of the symposium. Paris, France: Masson, 49–81.
Tucker MA, Jones PHM, Boice JD, . 1991. Therapeutic radiation at a young age is linked to secondary thyroid cancer. Cancer Res 51:2885–2888.1851664
Tunbridge WMG, Evered DC, Hall R, . 1977. The spectrum of thyroid disease in a community: The Whickham survey. Clin Endocrinol 7:481–493.
Tunbridge WMG, Harsoulis P, Goolden AWG. 1974. Thyroid function in patients treated with radioactive iodine for thyrotoxicosis. Br Med J 3:89–92.4855207
Turner FB, Martin WE. 1964. Food-chain relationships of iodine-131 in Nevada following the Sedan test of July 1962. Laboratory of Nuclear Medicine and Radiation Biology, University of California, Los Angeles, California. PNE-236f, Project 62.83.
Tvedten HW, Till GO. 1985. Effect of povidone, povidone-iodine, and iodide on locomotion (in vitro) of neutrophils from people, rats, dogs, and rabbits. Am J Vet Res 46(8):1797–1800.4037512
Tyler DD. 1968. Influence of mitochondrial inhibitors on the respiration and energy-dependent uptake of iodide by thyroid slices. Biochem J 107:121–123.5642616
Tzen K-Y, Oster ZH, Wagner HJ, . 1980. Role of iron-binding proteins and enhanced capillary permeability on the accumulation of gallium-67. J Nucl Med 21(1):31–35.7356736
Uchida S, Muramatsu Y, Sumiya M, . 1991. Biological half-life of gaseous elemental iodine deposited onto rice grains. Health Phys 60(5):675–679.2019499
Uchimura H, Amir SM, Ingbar SH. 1979. Failure of organic iodine enrichment to influence the binding of bovine thyrotropin to rat thyroid tissue. Endocrinology 104:1207–1210.436773
Ulmer DD. 1977. Trace elements. N Engl J Med 6:318–321.
Umans RS, Leski SA, Ts’o POP. 1969. Chemical linkage of carcinogenic 3,4-benzpyrene to DNA in aqueous solution induced by peroxide and iodine. Nature 221:763–764.5766646
Umeki K, Kotani T, Kawano J, . 2002. Two novel missense mutations in the thyroid peroxidase gene. R665W and G771R, result in a localization defect and cause congenital hypothyroidism. Eur J Endocrinol 146(4):491–498.11916616
Underwood EJ. 1971. Iodine. In: Trace elements in human and animal nutrition. New York, NY: Academic Press, 281–322.
Unger J. 1989. Thionamides and iodide in iodine-induced thryotoxicosis [Letter]. Acta Clin Belg 44(1):61.2763784
Unger J, Boeynaems JM, Van Herle A, . 1979. In vitro nonbutanol-extractable iodine release in dog thyroid. Endocrinology 105(1):225–231.87322
Unger J, Surmont DWA, Sarot J, . 1989. 24 H-kinetics of iodide uptake in amiodarone induced hypothyroidism. Thyroidology 2:101–102.
*UNSCEAR. 1993. Sources, effect and risks of ionizing radiation. Report to the general assembly, New York: United Nations.
*UNSCEAR. 2000. Sources, effect and risks of ionizing radiation. Report to the general assembly, New York: United Nations. ANNEX J. Exposures and Effects of the Chernobyl Accident, 451–566.
Untoro J, Schultink W, Gross R, . 1998. Efficacy of different types of iodized oil [Letter]. Lancet 351:752–753.9504541
Upton AC. 1981. Health impact of the Three Mile Island accident. Ann N Y Acad Sci 365:63–75.6942744
Ursu HI, Dumitriu L, Grigorie D, . 1993. Effects of radioioine therapy in hyperthyroidism (thyroid function, thyroid volume, Graves’ ophtalmopathy, thyrotoxic heart disease). Rom J Endocrinol 31(3–4):155–163.7697064
Usala SJ. 1997. Thyroid hormone resistance syndromes. In: Falk SA, eds. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 223–230.
*USC. 2001. Listed precursor for controlled substance. U.S. Code. 21 USC 802. http://www4.law.cornell.edu/uscode/21/802.text.html. May 16, 2001.
*U.S. DHHS. 1985. SEER cancer incidence and mortality in the United States, 1973-1981. Publ No. 85-1837, Bethesda, MD.
Usenko VS, Lepekhin EA, Kornilovska IN, . 1998. Immunohistochemical study of fibronectin and thyroglobulin in the thyroid gland of female rats after exposure to radioactive iodine. Anat Rec 252:600–607.9845210
Usenko V, Lepekhin E, Lyzogubov V, . 1999. The influence of low doses ^131^I-induced maternal hypothyroidism on the development of rat embryos. Exp Toxicol Pathol 51:223–227.10334462
*USGS. 1984. Element concentrations in soils and other surficial materials of the conterminous United States. Washington, DC: United States Government Printing Office. U.S. Geological Survey Professioal Paper 1270.
*USGS. 1998. Iodine. USGS Minerals Information. http://minerals.usgs.gov/minerals/pubs/commodity/iodine/index.html.
*USGS. 1999. Iodine. United States Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/iodine/770499.pdf.
*USGS. 2001. Iodine. U.S. Geological Survey, Mineral Commodities Summaries. January 2001.
*USGS. 2002. Iodine. United States Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/iodine/770302.pdf.
*USNRC. 1979. A dynamic model of the global iodine cycle for the estimation of dose to the world population from releases of iodine-129 to the environment. U.S. Nuclear Regulatory Commission, Division of Safeguards, Fuel Cycle, and Environmental Research. NUREG/CR-0717.
*USNRC. 1981. On the long-term behavior of ^129^I in the terrestrial environment. U.S. Nuclear Regulatory Commission, Division of Safeguards, Fuel Cycle, and Environmental Research. IAEA-SDM-257.
*USNRC. 1984. Lower limit of detection: definition and elaboration of a proposed position for radiological effluent and environment measurements. Washington, D.C.: Nuclear Regulatory Commission. U.S. Report NUREG/ CR-4604.
USNRC. 1987. Interpretative analysis of data for solute transport in the unsaturated zone. Washington, DC: U.S. Nuclear Regulatory Commission, Office of Nuclear Material Safety and Safeguards, Division of Waste Management. NUREG/CR-4737.
*USNRC. 1997. Minimum detectable concentrations with typical radiation survey instruments for various contaminants and field conditions. Nuclear Regulatory Commission. Rockville MD: NRC; U.S. Report NUREG-1507.
*USNRC. 2001a. Index of radioisotopes: Iodine. U.S. Nuclear Regulatory Commission. http://www.nrc.gov.
*USNRC. 2001b. Byproduct material list. U.S. Nuclear Regulatory Commission. http://www.nrc.gov.
*USNRC. 2001c. Packaging and transportation of radioactive material. Determination of A1 and A2. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 71, Appendix A. http://ecfrback.access.gpo.gov/otcgi/cfr/otfilter.cgi. May 16, 2001.
*USNRC. 2001d. Waste classification. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 61.55. http://ecfrback.access.gpo.gov/otcgi/cfr. May 16, 2001.
*USNRC. 2002. NRC Regulations. Appendix B. U.S. Nuclear Regulatory Commission. 10 CFR. http://www.nrc.gov/reading-rm/doc-collections/cfr/part020/part020-appb.html.
*USNRC. 2003. NRC Regulations (10 CFR). Requirements binding on all persons and organizations who receive a license from NRC to use nuclear materials or operate nuclear facilities. Washington, D.C.: Nuclear Regulatory Commission. http://www.nrc.gov/reading-rm/doc-collections/cfr.
Uy HL, Reasner CA, Samuels MH. 1995. Pattern of recovery of the hypothalmic-pituitary-thyroid axis following radioactive iodine therapy in patients with Graves’ disease. Am J Med 99:173–179.7625422
*Uyttersprot N, Pelgrims N, Carrasco N, . 1997. Moderate doses of iodide in vivo inhibit cell proliferation and the expression of thyroperoxidase and Na^+^/I^−^ symporter mRNAs in dog thyroid. Mol Cell Endocrinol 131:195–203.9296378
Vadstrup S. 1989. Renal iodide clearance in rabbits. Acta Endocrinol 21:246–250.
*Vadstrup S. 1993. Comparative aspects of iodine conservation in mammals. Comp Biochem Physiol 106A(1):15–17.
Vagenakis A, Abreau C, Braverman L. 1971a. Effect of tracer doses of ^131^I on serum protein bound iodine and serum thyroxine concentration. J Nucl Med 12:637–638.4105923
Vagenakis AG, Braverman LE, Foster AE, . 1971b. Stimulatory effect of 5-fluorouracil in thyroid/serum iodide concentration ratios in the rat. Endocrinology 88:1250–1252.5547246
Vagenakis AG, Downs P, Braverman LE, . 1973. Control of thyroid hormone secretion in normal subjects receiving iodides. J Clin Invest 52:528–532.4683889
*Vagenakis AG, Wang C-A, Burger A, . 1972. Iodide-induced thyrotoxicosis in Boston. N Engl J Med 287(11):523–527.5050425
Valenta LJ. 1974. Effect of iodide and thyrotrophin on in vitro ^14^C-amino acid incorporation into rat thyroid proteins. Acta Endocrinol 76:273–285.
van Best JA. 1981. Dose calculations for ^123^I, ^124^I, ^125^I and ^131^I in the thyroid gland of the mouse, rat and man and comparison with thyroid function for mice and rats. Phys Med Biol 26(6):1035–1053.7323144
Van Best JA. 1982. Comparison of thyroid function in mice after various injected activities of ^123^I, ^125^I and ^131^I. Int J Radiat Biol 42(5):545–557.
*Vandecasteele CM, Van Hees M, Hardeman F, . 2000. The true absorption of ^131^I , and its transfer to milk in cows given different stable iodine diets. J Environ Radioact 47(3):301–317.
Vandenbroucke MF, Herveg JP, Beckers C, . 1967. Iodide uptake studies on isolated thyroid cells. Arch Int Physiol Biochim 75(1):185–186.4168922
van den Hove MF, Beckers C, Devlieger H, . 1999. Hormone synthesis and storage in the thyroid of human preterm and term newborns: Effect of thyroxine treatment. Biochimie 81:563–570.10403191
van der Heyden JTM, Docter R, van Toor H, . 1986. Effects of caloric deprivation on thyroid hormone tissue uptake and generation of low-T_3_ syndrome. Am J Physiol 251(14):E156–E163.3740255
*Vanderpas JB, Contempre B, Duale NL . 1990. Iodine and selenium deficiency associated with cretinism in Northern Zaire. Am. J Clin. Nutr. 52:1087–1093.2239787
*Vanderpump MPJ, Tunbridge WMG. 2000. The epidemiology of thyroid diseases. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 474–482.
Vanderpump MPJ, Ahlquist JAO, Franklyn JA, . 1996. Consensus statement for good practice and audit measures in the management of hypothyroidism and hyperthyroidism. Br Med J 313:539–544.8789985
Van Der Willigen AH, Habets JMW, Van Joost T, . 1988. Contact allergy to Japanese sargassum. Contact Dermatitis 18(4):250–252.
*Van Dilla MA, Fulwyler MJ. 1963. Thyroid metabolism in children and adults using very small (nanocurie) doses of iodine^125^ and iodine^131^. Health Phys 9:1325–1331.14086680
*Van Dilla MA, Fulwyler MJ. 1964. Radioiodine metabolisms in children and adults after the ingestion of very small doses. Science 144:178–179.14107474
Van Herle AJ, Van Herle KA. 1997. Thyroglobulin in benign and malignant thyroid disease. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 587–599.
Van Middlesworth I. 1971. Persistence of ^125^I in thyroid. N Engl J Med 286(3):161.
*Van Middlesworth L. 1954. Radioactive iodide uptake of normal newborn infants. Am J Dis Child 88:439–442.
*Van Middlesworth L. 1993. ^129^I and ^137^Cs fission products in thyroids of animals, 1984-1991. Health Phys 64(1):52–58.8416215
Van Nostrand D, Neutze J, Atkins F. 1986. Side effects of “rational dose” iodine-131 therapy for metastatic well-differentiated thyroid carcinoma. J Nucl Med 27:1519–1527.3760975
Van Sande J, Dumont JE. 1973. Effects of thyrotropin, prostaglandin E1 and iodide on cyclic 3’,5’-AMP concentration in dog thyroid slices. Biochim Biophys Acta 313:320–328.4354954
Van Sande J, Cochaux P, Mockel J, . 1983. Stimulation by forskolin of the thyroid adenylate cyclase, cyclic AMP accumulation and iodine metabolism. Mol Cell Endocrinol 29:109–119.6298030
Van Sande J, Deneubourg F, Beauwens R, . 1990. Inhibition of iodide transport in thyroid cells by dysidenin, a marine toxin, and some of its analogs. Mol Pharmacol 37:583–589.2157965
Van Sande J, Erneux C, Dumont JE. 1977. Negative control of TSH action by iodide and acetylcholine: Mechanism of action in intact thyroid cells. J Cyclic Nucleotide Res 3:335–345.201681
Van Sande J, Grenier G, Willems C, . 1975. Inhibition by iodide of the activation of the thyroid cyclic 3’,5’-AMP system. Endocrinology 96:781–786.163738
Van Wyngaarden M, McDougall IR. 1996. What is the role of 1100 MBq (<30 mCi) radioiodine ^131^I in the treatment of patients with differentiated thyroid cancer. Nucl Med Commun 17:199–207.8692486
*Vargo GJ. 2000. The Chernobyl accident: A comprehensive risk assessment. Columbus, OH: Battelle Press.
Varma SK, Murray R, Stanbury JB. 1978. Effect of maternal hypothyroidism and triiodothyronine on the fetus and newborn in rats. Endocrinology 102(1):24–30.743948
Varma VM, Beierwaltes WH, Nofal MM, . 1970. Treatment of thyroid cancer: Death rates after surgery and after surgery followed by sodium iodide I 131. JAMA 214(8):1437–1442.5536343
Varrone S, Consiglio E, Covelli I. 1970. The nature of inhibition of mitochondrial malate dehydrogenase by thyroxine, iodine cyanide and molecular iodine. Eur J Biochem 13:305–312.4314809
Vasilenko IY. 1980. Iodine isotopes in radiation hygiene. J Hyg Epidemiol Microbiol Immunol 24(2):142–149.
*Vasilenko IY. 1986. A radiation-hygienic appraisal of biosphere contamination with ^129^I. J Hyg Epidemiol Microbiol Immunol 30:243–248.
Vassilopoulou-Sellin R, Sellin JH. 1996a. The gastrointestinal tract and liver in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 816–820.
Vassilopoulou-Sellin R, Sellin JH. 1996b. The gastrointestinal tract and liver in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 632–636.
Vatulina GG. 1977. [Metabolic changes in rat muscle tissue under separate and combined exposure to Iodine 131 and Strontium 89.] Radiobiologiia 17(5):728–732. (Russian)594330
Vejjajiva S, Poshyachinda M, Yenbutra D. 1979. ^131^I treated hypothyroidism and thyroid antibody levels. J Med Assoc Thai 62(2):51–53.762484
Veldhuis JD. 1978. ^131^I-induced hypothyroidism before recurrence of hyperthyroidism. Lancet 1(8071):993–994.
Velkeniers B, Cytryn R, Vanhaelst I, . 1988. Treatment of hyperthyroidism with radioiodine: Adjunctive therapy with antithyroid drugs reconsidered. Lancet 1:1127–1129.2452940
Venderpas JB, Rivera-Vanderpas MT, Bourdoux P, . 1986. Reversibility of severe hypothyroidism with supplmentary iodine in patients with endemic cretinism. N Engl J Med 315(13):791–795.3018564
Venkataraman GM, Yatin M, Ain KB. 1998. Cloning of the human sodium-iodide symporter promoter and characterization in a differentiated human thyroid cell line, KAT-50. Thyroid 8(1):63–69.9492156
Venturi S, Donati FM, Venturi A, . 2000. Environmental iodine deficiency: A challenge to the evolution of terrestrial life? Thyroid 10(8):727–729.11014322
*Verger P, Aurengo A, Geoffroy B, . 2001. Iodine kinetics and effectiveness of stable iodine prophylaxis after intake of radioactive iodine: A review. Thyroid 11(4):353–360.11349833
*Verma S, Hutchins P, Guo J . 2000. Role of MHC class I expression and CD8^+^ T cells in the evolution of iodine-induced thyroiditis in NOHh2^h4^ and NOS mice. Eur J Immunol 30:1191–1202.10760809
*Verma KK, Jain A, Verma A. 1992. Determination of iodide by high-performance liquid chromatography after precolumn derivatization. Anal Chem 64:1484–1489.
*Versloot PM, Schroder-van der Elst JP, van der Heide D, . 1997. Effects of marginal iodine deficiency during pregnancy: Iodide uptake by the maternal and fetal thyroid. Am J Physiol 273:E1121–E1126.9435527
Versloot PM, Schroder-van der Elst JP, van der Heide D, . 1998. Effects of marginal iodine deficiency on thyroid hormone production, distribution and transport in nonpregnant and near-term pregnant rats. Eur J Endocrinol 138:713–718.9678542
Vestergaard H, Laurberg P. 1989. Radioiodine and aggravation of Graves’ ophthalmopathy. Lancet 2(8653):47.2567820
Vetter RJ. 1997. Regulations for radioiodine therapy in the United States: Current status and the process of change. Thyroid 7(2):209–211.9133686
*Vicens-Calvet E, Potau N, Carreras E, . 1998. Diagnosis and treatment in utero of goiter with hypothyroidism caused by iodide overload. J Pediatr 133:147–148.9672530
Vickery ALJ, Williams ED. 1971. Comparative biological effects of ^125^I and ^131^I on the rat thyroid. Acta Endocrinol 66:201–212.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vieira JGH, Brandao CMA, Kasamatsu TS, . 1991. Parathyroid hormone secretory reserve in patients submitted to 131-iodine therapy for hyperthyroidism. Braz J Med Biol Res 24:1103–1105.1822999
Vilijn F, Carrasco N. 1989. Expression of the thyroid sodium/iodide symporter in Xenopus laevis oocytes. J Biol Chem 264(20):11901–11903.2745421
Villa SM, Alexander NM. 1987. Carbamazepine (Tegretol) inhibits in vivo iodide uptake and hormone synthesis in rat thyroid glands. Endocr Res 13(4):385–397.3447884
*Virion A, Deme D, Pommier J, . 1980. Opposite effects of thiocyanate on tyrosine iodination and thyroid hormone synthesis. Eur J Biochem 112:1–7.7449758
*Visser TJ. 1990. Importance of deiodination and conjugation in the hepatic metabolism of thyroid hormone. In: Greer MA, ed. The thyroid gland. New York, NY: Raven Press, Ltd, 255–283.
*Visser TJ. 1994. Role of sulfation in thyroid hormone metabolism. Chem Biol Interact 92:293–303.8033262
*Visser TJ, Kaptein E, van Raaij JAGM, . 1993. Multiple UDP-glucuronyltransferases for the glucuronidation of thyroid hormone with preference for 3,3’,5’-triiodothyronine (reverse T_3_). FEBS Lett 315(1):65–68.8416813
Vobecky M, Babicky A, Lener J, . 1997. [Environmental bromine and iodine interaction.] Hygiena 42(2):86–91. (Czech)
*Vogt R, Sander R, Von Glasgow R, . 1999. Iodine chemistry and its role in halogen activation and ozone loss in the marine boundary layers: A model study. J Atmos Chem 32:375–395.
Voigt G. 1993. Chemical methods to reduce the radioactive contamination of animals and their products in agricultural ecosystems. Sci Total Environ 137:205–225.8248768
*Voigt G, Henrichs K, Prohl G, . 1988. Measurements of transfer coefficients fro ^137^Cs, ^60^Co, ^54^Mn, ^22^Na, ^131^I and ^95m^Tc from feed into milk and beef. Radiat Environ Biophys 27:143–152.3393622
*Voigt G, Muller H, Prohl G, . 1989. Experimental determination of transfer coefficients of ^137^Cs and ^131^I from fodder into milk of cows and sheep after the Chernobyl accident. Health Phys 57(6):967–973.2584031
Voigt G, Schotola C, Probstmeier G, . 1994. Influence of stable iodine on the transfer of ^131^I into cows’ milk. Radiat Environ Biophys 33:243–250.7809370
Volkov AA, Iulbarisov AV, Zaitsev VM, . 1982. [Use of sodium iodide labeled with short-lived 123I for the study of the iodine absorption and topography of the thyroid.] Med Radiol 27(2):34–36. (Russian).
Voltti H, Piha RS. 1978. Iodine in the treatment of alloxan diabetes in rats. Isr J Med Sci 14(10):1081–1083.738872
Voltti H, Piha RS, Alavaikko M, . 1973. Antitumour activity of iodine in acidic medium with calcium. Nature 246:98–100.4585856
Von Hofe SE, Dorfman SG, Carretta RF, . 1978. The increasing incidence of hypothyroidism within one year after radioiodine therapy for toxic diffuse goiter. J Nucl Med 19:180–184.627898
*Von Zallinger C, Tempel K. 1998. Transplacental transfer of radionuclides. A review. Zentralbl Veterinarmed A 45:581–590.9923140
Vorhees CV, Butcher RE, Brunner RL. 1984. Developmental toxicity and psychotoxicity of potassium iodide in rats: A case for the inclusion of behaviour in toxicological assessment. Food Chem Toxicol 22(12):963–970.6210234
Vorherr H, Vorherr UF, Mehta P, . 1980. Vaginal absorption of povidone-iodine. JAMA 244(23):2628–2629.7431610
Vormittag W, Ring F, Kunze-Muhl E, . 1982. Structural chromosomal aberrations before and after administration of 20 uCi iodine-131. Mutat Res 105:333–336.7144790
*Vought RL, Brown FA, Wolff J. 1972. Erythrosine: An adventitous source of iodide. Journal of Clinical Endocrinology and Metabolism 34:747–752.5012776
*Vroye L, Beauwens R, Van Sande J, . 1998. The Na^+^-I^−^ cotransporter of the thyroid: Characterization of new inhibitors. Pflugers Arch(Eur J Physiol) 435:259–266.9382940
Vulsma T, Menzel D, Abbad FCB, . 1990. Iodine-induced hypothyroidism in infants treated with continuous cyclic peritoneal dialysis [Letter]. Lancet 336:812.
Vulsma T, Rammeloo JA, Gons MH, . 1991. The role of serum thyroglobulin concentration and thyroid ultrasound imaging in the detection of iodide transport defects in infants. Acta Endocrinol 124:405–410.
Vykhovanets EV, Chernyshov VP, Slukvin II, . 1997. ^131^I dose-dependent thyroid autoimmune disorders in children living around Chernobyl. Clin Immunol Immunopathol 84(3):251–259.9281383
Wachholz BW. 1990. Overview of the National Cancer Institute’s activities related to exposure of the public to fallout from the Nevada test site. Health Phys 59(5):511–514.2211110
Wadeleux PA, Etienne-Decerf J, Winand RJ, . 1978. Effects of thyrotropin on iodine metabolism of dog thyroid cells in tissue culture. Endocrinology 102(3):889–902.217607
Wagar G. 1971. Increase in thyroid uptake of radioiodine induced by actinomycin D. Acta Endocrinol 67:605–615.
*Wagner HN, Nelp WB, Dowling JH. 1961. Use of neutron activation analysis for studying stable iodide uptake by the thyroid. J Clin Invest 40:1984–1992.14004364
Wahl VR, Oekonomopoulos R, Steiner B, . 1973. Einflub von dijofphenolsulfonsaure (DJPS) auf den jodstoffwechsel der ratte und auf die bindung von thyroxin an humanserumpraalbumin. Arzneim Forsch 23(8):1009–1014.4128969
Wahlberg P. 1976a. Thyrotoxicosis induced by iodine in food [Letter]. Br Med J 2(6043):1070.
Wahlberg P. 1976b. Thyrotoxicosis induced by iodine in food [Letter]. Br Med J 1(6016):1016.
Wakeford R. 1999. Accidents and their consequences. J Radiol Prot 19(4):291–292.10616775
Waldhausen JHT. 1997. Controversies related to the medical and surgical management of hyperthyroidism in children. Semin Pediatr Surg 6(3):121–127.9263333
Waldstein SS. 1997. Replacement and suppressive treatment with thyroid hormone. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lipponcott-Raven Publishers, 475–494.
Walgraeve D, Verhoef G, Stul M, . 1991. Chronic myelogenous leukemia after treatment with ^131^I for thyroid carcinoma: Report of a case and review of the literature. Cancer Genet Cytogenet 55:217–224.1933823
Walicka MA, Adelstein SJ, Kassis AI. 1998. Indirect mechanisms contribute to biological effects produced by decay of DNA-incorporated iodine-125 in mammalian cells in vitro: Clonogenic survival. Radiat Res 149:142–146.9457893
Walinder G. 1971. Determination of the ^131^I dose to the mouse thyroid. Acta Radiol Ther Phys Biol 10:558–578.5149683
Walinder G. 1972. Quantitative effects of ^131^I on different tissue components in foetal and goitrogen challenged mouse thyroids. Acta Radiol 11:1–23.
Walinder G, Feinstein RE, Gimeno EJ. 1986. Effect of high ^131^I doses on the bone uptake and retention of ^90^Sr and ^90^Y. Acta Radiol Oncol 25:255–260.3030053
Walls RP. 1976. The characteristics and physiologic implications of the interaction of iodide with human erythrocytes. Diss Abstr Int B 36(11):5542-B.
*Walser M, Rahill WJ. 1965. Renal tubular reabsorption of iodide as compared with chloride. J Clin Invest 44(8):1371–1381.14322041
Walsh JP, Dayan CM, Potts MJ. 1999. Radioiodine and thyroid eye disease. Br Med J 319:68–69.10398607
Walthard VB. 1963. [Structural change of the struma maligna with respect to iodine prophylaxis of goiter.] Schweiz Med Wochenschr 93(23):809–814. (German)
Wang JF, Becks GP, Hanada E, . 1991. Hormonal regulation of insulin-like growth factor (IGF)-binding proteins secreted by isolated sheep thyroid epithelial cells: Relationship with iodine organification. J Endocrinol 130:129–140.1715378
Wang J-X, Boice JD, Li B-X, . 1988. Cancer among medical diagnostic x-ray workers in China. Journal of the National Cancer Institute 80:344–350.3357200
Wang Z, Boice JD, Wei L, . 1990. Thyroid nodularity and chromosome aberrations among women in areas of high background radiation in China. J Natl Cancer Inst 82:478–485.2313719
*Waran KD, Munsick RA. 1995. Anaphylaxis from povidone-iodine. Lancet 345:1506.
Warner TFCS. 1979. Iodine-131 and malignancy [Letter]. Lancet 1(8106):38.
Warters RL. 1977. 125-Iodine: A probe in radiobiology [Abstract]. Diss Abstr Int B 38(4):1598B.
Warters RL, Hofer KG. 1977. Radionuclide toxicity in cultured mammalian cells: Elucidation of the primary site for radiation-induced division delay. Radiat Res 69:348–358.841007
Warters RL, Hofer KG, Harris CR, . 1977. Radionuclide toxicity in cultured mammalian cells: Elucidation of the primary site of radiation damage. Curr Top Radiat Res Q 12:389–407.
Wartofsky L. 1995. Summation, commentary, and overview: Concerns over aggravation of Graves’ ophthalmopathy by radioactive iodine treatment and the use of retrobulbar radiation therapy. J Clin Endocrinol Metab 80(2):347–349.7852488
Wartofsky L. 1996a. Myxedema coma. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 871–877.
Wartofsky L. 1996b. Thyrotoxic storm. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 701–707.
Wartofsky L. 1997. Radioiodine therapy for Graves’ disease: Case selection and restrictions recommended to patients in North America. Thyroid 7(2):213–216.9133687
Wasserman HJ, Klopper JF. 1993. Analysis of radiation doses received by the public from ^131^I treatment of thyrotoxic outpatients. Nucl Med Commun 14:756–760.8233240
Wasserman J, Blomgren H, Petrini B, . 1988. Changes of the blood lymphocyte subpopulations and their functions following ^131^I treatment for nodular goitre and ^32^P treatment for polycythemia vera. Int J Radiat Biol 53(1):159–167.
Wassermann M, Wassermann D, Kedar E, . 1972. Effects of dieldrin and gamma BHC on serum proteins and PBI. Bull Environ Contam Toxicol 8(3):177–185.4117365
Watanabe N, Yokoyama K, Kinuya S, . 1998. Radiotoxicity after iodine-131 therapy for thyroid cancer using the micronucleus assay. J Nucl Med 39(3):436–440.9529288
Waterfall WK. 1980. Iodide. Br Med J 281:988–989.7427554
Waters W, Kutsim H, Wellner U. 1984. The influence of elevated iodide supply on the autonomously functioning thyroid gland. Nuklearmedizin 23:93–99.6473118
Watson AB, Brownlie BEW, Frampton CM, . 1988. Outcome following standardized 185 MBq dose ^131^I therapy for Graves’ disease. Clin Endocrinol 28:487–496.
*Wayne EJ, Koutras DA, Alexander WD. 1964. Clinical aspects of iodine metabolism. Philadelphia, PA: F.A. Davis Company.
Weber G, Vigone MC, Rapa A, . 1998. Neonatal transient hypothyroidism: Aetiological study. Arch Dis Child 79:F70–F72.
*Weetman AP. 2000. Chronic autoimmune thyroiditis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott-Raven, 721–732.
*Wehmann G. 1963. Comparison of ingestion to inhalation dose to man from I^131^. Health Physics 9:1221.14086664
*Weinberg HG, Yamada H. 1997. Sub part-per-billion analysis of bromate, iodate, and chlorite in drinking water using a new post ion chromatography column reaction and UV detection. In: Water quality technology conference proceedings, November 9-12, 1997, Denver, Co., 4B1/1-4B1/13.
Weinreich R. 1984. Iodine-124 in nuclear medicine: A critical evaluation. Radiakt Isot Klin Forsch 16(2):555–563.
*Weiss SJ, Philp NJ, Ambesi-Impiombato FS, . 1984a. Thyrotropin-stimulated iodide transport mediated by adenosine 3’,5’-monophosphate and dependent on protein synthesis. Endocrinology 114(4):1099–1107.6323129
*Weiss SJ, Philip NJ, Grollman EF. 1984b. Effect of thyrotropin on iodide efflux in FRTL-5 cells mediated by Ca^2+^. Endocrinology 114:1108–1113.6323130
Weiss WJ, Philp NJ, Grollman EF. 1984c. Iodide transport in a continuous line of cultured cells from rat thyroid. Endocrinology 114:1090–1098.6705729
*Wellner U, Eschner W, Hillger HW, . 1998. [The exposure of relatives to patients of a nuclear medicine ward after radio iodine therapy by inhalation of ^131^I in their home.] Nuklearmedizin 37:113–119. [Erratum published in “Nuklearmedizin 37(4):49 (1998)” attached] (German)9604232
Werner SC, Hamilton HB, Leifer E, . 1950. An appraisal of the radioiodine tracer technic as a clinical procedure in the diagnosis of thyroid disorders: Uptake measurement directly over the gland and a note on the use of thyrotropin (T.S.H.). J Clin Endocrinol 10:1054–1076.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Whaley JM, Little JB. 1990. Efficient mutation induction by ^125^I and ^131^I decays in DNA of human cells. Radiat Res 123:68–74.2371380
*Whitehead DC. 1979. Iodine in the U.K. environment with particular reference to agriculture. J Appl Ecol 16:269–279.
*Whitehead DC. 1984. The distribution and transformations of iodine in the environment. Environ Int 10:321–339.
*Whitnack GC. 1975. Single-sweep polarographic techniques useful in micropollution studies of ground and surface waters. Anal Chem 47:618–621.
Whybrow PC. 1972. Synergistic action between iodine and lithium [Letter]. JAMA 221(5):506.
Whybrow PC. 1996a. Behavioral and psychiatric aspects of hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 866–870.
Whybrow PC. 1996b. Behavioral and psychiatric aspects of thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 696–700.
*Wichers M, Benz E, Palmedo H, . 2000. Testicular function after radioiodine therapy for thyroid carcinoma. Eur J Nucl Med 27(5):503–507.10853804
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York, NY: Academic Press.
Wiener JD, Thijs LG, Meijer S. 1975. Thyroid carcinoma after ^131^I treatment for hyperthyroidism. Acta Med Scand 198:329–330.1189990
Wiersinga WM. 1998. Preventing Graves’ ophthalmopathy. N Engl J Med 338(2):121–122.9420345
Wiesenfeld D, Webster G, Cameron F, . 1983. Salivary gland dysfunction following radioactive iodine therapy. Oral Surg Oral Med Oral Pathol 55(2):138–141.6572864
Wilkin JK, Strobel D. 1985. Iododerma occurring during thyroid protection treatment. Cutis 36(4):335–337.4064756
*Willard DH, Bair WJ. 1961. Behaviour of I^131^ following its inhalation as a vapour and as a particle. Acta Radiol 55:486–496.13785332
Williams ED. 1990. TSH and thyroid cancer. Horm Metab Res suppl 23:72–75.
Williams ED, Doniach I, Bjarnason O, . 1977. Thyroid cancer in an iodide rich area. Cancer 39:215–222.832237
*Williams JA. 1969. Electrical polarization of thyroid follicles in the perfused rabbit thyroid gland. Am J Physiol 217(4):1094–1100.4980947
Williams JA, Malayan SA. 1975. Effects of TSH on iodide transport by mouse thyroid lobes in vitro. Endocrinology 97:162–168.166827
Williams JA, Berens SC, Wolff J. 1971. Thyroid secretion in vitro: Inhibition of TSH and dibutyryl cyclic-AMP stimulated and ^131^I release by Li^+1^. Endocrinology 88:1385–1388.4325079
Williams RL, Lipari F, Potter RA. 1990. Formaldehyde, methanol and hydrocarbon emissions from methanol-fueled cars. J Air Waste Manage Assoc 40:747–756.
Wilmott S, Nair S, Ponting AC. 1991. An uncertainty analysis of the ingestion dose following a discrete deposition from atmosphere. EUR EUR 13013/2:891–907.
Wilson LM, Barrington SF, Morrison ID, . 1998. Therapeutic implications of thymic uptake of radioiodine in thyroid carcinoma. Eur J Nucl Med 25:622–628.9618577
Wilson MG. 1962. The effect of maternal medications upon the fetus and the newborn infant. Am J Obstet Gynecol 83(6):818–825.14007397
Wilson O, Stone JM, Monty DE. 1983. Long-term study of thyroid function in healthy beagle dogs, using ^125^I. Am J Vet Res 44(7):1392–1398.6881678
Wingert DJ, Friesen SR, Iliopoulos JI, . 1986. Post-thyroidectomy hypocalcemia. Am J Surg 152:606–610.3789283
Winslow CP, Meyers AD. 1998. Hypocalcemia as a complication of radioiodine therapy. Am J Otolaryngol 19(6):401–403.9839917
Winternitz SR, Winternitz WW. 1976. Fatal hypothyroidism following treatment of Graves’ disease: A preventable complication. J Ky Med Assoc 74(9):459–460.989494
Winters JC, Fuselier HAJ. 1992. Invasive bladder cancer following ^125^iodine implants. J Urol 148:1898–1900.1433634
Wiseman JC, Hales IB, Joasoo A. 1982. Two cases of lymphoma of the parotid gland following ablative radioiodine therapy for thyroid carcinoma. Clin Endocrinol 17:85–89.
Wiszniewska B, Marchlewicz M, Piasecka M, . 1998. Phospholipid content and lamellar structures in the epididymal epithelial cells of rats treated chronically with lead acetate [Pb(II)]. Folia Biol 46:215–224.
Wolf M, Leventon G. 1990. Acute iodide-induced enlargement of the salivary glands. J Oral Maxillofac Surg 48:71–72.2294214
*Wolff J. 1964. Transport of iodide and other anions in the thyroid gland. Physiol Rev 44:45–90.14105583
Wolff J. 1980. Physiological aspects of iodide excess in relation to radiation protection. J Mol Med 4:151–165.
*Wolff J. 1983. Congenital goiter with defective iodide transport. Endocrine Rev 4(3):240–254.6313338
Wolff J. 1989. Excess iodide inhibits the thyroid by multiple mechanisms. Adv Exp Med Biol 261:211–244.2699970
Wolff J. 1996. Iodide prophylaxis for reactor accidents. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health. Amsterdam, The Netherlands: Elsevier Science, 227–237.
*Wolff J, Chaikoff IL. 1948. Plasma inorganic iodide as a homeostatic regulator of thyroid function. J. Biol Chem 74:555–564.
*Wolff J, Chaikoff IL, Goldberg RC, . 1949. The temporary nature of the inhibitory action of excess iodide on organic iodine synthesis in the normal thyroid. Endocrinol 45:504–513.
Wollman SH. 1995. Thyroid radioiodide transport: Models, rate-limiting steps, and relation to formation of iodoprotein. Eur J Cell Biol 66:217–225.7774607
Wollman SH, Reed FE. 1959. Transport of radioiodide between thyroid gland and blood in mice and rats. Am J Physiol 196(1):113–120.13617447
Wondisford FE, Magner JA, Weintraub BD. 1996. Thyrotropin: Chemistry and biosynthesis of thyrotropin. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 190–207.
*Wong FL, Ron E, Gierlowski T, . 1996. Benign thyroid tumors: General risk factors and their effects on rediation risk estimation. Am J Epidemiol 144:728–733.8857821
*Wong GTF, Cheng X-H. 1998. Dissolved organic iodine in marine waters: Determination, occurrence and analytical implications. Mar Chem 59:271–281.
Wongphatarakul V, Friedlander SK, Pinto JP. 1998. A comparative study of PM_2.5_ ambient aerosol chemical databases. Environ Sci Technol 32:3926–3934.
*Wood DH, Elefson EE, Horstman VG, . 1963. Thyroid uptake of radioiodine following various routes of administration. Health Phys 9:1217–1220.14086663
*Woodbury DM, Woodbury JW. 1963. Correlation of micro-electrode potential recordings with histology of rat and guinea-pig thyroid glands. J Physiol 169:553–567.14082118
Woolf PD. 1997. Thyroiditis. In: Falk SA, ed. Thyroid disease: Endocrinology, surgery, nuclear medicine, and radiotherapy. Philadelphia, PA: Lippincott-Raven Publishers, 393–410.
Worley RJ, Crosby WM. 1974. Hyperthyroidism during pregnancy. Am J Obstet Gynecol 119(2):150–155.4132686
Worthington-Roberts B. 1997. The role of maternal nutrition in the prevention of birth defects. J Am Diet Assoc 97(Suppl 2):S184–S185.9336586
Wright EM. 1974. Active transport of iodide and other anions across the choroid plexus. J Physiol 240:535–566.4369751
Wu JY, Shu SG, Yang CF, . 2002. Mutation analysis of thyroid peroxidase gene in Chinese patients with total iodide organification defect: Identification of five model mutations. J Endocrinol 172(3):627–635.11874711
Wuttke K, Streffer C, Muller WU, . 1996. Micronuclei in lymphocytes of children from the vicinity of Chernobyl before and after ^131^I therapy for thyroid cancer. Int J Radiat Biol 69(2):259–268.8609463
Wyburn JR. 1972. Human breast milk excretion of radionuclides following administration of radiopharmaceuticals. J Nucl Med 14(2):115–117.
Xiangbao L, Yangzhong X. 1992. Relationship between ^131^I ground surface contamination activity and gamma spectra above ground. Health Phys 62(4):328–331.1597382
*Xie Y-L, Hopke PK, Paatero P, . 1999. Identification of source nature and seasonal variations of Arctic aerosol by the multilinear engine. Atmos Environ 33:2549–2562.
Yadav HS, Chaudhuri BN, Mukherjee SK. 1970. Effect of ethyl alcohol on thyroidal iodide trapping and renal clearance of ^131^I label in rats. Indian J Med Res 58:1421–1427.5501452
Yalow RS. 1983. Risks in mass distribution of potassium iodide. Bull N Y Acad Med 59(10):1020–1027.6582963
Yalow R. 1990. Editorial: The contributions of ^131^I to the understanding of radiation carcinogenesis. Endocrinology 126(4):1787–1789.2318141
Yamamoto K, Onaya T, Yamada T, . 1972. Inhibitory effect of excess iodide on thyroid hormone release as measured by intracellular colloid droplets. Endocrinology 90:986–991.4334704
Yamane T, Yan Y, Yang L, . 1992. Tissue developmental anomalies of Corti’s organ of the inner ear in experimental cretin rats [Abstract]. Teratology 46(6):44B.
Yamashita H, Noguchi S, Murakami N, . 1994. Effect of thyroid-stimulating hormone on cultured thyrocytes obtained from patients with Graves’ disease and inhibitive effect by sodium iodide: A functional study. Pathol Int 44:827–831.7866565
Yamashita K, Aiyoshi Y, Oka K, . 1975. Effects of calcium ionophore (A-23187) on glucose oxidation and iodide transport in dog thyroid slices. Endocrinol Jpn 22(5):415–418.174902
Yamashita S, Ito M, Namba H, . 1996. Screening for childhood thyroid diseases around Chernobyl. In: Nagataki S, Yamashita S, eds. Nagasaki symposium radiation and human health: Proposal from Nagasaki. Amsterdam, The Netherlands: Elsevier, 103–116.
Yan T, Wang D, Zhang H, . 1994. Effect of iodine deficiency on the development of cerebral cells in rats. Teratology 50(6):49B.
Yan Y, Liu J, Yamane T, . 1993. Developmental anomalies of cerebellar cortex in experimental cretin rats [Abstract]. Teratology 48(5):531.
Yang CM, Olsen KR, Schwade JG, . 1993. Dose rate effect of ^125^I irradiation on normal rabbit eyes and experimental choroidal melanoma. Exp Eye Res 57:577–585.8282044
Yasui LS. 1992. Cytotoxicity of ^125^I decay in the DNA double strand break repair deficient mutant cell line, xrs-5. Int J Radiat Biol 62(5):613–618.1361518
Yasui LS, Hofer KG. 1986. Role of mitochondrial DNA in cell death induced by ^125^I decay. Int J Radiat Biol 49(4):601–610.
Yeh SDJ, La Quaglia MP. 1997. ^131^I therapy for pediatric thyroid cancer. Semin Pediatr Surg 6(3):128–133.9263334
Yi T. 1995. A case of blindness caused by acute iodine poisoning. Chin Med J 108(7):555–556.7555279
Yiou F, Raisbeck GM, Christensen GC, . 2002. ^129^I/^127^I, ^129^I/^137^Cs and ^129^I/^99^Tc in the Norwegian coastal current from 1980 to 1998. J Environ Radioact 60:61–71.11936614
Yokoyama N, Tominaga T, Eishima K, . 1991. Effect of iodide on human thyroid peroxidase in thyroid cells. In: Gordon A, Gross J, Hennemann G, eds. Progress in thyroid research. Rotterdam, the Netherlands: Balkema, 483–485.
Yoosufani Z, Slavin JD, Hellman RM, . 1987. Preleukemia following large dose radioiodide therapy for metastatic thyroid carcinoma. J Nucl Med 28:1348–1350.3612295
*Yoshida A, Sasaki N, Mori A, . 1997. Different electrophysiological character of I^−^, ClO^−^_4_, and SCN^−^ in the transport by NA^+^/I^−^ symporter. Biochem Biophys Res Commun 231:731–734.9070882
*Yoshida A, Taniguchi S, Hisatome I, . 2002. Pendrin is an iodide-specific apical porter responsible for iodide efflux from thyroid cells. J Clin Endocrinol Metab 87(7):3356–3361.12107249
Yoshida K, Aizawa Y, Kaise N, . 1998. Role of thyroid-stimulating blocking antibody in patients who developed hypothryoidsim with one year after ^131^I treatment for Graves’ disease. Clin Endocrinol 48:17–22.
Yoshimura S, Shishiba Y, Shimizu T. 1973. Evidence for stimulation of thyroidal secretion by iodoaminoacids or iodide. Endocrinol Jpn 20(2):217–219.4740602
Yoshinari M, Tokuyama T, Okamura K, . 1988. Iodide-induced thyrotoxicosis in a thyroidectomized patient with metastatic thyroid carcinoma. Cancer 61:1674–1678.3349427
*Young WF. 1990. Human liver tyrosylsulfotransferase. Gastroenterology 99:1072–1078.2394328
*Yuita K. 1994a. Overview and dynamics of iodine and bromine in the environment: 1. Dynamics and iodine and bromine in soil-plant system. JARQ 28:90–99.
Yuita K. 1994b. Overview and dynamics of iodine and bromine in the environment: 2. Iodine and bromine toxicity and environmental hazards. JARQ 28:100–111.
Yukimura Y, Ikejiri K, Kojima A, . 1976. Effects of excess iodide and other anions on thyroid hormone secretion in normal or hypophysectomized rats treated with graded doses of thyroid hormone. Endocrinology 99:541–548.182459
Zagrodzki P, Nicol F, McCoy MA, . 1998. Iodine deficiency in cattle: Compensatory changes in thyroidal selenoenzymes. Res Vet Sci 64(3):209–211.9690605
Zagrodzki P, Szmigiel H, Ratajczak R, . 2000. The role of selenium in iodine metabolism in children with goiter. Environ Health Perspect 108(1):67–71.10620526
Zanzonico PB. 1997. Radiation dose to patients and relatives incident to ^131^I therapy. Thyroid 7(2):199–204.9133684
*Zanzonico PB, Becker DV. 2000. Effects of time of administration and dietary iodine levels on potassium iodide (KI) blockade of thyroid irradiation by ^131^I from radioactive fallout. Health Phys 78(6):660–667.10832925
Zanzonico PB, Becker DV, Bigler RE, . 1987. Fetal radiation dosimetry for maternally administered I131-iodide: Effect of maternal thyroid function. J Nucl Med 28(4):581.
Zec N, Donovan JW. 1993. Reply to letter. N Engl J Med 328(5):356.
Zeighami EA, Morris MD. 1986. Thyroid cancer risk in the population around the Nevada test site. Health Phys 50(1):19–32.3943971
Zelicoff AP, Pezzullo JC. 2002. Thyroid cancer 15 years after Chernobyl. Lancet 359(9321):1946–1947.
*Zemlyn S, Wilson WW, Hellweg PA. 1981. A caution on iodine water purification. West J Med 135:166–167.7281653
Zhang M-L, Sugawa H, Mori T. 1995. Inhibition of thyrocyte iodide uptake by H^+^K^+^ATPase inhibitor, timoprazole. Endocr J (Tokyo) 42(4):489–496.
*Zhao J, Wang P, Shang L, . 2000. Endemic goiter associated with high iodine intake. Am J Public Health 90(10):1633–1635.11030003
Zhao W, Zhu H, Yu Z, . 1998. Long-term effects of various iodine and fluorine doses on the thyroid and fluorosis in mice. Endocr Regul 32:63–70.10330519
Zhorno LI, Il’in BN, Mikhaidarova PP. 1982. [Morphofunctional changes in the thyroid after separate and combined exposure to iodine radioisotope.] Radiobiologiia 22(4):553–556. (Russian)7146349
Zhu X, Lu T, Song X, . 1984. Endemic goiter due to iodine rich salt and its pickled vegetables. Chin Med J 97(7):545–548.6441691
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zimmermann M, Adou P, Torresani T, . 2000. Persistence of goiter despite oral iodine supplementation in goitrous children with iron deficiency anemia in Cote d’Ivoire. Am J Clin Nutr 71(1):88–93.10617951
Zsebok Z, Baumgartner E. 1978. [Chromosomal changes following irradiation with small doses (author’s translation).] Fortschr Geb Rontgenstrahlen Nuklearmed Erganzungsbd 129(6):781–784. (German)
Zuckier LS, Dadachova E, Dohan O, . 2001. The endogenous mammary gland Na^+^/I^−^ symporter may mediate effective radioiodide therapy in breast cancer. J Nucl Med 42(6):987–988.11390567
Zuckier LS, Li Y, Chang CJ. 1998. Evaluation in a mouse model of a thyroid-blocking protocol for ^131^I antibody therapy (short communication). Cancer Biother Radiopharm 13(6):457–460.10851439
Zuker CS, Cowman AF, Rubin GM. 1985. Isolation and structure of a rhodopsin gene from D. melanogaster. Cell 40:851–858.2580638
Zvonova IA. 1989. Dietary intake of stable I and some aspects of radioiodine dosimetry. Health Phys 57(3):471–475.2777553
Zvonova IA. 1996. The principles of radioiodine dosimetry following a nuclear accident. In: Radiodosimetry and preventative measures in the event of a nuclear accident. Austria: International Atomic Energy Agency, 15–33. IAEA-TECDOC-893.