# PEER REVIEW

A peer review panel was assembled for iodine. The panel consisted of the following members:

1. Dr. Lewis E. Braverman, Section Chief, Endocrinology, Diabetes, and Nutrition, Boston Medical Center, 88 East Newton Street, Evans 201, Boston, MA 02118;
2. Dr. Richard Leggett, Life Sciences Division, Oak Ridge National Laboratory, 11401 Glen Iris Lane, Knoxville, TN 37922-1744;
3. Dr. Ray Lloyd, Research Professor of Radiobiology, University of Utah School of Medicine, 6588 South Gold Medal Drive, Taylorsville, UT 84084-6964;
4. Dr. Marvin Rallison, Professor Emeritus of Pediatric Endocrinology and Metabolism, University of Utah School of Medicine, 1706 Oakridge Dr., Salt Lake City, UT 84106;
5. Dr. Elaine Ron, Senior Investigator, National Cancer Institute, Division of Cancer Epidemiology and Genetics, Radiation Epidemiology Branch, 6120 Executive Boulevard, EPS/7084, Rockville, MD 20852;
6. Dr. Kiyohiko Mabichi, National Cancer Institute, 6120 Executive Boulevard, Rockville, MD 20852;
7. Dr. Noel R. Rose, Professor of Molecular Medicine, Johns Hopkins University, 615 North Wolfe St., Baltimore, MD 21205; and
8. Dr. Roy E. Shore, Professor and Director, Division of Epidemiology and Biostatistics, New York University School of Medicine, 650 First Ave., New York, NY 10016-3240.

These experts collectively have knowledge of iodine’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.