# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding stable iodine in air, water, and other media are summarized in Table 8-1. The regulations regarding radioactive iodine are summarized in Tables 8-2 and 8-3.

No MRLs were derived for inhalation exposure to stable or radioactive iodine. Oral MRLs of 0.01 mg/kg/day were derived for both acute- and chronic-duration exposures. No oral MRL was derived for intermediate-duration exposure.

The EPA has not classified iodine for human carcinogenicity, nor has the EPA derived reference concentrations (RfCs) or reference doses (RfDs) for stable or radioactive iodine (IRIS 2000).

Table 8-1 Regulations and Guidelines Applicable to Stable Iodine

Agency | Description | Information | References
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | STEL (ceiling) | 0.1 ppm | ACGIH 2000
NIOSH | REL (ceiling) IDLH | 0.1 ppm 2.0 ppm | NIOSH 2001
OSHA | PEL (ceiling)—general industry | 0.1 ppm | OSHA 2001b; 29CFR1910.1000
OSHA | PEL (ceiling)—construction industry | 0.1 ppm | OSHA 2001a; 29CFR1926.55
OSHA | PEL (ceiling)—shipyard industry | 0.1 ppm | OSHA 2001c; 29CFR1915.1000
b. Water
EPA | Effluent limitation guidelines; inorganic chemicals manufacturing point source category for iodine production | Effluent reduction attainable by the application of BPT; no discharge of process wastewater pollutants to navigable waters | EPA 2001b; 40CFR415.432
c. Food
FDA | Drug products containing certain active ingredients offered over-the-counter for certain uses | Digestive aid and weight control drug product | FDA 2000a; 21CFR310.545
FDA | Drugs; recommended warning and caution statements—iodine and iodides (oral) | If a skin rash appears, discontinue use and consult physician | FDA 2000b; 21CFR369.20
FDA | Food additives permitted for direct addition to food for human consumption (as potassium iodide) | | FDA 2000c; 21CFR172.375
FDA | Total amount for foods labeled without reference to age or physiological state | 225 μg
FDA | Food additives permitted for direct addition to food for human consumption (as potassium iodide) | | FDA 2000c; 21CFR172.375
FDA | Infants | 45 μg
FDA | Children under 4 years of age | 105 μg
FDA | Adults and children 4 or more years of age | 225 μg
FDA | Pregnant or lactating women | 300 μg
FDA | Food labeling—RDI | 150 μg | FDA 2001b; 21CFR101.9
FDA | Indirect food additives; sanitizing solutions | Aqueous solution used on food and dairy processing equipment and utensils | FDA 2000d; 21CFR178.1010(b)(40)
FDA | Nutrients—minimum amount per 100 kilocalories | 5.0 μg | FDA 2001a
FDA | Nutrition labeling of dietary supplements | | FDA 2000e; 21CFR101.36
FDA | Nutritional quality guidelines | | FDA 2000f; 21CFR104.20(d)(3)
FDA | RDI^a^ | 150 μ;g | FDA 2000f; 21CFR104.20(d)(3)
FDA | Amount per 100 calories^b^ | 7.5 μg | FDA 2000f; 21CFR104.20(d)(3)
FDA | Trace minerals added to animal feeds—calcium iodate, calcium iodobehenate, cuprous iodide, 3,5-diiodosalicylic acid, ethylenediamine dihydroiodide, potassium iodate, potassium iodide, sodium iodate, sodium iodide, and thymol iodide | Recognized as safe when added at levels consistent with good feeding practice | FDA 2000i; 21CFR582.80
d. Other
ATF | List of denaturants authorized for denatured spirits | | ATF 2001a; 27CFR21.151
ATF | List of products and processes using specially denatured alcohol and rum, and authorized formula | | ATF 2001b; 27CFR21.141
USC | List II chemical—regulated by the Attorney General as a chemical used in manufacturing a controlled substance | | USC 2001; 21USC802
[underlined: STATE]
Regulations and Guidelines:
a. Air
Alaska | PEL (ceiling) | 0.1 ppm | BNA 2001h
California | Airborne contaminant | | BNA 2001h
California | HAP | | BNA 2001h
Hawaii | Air contaminant | | BNA 2001h
Idaho | Toxic air pollutants | | BNA 2001h
Idaho | OEL | 0.1 mg/m^3^
Idaho | EL | 6.7×10^−3^ pounds/hour
Idaho | AAC (24-hour average) | 5×10^−3^ mg/m^3^
Michigan | Occupational air contaminant; maximum allowable concentrations | 0.1 ppm | BNA 2001h
Michigan | Limits for air contaminants | | BNA 2001h
Michigan | PEL (ceiling) | 0.1 ppm
Montana | Occupational air contaminant | | BNA 2001h
Montana | TLV | 0.1 ppm
New Hampshire | Regulated toxic air pollutant | | BNA 2001h
New Hampshire | OEL | 1 mg/m^3^
New Mexico | Toxic air pollutant and emissions | | BNA 2001h
New Mexico | OEL | 0.1 ppm
New Mexico | Emissions | 6.67×10^−2^ pounds/hour
New York | Exposure limits | | BNA 2001h
New York | PEL (ceiling) | 0.1 ppm
Oregon | Air contaminant | | BNA 2001h
Oregon | PEL (8-hour TWA) | 0.1 ppm
Texas | Airborne contaminant | | BNA 2001h
Vermont | Hazardous air contaminant | | BNA 2001h
Vermont | Hazardous air contaminants that cause short-term irritant effects | | BNA 2001h
Vermont | Annual average | 100 μg/m^3^
Vermont | Averaging time | 8 hours
Vermont | Action level | 4.2 pounds/8 hours
Washington | Toxic air pollutant and acceptable source impact levels | 3.3 μg/m^3^ per 24-hour average | BNA 2001h
b. Water
Maine | Drinking water guideline—iodide ion | 340 μg/L | HSDB 2001
Rhode Island | Water resources—toxic pollutant | | BNA 2001h
c. Food | | No data
d. Other
California | Hazardous substance list | | BNA 2001h
Florida | Toxic substance in the workplace | | BNA 2001h
Massachusetts | Oil and hazardous material list | | BNA 2001h
Pennsylvania | Worker and Community Right-to-Know Act—hazardous substance list | | BNA 2001h

a RDI for adults and children 4 or more years of age

b 100 calories, based on 2,000 calorie intake as a daily standard

AAC = acceptable ambient concentrations; ACGIH = American Conference of Governmental Industrial Hygienists; ATF = Alcohol, Tobacco, and Firearms; BPT = best practicable control technology; BNA = Bureau of National Affairs; CFR = Code of Federal Regulations; EL = emissions level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HAP = hazardous air pollutant; HSDB = Hazardous Substances Data Bank;IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life and health;NIOSH = National Institute of Occupational Safety and Health; OEL = occupational exposure limit;OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; RDI = recommended daily intake; REL = relative exposure limit; STEL = short term exposure limit; TLV = threshold limit value; TWA = time weighted average; USC = United States Code

Table 8-2 Regulations and Guidelines Applicable to Radioactive Iodine

Agency | Description | Information | | | References
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data
ICRP | Occupational recommended dose limits^a^; effective dose | 20 mSv per year, averaged over defined period of 5 years^b^ | | | ICRP 1991
ICRP | Annual equivalent dose
ICRP | Lens of the eye | 150 mSv
ICRP | Skin^c^ | 500 mSv
ICRP | Hands and feet | 500 mSv
ICRP | General population recommended dose limits^a^ | | | | ICRP 1991
ICRP | Effective dose | 1.0 mSv per year^d^
ICRP | Annual equivalent dose
ICRP | Lens of the eye | 15 mSv
ICRP | Skin^c^ | 50 mSv
ICRP | Hands and feet | No data
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | Effective dose | | | | ACGIH 2000
ACGIH | Any single year | 50 mSv
ACGIH | Averaged over 5 years | 20 mSv
ACGIH | Annual equivalent dose to
ACGIH | Lens of the eye | 150 mSv
ACGIH | Skin | 500 mSv
ACGIH | Hands and feet | 500 mSv
ACGIH | Embryo-fetus exposures once the pregnancy is known
ACGIH | Monthly equivalent dose | 0.5 mSv
ACGIH | Dose to the surface of women’s abdomen (lower trunk) | 2 mSv for the remainder of the pregnancy
ACGIH | Intake of radionuclide | 1/20 ALI
NIOSH | REL | No data
USNRC | Occupational values—inhalation | [underlined: ALI (μCi)] | [underlined: DAC^e^ (μCi/mL)] | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^120^I | 1×10^4^ | 4×10^−6^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^120^I | 2×10^4^ | 9×10^−6^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^121^I | 5×10^4^ | 8×10^−6^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^123^I | 6×10^3^ | 3×10^−6^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^124^I | 3×10^2^ | 3×10^−8^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^125^I | 2×10^2^ | 3×10^−8^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^126^I | 1×10^2^ | 1×10^−8^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^128^I | 1×10^5^ | 5×10^−5^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^129^I | 3×10^1^ | 4×10^−9^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^130^I | 2×10^3^ | 3×10^−7^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^131^I | 2×10^2^ | 2×10^−8^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^132^I | 1×10^4^ | 3×10^−6^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^132m^I | 2×10^4^ | 4×10^−6^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^133^I | 9×10^2^ | 1×10^−7^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^134^I | 5×10^4^ | 2×10^−5^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^135^I | 4×10^3^ | 7×10^−7^ | | USNRC 2001a; 10CFR20, Appendix B
USNRC | Effluent concentrations (μCi/mL) | | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^120^I | 2×10^−8^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^120m^I | 3×10^−8^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^121^I | 7×10^−8^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^124^I | 4×10^−10^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^125^I | 3×10^−10^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^126^I | 2×10^−10^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^128^I | 2×10^−7^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^129^I | 4×10^−11^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^130^I | 3×10^−9^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^131^I | 2×10^−10^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^132^I | 2×10^−8^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^132m^I | 3×10^−8^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^133^I | 1×10^−9^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^134^I | 6×10^−8^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^135^I | 6×10^−9^ | | | USNRC 2001a; 10CFR20, Appendix B
OSHA | PEL (8-hour TWA) | No data
b. Water
USNRC | Effluent concentrations ([underlined: μ]Ci/mL) | | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^120^I | 1×10^−4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^120m^I | 2×10^−4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^121^I | 4×10^−4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^124^I | 2×10^−6^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^125^I | 2×10^−6^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^126^I | 1×10^−6^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^128^I | 8×10^−4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^129^I | 2×10^−7^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^130^I | 2×10^−5^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^131^I | 1×10^−6^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^132^I | 1×10^−4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^132m^I | 1×10^−4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^133^I | 7×10^−6^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^134^I | 4×10^−4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^135^I | 3×10^−5^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | Releases to sewers; monthly average concentration ([underlined: μ]Ci/mL) | | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^120^I | 1×10^−3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^120m^I | 2×10^−3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^121^I | 4×10^−3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^124^I | 2×10^−5^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^125^I | 2×10^−5^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^126^I | 1×10^−5^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^128^I | 8×10^−3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^129^I | 2×10^−6^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^130^I | 2×10^−4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^131^I | 1×10^−5^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^132^I | 1×10^−3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^132m^I | 1×10^−3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^133^I | 7×10^−5^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^134^I | 4×10^−3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^135^I | 3×10^−4^ | | | USNRC 2001a; 10CFR20, Appendix B
c. Food
FDA | Derived intervention level^f^ (DIL; Bq/kg food) for ^131^I in accidentally-contaminated human food | 167 | | | FDA 1998
FDA | Sources of radiation used for food inspection: sealed units producing radiation (^25^I) | Not more than 2.2 million electron volts | | | FDA 2000h; 21CFR179.21
FDA | Requirements regarding certain radioactive drugs (^131^I) | Diagnosis of thyroid functions; thyroid scans; treatment of hyper-thyroidism and/or cardiac dysfunction; treatment of thyroid carcinoma | | | FDA 2000g; 21CFR310.503
d. Other
DOE | Radiation standards; DAC^g^ for controlling radiation exposure to workers at DOE facilities^h^ ([underlined: μ]Ci/mL) | | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^120m^I | 9×10^−6^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^120^I | 4×10^−6^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^121^I | 7×10^−6^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^123^I | 3×10^−6^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^124^I | 3×10^−8^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^125^I | 3×10^−8^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^126^I | 1×10^−8^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^128^I | 5×10^−5^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^129^I | 4×10^−9^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^130^I | 3×10^−7^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^131^I | 2×10^−8^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^132m^I | 4×10^−6^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^132^I | 3×10^−6^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^133^I | 1×10^−7^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^134^I | 2×10^−5^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | ^135^I | 7×10^−7^ | | | DOE 2001b; 10CFR835, Appendix A
DOE | Radiation standards; DAC^g^ for workers from external exposure during immersion in contaminated atmospheric cloud (Ci/mL) | | | | DOE 2001a; 10CFR835, Appendix C
DOE | ^122^I | 5×10^−6^
DOE | ^128^I | 5×10^−5^
DOE | ^132^I | 2×10^−6^
DOE | ^134^I | 1×10^−6^
DOE | ^135^I | 7×10^−7^
DOE | ^136^I | 1×10^−6^
DOE | Values for establishing sealed radioactive source accountability and radioactive material posting and labeling requirements | | | | DOE 2001c; 10CFR835, Appendix E
DOE | ^125^I | 3.5×10^2^
DOE | ^129^I | 1.8×10^2^
DOT | General requirements for shipments and packagings; A1 and A2 values for radionuclides | [underlined: A1 (Ci)] | [underlined: A2 (Ci)] | | DOT 2001a; 49CFR173.435
DOT | ^123^I | 6 | 162 | | DOT 2001a; 49CFR173.435
DOT | ^124^I | 0.9 | 24.3 | | DOT 2001a; 49CFR173.435
DOT | ^125^I | 2 | 54.1 | | DOT 2001a; 49CFR173.435
DOT | ^126^I | 0.9 | 24.3 | | DOT 2001a; 49CFR173.435
DOT | ^129^I | Unlimited | Unlimited | | DOT 2001a; 49CFR173.435
DOT | ^131^I | 0.5 | 13.5 | | DOT 2001a; 49CFR173.435
DOT | ^132^I | 0.4 | 10.8 | | DOT 2001a; 49CFR173.435
DOT | ^133^I | 0.5 | 13.5 | | DOT 2001a; 49CFR173.435
DOT | ^134^I | 0.3 | 8.11 | | DOT 2001a; 49CFR173.435
DOT | ^135^I | 0.3 | 13.5 | | DOT 2001a; 49CFR173.435
DOT | Hazardous substance and reportable quantity (Ci) | | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^120^I | 10 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^120m^I | 100 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^121^I | 100 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^123^I | 10 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^124^I | 0.1 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^125^I | 0.01 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^126^I | 0.01 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^128^I | 1,000 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^129^I | 0.001 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^130^I | 1.0 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^131^I | 0.01 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^132^I | 10 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^132m^I | 10 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^133^I | 0.1 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^134^I | 100 | | | DOT 2001b; 49CFR171.101, Appendix A
DOT | ^135^I | 10 | | | DOT 2001b; 49CFR171.101, Appendix A
EPA | Annual possession quantities for environmental compliance (Ci/year) | [underlined: Gas] | [underlined: Liquid/Solid] | [underlined: Powder] | EPA 2001a; 40CFR61, Appendix E
EPA | ^123^I | 4.9×10^−1^ | 4.9×10^5^ | 4.9×10^2^ | EPA 2001a; 40CFR61, Appendix E
EPA | ^124^I | 9.3×10^−3^ | 9.3×10^3^ | 9.3×10^0^ | EPA 2001a; 40CFR61, Appendix E
EPA | ^125^I | 6.2×10^−3^ | 6.2×10^3^ | 6.2×10^0^ | EPA 2001a; 40CFR61, Appendix E
EPA | ^126^I | 3.7×10^−3^ | 3.7×10^3^ | 3.7×10^0^ | EPA 2001a; 40CFR61, Appendix E
EPA | ^128^I | 9.3×10^0^ | 9.3×10^6^ | 9.3×10^3^ | EPA 2001a; 40CFR61, Appendix E
EPA | ^129^I | 2.6×10^−4^ | 2.6×10^2^ | 2.6×10^−1^ | EPA 2001a; 40CFR61, Appendix E
EPA | ^130^I | 4.6×10^−2^ | 4.6×10^4^ | 4.6×10^1^ | EPA 2001a; 40CFR61, Appendix E
EPA | ^131^I | 6.7×10^−3^ | 6.7×10^3^ | 6.7×10^0^ | EPA 2001a; 40CFR61, Appendix E
EPA | ^132^I | 2.0×10^−1^ | 2.0×10^5^ | 2.0×10^2^ | EPA 2001a; 40CFR61, Appendix E
EPA | ^133^I | 6.7×10^−2^ | 6.7×10^4^ | 6.7×10^1^ | EPA 2001a; 40CFR61, Appendix E
EPA | ^134^I | 3.2×10^−1^ | 3.2×10^5^ | 3.2×10^2^ | EPA 2001a; 40CFR61, Appendix E
EPA | ^135^I | 1.2×10^−1^ | 1.2×10^5^ | 1.2×10^2^ | EPA 2001a; 40CFR61, Appendix E
EPA | Release limits for containment^i^ | | | | BNA 2001e; 40CFR191, Appendix A
EPA | ^129^I | 100 Ci | | | BNA 2001e; 40CFR191, Appendix A
EPA | Reportable quantity (Ci) | | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^120m^I | 100 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^120^I | 10 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^121^I | 100 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^123^I | 10 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^124^I | 0.1 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^125^I | 0.01 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^126^I | 0.01 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^128^I | 1,000 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^129^I | 0.001 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^130^I | 1.0 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^131^I | 0.01 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^132m^I | 10 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^132^I | 10 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^133^I | 0.1 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^134^I | 100 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | ^135^I | 10 | | | BNA 2001f; 40CFR302.4 Appendix B
EPA | Carcinogenicity slope factors^j^ | | | | EPA 2002b
EPA | Ingestion—lifetime excess total cancer risk/pCi | | | | EPA 2002b
EPA | Water | | | | EPA 2002b
EPA | ^122^I | No data | | | EPA 2002b
EPA | ^123^I | 6.96×10^−13^ | | | EPA 2002b
EPA | ^125^I | 2.54×10^−11^ | | | EPA 2002b
EPA | ^126^I | 8.73×10^−11^ | | | EPA 2002b
EPA | ^129^I | 1.48×10^−10^ | | | EPA 2002b
EPA | ^130^I | 6.36×10^−12^ | | | EPA 2002b
EPA | ^131^I | 4.55×10^−11^ | | | EPA 2002b
EPA | ^132^I | 8.44×10^−13^ | | | EPA 2002b
EPA | ^133^I | 1.44×10^−11^ | | | EPA 2002b
EPA | ^134^I | 2.50×10^−13^ | | | EPA 2002b
EPA | ^135^I | 3.05×10^−12^ | | | EPA 2002b
EPA | Ingestion—lifetime excess total cancer risk/pCi | | | | EPA 2002b
EPA | Food
EPA | ^122^I | No data
EPA | ^123^I | 2.05×10^−12^
EPA | ^125^I | 6.29×10^−11^
EPA | ^126^I | 2.48×10^−10^
EPA | ^129^I | 3.22×10^−10^
EPA | ^130^I | 1.88×10^−11^
EPA | ^131^I | 1.34×10^−10^
EPA | ^132^I | 2.34×10^−12^
EPA | ^133^I | 4.40×10^−11^
EPA | ^134^I | 6.44×10^−13^
EPA | ^135^I | 8.99×10^−12^
EPA | Ingestion—lifetime excess total cancer risk/pCi
EPA | Soil
EPA | ^122^I | No data
EPA | ^123^I | 1.96×10^−12^
EPA | ^125^I | 5.55×10^−11^
EPA | ^126^I | 2.31×10^−10^
EPA | ^129^I | 2.71×10^−10^
EPA | ^130^I | 1.80×10^−11^
EPA | ^131^I | 1.26×10^−10^
EPA | ^132^I | 2.22×10^−12^
EPA | ^133^I | 4.26×10^−11^
EPA | ^134^I | 5.96×10^−13^
EPA | ^135^I | 8.62×10^−12^
EPA | Inhalation^k^—lifetime excess total cancer risk/pCi
EPA | ^122^I | No data
EPA | ^123^I | 3.03×10^−13^
EPA | ^125^I | 1.06×10^−11^
EPA | ^126^I | 3.70×10^−11^
EPA | ^129^I | 6.07×10^−11^
EPA | ^130^I | 2.76×10^−12^
EPA | ^131^I | 1.95×10^−11^
EPA | ^132^I | 3.74×10^−13^
EPA | ^133^I | 6.25×10^−12^
EPA | ^134^I | 1.02×10^−13^
EPA | ^135^I | 1.34×10^−12^
EPA | External exposure^l^—risk/year per pCi/g in soil
EPA | ^122^I | 4.17×10^−6^
EPA | ^123^I | 5.10×10^−7^
EPA | ^125^I | 7.24×10^−9^
EPA | ^126^I | 1.96×10^−6^
EPA | ^129^I | 6.10×10^−9^
EPA | ^130^I | 9.67×10^−6^
EPA | External exposure—risk/year per pCi/g in soil | | | | EPA 2002b
EPA | ^131^I | 1.59×10^−6^
EPA | ^132^I | 1.06×10^−5^
EPA | ^133^I | 2.72×10^−6^
EPA | ^134^I | 1.24×10^−5^
EPA | ^135^I | 7.83×10^−6^
NCRP | Occupational exposures^m^ | | | | NCRP 1993
NCRP | Effective dose limits
NCRP | Annual | 50 mSv
NCRP | Cumulative | 10 mSv x age
NCRP | Equivalent dose annual limits for tissues and organs
NCRP | Lens of eye | 150 mSv
NCRP | Skin, hands, and feet | 500 mSv
NCRP | Public exposures (annual)
NCRP | Effective dose limit, continuous or frequent exposure^m^ | 1.0 mSv
NCRP | Effective dose limit, infrequent exposure^m^ | 5 mSv
NCRP | Equivalent dose limits for tissues and organs^m^
NCRP | Lens of eye | 15 mSv
NCRP | Skin, hands, and feet | 50 mSv
USNRC | ALI ([underlined: μ]Ci)—oral ingestion | | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^120^I | 8×10^3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^120m^I | 1×10^4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^121^I | 3×10^4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^123^I | 3×10^3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^124^I | 2×10^2^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^125^I | 1×10^2^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^126^I | 7×10^1^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^128^I | 6×10^4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^129^I | 2×10^1^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^130^I | 1×10^3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^131^I | 9×10^1^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^132^I | 9×10^3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^132m^I | 1×10^4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^133^I | 5×10^2^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^134^I | 3×10^4^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | ^135^I | 3×10^3^ | | | USNRC 2001a; 10CFR20, Appendix B
USNRC | Byproduct material listing (Ci) | [underlined: Column I^n^] | [underlined: Column II^o^] | | USNRC 2001b; 10CFR33.100, Schedule A
USNRC | ^125^I | 0.1 | 0.00 | | USNRC 2001b; 10CFR33.100, Schedule A
USNRC | ^126^I | 0.1 | 0.001 | | USNRC 2001b; 10CFR33.100, Schedule A
USNRC | ^129^I | 0.1 | 0.01 | | USNRC 2001b; 10CFR33.100, Schedule A
USNRC | ^131^I | 0.1 | 0.001 | | USNRC 2001b; 10CFR33.100, Schedule A
USNRC | ^132^I | 10 | 0.1 | | USNRC 2001b; 10CFR33.100, Schedule A
USNRC | ^133^I | 1.0 | 0.01 | | USNRC 2001b; 10CFR33.100, Schedule A
USNRC | ^134^I | 10 | 0.1 | | USNRC 2001b; 10CFR33.100, Schedule A
USNRC | ^135^I | 1.0 | 0.01 | | USNRC 2001b; 10CFR33.100, Schedule A
USNRC | Individual monitoring | 1.0 Ci | | | BNA 2001a; 10CFR20.2206
USNRC | ^131^I | | | | BNA 2001a; 10CFR20.2206
USNRC | Laboratory testing and use | | | | BNA 2001b; 10CFR32.71
USNRC | ^125^I and ^131^I | ≤10 [underlined: μ]Ci | | | BNA 2001b; 10CFR32.71
USNRC | Packaging and transportation of radioactive material; determination of A1 and A2 | [underlined: A1 (Ci)] | [underlined: A2 (Ci)] | [underlined: Specific Activity] | USNRC 2001c; 10CFR71, Appendix A
USNRC | ^123^I | 6.0 | 162 | 1.9×10^6^
USNRC | ^124^I | 0.9 | 24.3 | 2.5×10^5^
USNRC | ^125^I | 2.0 | 54.1 | 1.7×10^4^
USNRC | ^126^I | 0.9 | 24.3 | 8.0×10^4^
USNRC | ^129^I | Unlimited | Unlimited | 1.8×10^4^
USNRC | ^131^I | 0.5 | 13.5 | 1.2×10^5^
USNRC | ^132^I | 0.4 | 10.8 | 1.0×10^7^
USNRC | ^133^I | 0.5 | 13.5 | 1.1×10^6^
USNRC | ^134^I | 0.3 | 8.11 | 2.7×10^7^
USNRC | ^135^I | 0.5 | 13.5 | 3.5×10^6^
USNRC | Quantities requiring consideration of the need for an emergency plan; ^125^I and ^131^I | | | | BNA 2001c; 10CFR30.72, Schedule C
USNRC | Release fraction | | | | BNA 2001c; 10CFR30.72, Schedule C
USNRC | Quantity | 0.5% | | | BNA 2001c; 10CFR30.72, Schedule C
USNRC | | 10 Ci | | | BNA 2001c; 10CFR30.72, Schedule C
USNRC | Standards for protection against radiation; quantities of licensed material requiring labeling ([underlined: μ]Ci) | | | | BNA 2001d; 10CFR20, Appendix C
USNRC | ^120m^I | 1,000
USNRC | ^120^I | 100
USNRC | ^121^I | 1,000
USNRC | ^123^I | 100
USNRC | ^124^I | 10
USNRC | ^125^I | 1.0
USNRC | ^126^I | 1.0
USNRC | ^128^I | 1,000
USNRC | ^129^I | 1.0
USNRC | ^130^I | 10
USNRC | ^131^I | 1.0
USNRC | ^132m^I | 100
USNRC | ^132^I | 100
USNRC | ^133^I | 10
USNRC | ^134^I | 1,000
USNRC | ^135^I | 100
USNRC | Waste classification | | | | USNRC 2001d; 10CFR61.55
USNRC | Concentration of ^129^I | 0.08 Ci/m^3^ | | | USNRC 2001d; 10CFR61.55
[underlined: STATE]
Regulations and Guidelines:
a. Air | | No data
b. Water
Kentucky | Maximum groundwater contaminant level | | | | BNA 2001h
Kentucky | ^131^I | 3 pCi/L
c. Food | | No data
d. Other
Arkansas | Licensing of radioactive materials; exempt concentrations (Ci/mL, solids are Ci/g) | [underlined: Column 1^n^] | [underlined: Column 2^o^] | | BNA 2001h
Arkansas | ^126^I | 3×10^−9^ | 6×10^−4^
Arkansas | ^131^I | 2×10^−5^ | 1×10^−8^
Arkansas | ^132^I | 3×10^−9^ | 7×10^−5^
Arkansas | ^133^I | 2×10^−5^ | 2×10^−7^
Arkansas | ^134^I | 8×10^−8^ | 1×10^−3^
California | Licensing of radioactive materials; Schedule C ([underlined: μ]Ci/mL) | [underlined: Column 1^n^] | [underlined: Column 2^o^] | | BNA 2001h
California | ^126^I | 3×10^−9^ | 2×10^−5^
California | ^131^I | 3×10^−9^ | 2×10^−3^
California | ^132^I | 8×10^−8^ | 6×10^−4^
California | ^133^I | 1×10^−8^ | 7×10^−3^
California | ^134^I | 2×10^−7^ | 1×10^−3^
Florida | Quantities requiring consideration of the need for an emergency plan; ^125^I and ^131^I | | | | BNA 2001h
Florida | Release fraction
Florida | Quantity | 0.5%; 10 Ci
Indiana | Licensing of radioactive materials; Schedule A; exempt concentrations [underlined: μ]Ci/mL) | [underlined: Column 1^n^] | [underlined: Column 2^o^] | | BNA 2001h
Indiana | ^126^I | 3×10^−9^ | 2×10^−5^
Indiana | ^131^I | 3×10^−9^ | 2×10^−3^
Indiana | ^132^I | 8×10^−8^ | 6×10^−4^
Indiana | ^133^I | 1×10^−8^ | 7×10^−3^
Indiana | ^134^I | 2×10^−7^ | 1×10^−3^
Kansas | Licensing of sources of radiation; Schedule B; exempt quantities of radioactive material ([underlined: μ]Ci) | | | | BNA 2001h
Kansas | ^123^I | 100
Kansas | ^125^I | 1.0
Kansas | ^126^I | 1.0
Kansas | ^129^I | 0.1
Kansas | ^131^I | 1.0
Kansas | ^132^I | 10
Kansas | ^133^I | 1.0
Kansas | ^134^I | 10
Kansas | ^135^I | 10
Louisiana | Standards for protection against radiation | | | | BNA 2001h
Louisiana | ^120m^I | 100
Louisiana | ^120^I | 10
Louisiana | ^121^I | 100
Louisiana | ^123^I | 10
Louisiana | ^124^I | 0.1
Louisiana | ^125^I | 0.01
Louisiana | ^126^I | 0.01
Louisiana | ^128^I | 1,000
Louisiana | ^129^I | 0.001
Louisiana | ^130^I | 1.0
Louisiana | ^131^I | 0.01
Louisiana | ^132m^I | 10
Louisiana | ^132^I | 10

a The limits apply to the sum of the relevant doses from external exposure in the specified period and the 50-year committed dose (to age 70 years for children) from intakes in the same period.

b With the further provision that the effective dose should not exceed 50 mSv in any single year. Additional restrictions apply to the occupational exposure of pregnant women.

c The limitation on the effective dose provides sufficient protection for the skin against stochastic effects. An additional limit is needed for localized exposures in order to prevent deterministic effects.

d In special circumstances, a higher value of effective dose could be allowed in a single year, provided that the average over 5 years does not exceed 1.0 mSv per year.

e DAC is the concentration of radioactive material in air and the time of exposure to that radionuclide, in hours. An NRC licensee may take 2,000 hours to represent one ALI, equivalent to a committed effective dose equivalent of 5 rems (0.05 sievert).

f The FDA-recommended Derived Intervention Level (DIL) for radionuclides of ^131^I, is defined as the DIL for the most sensitive age group (1 year) that was calculated from the most limiting Protective Action Goal (PAG; 50 mSv committed dose equivalent to the thyroid).

g DAC for the radionuclides listed in Appendix A of 10CFR835, the airborne concentration that equals ALI divided by the volume of air breathed by an average worker for a working year of 2,000 hours (assuming a breathing volume of 2,400 m^3^). For the radionuclides listed in Appendix C of 10CFR835, the air immersion DACs were calculated for a continuous, non-shielded exposure via immersion in a semi-infinite atmospheric cloud.

h Class D: approximate length of retention in the pulmonary region is less than 10 days.

i Release limit per 1,000 metric tons of heavy metal or other unit of waste.

j Radioactive slope factors calculated by EPA’s Office of Radiation and Indoor Air (ORIA). Slope factors are central estimates in a linear model of the age-averaged, lifetime attributable radiation cancer incidence (fatal and nonfatal cancer) risk per unit of activity ingested, expressed as risk per picocurie (pCi).

k Inhalation slope factors are central estimates in a linear model of the age-average, lifetime attributable radiation cancer incidence (fatal and nonfatal cancer) risk per unit of activity inhaled, expressed as risk per picocurie (pCi).

l External slope factors are central estimates of the lifetime attributable radiation cancer incidence risk for each year of exposure to external radiation from photon-emitting radionuclides distributed uniformly in a thick layer of soil, expressed as risk/year per pCi per gram of soil.

m Sum of external and internal exposures but excluding doses from natural sources.

n Column 1: gas concentration

o Column 2: liquid and solid concentration

ACGIH = American Conference of Governmental Industrial Hygienists; ALI = annual limits on intake; BNA = Bureau of National Affairs; CFR = Code of Federal Regulations; DAC = derived air concentrations; DOE = Department of Energy; DOT = Department of Transportation; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARc = International Agency for Research on Cancer; ICRP = International Commission on Radiological Protection; mSv = millisievert; NIOSH = National Institute of Occupational Safety and Health;NCRP = National Council on Radiation Protection; USNRC = U.S. Nuclear Regulatory Commission;OSHA = Occupational Safety and Health Administration; PAG = protective action guide; PEL = permissible exposure limit; REL = relative exposure limit; TLV = threshold limit value; TWA = time-weighted average

Table 8-3 Dose Coefficients^a^ (e(50)) for Intakes of Iodine Radionuclides

Radionuclide | Half-life | f1^c^ | Inhalation, 1pm AMAD^b^ | Inhalation, 5pm AMAD | Ingestion
Radionuclide | Half-life | f1^c^ | e(50) | e(50) | e(50)
^120^I | 1.35/hour | 1.0 | 1.0×10^−10^ | 1.9×10^−10^ | 3.4×10^−10^
^120m^I | 0.883/hour | 1.0 | 8.7×10^−11^ | 1.4×10^−10^ | 2.1×10^−10^
^121^1 | 2.12/hour | 1.0 | 2.8×10^−11^ | 3.9×10^−11^ | 8.2×10^−11^
^123^I | 13.2/hour | 1.0 | 7.6×10^−11^ | 1.1×10^−10^ | 2.1×10^−10^
^124^I | 4.18/day | 1.0 | 4.5×10^−9^ | 6.3×10^−9^ | 1.3×10^−8^
^125^I | 60.1/day | 1.0 | 5.3×10^−9^ | 7.3×10^−9^ | 1.5×10^−8^
^126^I | 13.0/day | 1.0 | 1.0×10^−8^ | 1.4×10^−8^ | 2.9×10^−8^
^128^I | 0.416/hour | 1.0 | 1.4×10^−11^ | 2.2×10^−11^ | 4.6×10^−11^
^129^I | 1.57×10^7^/year | 1.0 | 3.7×10^−8^ | 5.1×10^−8^ | 1.1×10^−7^
^130^I | 12.4/hour | 1.0 | 6.9×10^−10^ | 9.6×10^−10^ | 2.0×10^−9^
^131^I | 8.04/day | 1.0 | 7.6×10^−9^ | 1.1×10^−8^ | 2.2×10^−8^
^132^1 | 2.30/hour | 1.0 | 9.6×10^−11^ | 2.0×10^−10^ | 2.9×10^−10^
^132m^I | 1.39/hour | 1.0 | 8.1×10^−11^ | 1.1×10^−10^ | 2.2×10^−10^
^133^I | 20.8/hour | 1.0 | 1.5×10^−9^ | 2.1×10^−9^ | 4.3×10^−9^
^134^I | 0.876/hour | 1.0 | 4.8×10^−11^ | 7.9×10^−11^ | 1.1×10^−10^
^135^I | 6.61/hour | 1.0 | 3.3×10^−10^ | 4.6×10^−10^ | 9.3×10^−10^

a ICRP (1994a)

b ICRP (1994a) calculated inhalation dose coefficients for particles with AMAD of 1 or 5 pm.

c Fractional absorption factor used by ICRP (1994, Annexes E and F) to calculate effective dose coefficients.

ALI = annual limits on intake; AMAD = activity median average diameters; Ci = curies