# 4 CHEMICAL, PHYSICAL, AND RADIOLOGICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Iodine is a nonmetallic element belonging to the halogen family in Group VIIA of the periodic table. Iodine is found in nature as iodide (i.e., I^−^) in brines or in molecular compounds with other elements (e.g., iodate or IO_3_^−^). The chemical information for elemental iodine and some of its compounds is listed in Table 4-1. Radioactive isotopes of iodine (e.g., see Section 4.2) are an additional cause of concern with regard to human health (see Chapter 3).

## 4.2 PHYSICAL, CHEMICAL, AND RADIOLOGICAL PROPERTIES

The physical properties of iodine and selected iodine compounds are listed in Table 4-2. The percent occurrence of iodine isotopes and radiological properties of iodine isotopes is listed in Table 4-3.

Iodine can exist in several oxidation states: −1, 0, +1, +3, +5, and +7. Under normal environmental conditions, the −1, 0, and +5 oxidation states are the most important. There are 36 isotopes of iodine having masses between 108 and 143 (Chu et al. 1999); 14 of these yield significant radiation. The only naturally-occurring isotopes of iodine are ^127^I and ^129^I, which are stable and radioactive, respectively. Isotopes of mass less than 127 are produced in particle accelerators (common examples are ^123^I and ^125^I), while those >127 are formed in neutron generators such as nuclear reactors and atomic bombs (common examples are ^129^I and ^131^I). A total of 72% of uranium fissions and 75% of plutonium fissions leads directly or by beta decay of precursors, to iodine isotopes. For example, 2.89% of ^235^U and 3.86% of ^239^Pu fission atoms lead to the formation of a series of isobar 131 isotopes, including ^131^In, ^131^Sn, ^131^Sb, ^131^Te, ^131^I, and ^131^Xe. Each isotope can be formed as an initial fission product and, once formed, each isotope decays by beta-ray emission to the right on the sequence, through ^131^I, and with stable ^131^Xe. The process can be displayed as:

Chemical Physical and Radiological information

Table 4-1 Chemical Identity of Iodine and Iodine Compounds

Property | Iodine | Hydrogen iodide | Sodium iodide | Potassium iodide | Methyl iodide | Cesium iodide | Potassium iodate | Sodium periodate | Calcium iodide | Copper (I) iodide | Povidone iodine
Chemical formula | I_2_ | HI | NaI | KI | CH_3_I | CsI | KIO_3_ | NaIO_4_ | CaI_2_ | CuI | C_6_H_9_I_2_NO
Chemical structure | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Synonyms | Actomar; diiodine; eranol; iodine-127; molecular iodine | Hydroiodic acid | Sodium monoiodide; sodium Iodine | Hydroiodic acid, potassium salt; PIMA; SSK; iodide of potash | Monoiodo-methane; iodomethane | No data | lodic acid, potassium salt | Sodium metaperiodate | Calcium diiodide; calcium iodide hydrate | Copper monoiodide; natural marshite; cuprous iodide | Poly(1-(2-OXO-1-pyrrolidinyl)-ethylene)iodine complex; betadine; efodine; Iodopoly(vinyl pyrrolidinone); isobetadyne; isodine; poly(vinylpyrrolidinone) iodide; ultradine
Trade names | None | None | None | None | Halon 10001 | No data | None | None | None | None | None
Identification numbers
CAS registry | 7553-56-2 | 10034-85-2 | 7681-82-5 | 7681-11-0 | 74-88-4 | 7789-17-5 | 7758-05-6 | 7790-28-5 | 10102-68-8 | 7681-65-4 | 25655-41-8
NIOSH RTECS | NN1575000 | MW3760000 | WB6475000 | TT2975000 | PA9450000 | No data | NN1350000 | None | None | None | TR1579600
EPA hazardous waste | None | None | None | None | U138 | None | None | None | None | None | None
OHM/TADS | None | None | None | None | None | None | None | None | None | None | None
DOT/UN/NA/IMO shipping | UN 1759; UN 1760 | UN 2197; UN 1787 Corrosive material/IMO 8.0; IMO 2.0 | None | None | UN 2644 Poison/IMO 6.1 | None | None | None | None | None | None
HSDB | 34 | 2155 | 750 | 5040 | 1336 | None | 1231 | None | None | 271 | 6831
NCI | 42355 | None | None | 77362 | 9366 | None | None | None | None | None | 26245
STCC | None | None | None | None | None | None | None | None | None | None | None

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transport lation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSIH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances; STCC = Standard Traiisportation Commercial Code

Source: HSDB 2001; Lide 2000

Table 4-2 Physical and Chemical Properties of Iodine and Iodine Compoundsa

Property | Iodine | Hydrogen iodide | Sodium iodide | Potassium iodide | Methyl iodide | Cesium iodide | Potassium iodate | Sodium periodate | Calcium iodide | Copper (I) iodide | Povidone iodine
Molecular weight, g/mole | 253.809^a^ | 127.91^a^ | 149.89^a^ | 166.02^a^ | 141.94^a^ | 259.81^a^ | 214.02^a^ | 213.892^d^ | 293.89^a^ | 190.45^a^ | 364.95^c^
Color | Bluish-black^a^ | Colorless^a^ | White | Colorless or white^a^ | Colorless^a^ | Colorless^d^ | White^a^ | White^d^ | Yellow^a^ | Red-brown^a^ | Yellow-brown^c^
Physical state | Solid; scales or plates^a^ | Gas^a^ | Solid; crystals or granules | Solid; crystals, granules, or powder^a^ | Liquid^a^ | Solid; crystals, or powder^a^ | Solid, crystals^a^ | Solid; crystals^d^ | Solid lumps or powder^a^ | Solid; powder or crystals^a^ | Solid; powder^c^
Melting point | 113.60 °C^a^ | −50.8 °C^a^ | 651 °C^a^ | 680 °C^a^ | −66.5 °C^a^ | 621 °C^a^ | 560 °C^a^ | Decomposes ~300 °C | 740 °C | 588–606 °C^a^ | 300 °C
Boiling point | 185.24 °C^a^ | −35.1 °C^a^ | 1,304 °C^d^ | 1,323 °C^d^ | 42.5 °C^a^ | ca. 1,280 °C^a^ | No data | No data | 1,100°C | ~1,290 °C^a^ | No data
Density, g/cm^3^ (25 °C) | 4.93^a^ | 5.23^a^ | 3.67^a^ | 3.12^a^ | 2.28 (20 °C)^a^ | 4.5^a^ | 3.98^c^ | 3.86^d^ | | 5.63^a^
Odor | Characteristic^a^ | No data | Odorless^a^ | No data | Pungent, ether-like^c^ | No data | No data | No data | No data | No data | Slight characteristic^c^
Odor threshold:
Water | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Air | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Solubility (25 °C):
Water | 330 mg/L^a^ | 2,340 g/L (10 °C)^a^ | 2,000 g/L^a^ | 1,429 g/L^a^ | 13.9 g/L (20 °C)^c^ | Miscible^a^ | 9.16 g/100 g^c^ | Soluble^d^ | Very soluble^a^ | 80 mg/L (18°C)^c^ | Soluble^c^
Organic solvents(s) | 141 g/kg benzene^a^ | Soluble^a^ | 500 g/L alcohol^a^ | 13 g/L acetone^a^ | Miscible^a^ | Soluble in alcohol; insoluble in acetone^a^ | No data | No data | Very soluble in alcohol, acetone^a^ | Insoluble^a^ | Insoluble^c^
Partition coefficients:
Log K_ow_ | 2.49^b^ | No data | No data | No data | 1.51^c^ | No data | No data | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Vapor pressure (25 °C) | 0.305 mm Hg^a^ | 5,940 mm Hg^c^ | 1 mm Hg (767 °C)^c^ | No data | 405 mm Hg | No data | No data | No data | No data | No data | No data
Henry’s Law constant | No data | No data | No data | No data | 0.00526 atm-cu m/mole | No data | No data | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data | No data | No data | No data | No data
Flammability limits | No data | Non-flammable | No data | No data | No data | No data | No data | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data

a Budavari et al. 1998

b Hansch and Leo 1995

c HSDB 2000

d Lide 2000

Source: Chemfinder 2001, unless otherwise specified

Table 4-3 Percent Natural Occurrence and Radioactive Properties of Isotopes of Iodine

Isotope | CAS registry number | Natural abundance (%) | Beta energies, MeV^a^ (intensity) | Gamma energies, keV^a^ | Half-life | Activity, Ci/gram^c^
^123^I | 15715-08-9 | No data | 1.08 (97.0%) | 158.97 | 13.3 hours | 1.92×10^6^
^124^I | 14158-30-6 | No data | EC^b^ | 602.7; 722.8; 1691.0 | 4.18 days | 2.52×10^5^
^125^I | 14158-31-7 | No data | EC^b^ | 35.5 | 59.4 days | 1.76×10^4^
^126^I | 14158-32-8 | No data | EC^b^ | 388.6; 666.3; 753.8 | 13.11 days | 7.91×10^4^
^127^I | 7553-56-2 | <100 | No data | No data | Stable | No data
^129^I | 15046-84-1 | 1×10^−13^ to 1×10^−10^ | 0.154 | 29.5; 29.8; 33.6 | 1.57×10^7^ years | 1.77×10^−4^
^131^I | 10043-66-0 | No data | 0.334 (7.3%); 0.606 (89.9%) | 284.3; 364.5 | 8.04 days^d^ | 1.24×10^5^
^132^I | 14683-16-0 | No data | 0.74 (13.0%); 0.96 (8.2%); 1.18 (18.8%); 1.61 (12.6%); 2.14 (19.0%) | 667.7; 772.6; 954.6 | 2.30 hours | 1.03×10^7^
^133^I | 14834-67-4 | No data | 0.54 (87.0%); 0.88 (4.5%) | 529.9; 875.3 | 20.8 hours | 1.13×10^6^
^134^I | 14914-27-3 | No data | 1.31 (30.4%); 1.59 (16.2%); 1.82 (11.0%); 2.44 (12.5%) | 847.0; 884.1 | 52.5 minutes | 2.67×10^7^
^135^I | 14834-68-5 | No data | 679.7 (8.0%); 856.8 (8.8%); 969.9 (21.9%); 1,082.7 (8.0%); 1,387.6 (23.8%) | 546.6; 836.8; 1.038.8; 1,131.5 | 6.57 hours | 3.53×10^6^

a Not all gamma and beta energies are included in summary; see Chu et al. (1999) for a complete listing

b EC = electron capture decay

c Activity = (N_A_ ln2)/(M_w_ t_1/2_)

d Lide 2000

Source: Chu et al. 1999

The same process occurs for ^129^I (t½=1.6x107 years) and includes mass 129 isobars beginning with ^129^Cd and ending with ^129^Xe. Iodine isotopes above ^127^I decay by emitting beta and gamma radiation, whose combined energies are unique to each iodine isotope. ^131^I, for example, decays by beta particle emission, and 0.96 MeV of energy is shared between the beta particle and the gamma ray. At least seven possible beta/gamma combinations occur. In 90.4% of the decays, a 0.61 MeV beta particle is emitted. The remaining excess energy is emitted as either a 0.364 MeV gamma ray for 85.3% of the time, or a pair of 0.284 and 0.080 MeV gamma rays for the other 5.1% of the time. The following is the decay scheme for ^131^I (Cember 1996):

Isotopic masses of iodine <127 can be produced using a beam of high energy protons generated using a linear accelerator. Proton beams tuned at fixed energies up to 30 MeV produce isotopes, such as ^123^I, by interaction of the proton beam with a target of high atomic mass.