# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Iodine (sodium iodide, potassium iodide) Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Iodine (sodium iodide, potassium iodide)
CAS Number: | 7553-56-2 (7681-82-5, 7681-11-0)
Date: | March 2004
Profile Status: | Draft 3 Post Public
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 6
Species: | Human

[underlined: Minimal Risk Level]: 0.01 [X] mg/kg/day [ ] ppm

The administered doses of iodide (as sodium iodide) were 250, 500, or 1,500 µg I/day for 14 days (Paul et al. 1988); or 500, 1,500, or 4,500 µg I/day (Gardner et al. 1988). The pre-existing dietary iodide intakes were estimated from the reported 24-hour urinary iodide excretion rate, which was 200 µg/day (Paul et al. 1988) or 300 µg I/day (Gardner et al. 1988). The total intake of iodide was estimated as the sum of the administered iodide and the estimated dietary intake: 450, 700, or 1,700 µg/day (Paul et al. 1988); or 300, 800, 1,800, or 4,800 µg/day (Gardner et al. 1988). The estimated dosages on a per kg body weight (70 kg) were: 0.0064, 0.010, or 0.024 mg/kg/day (Paul et al. 1988); or 0.011, 0.026, or 0.069 mg/kg/day (Gardner et al. 1988).

In protecting public health ATSDR recommends using the conservative lower end of this calculated NOAEL range, 0.01 mg/kg/day, to derive an acute-duration MRL of 0.01 mg/kg/day.

[underlined: Reference]: Gardner DF, Centor RM, Utiger RD. 1988. Effects of low dose oral iodide supplementation on thyroid function in normal men. Clin Endocrinol 28:283–288; Paul T, Meyers B, Witorsch RJ, . 1988. The effect of small increases in dietary iodine on thyroid function in euthyroid subjects. Metabolism 37(2):121–124.3340004

[underlined: Experimental design:] Healthy euthyroid adults (9 males, 9 females) who had no history of thyroid disease or detectable antithyroid antibodies received daily oral doses of 250, 500, or 1,500 µg I/day as sodium iodide for 14 days (Paul et al. 1988). Based on 24-hour urinary excretion of iodide prior to the iodide supplement, the background iodine intake was estimated to be approximately 200 µg/day; thus, the total iodide intake was approximately 450, 700, or 1,700 µg I/day (approximately 0.0064, 0.01, or 0.024 mg/kg/day, assuming a 70-kg body weight).

Ten healthy, euthyroid, adult males received daily oral doses of 500, 1,500, or 4,500 µg I/day (as sodium iodide) for 14 days (Gardner et al. 1988). Based on 24-hour urinary excretion of iodide prior to the iodide supplement of 250–320 µg/day, the total estimated intakes were 800, 1,800, or 4,800 µg/day or approximately 0.011, 0.026, or 0.069 mg/kg/day.

[underlined: Effects noted in study and corresponding doses]: In the Paul et al. (1988) study, subjects who received 1,700 µg/day (0.024 mg/kg/day) had significantly depressed (5–10%) serum concentrations of TT_4_, FT_4_, and TT_3_ compared to pretreatment levels, and serum TSH concentrations were significantly elevated (47%) compared to pretreatment values. Hormone levels were within the normal range during treatment. In this same study, nine females received daily doses of 250 or 500 µg I/day for 14 days (total intake was approximately 450 or 700 µg/day [0.0064 or 0.010 mg/kg/day]) and there were no significant changes in serum hormone concentrations.

In the Gardner et al. (1988) study, there were no effects on serum thyroid hormone or TSH concentrations at the 800 µg/day intake (0.011 mg/kg/day); however, intakes of 1,800 or 4,800 µg I/day (0.026 or 0.064 mg/kg/day) produced small (10%), but significant, transient decreases in serum TT_4_ and FT_4_ concentrations and an increase (48%) in serum TSH concentration, relative to the pretreatment values.

[underlined: Dose and end point used for MRL derivation]: 0.01 mg/kg/day; reversible subclinical hypothyroidism.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [ ] 10 for human variability

Although the acute NOAEL is derived from acute studies of healthy adults, supporting studies indicate that the NOAEL would be applicable to children and elderly adults (Boyages et al. 1989; Chow et al. 1991). On this basis, an uncertainty factor is not needed to adjust the NOAEL to account for human variability in sensitivity. In the Chow et al. (1991) study, 30 healthy elderly adult females, without evidence of thyroid peroxidase antibodies (TPA), received daily doses of 500 µg I/day (as potassium iodide) for 14 or 28 days. Serum concentrations of FT_4_ were significantly decreased and serum TSH concentrations were significantly elevated in the women who received the iodide supplements, relative to a placebo control group. On average, the magnitude of the changes did not produce clinically significant depression in thyroid hormone levels; however, five subjects had serum TSH concentrations that exceeded 5 mU/L. The subjects had a lower dietary iodine intake than those in the Gardner et al. (1988) study; approximately 72–100 µg/day, based on urinary iodide measurements. Therefore, the total iodide intake was approximately 600 µg/day (0.0086 mg/kg/day).

In the Boyages et al. (1989) study, thyroid status was compared in groups of children, ages 7–15 years, who resided in two areas of China where drinking water iodide concentrations were either 462 µg/L (n=120) or 54 µg/L (n=51) (Boyages et al. 1989; Li et al. 1987). Although the subjects were all euthyroid with normal values for serum thyroid hormones and TSH concentrations, TSH concentrations were significantly higher in the high iodine group. The high iodide group had a 65% prevalence of goiter and a 15% prevalence of Grade 2 goiter compared to 15% for goiter and 0% for Grade 2 goiter in the low iodine group. Urinary iodine was 1,236 µg I/g creatinine in the high iodine group and 428 µg I/g creatinine in the low iodine group. Assuming a body weight of 40 kg and lean body mass of 85% of body weight, the above urinary iodine/creatinine ratios are approximately equivalent to iodine excretion rates, or steady-state ingestion rates of 1,150 µg/day (0.029 mg/kg/day) and 400 µg/day (0.01 mg/kg/day) in the high and low iodide groups, respectively.

The MRL is higher than the National Research Council Recommended Dietary Allowance of 150 µg/day (0.0021 mg/kg/day for a 70-kg adult), with additional allowances of 25 µg/day (0.0025 mg/kg/day) and 50 µg/day (0.0029 mg/kg/day) during pregnancy and lactation, respectively (NRC 1989).

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No; however, urinary iodide levels were converted to estimates of iodine intakes. Steady-state baseline dietary intakes of iodide were assumed to be equivalent to the reported 24-hour urinary iodine excretion rates. This assumption is consistent with information available on the toxicokinetics of iodide that indicates nearly complete absorption of ingested iodide and that urinary excretion accounts for >97% of the absorbed dose (see Sections 3.5.1.2 and 3.5.4.2). The assumption is also supported by studies in which 24-hour urinary iodide was measured before and after supplementation (Kahaly et al. 1998; Konno et al. 1993b). For example, 31 patients received oral supplements of 382 µg I/day for 6 months. Prior to the supplementation, the mean 24-hour urinary iodide excretion rate was 36 µg/day (range, 13–69 ), whereas, after 6 months of iodide supplementation, the mean 24-hour urinary iodide excretion rate was 415 µg/day (Kahaly et al. 1998). The difference between these two values, 379 µg/day, is nearly identical to the supplemental dose of 382 µg/day.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: NA

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL:] Two other acute studies reported NOAELs and LOAELs of 0.3 and 1.0 mg/kg/day, respectively (Robison et al. 1998, 1999), which are substantially higher than those from the Paul et al. (1988) and Gardner et al. (1988) studies. These suggest that doses much higher than the MRL can be tolerated in some people without producing thyroid gland suppression.

[underlined: Agency Contact (Chemical Manager)]: John Risher, Ph.D.

## Iodine (sodium iodide, potassium iodide) Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Iodine (sodium iodide, potassium iodide)
CAS Number: | 7553-56-2 (7681-82-5, 7681-11-0)
Date: | March 2004
Profile Status: | Draft 3 Post Public
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 29
Species: | Human

[underlined: Minimal Risk Level]: 0.01 [X] mg/kg/day [ ] ppm

Iodine intakes estimated from urinary iodine levels (see below) were 400 and 1,150 µg/day. These correspond to 0.010 or 0.029 mg/kg/day for a 40-kg child of age 11 years.

[underlined: Reference]: Boyages SC, Bloot AM, Maberly GF, . 1989. Thyroid autoimmunity in endemic goiter caused by excessive iodine intake. Clin Endocrinol 31:452–465; Li W, Qu C, Jia G, . 1987. Endemic goitre in Central China caused by excessive iodine intake. Lancet, August 1:257–258.

[underlined: Experimental design:] Thyroid status was compared in groups of children, ages 7–15 years, who resided in two areas of China where drinking water iodide concentrations were either 462 µg/L (n=120) or 54 µg/L (N=51) (Boyages et al. 1989; Li et al. 1987). Urinary iodine was 1,236 µg I/g creatinine in the high iodine group and 428 µg I/g creatinine in the low iodine group. Assuming a body weight of 40 kg and lean body mass of 85% of body weight, the above urinary iodine/creatinine ratios are approximately equivalent to iodine excretion rates, or steady state ingestion rates of 1,150 (29 µg/kg/day) and 400 µg/day (10 µg/kg/day) in the high and low iodide groups, respectively.

[underlined: Effects noted in study and corresponding doses]: Although the subjects were all euthyroid with normal values for serum thyroid hormones and TSH concentrations, TSH concentrations were significantly higher (33%) in the high iodine group. The high iodide group had a 65% prevalence of goiter and a 15% prevalence of Grade 2 goiter compared to 15% for goiter and 0% for Grade 2 goiter in the low iodine group.

[underlined: Dose and end point used for MRL derivation]: 0.01 mg/kg/day; subclinical hypothyroidism with thyroid gland enlargement.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [ ] 10 for human variability

An uncertainty factor is not needed to adjust the NOAEL to account for human variability in sensitivity because the NOAEL is based on a sensitive end point in children, a sensitive subpopulation. Supporting studies indicate that the NOAEL would be applicable to elderly adults who may represent another sensitive subpopulation (Chow et al. 1991; Szabolcs et al. 1997). In the Chow et al. (1991) study, 30 healthy elderly adult females, without evidence of thyroid peroxidase antibodies (TPA), received daily doses of 500 µg I/day (as potassium iodide) for 14 or 28 days. Serum concentrations of FT_4_ were significantly decreased and serum TSH concentrations were significantly elevated in the women who received the iodide supplements, relative to a placebo control group. On average, the magnitude of the changes did not produce clinically significant depression in thyroid hormone levels; however, five subjects had serum TSH concentrations that exceeded 5 mU/L. The pre-existing dietary iodine intake was approximately 72–100 µg/day, based on urinary iodide measurements. Therefore, the total iodide intake was approximately 600 µg/day (0.0086 mg/kg/day).

Szabolcs et al. (1997) studied a group of elderly nursing home residents in the Carpathian Basin and revealed a prevalence of hypothyroidism that increased with increasing iodine intake. Subjects were from one of three regions where, based on reported urinary iodine levels of 72, 100, or 513 µg I/g creatinine, the iodine intakes were approximately 117, 163, or 834 µg/day (0.0017, 0.0023, or 0.012 mg/kg/day for low, n=119; moderate, n=135; or high intake, n=92, respectively). The prevalence of elevated serum TSH concentrations together with serum FT_4_ concentrations below the normal range, was 0.95, 1.5, and 7.6% in the low, moderate, and high iodine groups, respectively. If a prevalence of abnormal thyroid hormone levels of less than 5% is considered a NOAEL, this study supports a NOAEL in elderly adults that is slightly below 0.012 mg/kg/day. Linear interpolation of the dose-prevalence data reported above yields an estimate of a 5% prevalence at an iodine intake of approximately 0.008 mg/kg/day.

The MRL is higher than the National Research Council Recommended Dietary Allowance of 150 µg/day (0.0021 mg/kg/day for a 70-kg adult), with additional allowances of 25 µg/day (0.0025 mg/kg/day) and 50 µg/day (0.0029 mg/kg/day) during pregnancy and lactation, respectively (NRC 1989).

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No; however, urinary iodide levels were converted to estimates of iodine intakes. Urinary iodide:creatinine ratios were converted to estimated iodide intake as follows assuming a constant relationship between urinary creatinine excretion rate and lean body mass. The rate of creatinine excretion (e.g., U_Cr_, mg creatinine/day) was calculated from the relationship between lean body mass (LBM) and U_cr_:

L B M = 0.0272 ⋅ U˙_C r_ + 8.58

where the constants 0.0272 and 8.58 are the weighted arithmetic mean of estimates of these variables from eight studies reported in Forbes and Bruining (1976). Lean body mass was calculated as follows (ICRP 1981):

L B M = B W ⋅ 0.85 , f e m a l e s L B M = B W ⋅ 0.88 , m a l e s

where BW is the reported body weight for children of age 11 years (40 kg) (EPA 1997). Iodide intake was calculated as:

I n t a k e_I_ = U_I / C r_ ⋅ U˙_C r_

where U_I/Cr_ is the urinary iodide:creatinine ratio (µg I/g creatinine). This approach yields relationships between 24-hour urinary iodide excretion rates and the urinary iodide:creatinine ratios that are in reasonable agreement with observation (Konno et al. 1993b). The approach is consistent with information available on the toxicokinetics of iodide that indicates nearly complete absorption of ingested iodide and that urinary excretion accounts for >97% of the absorbed dose (see Sections 3.5.1.2 and 3.5.4.2).

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: NA

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL:] One other study of elderly adults supports the MRL as being protective of this population. Thyroid status was compared in 423 residents (ages 66–70 years) of Jutland, Denmark who had iodine intakes of 40–60 µg/day (0.7 µg/kg/day) and 100 residents of Iceland who had intakes of 300–350 µg/day (5 µg/kg/day) (Laurberg et al. 1998). Subjects from the high iodine intake region had a significantly higher prevalence (18%) of serum TSH levels above the high end of the normal range (>4 mU/L) compared to subjects from the low iodine region (3.8%). The prevalence of serum TSH concentrations above 10 mU/L was 4.0% in the high iodine region and 0.9% in the low iodine region. Females in both regions had a significantly higher prevalence of elevated TSH concentrations than males. Serum concentrations of T_4_ were not depressed, even in subjects with TSH concentrations that exceeded 10 mU/L. Thus, although the subjects appeared to be euthyroid, the higher iodine intakes were associated with a subclinical suppression of the thyroid gland as indicated by a high prevalence of elevated serum TSH concentrations.

[underlined: Agency Contact (Chemical Manager)]: John Risher, Ph.D.