# UPDATE STATEMENT

A Toxicological Profile for Hydrogen Sulfide and Carbonyl Sulfide, Draft for Public Comment was released in October 2014. This edition supersedes any previously released draft or final profile.

Toxicological profiles are revised and republished as necessary. For information regarding the update status of previously released profiles, contact ATSDR at:

- Agency for Toxic Substances and Disease Registry
- Division of Toxicology and Human Health Sciences
- Environmental Toxicology Branch
- 1600 Clifton Road NE
- Mailstop F-57
- Atlanta, Georgia 30329-4027